# List of Acronyms, Abbreviations, and Parameters

## Acronyms and abbreviations

Abbreviation | Definition
* | P<.05
** | P<.01
*** | P<.001
A | Amplitude
AA (20:4 n-6) | Arachidonic acid
Ac | Activation parameter
AC | Intra-atrial conduction time
AHRQ | Agency for Healthcare Research and Quality
AI | Adequate Intake
ALA (18:3 n-3) | Alpha-linolenic acid
Amb | Ambient
AP or APR | Action potential rate
APA | Action-potential amplitude
APD_40_ | Action-potential duration at 40% depolarization
APD_80_ | Action-potential duration at 80% depolarization
Apo | Apoprotein
APS | Active pump sites
APT | Action potential threshold
AR | Arrhythmia
ARAr | Areas at risk of arrhythmias
ARP | Functional refractory period of the atrium
AS | Arrhythmia scores
ASC | Asynchronous contraction
ATP | Adenosine triphosphate
ATPase | Adenosine triphosphatase
AVC | Atrioventricular conductance time
AVRP | Functional refractory period of atrio-ventricular conducting system
B | Basal
B | Blocked (when used with arrythmias)
BAY | Bay K8644
BEP | Basal electromechanical parameters
B_max_ | High and low affinity binding sites
BMI | Body mass index
BP | Blood pressure
BSA | Bovine serum albumin
BT | Benzonthiazepine calcium current-voltage (I_Ca_-V) curves
BUME | Bumetamide
BW | Lipoxygenase inhibitor
C_20_ | Contraction coupling delay (ms)
Ca | Calcium
Ca^2+^ | Calcium
CAB | Commonwealth Agricultural Bureau
cAMP | Cyclic adenosine monophosphate
CAFF | Caffeine
CaFlu | Calcium intermittent fluctuations
CCTR | Cochrane Central Register of Controlled Trials
CD_20_ | Contraction duration at 20% relaxation (ms)
CD_80_ | Contraction duration at 80% relaxation (ms)
CICR | Calcium induced contractile response
CL | Cell Length
CLO | Cod liver Oil
+Cmax | Cell shortening velocity
-C_max_ | Relaxation time
CO | Corn Oil
Contra | Contractility or beating rate (beats/min)
COX | Cyclo-oxygenase
CP | contractile parameters
CSF II | Continuing Food Survey of Intakes by Individuals 1994-1998
CRP | C reactive protein
Ctrl | Control
CVD | Cardiovascular disease
Cys | Cytosolic
D | Dietary supplement company (in evidence table)
D | Duration (in summary table)
D | Decreased (when in footnote of table)
dBcAMP | Dibutyryl cyclic adenosine monophosphate
DBHQ | 2,4-Di-tert-butylhydroquinone
DCL | Diastolic cell length
DD | Dose dependent
Dep APT | Depolarizing action potential threshold
df/dt | Maximum rate of rise of contraction
-df/dt | Maximum rate of rise of relaxation
DHA (22:6 n-3) | Decosahexaenoic acid
DHAe | DHA esters
DHPA | 3H-dihydroalprenolol
Dia | Diastolic
DIL | Diltiazem
DL | Diastolic length
DM | Diabetes mellitus
DPA (22:5 n-3 or n-6) | Docosapentaenoic acid
DRI | Dietary References Intakes
DTS | Dense tubular system
DXR | Doxorubicin
EA | Electrical automaticity/excitability
EAR | Estimated Average Requirement
ECG | Electrocardiogram
EC50 | That concentration needed to produce a 50% effect
e.e. | ethylated
EFA | Essential fatty acid
endo | endocardial
EPA (20:5 n-3) | Eicosapentaenoic acid
EPA-e | EPA esters
EPC | Evidence-based Practice Center
Epi | epicardial
ET-1 | Endothelin-1
ETYA | Eicosatetraynoic acid
F | Frequency
FAC | Fatty acid composition
FDA | Food and Drug Administration
FO | Fish Oil
FOC | Force of contraction
FRGS | Free radical generating system
FVR | Force-velocity relationship (Vmax, initial muscle length, maximum extent of twitch muscle shortening, time to peak shortening, positive peak of the normalized force derivative of the fully isometric twitch, total isometric force normalized per cross-sectional area, time to peak force)
G | Government
GLA (18:3 n-6) | Gamma linolenic acid
HC | High Cholesterol
HDL | High density lipoprotein
HF | High fat
HTN | Hypertension
Hy RMP | Hyperpolarizing
I | Industry
I | Increased (when in footnote of table)
I_Ca.L_ | Voltage dependent L-type Ca^2+^ current/inward Ca^2+^ current/Ca^2+^ sparks
I_Ca_-V | Calcium current-voltage
ICH | Ion channel
I_Cl.Ca_ | Caffeine and Neurokinin A elicited Ca^2+^ dependent Cl^-^ current
ICU | Ion currents
IC50 | That concentration that produces a 50% reduction in the effect
I_K_ | Delayed rectifier K^+^ current
I_KI_ | Inward rectifier K^+^ current or tail current
I_KUR_ | Ultra rapid potassium current
IL | Interleukin
InAc | Inactivation parameter
In | Ionomycin
I_Na_ | Sodium current
INDO | Indomethacin
InsP | Inositol phosphate
IOM | Institute of Medicine
IP | Inotropic Parameters
IPIM | - Ion pumps and ion movement
IS | Infarct size
ISO | Isoproteronol;
I_SUS_ | Outward K^+^ current
I_to_ | Transient K^+^ outward current or initial outward current
K^+^ | Potassium
KCl | Potassium chloride
Kd | Affinity
KRB | Krebs Ringer bicarbonate
L | Membrane leakiness
L | Resting cell length (inotropic measure in contractile parameter table)
LA (18:2 n-6) | Linoleic acid
LC PUFA | Long-chain polyunsaturated fatty acid
LD | Lactate dehydrogenase
LDL | Low density lipoprotein
LIN | Linseed Oil
LP | Lipoprotein
LPC | lysophosphatidylcholine
LPS | lipopolysaccharide
LT | Leukotriene
LVH | Left ventricular hypertrophy
Mag | Magnitude
MAP | Monophasic action potential duration
MDP | Maximal diastolic potential
m.e. | Methyl ester
MenO | Menhaden oil
MEX | Mexiletine
Mg | Magnesium ATPase
MI | Myocardial infarction
MO | Mitochondrial oligomycin sensitive ATPase
MP | Metabolites and pathways
MUFA | Monounsaturated fatty acit
N | Non-government / non-profit
Na | Sodium
Na^+^ | Sodium
NA | Not available
Nad | Sodium dependent
Na/K | Sodium potassium
NB | No blocks
NC | No change
Na/H exch | Sodium/hydrogen exchanger
NCHS | National Center for Health Statistics
ND | No data
NDGA | Nordihydroguiarectic acid
NEMC | New England Medical Center
NEU | Neurokinin
NHANES III | National Health and Nutrition Examination 1988-1994
NIH | National Institutes of Health
NIT | Nitrendipine
NorEpi | Norepinephrine
NP | Not for Profit
O | Other (in evidence table)
O2 | Oxygen
ODS | Office of Dietary Supplements
OO | Olive Oil
OS | overshoot potential
OUA | Ouabain
OvAI | ovalbumin
P | Prevented (when in footnote of table)
PAA | Phenylalkylamine
PAI | Plasminogen activator inhibitor
Pas | Passive
PCL | Percent cell length
PE/A | Pump efficiency or affinity for ATP
PG | Prostaglandin
PHE | Phenylephrine
PIR | Poverty Income Ratio
PLC-b | Receptor mediated phospholipase C
PPAR | Peroxisome proliferator activated receptor
PRP | Post rest potentiation
PTC | Palmitoylcarnitine
PUFA | Polyunsaturated fatty acid
QRS | Ventricular conductance time
Qt | Electrocardiogram interval
RCL | Resting cell length
RDA | Recommended Dietary Allowances
RDT | Resting/developed tension
ReOxy | Reoxygenation
RO | Rapeseed oil (canola oil)
RP | Resting potential
RRP | Relative refractory period
RSE | Relative standard error
SAF | Safflower Oil
SC | Spontaneous contraction
SCL | Systolic cell length
SC-RAND | Southern California-RAND
SD | Standard deviation
SEM | Standard error of the mean
SF | Saturated fat
SFA | Saturated fatty acid
SL | Sarcolemma
SM3 | Synthesized medium for omega-3 group
SM6 | Synthesized medium for omega-6 group
SR | Sarcoplasmic reticulum
SREBP | Sterol regulatory element binding protein
STA or STD | Standard
SUP | Supplement
Sys | Systolic
T | Terminated (when in footnote of table)
TA | Twitch amplitude
TC | Total cholesterol
tC_20_ | Contracting coupling delay
TD | Time dependent
TEP | Technical Expert Panel
Tg | Triglycerides
TIC | Time constant of I_to_ inactivation
TIM | Timolol
TNF | Tumor necrosis factor
TPA | Tissue plasminogen activator
TS | Twitch size
TSR | Time in sinus rhythm
TT FA | Total Fatty Acids
Tx | Thromboxane
UO | University of Ottawa
USDA | United States Department of Agriculture
VCAM | Vascular cell adhesion molecule
VEB | Ventricular ectopic beats
VEN | Ventricular
VER | Verapamil
VERP | Left ventricular effective refractory period
VF | Ventricular fibrillation
VFT | Ventricular fibrillation threshold
VLDL | Very low density lipoprotein
VLN-3FA | Very long chain n-3 fatty acid
V_max_ | Maximum rate of depolarization
VP | Vasopressin
VPB | Ventricular premature beat
VS | Velocity of shortening
VSRM | Voltage-sensitive release mechanism
VT | Ventricular tachycardia
W/W | Weight-by-weight

## Parameters

### Arrhythmia-related parameters used in this report

Category | Sub Categories
Ion Channels, Pumps and Currents | • Basal Electromechanical Parameters
| - Resting potential (RP)
| - Action Potential Threshold (APT)
| - Action Potential Amplitude (APA)
| - Action Potential Duration at 40% repolarization (ADP_40_)
| - Action Potential Duration at 80% repolarization (ADP_80_)
| - Maximum rate of depolarization (V_max_)
| - Maximum Diastolic Potential (MDP)
| - Overshoot potential or overshoot plateau potential (OS)
| • Ion Currents
| - Initial fast Na^+^ current (I_Na_)
| - Initial outward K^+^ current/Transient K^+^ outward current (I_to_)
| - Voltage dependent L-type Ca^2+^ current/Inward Ca^2+^ current/Ca^2+^ sparks (I_Ca.L_)
| - Delayed rectifier K^+^ current (I_K_)
| - Inward rectifier K^+^ current (I_KI_) or tail current
| - Caffeine and Neurokinin A elicited Ca^2+^ dependent Cl^-^ current (I_Cl.Ca_)
| - Outward K^+^ current (I_SUS_)
| - Receptor mediated Ca^2+^ permeable non selective cation currents (?)
| - Kv4.3 current (?)
| • Ion Channels
| - Slow Ca^2+^ channel and L-type Ca^2+^ channel
| - Delayed rectifier K^+^ channel
| - Kv1.1, Kv2.1 and Kv1.5 channels
| - Na^+^-K^+^-2Cl^-^ cotransporter
| • Ion Pumps and Ion Movement
| - Sodium Pump or Na, K-ATPase
| - Ca^2+^ influx or uptake or rise or cytosolic free Ca^2+^
| - Na^+^ dependent Ca^2+^ influx
| - Na^+^/H^+^ uptake
| - Passive Ca^2+^ efflux
| - Na^+^ uptake
| - Sarcoplasmic reticulum (SR) Ca^2+^ content or release
Contractile Parameters | • Inotropic parameters (IP)
| - Frequency (_F_)
| - Amplitude (_A_)
| - Duration (_D_)
| - Resting cell length (_L_)
| • Arrhythmia (AR)
| • Action Potential Rate, or beating rate or frequency, or contraction rate (APR)
| • Contraction coupling delay (tC_20_)
| • Contraction duration at 20% relaxation (CD_20_)
| • Contraction duration at 80% relaxation (CD_80_)
| • Relaxation time (-C_max_)
| • Cell shortening velocity (+C_max_)