# Summary Tables

Summary Table 3-1. Summary of Study Design and Outcomes Evaluated in Whole Animal Studies (23 feeding and 3 infusion studies) *

Table 3-1 Summary Table 3-1. Summary of Study Design and Outcomes Evaluated in Whole Animal Studies (23 feeding and 3 infusion studies) *

Author, Year | Omega-3 Arm(s) | Control Arm* | Animals | Outcomes Evaluated
| | | | VF | VT | VPB | AS | Deaths | IS | TSR | VFT
Feeding studies:
Omega-3 PUFAs vs Omega-6 PUFAs
Abeywardena, 1995 | Soybean, MaxEPA™ | SSO | Rats | v | v | v | v | v
Anderson, 1996 | MaxEPA™ | Safflower | Rats | v | v | v | v
Charnock, 1992 | Fish oil | SSO | Monkeys | v | | | | | | | v
Charnock, 1991 | Fish oil | SSO | Rats | v | v | v | v
Hock, 1990 | Menhaden | Corn | Rats | v | | | v | v
Hock, 1987 | Menhaden | Corn | Rats | | | v | | v
Isensee, 1994 | Linseed, Fish oil | Corn | Rats | v | v | | | | v | v
McLennan, 1995 | Canola, Soybean | SSO | Rats | v | v | v | v | v
McLennan, 1992 | Tuna | SSO | Monkeys | v | | | | | | | v
McLennan, 1993 | Fish oil | SSO | Rats | v | v | v | v | v | | v
McLennan, 1990 | Tuna | SSO | Rats | v | v | v | v | v | | v
McLennan, 1988 | Tuna | SSO | Rats | v | v | | v | v | v
McLennan, Bridle, 1993 | Fish oil | SSO | Monkeys | v | | | | | | | v
Omega-3 PUFAs vs MUFAs
McLennan, 1996 | EPA-e, DHA-e, EPA-e+DHA-e | Olive | Rats | v | | | v
Omega-3 PUFAs vs SFAs
al Makdessi, 1995 | Sardine | Coconut | Rats | | | | | | v | v
Chen, 1994 | Fish oil | Coconut | Rabbits | | | v | | v
Hartog, 1987 | Mackerel | Lard | Piglets | v | v | v | | v
Pepe, 1996 | Fish oil | Sheep fat | Rats | v | v | v | | | | | v
Yang, 1993 | Fish oil | Butter | Rats | v | v
Omega-3 PUFAs vs Chows
Culp, 1980 | Menhaden | Friskies Dinner | Dogs | | | v | | v | v
Kinoshita, 1994 | EPA-e | Oriental Yeast Co. | Dogs | v | v | v | v
Oskarsson, 1993 | MaxEPA™ | Chows | Dogs | | | | | | v
Otsuji, 1993 | EPA-e | Oriental Yeast Co. | Dogs | | | | | v | v | v
| Total = | | | 17 | 12 | 12 | 10 | 11 | 6 | 5 | 4
Infusion studies:
Omega-3 PUFAs vs Omega-6 PUFAs
Billman, 1999 | Albumin-bound ALA, EPA, DHA | Soybean or saline | Dogs | v
Billman, 1994 | Fish oil emulsion | Soybean | Dogs | v
Omega-3 PUFAs vs Chows
Lo, 1991 | ALA | Buffer | Dogs | | v | v
| Total = | | | 2 | 1 | 1

SSO = sunflower seed oil; VF=ventricular fibrillation; VT=ventricular tachycardia; VPB=ventricular premature beats; AS=arrhythmia score; IS=infarct size; VFT=ventricular fibrillation threshold, measured only in VF inducible animals; TSR =length of time in normal sinus rhythm; EPA-e = EPA esters; DHA-e = DHA esters

* For the purposes of our evidence review, only optimal comparison group was chosen. See Chapter 2: Methods.

Summary Table 3-2. Summary Of Study Design And Outcomes Evaluated In Whole Animal/Isolated Organ And Cell Studies

Summary Table 3-2. Summary Of Study Design And Outcomes Evaluated In Whole Animal/Isolated Organ And Cell Studies

Author | Species | Stage | Sex | Omega-3 | Ctrl | Omega-3 | Omega-3 | ICU | ICH | IPIM | BEP | CP
Croset, 1989a | Mouse | W | M | STD+DHA-DOSE | STD | | | | | v
Croset, 1989b | Mouse | W | M | ALAe | OO+SAF | EPAe | DHAe | | | v
Benediktsdottir, 1988 | Rat | A | M | CLO | CO | | | | | v
Demaison, 1993 | Rat | W | M | LIN | SF | | | | | | | v
Karmazyn, 1987 | Rat | W | M+F | STD+CLO | STD | | | | | v | v
Laustiola, 1986 | Rat | W | M | STD+CLO | STD | | | | | | | v
Leifert, 2000 | Rat | YA | M | FO | LARD | | | v | | | | v
Minarovic, 1997 | Rat | YA | M | FO | HF | | | v | v
Taffet, 1993 | Rat | YA | F | CO+MenO | CO | | | | | v
Maixent, 1999 | Rat | A | M | STD+FO | STD | | | | | v
Chen, 1994 | Rabbit | A | M | HC+FO | HC | | | | | v
Heard, 1992 | Rat | A | M | SAF+MenO | SAF | | | | | | | v
Gudmundsdottir, 1991 | Rat | A,O | M | CLO | CO | | | v
Reig, 1993 | Rat | YA | M | HF+FO | HF | | | | | | v | v
Ku, 1997 | Rat | O | F | HC+EPA | HC | HC+DHA | | | | | | v
Honen, 2002 | Rat | A | M | FO | RO | | | | | v
Leifert, 2001 | Rat | A | M | FO | SF | | | | | v | | v
Pepe, 1999 | Rat | A,O | M | FO | N-6 | | | | | v
Swanson, 1989 | Mouse | W | M | SAF+MenO | SAF+CO | | | | | v
Gillis, 1992 | Rabbit | W | ND | FO | SAF | | | | | | v
Kinoshita, 1994 | Dog | A | ND | STD+EPAe | STF | | | | | v
| | | | | | | | 3 | 1 | 12 | 3 | 7

ICU=ion currents; ICH=ion channels; IPIM=ion pumps and ion channels; BEP=basel electromechanical parameters; CP=contractile parameters.

A=Adult

ALAe=Esterified alpha linoleic acid

CLO=cod liver oil

CO=corn oil

EPAe=Esterified eicosapentaenoic acid

FO=fish oil

HC=high cholesterol

HF=high fat

LIN=linseed oil

MenO=menhaden oil

N-6=nOmega-6 fatty acid

O=old

OO=olive oil

RO=rapeseed or canola oil

SAF=safflower oil

SF=saturated fat

STD=standard chow

W=weanling

YA=Young adult

Summary Table 3-3. Summary of Study Design and Outcomes Evaluated in Isolated Organ and cell Studies

Summary Table 3-3. Summary of Study Design and Outcomes Evaluated in Isolated Organ and cell Studies

Author | Species | Stage* | ICU | ICH | IPIM | BEP | CP
Bogdanov, 1998 | Rat | Adult | v | | | v
Courtois, 1992 | Rat | W | | | | | v
De Jonge, 1996 | Rat | W | | | | | v
Hallaq, 1990 | Rat | W | | | v | | v
Hallaq, 1992 | Rat | W | | v | v | | v
Honore, 1994 | Mouse | W | v | v
Jahangiri, 2000 | Rat | Adult | | | | | v
Kang, 1994 | Rat | W | | | | | v
Juan, 1987 | Guinea pig | Adult | | | | | v
Xiao, 2002 | Ferret | Adult | v
Kang, 1996 | Rat | W | | | v | | v
Leifert, 1999 | Rat | Adult | v
Leifert, 2000 | Rat | Adult | | | | | v
Rodrigo, 1999 | Rat, guinea pig | ND | v | | | | v
MacLeod, 1998 | Rat, guinea pig | Adult | v | | | | v
O'Neill, 2002 | Rat | Not sure | v | | v
Durot, 1997 | Rat | W | | | | v | v
Grynberg, 1988 | Rat | W | | | | v | v
Kang, 1995a | Rat | W | | | | v
Kang, 1997 | Rat | W | | v
Li, 1997 | Rat | W | | | | | v
Negretti, 2000 | Rat | ND | v | | v | | v
Pepe, 1994 | Rat | 2–3 mo | v | | v | | v
Phillipson, 1985 | Dog | ND | | | v
Phillipson, 1987 | Dog | ND | | | v
Grynberg, 1996 | Rat | W | | | | v | v
Kang, 1995b | Rat | W | | | | | v
Fournier, 1995 | Rat | W | | | | v | v
Grynberg, 1995 | Rat | W | | | | | v
Ferrier, 2002 | Guinea pig | Adult | v | | | | v
Reithman, 1996 | Rats | W | | | | v | v
Ponsard, 1999 | Rats | W | | | | | v
Xiao, 1997 | Rats | Adult | v | | v
Xiao, 1995 | Rats | W | v
Goel, 2002 | Pig | Adult | | | v
Vitelli, 2002 | Rats | Adult | | | v
Weylandt,1996 | Rats | W | | | | v
Rinaldi, 2002 | Rats | Adult | | | v | v
Bayer, 1979 | Cat | Adult | | | | v
Total | | | 12 | 3 | 12 | 10 | 23

ICU=ion currents; ICH=ion channels; IPIM=ion pumps and ion channel movement; BEP=basal electromechanical parameters; CP=contractile parameters.

* Stage: ND=no data; W = weanling

Summary Table 3-4. Total Deaths in Ischemia-Reperfusion-Induced Arrhythmia: Comparison of Rates Fed Omega-3 Fatty Acids With Controls Fed Omega-6 PUFA Oils

Summary Table 3-4. Total Deaths in Ischemia-Reperfusion-Induced Arrhythmia: Comparison of Rates Fed Omega-3 Fatty Acids With Controls Fed Omega-6 PUFA Oils

Author, Year | Omega-3 Arms | Dosage, g/100 g | Duration | Omega-3 Fatty Acids | | Control | | RR (95% CI) | Experiment Protocols
| | | | Event | Total | Event | Total
ALA Oils
Abeywardena, 1995 | Soybean | 0.4 | 9 months | 2 | 18 | 1 | 18 | 2.0 (1.5–20) | 5-min ischemia; 10-min reperfusion
McLennan, 1995 | Soybean | 1.1 | 5 weeks | 3 | 10 | 2 | 10 | 1.5 (0.32–7.1) | 5-min ischemia; reperfusion
| | | | | | | | 1.3 (0.25–6.8)
McLennan, 1995 | Soybean | 1.1 | 5 weeks | 2* | 13 | 2^†^ | 14 | 0.20 (0.01–3.7) | 15-min ischemia; reperfusion
| | | | | | | | 1.3 (0.25–6.8)
McLennan, 1995 | Canola | 1.2 | 5 weeks | 0 | 10 | 2 | 10 | 0.20 (0.01–3.7) | 5-min ischemia; reperfusion
McLennan, 1995 | Canola | 1.2 | 5 weeks | 3^‡^ | 16 | 2^†^ | 14 | 1.1 (0.18–6.6) | 15-min ischemia; reperfusion
Meta-analysis: Total subjects = 133 | | | | 10 | 67 | 9 | 66 | 1.2 (0.51–2.6) | Random-effect model
Fish Oils (EPA+DHA)
Hock, 1987 | Menhaden | 1.0 | 4 weeks | 2^‡^ | 13 | 2^‡^ | 14 | 1.1 (0.18–6.6) | 15-min after ischemia without reperfusion
Hock, 1990 | Menhaden | 1.0 | 4 weeks | 5 | 21 | 13 | 22 | 0.40 (0.17–0.93) | 15-min ischemia; 24 h reperfusion
McLennan, 1993 | Fish oil | 2.6 | 12 weeks | 0 | 10 | 1* | 12 | 0.39 (0.02–8.7) | 5-min ischemia; 5-min reperfusion
McLennan, 1993 | Fish oil | 2.6 | 12 weeks | 0 | 14 | 1* | 13 | 0.31 (0.01–7.0) | 15-min ischemia; 5-min reperfusion
Abeywardena, 1995 | MaxEPA^™^ | 3.3 | 9 months | 0 | 18 | 1 | 18 | 0.33 (0.01–7.7) | 5-min ischemia; 10-min reperfusion
McLennan, 1988 | Tuna | 3.7 | 12 months | 0 | 10 | 0 | 10 | 1.0 (0.02–46) | 15-min ischemia; reperfusion
McLennan, 1990 | Tuna | 3.7 | 18 months | 0 | 7 | 0 | 7 | 1.0 (0.02–45) | 15-min ischemia; reperfusion
Meta-analysis: Total subjects = 169 | | | | 7 | 83 | 18 | 86 | 0.47 (0.23–0.93) | Random-effect model

RR=risk ratio=(omega-3 FA event rate)/(control's event rate)

* All deaths occured during ischemia procedure

† One death occured during ischemia procedure

‡ Deaths were observed 15-min after ischemia procedure without reperfusion

Summary Table 3-5. Sensitivity Analysis on Total Deaths In Ischemia-ReperfusionIinduced Arrhythmia: Comparison of Rats Fed Fish Oil With Controls Fed Omega-6 PUFA Oils

Summary Table 3-5. Sensitivity Analysis on Total Deaths In Ischemia-ReperfusionIinduced Arrhythmia: Comparison of Rats Fed Fish Oil With Controls Fed Omega-6 PUFA Oils

Sensitivity Analysis - Sequential Dropping of One Study Random Effects Model - Risk Ratio (D&L method)
Study Dropped | Study Year | Size | Total N | Risk Ratio | 95% CI | | 2P
| | | | | Low | High
Hock | 1987 | 27 | 142 | 0.41 | 0.19 | 0.86 | 0.018
Hock | 1990 | 43 | 126 | 0.64 | 0.19 | 2.14 | 0.47
McLennan | 1993 | 22 | 147 | 0.47 | 0.23 | 0.96 | 0.038
McLennan | 1993 | 27 | 142 | 0.48 | 0.24 | 0.97 | 0.041
Abeywardena | 1995 | 36 | 133 | 0.48 | 0.23 | 0.97 | 0.040
McLennan | 1990 | 14 | 155 | 0.46 | 0.23 | 0.92 | 0.028

Summary Table 3-6. Total VF Deaths: Comparison of Monkeys Fed Tuna Fish Oil With Controls Fed Sunflower Seed Oil (Omega-6 PUFA)*

Summary Table 3-6. Total VF Deaths: Comparison of Monkeys Fed Tuna Fish Oil With Controls Fed Sunflower Seed Oil (Omega-6 PUFA)*

Author, Year | Omega-3 Arms | Dosage, g/100 g | Duration | Omega-3 Fatty Acids | | Control | | Experiment Protocols
| | | | Event | Total | Event | Total
McLennan, 1992 | Tuna | 2.8 | 30 months | 0 | 16 | 3 | 13 | Control condition, ischemia, and isoproterenol (0.5 ug/kg body weight/minute) models

* Total ventricular fibrillation (VF) deaths were combined in control condition, ischemia, and isoproterenol models.

Summary Table 3-7. Ventricular Tachycardia in Ischemia-Induced Arrhythmias: Comparison of Rats Fed Omega-3 Fatty Acids With Controls Fed Omega-6 PUFA Oils

Summary Table 3-7. Ventricular Tachycardia in Ischemia-Induced Arrhythmias: Comparison of Rats Fed Omega-3 Fatty Acids With Controls Fed Omega-6 PUFA Oils

Author, Year | Omega-3 Arms | Dosage, g/100 g | Duration | Omega-3 Fatty Acids | | Control | | RR (95% CI) | Experiment Protocols
| | | | Event | Total | Event | Total
ALA Oils
Abeywardena, 1995 | Soybean | 0.4 | 9 months | 8 | 18 | 7 | 18 | 1.1 (0.53–2.5) | 5-min ischemia
McLennan, 1995 | Soybean | 1.1 | 12 weeks | 8 | 13 | 13 | 14 | 0.66 (0.42–1.0) | 15-min ischemia
McLennan, 1995 | Canola | 1.2 | 12 weeks | 12 | 16 | 13 | 14 | 0.81 (0.59–1.1) | 15-min ischemia
Isensee, 1994 | Linseed | 5.2 | 10 weeks | 6 | 10 | 4 | 9 | 1.4 (0.56–3.3) | 20-min ischemia
Meta-analysis: Total subjects = 112 | | | | 34 | 57 | 37 | 55 | 0.82 (0.65–1.0) | Random-effect model
Fish Oils (EPA+DHA)
Charnock, 1991 | Fish oil | 2.1 | 12 months | 7 | 10 | 10 | 10 | 0.71 (0.41–1.1) | 15-min ischemia
McLennan, 1993 | Fish oil | 2.6 | 12 weeks | 5 | 14 | 12 | 13 | 0.39 (0.19–0.79) | 15-min ischemia
Isensee, 1994 | Fish oil | 3.0 | 10 weeks | 0 | 10 | 4 | 9 | 0.10 (0.01–1.7) | 20-min ischemia
Abeywardena, 1995 | MaxEPA | 3.3 | 9 months | 1 | 18 | 7 | 18 | 0.14 (0.02–1.1) | 5-min ischemia
McLennan, 1988 | Tuna | 3.7 | 12 months | 2 | 10 | 8 | 10 | 0.25 (0.07–0.90) | 15-min ischemia
McLennan, 1990 | Tuna | 3.7 | 18 months | 4 | 7 | 4 | 7 | 1.0 (0.40–2.5) | 15-min ischemia
Meta-analysis: Total subjects = 136 | | | | 19 | 69 | 45 | 67 | 0.49 (0.29–0.83) | Random-effect model

Summary Table 3-8. Ventricular Tachycardia in Reperfusion-Induced Arrhythmias: Comparison of Rats Fed Omega-3 Fatty Acids With Controls Fed Omega-6 PUFA Oils

Summary Table 3-8. Ventricular Tachycardia in Reperfusion-Induced Arrhythmias: Comparison of Rats Fed Omega-3 Fatty Acids With Controls Fed Omega-6 PUFA Oils

Author, year | Omega-3 Arms | Dosage, g/100 g | Duration | Omega-3 Fatty Acids | | Control | | RR (95% CI) | Experiment Protocols
| | | | Event | Total | Event | Total
ALA oils
Abeywardena, 1995 | Soybean | 0.4 | 9 months | 13 | 17 | 7 | 18 | 2.0 (1.0–3.7) | 5-min Ischemia; 10-min Reperfusion
McLennan, 1995 | Soybean | 1.1 | 12 weeks | 9 | 10 | 7 | 10 | 1.3 (0.82–2.0) | 5-min Ischemia; 10-min Reperfusion
McLennan, 1995 | Soybean | 1.1 | 12 weeks | 7 | 11 | 9 | 13 | 0.92 (0.52–1.6) | 15-min Ischemia; 10-min Reperfusion
McLennan, 1995 | Canola | 1.2 | 12 weeks | 7 | 10 | 7 | 10 | 1.0 (0.56–1.8) | 5-min Ischemia; 10-min Reperfusion
McLennan, 1995 | Canola | 1.2 | 12 weeks | 4 | 13 | 9 | 13 | 0.44 (0.18–1.1) | 15-min Ischemia; 10-min Reperfusion
Meta-analysis: Total subjects = 125 | | | | 40 | 61 | 39 | 64 | 1.1 (0.73–1.6) | Random-effect model
Fish Oils (EPA+DHA)
Anderson, 1996 | MaxEPA | 41% of TT FAs | 8 weeks | 3* | 8 | 3* | 6 | 0.75 (0.23–2.5) | 20-min ischemia; reperfusion
McLennan, 1993 | Fish oil | 2.6 | 12 weeks | 6 | 10 | 10 | 12 | 0.72 (0.41–1.3) | 5-min Ischemia; 5-min Reperfusion
McLennan, 1993 | Fish oil | 2.6 | 12 weeks | 3 | 14 | 8 | 12 | 0.32 (0.11–1.0) | 15-min ischemia; 5-min reperfusion
Abeywardena, 1995 | MaxEPA | 3.3 | 9 months | 4 | 18 | 7 | 18 | 0.57 (0.20–1.6) | 5-min ischemia; 10-min reperfusion
McLennan, 1988 | Tuna | 3.7 | 12 months | 5 | 10 | 8 | 10 | 0.63 (0.31–1.3) | 15-min ischemia; reperfusion
McLennan, 1990 | Tuna | 3.7 | 18 months | 5 | 7 | 6 | 7 | 0.83 (0.48–1.5) | 15-min ischemia; 10-min reperfusion
Meta-analysis: Total subjects = 132 | | | | 26 | 67 | 42 | 65 | 0.68 (0.50–0.91) | Random-effect model

TT FAs = total fatty acids; RR = risk ratio; VF = ventricular fibrillation; VT = ventricular tachycardia

* Sustained VT and/or VF were excluded from the analyses

Summary Table 3-9. Ventricular Fibrillation in Ischemia-Induced Arrhythmias: Comparison of Rats Fed Omega-3 Fatty Acids With Controls Fed Omega-6 PUFA Oils

Summary Table 3-9. Ventricular Fibrillation in Ischemia-Induced Arrhythmias: Comparison of Rats Fed Omega-3 Fatty Acids With Controls Fed Omega-6 PUFA Oils

Author, Year | Omega-3 Arms | Dosage, g/100 g | Duration | Omega-3 Fatty Acids | | Control | | RR (95% CI) | Experiment Protocols
| | | | Event | Total | Event | Total
ALA oils
McLennan, 1995 | Soybean | 1.1 | 12 weeks | 5 | 13 | 6 | 14 | 0.90 (0.36–2.2) | 15-min ischemia
McLennan, 1995 | Canola | 1.2 | 12 weeks | 7 | 16 | 6 | 14 | 1.0 (0.45–2.3) | 15-min ischemia
Isensee, 1994 | Linseed | 5.2 | 10 weeks | 4 | 10 | 4 | 9 | 0.90 (0.31–2.6) | 20-min ischemia
Meta-analysis: Total subjects = 76 | | | | 16 | 39 | 16 | 37 | 0.95 (0.56–1.6) | Random-effect model
Fish Oils (EPA+DHA)
Charnock, 1991 | Fish oil | 2.1 | 12 months | 0 | 10 | 6 | 10 | 0.08 (0.00–1.2) | 15-min ischemia
McLennan, 1993 | Fish oil | 2.6 | 12 weeks | 0 | 14 | 5 | 13 | 0.08 (0.01–1.4) | 15-min ischemia
Isensee, 1994 | Fish oil | 3.0 | 10 weeks | 1 | 10 | 4 | 9 | 0.22 (0.03–1.7) | 20-min ischemia
McLennan, 1988 | Tuna | 3.7 | 12 months | 0 | 10 | 1* | 10 | 0.33 (0.02–7.3) | 15-min ischemia
McLennan, 1990 | Tuna | 3.7 | 18 months | 1 | 7 | 2 | 7 | 0.50 (0.06–4.3) | 15-min ischemia
Meta-analysis: Total subjects = 100 | | | | 2 | 51 | 18 | 49 | 0.21 (0.07–0.63) | Random-effect model

* Estimated from graph

Summary Table 3-10. Ventricular Fibrillation in Reperfusion-Induced Arrhythmias: Comparison of Rats Fed Omega-3 Fatty Acids With Controls Fed Omega-6 PUFA Oils

Summary Table 3-10. Ventricular Fibrillation in Reperfusion-Induced Arrhythmias: Comparison of Rats Fed Omega-3 Fatty Acids With Controls Fed Omega-6 PUFA Oils

Author, Year | Omega-3 Arms | Dosage, g/100 g | Duration | Omega-3 Fatty Acids | | Control | | RR (95% CI) | Experiment Protocols
| | | | Event | Total | Event | Total
ALA Oils
Abeywardena, 1995 | Soybean | 0.4 | 9 months | 4 | 17 | 2 | 18 | 2.1 (0.44–10) | 5-min ischemia; 10-min reperfusion
McLennan, 1995 | Soybean | 1.1 | 12 weeks | 5 | 10 | 5 | 10 | 1.0 (0.42–2.4) | 5-min Ischemia; Reperfusion
McLennan, 1995 | Soybean | 1.1 | 12 weeks | 3 | 11 | 3 | 13 | 1.2 (0.30–4.7) | 15-min ischemia; reperfusion
McLennan, 1995 | Canola | 1.2 | 12 weeks | 1 | 10 | 5 | 10 | 0.20 (0.03–1.4) | 5-min ischemia; reperfusion
McLennan, 1995 | Canola | 1.2 | 12 weeks | 0 | 13 | 3 | 13 | 0.14 (0.01–2.5) | 15-min ischemia; reperfusion
Isensee, 1994 | Linseed | 5.2 | 10 weeks | 6 | 10 | 7 | 9 | 0.77 (0.42–1.4) | 20-min ischemia; 20-min reperfusion
Meta-analysis: Total subjects = 144 | | | | 19 | 71 | 25 | 73 | 0.84 (0.52–1.3) | Random-effect model
Fish Oils (EPA+DHA)
Anderson, 1996 | MaxEPA™ | 41% of TT FAs | 8 weeks | 1* | 8 | 2* | 6 | 0.38 (0.04–3.2) | 20-min ischemia; reperfusion
Hock, 1990 | Menhaden | 1.2 | 4 weeks | 1^†^ | 7 | 9^†^ | 10 | 0.16 (0.03–0.99) | 15-min ischemia; 6-hr reperfusion
McLennan, 1993 | Fish oil | 2.6 | 12 weeks | 1 | 10 | 3 | 12 | 0.40 (0.05–3.3) | 5-min ischemia; 5-min reperfusion
McLennan, 1993 | Fish oil | 2.6 | 12 weeks | 0 | 14 | 1 | 12 | 0.29 (0.01–6.5) | 15-min ischemia; 5-min reperfusion
Isensee, 1994 | Fish oil | 3.0 | 10 weeks | 4 | 10 | 7 | 9 | 0.51 (0.22–1.2) | 20-min ischemia; 20-min reperfusion
Abeywardena, 1995 | MaxEPA™ | 3.3 | 9 months | 1 | 18 | 2 | 18 | 0.50 (0.05–5.0) | 5-min ischemia; 10-min reperfusion
McLennan, 1988 | Tuna | 3.7 | 12 months | 0 | 10 | 3 | 10 | 0.14 (0.01–2.5) | 15-min ischemia; reperfusion
McLennan, 1990 | Tuna | 3.7 | 18 months | 2 | 7 | 2 | 7 | 1.0 (0.19–5.2) | 15-min ischemia; reperfusion
Meta-analysis: Total subjects = 168 | | | | 10 | 84 | 29 | 84 | 0.4 (0.25–0.79) | Random-effect model

TT FA = total fatty acids; VT = ventricular tachycardia; VF = ventricular fibrillation

* Sustained VT and/or VF were excluded from the analyses

† VT or VF (%)

Summary Table 3-11. Ventricular Fibrillation in Induced Arrhythmia: Comparison of Monkeys Fed Fish Oils With Controls Fed Sunflower Seed Oil (Omega-6 PUFA)

Summary Table 3-11. Ventricular Fibrillation in Induced Arrhythmia: Comparison of Monkeys Fed Fish Oils With Controls Fed Sunflower Seed Oil (Omega-6 PUFA)

Author, Year | Omega-3 Arms | Dosage, (g/100 g) | Duration | Omega-3 Fatty Acids | | Control | | VFT^¶^ | Experiment Protocols
| | | | Event | Total | Event | Total
Electrical-Stimulation Arrhythmias^†^
McLennan, Bridle, 1993 | Fish oil | 1.8 | 16 weeks | 6 | 10 | 5 | 9 | +133% * | Electrical stimulation in control condition
Charnock, 1992 | Fish oil | 2.4 | 16 weeks | 8% | ND | 13% | ND | NS | Electrical stimulation in control condition
McLennan, 1992 | Tuna | 2.8 | 30 months | 10 | 16 | 8 | 13 | NS | Electrical stimulation in control condition
Electrical-Stimulation Arrhythmias in Ischemic Hearts^†^
McLennan, Bridle, 1993 | Fish oil | 1.8 | 16 weeks | 10 | 10 | 9 | 9 | +79% * | Electrical stimulation + 5-min ischemia
Charnock, 1992 | Fish oil | 2.4 | 16 weeks | Nil | ND | 13% | ND | NS | Electrical stimulation + ischemia
McLennan, 1992 | Tuna | 2.8 | 30 months | 12 | 16 | 8 | 13 | NS | Electrical stimulation + 5-min ischemia
Electrical-Stimulation Arrhythmias With Isoproterenol^†^
McLennan, Bridle, 1993 | Fish oil | 1.8 | 16 weeks | 3 | 10^‡^ | 7 | 9^‡^ | +55% * | Electrical stimulation + 30-min isoproterenol (0.5 ug/kg BW/min)
McLennan, Bridle, 1993 | Fish oil | 1.8 | 16 weeks | 5 | 10^‡^ | 9 | 9^‡^ | +75% | Electrical stimulation + 30-min isoproterenol (2.0 ug/kg BW/min)
McLennan, 1992 | Tuna | 2.8 | 30 months | 7 | 16 | 10 | 13 | NS | Electrical stimulation + 30-min Iisoproterenol (0.5 ug/kg BW/min)

ND = no data; BW = body weight; min = minute; VFT = ventricular fibrillation threshold, measured only in VF inducible animals; NS = no significant difference compared to controls

* P<0.05 compared to control animals

† Same monkeys underwent electrical stimulation in control condition, 5 minutes after ischemia. procedure, and 30 minutes after restoration of coronary blood flow during the infusion of isoproterenol.

‡ Same monkeys injected 0.5 ug/kg BW/min isoproterenol, then the dosage of isoproterenol was increased to 2.0 ug/kg BW/min.

¶ An increase in VFT is a desirable outcome for antiarrhythimic effects. See Chapter 2: Methods for the effects expressed as percent change.

Summary Table 3-12. Ventricular Premature Beats/Complex, Infarct Size, Arrhythmia Score and Length of Time in Normal Sinus Rhythm: Comparison of Rats Fed Omega-3 Fatty Acids With Controls Fed Omega-6 PUFA Oils

Summary Table 3-12. Ventricular Premature Beats/Complex, Infarct Size, Arrhythmia Score and Length of Time in Normal Sinus Rhythm: Comparison of Rats Fed Omega-3 Fatty Acids With Controls Fed Omega-6 PUFA Oils

Author, Year | Omega-3 Arms | Dosage, g/100 g | Duration | Total N | Arrhythmia Outcomes^1^ | | | | Experimental Protocols
| | | | | VPB | AS^2^ | IS | TSR^3^
ALA Oils
Abeywardena, 1995 | Soybean | 0.4 | 9 months | 36 | +176% | +107%* | - | - | 5-min ischemia; 10-min reperfusion
McLennan, 1995 | Canola | 1.1 | 5 weeks | 30 | -13% | -11% | - | - | 15-min ischemia
| | | | | -43% | -64% | - | - | 10-min reperfusion
McLennan, 1995 | Canola | 1.1 | 5 weeks | 20 | -19% | -41%* | - | - | 5-min ischemia; 10-min reperfusion
Isensee, 1994 | Linseed | 5.2 | 10 weeks | 20 | - | - | NS | NS | 20-min ischemia
McLennan, 1995 | Soybean | 1.2 | 5 weeks | 27 | -14% | -18% | - | - | 15-min ischemia
| | | | | -2% | -12% | - | - | 10-min reperfusion
McLennan, 1995 | Soybean | 1.2 | 5 weeks | 20 | +34% | +30% | - | - | 5-min ischemia; 10-min reperfusion
Fish Oils (EPA+DHA)
Anderson, 1996 | MaxEPA | 41% of TT FAs | 8 weeks | 14 | -31% | -54% | - | - | 20-min ischemia; reperfusion
Hock, 1990 | Menhaden | 1.0 | 4 weeks | 17 | - | -77%^†^ | - | - | 15-min ischemia; 6-hr reperfusion
Hock, 1987 | Menhaden | 1.0 | 4 weeks | 23 | NC | - | - | - | 15-min after ischemia w/o reperfusion
Charnock, 1991 | Fish oil | 2.1 | 12 months | 20 | -72%* | -59%* | - | - | 15-min ischemia
McLennan, 1993 | Fish oil | 2.6 | 12 weeks | 27 | -10% | -41%* | - | +12% | 15-min ischemia
| | | | | -31% | -63%* | - | +2% | 5-min reperfusion
McLennan, 1993 | Fish oil | 2.6 | 12 weeks | 22 | -27% | -48% | - | +16% | 5-min ischemia; 5-min reperfusion
Isensee, 1994 | Fish oil | 3.0 | 10 weeks | 20 | - | - | NS | Increased* | 20-min ischemia
Abeywardena, 1995 | MaxEPA | 3.3 | 9 months | 36 | -13% | -40% | - | - | 5-min ischemia; 10-min reperfusion
McLennan, 1990 | Tuna | 3.7 | 18 months | 14 | +6% | NS | - | -5% | 15-min ischemia
| | | | | -24%* | NS | | +21% | 10-min reperfusion
McLennan, 1988 | Tuna | 3.7 | 12 months | 20 | - | NS -44%* | +7%, NS | - | 15-min ischemia reperfusion

TT FAs = total fatty acids; VPB = ventricular premature beats/complex; IS = infarct size/size of ischemia zone; AS = arrhythmia score (according to Curtis et. al.); TSR =length of time in normal sinus rhythm; ISO = Isoproterenol

- Not reported NS = no significant difference compared to controls

* P<0.05 compared to controls

† P<0.01 compared to controls

1 See Methods for the effects expressed as percent change.

2 AS in all studies were calculated according to Curtis et al [Cardiovascular Research 22, 656–665], except Hock, 1990 used a modified method

3 An increase in TSR is a desirable outcomes for antiarrhythmic effects.

Summary Table 3-13. Arrhythmic Effects in Studies Comparing Omega-3 Long-Chain PUFAs with a Linolenic Acid

Summary Table 3-13. Arrhythmic Effects in Studies Comparing Omega-3 Long-Chain PUFAs with a Linolenic Acid

Author, Year | Omega-3 Arms | Dosage, g/100 g | Duration | Animal | Sample Size | Arrhythmia Outcomes | | | | | | | Experimental Protocols
| | | | | | Deaths | VT | VF | VPB/10 min | IS | AS | TSR^¶^, min
Abeywardena, 1995 | Soybean | 0.4 | 9 months | Rats | 18 | 11% | 76% | 23% | 298 | - | 3.1 | - | 5-min ischemia
| MaxEPA | 3.3 | 9 months | Rats | 18 | 0% | 22% | 5% | 94 | - | 0.9 | - | 10-min reperfusion
Isensee, 1994 | Linseed | 5.2 | 10 weeks | Rats | 10 | - | 60% | 40% | - | 35%* | - | 5.5*^†^ | 20-min ischemia
| | | | | | | - | 60% | | - | | - | 20-min reperfusion
| Fish oil | 3.0 | 10 weeks | Rats | 10 | - | 0% | 10% | - | 36%* | - | 10*^†^ | 20-min ischemia
| | | | | | | - | 40% | | - | | - | 20-min reperfusion

VT = ventricular tachycardia; VF = ventricular fibrillation; VPB = ventricular premature beats; IS = infarct size/size of ischemia zone; AS = arrhythmia score (according to Curtis et. al.); TSR = length of time in normal sinus rhythm; min = minute

- Not reported

* estimated value from figures

† p<0.05 between groups

¶ An increase in TSR is a desirable outcomes for antiarrhythmic effects

Summary Table 3-14. Total Deaths in Ischemia-Reperfusion-Induced Arrhythmias: Comparison of Animals Fed Fish Oil (EPA+DHA) With Controls Fed Saturated Fats

Summary Table 3-14. Total Deaths in Ischemia-Reperfusion-Induced Arrhythmias: Comparison of Animals Fed Fish Oil (EPA+DHA) With Controls Fed Saturated Fats

Author, year | Omega-3 Arms | Dosage, g/100 g | Duration | Omega-3 Fatty Acids | | Control | | Experiment Protocols
| | | | Event | Total | Event | Total
Rabbits
Chen, 1994 | Fish oil | 5.2 %kcal | 2 weeks | 3* | 12 | 5* | 14 | 10-min ischemia; 1-hr reperfusion
Chen, 1994 | Fish oil | 5.2 %kcal | 2 weeks | 6 ^†^ | 14 | 8 ^†^ | 15 | 1-hr ischemia; 4-hr reperfusion
Piglets
Hartog, 1987 | Mackerel | 0.6 | 16 weeks | 1 | 7 | 0 | 6 | 5-min ischemia; 10-min reperfusion

* Two deaths in each group occurred during reperfusion

† 50% deaths occurred during ischemia; 50% occurred during reperfusion

Summary Table 3-15. Ventricular Tachycardia in Ischemia-Reperfusion-Induced Arrhythmias: Comparison of Animals Fed Fish Oil With Controls Fed Saturated Fats

Summary Table 3-15. Ventricular Tachycardia in Ischemia-Reperfusion-Induced Arrhythmias: Comparison of Animals Fed Fish Oil With Controls Fed Saturated Fats

Author, year | Omega-3 Arms | Dosage, g/100 g | Duration | Omega-3 Fatty Acids | | Control | | Experiment Protocols
| | | | Event | Total | Event | Total
Rats
Pepe, 1996 | Fish oil | 5.2 | 16 weeks | 7 ^†^ | 20 | 14 ^†^ | 20 | 15-min ischemia; 10-min reperfusion
Piglets
Hartog, 1987 | Mackerel | 0.6 | 16 weeks | 2* | 7 | 1* | 6 | 5-min ischemia; 10-min reperfusion

1 All events occurred during ischemia procedure

† Some events occurred during ischemia; some occurred during reperfusion

Summary Table 3-16. Ventricular Tachycardia in Ischemia-Reperfusion-Induced Arrhythmias: Comparison of Animals Fed Fish Oil With Controls Fed Saturated Fats

Summary Table 3-16. Ventricular Tachycardia in Ischemia-Reperfusion-Induced Arrhythmias: Comparison of Animals Fed Fish Oil With Controls Fed Saturated Fats

Author, year | Omega-3 Arms | Dosage, g/100 g | Duration | Omega-3 Fatty Acids | | Control | | Experiment Protocols
| | | | Event | Total | Event | Total
Rats
Pepe, 1996 | Fish oil | 5.2 %kcal | 16 weeks | 0 | 20 | 16 | 20 | 15-min ischemia; 10-min reperfusion
Yang, 1993 | Fish oil | 5.4 %kcal | 5 days | 3 * | 8 | 7* | 9 | 15-min ischemia; 10-min reperfusion
Piglets
Hartog, 1987 | Mackerel | 0.6 | 16 weeks | 3 ^†^ | 7 | 0 | 6 | 5-min ischemia; 10-min reperfusion

* VT (%) or VF (%). All events occurred during reperfusion

† Some events occurred during ischemia; some occurred during reperfusion

Summary Table 3-17. Ventricular Premature Beats in Ischemia-Reperfusion-Induced Arrhythmias: Comparison of Animals Fed Fish Oil With Controls Fed Saturated Fats

Summary Table 3-17. Ventricular Premature Beats in Ischemia-Reperfusion-Induced Arrhythmias: Comparison of Animals Fed Fish Oil With Controls Fed Saturated Fats

Author, Year | Omega-3 Arms | Dosage, g/100 g | Duration | Animals | Total N | VPB ^1^ | Experiment Protocols
Ischemia-Induced Arrhythimas
Chen, 1994 ^2^ | Fish oil | 5.2 %kcal | 2 weeks | Rabbits | 22 | -50% | 10-min ischemia
| | | | | | -35% | 1-hr ischemia
Hartog, 1987 | Mackerel | 0.6 | 16 weeks | Piglets | 13 | +53% | 5-min ischemia
Pepe, 1996 | Fish oil | 5.2 %kcal | 5 days | Rats | 40 | -73%* | 15-min ischemia
Reperfusion-Induced Arrhythimas
Chen, 1994 ^2^ | Fish oil | 5.2 %kcal | 2 weeks | Rabbits | 22 | 0% | 10-min ischemia; 1-hr reperfusion
| | | | | | -25% | 1-hr ischemia; 4-hr reperfusion
Hartog, 1987 | Mackerel | 0.6 | 16 weeks | Piglets | 13 | -65%* | 15-min ischemia; 10-min reperfusion

VPB = ventricular premature beat

* P<0.05

1 See Chapter 2: Methods for the effects expressed as percent change

2 Study results were biased by excluding more subjects who died from

Summary Table 3-18. Total Deaths in Induced Arrhythmias: Comparison of Dogs Fed EPA and/or DHA With No Treatment Controls

Summary Table 3-18. Total Deaths in Induced Arrhythmias: Comparison of Dogs Fed EPA and/or DHA With No Treatment Controls

Author, Year | Omega-3 Arms | Dosage, g/100 g | Duration | Omega-3 Fatty Acids | | Control | | Experiment Protocols
| | | | Event | Total | Event | Total
Culp, 1980 | Menhaden | 3.3 %kcal | 5~7 weeks | 3 | 10 | 5 | 17 | Coronary artery thrombosis induced by electrical stimulation
Otsuji, 1993 | EPA ester | 1.0 | 8 weeks | 0 | 10 | 5 | 15 | Coronary artery ligation (or ischemia)

Summary Table 3-19. Ventricular Premature Beats/Complex, Infarct Size, Arrhythmia Score and Areas at Risk of Arrhythmias: Comparison of Dogs Fed EPA and/or DHA With No Treatment Controls

Summary Table 3-19. Ventricular Premature Beats/Complex, Infarct Size, Arrhythmia Score and Areas at Risk of Arrhythmias: Comparison of Dogs Fed EPA and/or DHA With No Treatment Controls

Author, Year | Omega-3 Arms | Dosage, g/100 g | Duration | Total N | Arrhythima Outcomes ^1^ | | | | Experimental Protocols
| | | | | VPB | AS ^3^ | IS | ARAr
Kinoshita, 1994 | EPA ester | 1.0 | 8 weeks | 20 | -44%* | -55% ^†^ | - | - | 3-hr ischemia
Culp, 1980 | Menhaden | 3.3 %kcal | 5~7 weeks | 27 | Decreased | - | -52% | - | Electrical stimulation
Otsuji, 1993 ^2^ | EPA ester | 1.0 | 8 weeks | 20 | - | - | -40%^†^ | NS | Ischemia
Oskarsson, 1993 | MaxEPA | 1.0 | 6 weeks | 22 | - | - | -55%* | NS | 90-min ischemia; 30-min reperfusion

VPB = ventricular premature beats/complex; IS = infarct size/size of ischemia zone; AS = arrhythima score (according to Curtis et al, 1987); TSR =length of time in normal sinus rhythm; ARAr = areas at risk of arrhythmias; ISH = ischemia

- Not reported NS = no significant difference compared to controls

* P<0.05 compared to controls

† p<0.01 compared to controls

1 See Chapter 2: Methods for the effects expressed as percent change

2 Study results were biased by excluding more subjects who died from arrhythmias in the control group

Summary Table 3-20. Effects of Intravenously Infused Omega-3 Fatty Acids on Ischemia-Induced or Spontaneous Arrhythmias in Mongrel Dogs

Summary Table 3-20. Effects of Intravenously Infused Omega-3 Fatty Acids on Ischemia-Induced or Spontaneous Arrhythmias in Mongrel Dogs

Author, Year | Omega-3 Arms (N) | Dosage | Controls (N) | Results | | | | Experiment Protocols
Billman, 1994 | 10 ml fish oil conc (n=4), or 5 ml fish oil + 5 ml Tg conc (n=4) | Fish oil conc.: 70% EPA+DHA | Saline (n=3) or lipid emulsion (n=5) | | [underlined: N] | [underlined: VF incidence] | | Exercise-ischemia (2-min) test
| | T conc.: 65% EPA+DHA | | Fish oil infusion | 8 | 13%*
| | | | Controls | 8 | 100%
| | | | *P<0.005 compared to controls
Billman, 1999 | Albumin-bound | 98% EPA | SBO lipid emulsion, containing 7%~8% ALA (n=7) | | [underlined: N] | [underlined: VF incidence] | | Exercise-ischemia (2-min) test
| ALA (n=8) | 91% DHA | | ALA | 8 | 25%*
| EPA (n=7) | >99% ALA | | EPA | 7 | 29%*
| DHA (n=8) | No data on the amount (ml) infused | | DHA | 8 | 25%*
| | | | Controls | 7 | 100%
| | | | *P<0.05 compared to controls
Lo, 1991 | ALA (n=8)^1^ | 1, 5, 10, 20, 30, or 60 mg/kg | Control buffer, pH 8.1 (no lipids) | Eight dogs were infused control buffer or different doses of ALA. No events of VT or VPB were observed when infusing control buffer, or ALA up to 10 mg/kg. | | | | Normal condition
| | | | ALA (mg/kg) | 20 | 30 | 60
| | | | VPC | 25% | 75% | 88%
| | | | VT | 13% | 38% | 63%
| | | | *P<0.05 compared to control buffer

Tg = triglyceride; VF = ventricular fibrillation; VPC = ventricular premature complex; VT = ventricular tachycardia; conc = concentrate; SBO = soybean oil

1 A left atrial injection instead of intravenous injection was used as the route of administration in this study

Summary Table 3-21. Effects of Omega-3 Fatty Acids on Contractile Parameters in Whole Animal Isolated Organ and Cell Studies

Summary Table 3-21. Effects of Omega-3 Fatty Acids on Contractile Parameters in Whole Animal Isolated Organ and Cell Studies

Author, Year | Animal Model [Type, Age, Sex] | Exposure Duration (Weeks) | Comparison Groups^a^ | | Amount of Omega-3 Fatty Acid | Experimental Condition | Agent^b^ | Heart Rate | Contractility^c^ | IP^d^ | Cardiac Work
| | | Omega-3 Fatty Acid (n) | Control (n)
RAT
Chemla, 1995 | Myocardium, Adult, Male | 4 | N-3 (15) | N-3 (16) | 15%wt | Ambient | None | | NC (FVR)
Demaison, 1993 | Isolated heart, weanling, male | 8 | LIN (29) | SF (32) | 100g/kg | Ambient | None | | | | NC
Heard, 1992 | Atrial tissue, adult, male | 4 | FO+SAF (6–11) | SAF (6–11) | 19.5%+0.5%wt | Ambient | ISO | | NC (FOC)
| | | FO+SAF (6–11) | SAF (6–11) | 19.5%+0.5%wt | Ambient | Saline | NC | NC (FOC)
| | | | | | | | | NC (df/dt)
| | | | | | | | | NC (-df/df)
| | | FO+SAF (6–11) | SAF (6–11) | 19.5%+0.5%wt | Ambient | LPS | D* | I* (FOC)
| | | | | | | | | I* (df/dt)
| | | | | | | | | I* (-df/df)
Ku, 1997 | Isolated heart, aged female | 12 | HC+EPA | HC | 300mg/kg | Ambient | None | NC
| | | HC+DHA | HC | 300mg/kg | Ambient | None | NC
| | | HC+DHA | HC+EPA | 300mg/kg | Ambient | None | NC
Leifert, 2000 | Ventricular myocyte, young adult, male (Gavage) | 3 | FO (29–36) | LARD (29–36) | 35g/d | Ambient | None | | | NC (DCL)
| | | | | | | | | | NC (SCL)
| | | | | | | | | | NC (PCL)
| | | | | | | | | | NC (PRP)
| | | FO (6 animals) | LARD (6 animals) | 35g/d | Ambient | ISO | | D*
| | | FO (6–9 animals) | LARD (6–9 animals) | 35g/d | Ambient | FRGS | | D*
Leifert, 2001 | Ventricular myocyte, adult male | 3 | FO (6 animals) | SF (6 animals) | 10%wt | Ambient | ISO | | D***
| | | | | | | | | D* (Time)
| | | | | | | | | NC (#)
Reig, 1993 | Ventricular tissue, young adult, male | 5 | FO (5) | HF (5) | 6%wt | Ambient | None | NC
Laustiola, 1986 | Atrial myocyte, weanling, male | 16 | CLO (7–11) | Std (7–11) | 10% wt | High O_2_ | None | D*** | | D*** (A)
| | | CLO (4–11) | Std (4–11) | 10% wt | High O_2_ | NA | NC | | NC (A)
| | | CLO (4–11) | Std (4–11) | 10% wt | Hypoxia | NA | D*** | | D*** (A)
| | | CLO (4–11) | Std (4–11) | 10% wt | Reoxygenation | NA | NC | | NC (A)

IP= inotropic parameters; D = decrease; I = increase; NA = not applicable ; NC = no change; ND= no data;

* = p<0.05

** = p<0.01;

*** = p<0.001

A = amplitude

CLO = cod liver oil

D = decrease

DCL =diastolic cell length

df/dt =maximum rate of rise of contraction

DHA =decosahexaenoic acid

EPAe =EPA esters

FO = fish oil

FOC =force of contraction

FRGS =free radical generating system

FVR =force-velocity relationship

HC = high cholesterol

HF = high fat

ISO =isoproteronol

LIN = linseed oil

LPS =lipopolysaccharide

PCL =percent cell length

PRP =post rest potentiation

SAF = safflower oil

SF = saturated fat

STD = standard chow

Summary Table 3-22. Effects of Omega-3 Fatty Acids on Basoelectromechanical Parameters in Whole Animal Isolated organ and Cell Studies

Summary Table 3-22. Effects of Omega-3 Fatty Acids on Basoelectromechanical Parameters in Whole Animal Isolated organ and Cell Studies

Author, Year | Animal Model [Type, Age, Sex] | Exposure Duration (Weeks) | Comparisons^a^ | | Amount of Omega-3 | Experiment Condition | Agent | VERP | ARP | RRP | QRS | QT | MAP | RDT
| | | Omega-3 Fatty Acid (n) | Control (n)
RAT
Reig, 1993 | Ventricular, young adult, male | 5 | FO+HF (5) | HF (5) | 6+31% wt | Ambient | None | D*
Karmazyn, 1987 | Isolated heart weanling male/female | 12 | CLO (5–9) | STD (5–9) | 10% wt | Ischemia | None | | | | | | | NC
RABBIT
Gillis, 1992 | SR vesicles, weanling, ND | 6 | FO (9) | SAF (9) | 10% wt | Ambient | None | NC | NC | NC | NC | NC | NC epi
| | | | | | | | | | | | | NC endo

VERP=left ventricular effective refractory period; ARP=absolute refractory period; RRP=relative refractory period; QRS=ventricular conductance time; Qt=electrocardiogram interval; MAP=monophasic action potential duration; RDT=developed or resting tention; D=decrease; I=increase; NA=not applicable; NC=no change; ND=no data;

* =p<0.05

** =p<0.01;

*** =p<0.001

CLO=cod liver oil

D=decrease

endo=endocardial

epi=epicardial

FO=fish oil

HF=high fat

NC=no change

ND=no data

SAF=safflower oil

STD=standard chow

SR=sarcoplasmic reticulum

Summary Table 3-23. Effects of Omega-3 Fatty Acids on Ion Pumps and Ion Movement in Whole Animal Isolated Organ and Cell Studies

Summary Table 3-23. Effects of Omega-3 Fatty Acids on Ion Pumps and Ion Movement in Whole Animal Isolated Organ and Cell Studies

Author, Year | Animal Model [Type, Age, Sex] | Feeding Duration (Weeks) | Comparison Groups^a^ | | Am-mount of Omega-3 | Experiment Condition | Agent | Pump^a^ Activity | Cys Ca^2+^ Influx | Cys Ca^2+^ Efflux | Cys Ca^2+^ Content | SR Ca^2+^ Content | SR Ca^2+^ Release | SR Ca^2+^ Uptake
| | | Omega-3 Fatty Acid (N) | Control (N)
MOUSE
Croset, 1989b | SR vesicles, weanling, male | 2 | ALA ester (3) | SAF (3) | 0.5%wt | Ambient | None | | | | | D*
| | | EPA ester (3) | SAF (3) | 0.5%wt | Ambient | None | NC SR _Ca2+Mg2+_ | | | | D*
| | | DHA ester (3) | SAF (3) | 0.5%wt | Ambient | None | NC SR _Ca2+Mg2+_ | | | | D*
Swanson, 1989 | SR vesicles, weanling, male | 2 | SAF+FO (3ht) | SAF+CO (3ht) | 10% wt | Ambient | None | D* Ca2+Mg2+ | | | | | | D**
Croset, 1989a | SR vesicles, weanling, male | 2 | DHA ester (10) | STD (10) | 0.4 g/100 g | Ambient | None | NC SR _Ca2+Mg2+_
| | | DHA ester (10) | STD (10) | 0.8 g/100 g | Ambient | None | NC SR _Ca2+Mg2+_
| | | DHA ester (10) | STD (10) | 4 g/100 g | Ambient | None | NC SR_Ca2+Mg2+_
| Cardiac, weanling, male | 2 | DHA ester (10) | STD (10) | 0.4 g/100 g | Ambient | Oligomycin | I* _Ca2+Mg2+_
| | | DHA ester (10) | STD (10) | 0.8 g/100 g | Ambient | Oligomycin | I* _Ca2+Mg2+_
| | | DHA ester (10) | STD (10) | 4 g/100 g | Ambient | Oligomycin | NC_Ca2+Mg2+_
RAT
Benedikts-dottir, 1988 | Cardiac, adult male | 16 | Cod liver (ND) | Corn (ND) | 10% wt | Ambient | None | NC _Na+K+_
Pepe, 1999 | Cardiac, aged & young adults, male | 2 | Fish oil (5) | Omega-6 (6) | 11.7% wt | Ambient | None | | | | NC
| | | Fish oil (5) | Omega-6 (6) | 11.7% wt | Ambient w/ NorEpi | None | | | | D* total
| | | | | | | | | | | D* aged
| | | | | | | | | | | NC young
| | | Fish oil (5) | Omega-6 (6) | 11.7% wt | 15-minute ischemia; 5-minute reperfusion | None | | | | D* aged
| | | | | | | | | | | D*** young
Taffet, 1993 | SR vesicle, young adult, female | 3 | CO+FO (11–12) | CO (11–12) | 17% wt | Ambient | None | | | | | | | D*
| | | CO+FO (11–12) | CO (11–12) | 17% wt | Ambient | Ca2+ 50uM ATP | D* SR
| | | | | | | | Ca2+Mg2+
| | | | | | | | D* Ca2+
| | | CO+FO (11–12) | CO (11–12) | 17% wt | Ambient | Ca2+ 50uM ATP+ Ionomycin | D* SR
| | | | | | | | Ca2+Mg2+
| | | | | | | | D* Ca2+
| | | | | | | | NC Mg2+
| | | CO+FO (11–12) | CO (11–12) | 17% wt | Ambient | Ca2+ 1 mM ATP+ Ionomycin | D* Ca2+Mg2+ | | | | D*
| | | | | | | | D* Ca2+
| | | | | | | | D*Mg2+
Leifert, 2001 | Cardiac, adult, male | 3 | Fish oil (8) | SFA (8) | 10% wt | Ambient | | | | | NC | NC
| | | Fish oil (8) | SFA (8) | 10% wt | Ambient | Caffeine | | | | | NC
| | | Fish oil (8) | SFA (8) | 10% wt | Ambient | DBHQ | | | | | NC | | I* _Ca2+ exchanger efflux_
| | | Fish oil (8) | SFA (8) | 10% wt | Ambient | ISO | | | | NC | | | I* _Ca2+ exchanger or SR efflux_
Black, 1989 | SR, adult, male (Gavage) | 4 | FO (6) | STD(6) | 0.5 ml/kg/d | Ambient | Ca^2+^ | | | | | | | NC_Ca2+ transport activity_
Karmazyn, 1987 | Ventricular, weanling, male/female | 12 | Cod liver (5–9) | STD (up to 11) | 10%wt | 20-minute ischemia; 30-minute reperfusion | None | | I** | NC
Maixent, 1999 | Cardiac, adult, male | 8 | Fish oil (4) | STD (4) | 0.5 g/kg | Ambient | OUA | NC _Na+K+_
Chen, 1994 | Cardiac, adult, male | 2 | Fish oil (5) | Coconut (5) | 10%wt | Ischemia | None | | | | NC
| | | Fish oil (5) | Coconut (5) | 10%wt | 10-minute ischemia; 1-hour reperfution | None | | | | NC
| | | Fish oil (5) | Coconut (5) | 10%wt | 1-hour ischemia; 4-hour reperfusion | None | | | | NC
Kinoshita, 1994 | Cardiac, adult ND | 8 | EPA ester (6) | STD (ND) | 100 mg/kg/d | Ambient | None | I* _Ca2+Mg2+ (Vmax)_
| | | | | | | | NC _Km_
| | | EPA ester (6) | STD (ND) | 100 mg/kg/d | Ischemic | None | I* _Ca2+Mg2+ (Vmax)_
| | | | | | | | NC _Km_
| | | EPA ester (6) | STD (ND) | 100 mg/kg/d | Ambient | OUA | NC _Na+K+_
| | | EPA ester (6) | STD (ND) | 100 mg/kg/d | Ischemic | OUA | NC _Na+K+_
Honen, 2002 | Atrial, adult, male | 3 | Fish oil (6) | Canola (6) | 3 ml/d | Ambient | None | | NC
PIG
Lamers, 1988 | Sarcolemma, weanling, male/female | 8 | Fish oil (8) | Lard (8) | 4.5%w | Ambient | Ca^2+^ | I*_Ca2+_
| | | | | | Ischemia Reper-fusion | Ca^2+^ | I*_Ca2+_

Cys= cytosolic; SR= sarcoplasmic reticulum; D = decrease; I = increase; NC = no change; ND= no data;

* = p<0.05

** = p<0.01;

*** = p<0.001

ALAe =alpha linoleic acid

ATP =adenosine triphosphate

CO = corn oil

D = decrease

DBHQ =2,4-Di-tert-buytlhydroquinone

DHA =decosahexaenoic acid

EPAe =eicosapentaenoic acid

FO = fish oil

I =increase

ISO =isoproteronol

Mg2+=magnesium

NC =no change

ND =no data

OUA =ouabain

SAF = safflower oil

SFA =saturated fatty acid

STD =standard chow

SR=sarcoplasmic reticulum

uM =micromoles

Summary Table 3-24. Effects of Omega-3 Fatty Acids on Ion Currents In Whole Animal Isolated Organ and Cell Studies

Summary Table 3-24. Effects of Omega-3 Fatty Acids on Ion Currents In Whole Animal Isolated Organ and Cell Studies

Author, year | Animal Model [Type, Age, Sex] | Exposure Duration (weeks) | Comparison Group^a^ | | Amount of Omega-3 | Expt. Condition | Agent | I_Na_ | I_to_ | I_CaL_ | I_K_ | I_KI_ | I_KUR_
| | | Omega-3 Fatty Acid (n) | Control (n)
RAT
Minarovic, 1998 | ventricular myocyte, Young adult, male | 2 | FO (ND) | HF (ND) | 100g/Kg/d | Ambient | None | | | NC Ac
| | | | | | | | | | NC InAc
| | | | | | | | | | NC A
Leifert, 2000 | ventricular myocyte, Young adult, male | 3 | FO (17–28) | LARD (17–28) | 29% Energy | Ambient | None | NC Ac | NC Ac
| | | | | | | | NC InAc | NC InAc

INa=initial fast current; Ito=transient K + outward current or initial outward current; Ica.L=voltage dependent L-type Calcium current/inward current/calcium sparks; I K=delayed rectifier K + current; Iki=inward rectifier K + current; Ikur=ultra rapid K + current; Ac-activation parameter; In Ac = inactivation parameter; D = decrease; I = increase; NC = no change; ND=no data;

* = p<0.05

** = p<0.01;

*** = p<0.001

A =amplitude

Ac =activation parameter

FO = fish oil

InAc =inactivation parameter

HF =high fat

NC =no change

Summary Table 3-25. Effects of Omega-3 Fatty Acids on Ion Channels in Whole Animal Isolated Organ and Cell Studies

Summary Table 3-25. Effects of Omega-3 Fatty Acids on Ion Channels in Whole Animal Isolated Organ and Cell Studies

Author, year | Animal Model [Type, Age, Sex] | Exposure Duration (weeks) | Comparison Groups^a^ | | Amount of omega-3 | Experimental Condition | Agent^b^ | Binding to the Ca^2+^ Channel
| | | Omega-3 FA (n) | Control (n)
RAT
Gudmundsdottir, 1991 | Ventricular SL, Adult, male | 20 | CLO (4–5) | CO (4–5) | 10% wt | Ambient | NIT | NC K_d_
| | | | | | | | NC B_max_
| Ventricular SL, Aged, male | 88 | CLO (4–5) | CO (4–5) | 10% wt | Ambient | NIT | NC K_d_
| | | | | | | | NC B_max_
| Ventricular SL, Adult & aged, male | 20 & 88 | CLO (5) | CO (5) | 10% wt | Ambient | NIT | D* K_d_
| | | | | | | | NC B_max_
Minarovic, 1997 | Ventricular myocytes, Young adult, male | 2 | FO (ND) | HF (ND) | 100g/kg | Ambient | VER | No effect of agent
| | | FO (ND) | HF (ND) | 100g/kg | Ambient | DIL | No effect of agent

D = decrease; I = increase; NC = no change; ND= no data;

* = p<0.05

** = p<0.01;

*** = p<0.001

CLO = cod liver oil

CO = corn oil

D = decrease

DIL =diltiazem

FA =fatty acid

FO = fish oil

HF = high fat

NC =no change

ND =no data

NIT =nitrendipine

VER =verapamil

Summary Table 3-26. Effects of Omega-3 Fatty Acids on Arrhythmogenic and Contractile Parameters in Isolated Organ and Cell Culture Studies

Summary Table 3-26. Effects of Omega-3 Fatty Acids on Arrhythmogenic and Contractile Parameters in Isolated Organ and Cell Culture Studies

Author, Year | Model [Animal, Age, Type] | Exposure Duration | Comparison Groups^a^ | | Am-ount of Omega-3 | Experi-mental Con-dition | Agent^b^ | AR^c^ | Con- Tractility^d^ | IP | tC_20_ | CD_20_ | CD_80_ | -C_max_ | +C_max_
| | | Omega-3 Fatty Acid (n) | Control (n)
RAT
Hallaq, 1992 | Rat, neonatal, ventricular | 1–2 min Free | DHA (6) | STD (6) | 5uM | Ambient | None | | NC
| | | DHA (10) | STD (10) | 5uM | Ambient | OUA | P* T*
| | | DHA (6) | STD (6) | 5uM | Ambient | NIT | | B*
| | | DHA (4) | STD (4) | 5uM | Ambient | BAY | | B*
| | | DHA (3–4) | STD (3–4) | 5uM | Ambient | VER | | NB
| | | DHA (3–4) | STD (3–4) | 5uM | Ambient | DIL | | NB
| | | EPA (ND) | STD (ND) | 5uM | Ambient | OUA | P*
Jahangiri, 2000 | Rat, adult, atrial | 7 minFree | EPA (107/7ht) | STD (107/7ht) | 10uM | Ambient | ISO | | D**
| | | DHA (101/5ht) | STD (101/5ht) | 10uM | Ambient | ISO | | D*
| | | DHA m.e. (71/4ht) | STD (71/4ht) | 10uM | Ambient | ISO | | NC
Kang & Leaf, 1994 | Rat, neonatal, cardiac | 3 minFree | ALA (5) | STD (5) | 5–10uM | Ambient | None | | D*
| | | EPA (46) | STD (46) | 5–10uM | Ambient | None | | D* | NC A
| | | EPA (ND) | STD(ND) | 5–10uM | Ambient | Var^a^ | | D*
| | | EPA (ND) | STD(ND) | 5–10uM | Ambient | Ca^2+^ | P* T*
| | | EPA (ND) | STD(ND) | 5–10uM | Ambient | OUA | P* T*
| | | EPAe.e.(3) | STD(3) | 5–10uM | Ambient | None | | NC
| | | DHA (32) | STD(32) | 5–10uM | Ambient | None | | D* | NC A
| | | DHA (ND) | STD(ND) | 5–10uM | Ambient | Ca^2+^ | P* T*
| | | DHA (ND) | STD(ND) | 5–10uM | Ambient | OUA | P* T*
Kang & Leaf, 1996 | Rat, neonatal, cardiac | 3–7 min free | ALA (5) | STD (5) | 10–15uM | Ambient | LPC | P* | D*
| | 3–7 min free | ALA (5) | STD (5) | 10–15uM | Ambient | PTC | P* T*
| | 3–7 min free | EPA (5) | STD (5) | 10–15uM | Ambient | LPC | P* T* | D*
| | 3–7 min free | EPA (5) | STD (5) | 10–15uM | Ambient | PTC | P* T*
| | 3–7 min free | EPA (5) | STD (5) | 10–15uM0 | Ambient | Ca^2+^ Ionophore | P* T*
| | 3–7 min free | EPA (7) | STD (7) | 15uM | Ambient | Electrical pacing | | D** EA
| | 3–7 min free | DHA (5) | STD (5) | 10–15uM | Ambien | LPC | P* | D*
| | 3–7 min free | DHA (5) | STD (5) | 10–15uM | Ambient | PTC | P* T*
Kang, 1995b | Rat, neonatal, cardiac | 5 min Free | EPA (4) | STD (4) | 8uM | Ambient | Cholera toxin | | D^ND^
| | | EPA (5–8) | STD (5–8) | 5–10uM | Ambient | ISO | P* T* | D^ND^
| | | EPA (3) | STD (3) | 5–10uM | Ambient | ISO+INDO+BW | P*
| | | EPA (5) | STD (5) | 5–10uM | Ambient | cAMP | T*
| | | DHA (3) | STD (8) | 5–10uM | Ambient | ISO+INDO+BW | P*
Leifert, 2000 | Rat, adult, ventricular | ND Free | DHA (5) | DA (5) | 10uM | Ambient | ISO | | D**
| | | DHA (4) | Stearic A (4) | 10uM | Ambient | LPC | | D**
| | | DHA (4) | Stearic A (4) | 10uM | Ambient | ISO | | D*
Li, 1997 | Rat, neonatal, cardiac | ND Free | EPA (ND) | STD (ND) | 10uM | Ambient | Eico | T* | D*
MacLeod, 1998 | Rat,adult, ventricular | 5 min Free | EPA (6–8) | STD (6–8) | 1–7.5uM | Ambient | None | | I^ND^ TS
| | | EPA (6–8) | STD (6–8) | >10uM | Ambient | None | | D^ND^ TS
| | | DHA (6–8) | STD (6–8) | 1–7.5uM | Ambient | None | | I^ND^ TS
| | | DHA (6–8) | STD (6–8) | >10uM | Ambient | None | | D^ND^ TS
Negretti, 2000 | Rat, adult ventricular | ND Free | EPA (6–57) | STD (6–57) | 10uM | Ambient | None | | D*** F | I*** RCL
Pepe, 1994 | Rat, adult, cardiac | 4 min Free | DHA (6) | STD (6) | 5 uM | Ambient | None | | NC DL
| | | | | | | | | NC TA
| | | | | | | | | NC VS/DL
| | | DHA (6) | STD (6) | 5 uM | Ambient | NIT | | B* TA
| | | | | | | | | B* VS/DL
| | | DHA (6) | STD (6) | 5 uM | Ambient | ISO | | NC TA
| | | | | | | | | NC DL
| | | DHA (6) | STD (6) | 5 uM | Ambient | BAY | | B* TA
| | | | | | | | | B* VS/DL
Rodrigo, 1999 | Rat, adult, ventricular | 10 min Free | EPA (8) | STD (8) | 5uM | Ambient | None | | D***TS
| Rat, adult, SSP ventricular | 10 min Free | EPA (5) | STD (5) | 5uM | Ambient | Ca^2+^ | | D* F
| | | | | | | | | NC Relax
| | | EPA (5) | STD (5) | 10uM | Ambient | Ca^2+^ | | D* F
| | | | | | | | | NC Relax
Weylandt, 1996 | Rat, neonatal, cardiac | 3–12min Free | EPA (8) | STD (8) | 15uM | Ambient | ISO | T*
| | | EPA (12) | STD (12) | 15uM | Ambient | Ca^2+^ | D*
| | | DHA (8) | STD (8) | 15uM | Ambient | ISO | T*
| | | DHA (12) | STD (12) | 15uM | Ambient | Ca^2+^ | D*
| | 3–12 min Free 48 hr Bound | DHA Free (23) | DHA Bound (23) | 15uM | Ambient | ISO | T*
| | | EPA Free (23) | EPA Bound (23) | 15uM | Ambient | ISO | T*
| | | DHA Free (10) | DHA Bound (10) | 15uM | Ambient | Ca^2+^ | D*
| | | EPA Free (10) | EPA Bound (10) | 15uM | Ambient | Ca^2+^ | D*
Courtois, 1992 | Rat, neonatal, ventricular | 24 hr Bound | SM3-Na-Al (5) | STD (5) | 28%ALA+ 30%EPA | Ambient | None | | NC | | | | NC | NC | NC
| | | SM3-Na-Al (5) | STD (5) | 28%ALA+ 30%EPA | Ambient | ISO | | D* | | | | NC | NC | NC
| | | SM3-Na-Al (5) | SM6-Na-Al (5) | 28%ALA+ 30%EPA | Ambient | None | | NC | | | | NC | NC | I**
| | | SM3-Na-Al (5) | SM6-Na-Al (5) | 28%ALA+ 30%EPA | Ambient | ISO | | NC | | | | NC | NC | NC
De Jonge, 1996 | Rat, neonatal, ventricular | 4–5 d Bound | EPA (4) | STD (4) | 214uM | Ambient | None | | D*
Durot, 1997 | Rat, neonatal, ventricular | 4 d Bound | SM3 (6) | SM6 (6) | 25uM EPA+ 25 uM DHA-Al | Ambient | None | | | | NC | NC | NC | NC | NC
| | | SM3 (6) | SM6 (6) | 25uM EPA+ 25uM DHA-Al | Hypoxia | None | | | | NC | NC | NC | NC | NC
| | | SM3 (6) | SM6 (6) | 25uM EPA+ 25uM DHA-Al | Reoxy | None | | | | NC | NC | NC | NC | NC
Fournier, 1995 | Rat, neonatal, ventricular | 4 d Bound | EPA (11) | DHA (11) | 100uM | Ambient | None | | | | NC | NC | NC | NC | NC
Grynberg, 1988 | Rat, neonatal, ventricular | 24 h Bound | SM3 (11) | SM6 (11) | 57%ALA +7%LA +0.2% AA-Na-Al | Ambient | None | | | | NC | | NC
| | | SM3 (11) | SM6 (11) | 57%ALA +7%LA +0.2% AA-Na-Al | Hypoxia | None | | | | NC | | NC
| | | SM3 (11) | SM6 (11) | 57%ALA +7%LA +0.2% AA-Na-Al | Reoxy | None | | | | NC | | NC
Grynberg, 1995 | Rat, neonatal, ventricular | 4 d Bound | EPA-Na-Al (12) | DHA-Na-Al (12) | 100uM | Ambient | None | | NC F | | | NC | NC | NC | NC
| | | EPA-Na-Al (6) | DHA-Na-Al (6) | 100uM | Ambient | ISO | | D* F | | | | NC
| | | EPA-Na-Al (6) | DHA-Na-Al (6) | 100uM | Ambient | Phe | | NC | | | | NC
| | | EPA-Na-Al (6) | DHA-Na-Al (6) | 100uM | Ambient | dBcAMP | | D*
Grynberg, 199 | Rat, neonatal, ventricular | 4 d Bound | EPA-Al (10) | DHA-Al (10) | 0.1mM | Ambient | None | | NC | | | NC | NC | NC | NC
| | 4 d Bound | EPA-Al (10) | DHA-Al (10) | 0.1mM | Ambient | Phe | | NC
| | 4 d Bound | EPA-Al (10) | DHA-Al (10) | 0.1mM | Ambient | ISO | | D**
| | 4 d Bound | EPA-Al (10) | DHA-Al (10) | 0.1mM | Ambient | dBcAMP | | D**
Hallaq, 1990 | Rat, neonatal | 3–5 d Bound | EPA (6) | STD (6) | 5uM | Ambient | None | | NC | NC A
| | | EPA (6) | STD (6) | 5uM | Ambient | OUA | | D*** | I***A
Ponsard, 1999 | Rat, neonatal, ventricular | 4 d Bound | EPA+DHA-Al (13) | STD (13) | 5%EPA+ 7%DHA | Ambient | None | | NC | | | NC | NC | NC | NC
| | | EPA+DHA-Al (7) | N-6 (7) | 5%EPA+ 7%DHA | Ambient | ISO | | I* | | | NC | NC | NC | NC
| | | EPA+DHA-Al (6) | N-6 (6) | 5%EPA+ 7%DHA | Ambient | PHE | | I* | | | NC | NC | NC | NC
Reithman, 1996 | Rat, neonatal, cardiac | 3 d Bound | DHA (15) | STD (15) | 60uM | Ambient | NA+TIM | D**
Weylandt, 1996 | Rat, neonatal, cardiac | 48 hr Bound | EPA (107) | STD (51) | 15uM | Ambient | ISO | NC
| | | EPA (20) | STD (14) | 15uM | Ambient | Ca^2+^ | NC
| | | DHA (51) | STD (13) | 15uM | Ambient | ISO | NC
| | | DHA (20) | STD (6) | 15uM | Ambient | Ca^2+^ | NC
| | | EPA (107) | DHA (51) | 15uM | Ambient | ISO | NC
| | | EPA (6–14) | DHA (6–14) | 15uM | Ambient | Ca^2+^ | NC
GUINEA PIG
Ferrier, 2002 | Guinea pig, adult, ventricular | 15–20 min Free | DHA m.e. (18–24) | STD (18–24) | 10uM | Ambient | None | | D***CICR
| | | | | | | | | NC VSRM
Juan, 1987 | Guinea pig, adult, isolated heart | 30 min Free | EPA-Na (8) | STD (8) | 6x10^-8^ mol/min | Ambient | OvAl | NC
| | | EPA-Na (8) | STD (8) | 15x10^-8^ mol/min | Ambient | OvAl | D*
| | | EPA-Na (5) | STD (5) | 15×10^-8^ mol/min | Ambient | OvAl+Es | D*
MacLeod, 1998 | Guinea pig, adult, ventricular | 5 min Free | EPA (6–8) | STD (6–8) | 5–20uM | Ambient | None | | D^ND^ TS dd
| | | DHA (6–8) | STD (6–8) | 5–20uM | Ambient | None | | D^ND^ TS dd
Rodrigo, 1999 | Guinea pig, adult, ventricular | 10 min Free | EPA (7) | STD (7) | 5uM | Ambient | None | | D***TS
| Guinea pig, adult, SSP ventricular | 10 min Free | EPA (5) | STD (5) | 5uM | Ambient | Ca^2+^ | | D* F
| | | | | | | | | NC Relax

AR = arrhthymia; IP = inotropic parameters; tC20 = contracting coupling delay; CD20 = contraction delay at 20% relaxation ; CD80 = contraction delay at 80% relaxation ; -Cmax = relaxation time; +Cmax = cell shortening velocity; D = decrease; I = increase; NC = no change; ND = no data;

* = p<0.05

** = p<0.01;

*** = p<0.001

A = amplitude

AI = adequate intake

ALA = alpha linoleic acid

AR = arrhythmia

B = blocked

BAY = Bay K8644

BW = BW 755c lipoxygenase inhibitor

cAMP = cyclic adenosine monophosphate

CICR = calcium induced contractile response

D = decrease

DA = amplitude

dBcAMP = dibutyryl cyclic adenosine monophosphate

DHA m.e. = decosahexaenoic acid methylated

DIL = diltiazem

DL = diastolic length

Eico = eicosanoids

EPA = eicosapentaenoic acid

EPAe.e. = eicosapentaenoic acid ethylated

Es = esculetin

F = frequency

INDO = indomethacin

IP = inotropic parameters

ISO = isoproteronol

LA = linoleic acid

LPC = lysophosphatidylcholine

N-6 = omega-6

NA+TIM = sodium and timolol

NB = no block

NC = no change

ND = no data

NIT = nitrendipine

OUA = ouabain

OvAI = ovalbumin

P = prevented

PHE = phenylephrine

PTC = palmitoylcamitine

RCL = resting cell length

SM3 = synthesized medium for omega-3 group

SM6 = synthesized medium for omega-6 group

STD = standard chow

T = terminated

TA = twitch amplitude

TS = twitch size

uM = micromoles

VER = verapamil

VS/DL = velocity of shortening/diastolic length

VSRM = voltage sensitive release mechanism

Summary Table 3-27. Effects of Omega-3 Fatty Acids on Basoelectromechanical Parameters in Isolated Organ and Cell Culture Studies

Summary Table 3-27. Effects of Omega-3 Fatty Acids on Basoelectromechanical Parameters in Isolated Organ and Cell Culture Studies

Author, Year | Model [Animal, Type, Age] | Exposure Duration | Omega-3 Fatty Acid (n) | Control (n) | Amount of Omega-3 | Experimental Condition | Agent | AP | APA | APD_40_ | APD_80_ | V_max_ | MDP | OS | Other
RAT
Bogdanov, 1998 | Rat, adult ventricular | 10–15 min Free | EPA (ND) | STD (ND) | 5–10uM | Ambient | None | I^ND^ | NC
| | | EPA (ND) | STD (ND) | 20uM | Ambient | None | | D^ND^ | I^ND^ | | D^ND^
| | | DHA (ND) | STD (ND) | 10–50uM | Ambient | None | | D^ND^ | I^ND^ | | D^ND^
Kang, 1995 | Rat, neonatal, ventricular | 2–5 min Free | EPA (8) | STD (8) | 10uM | Ambient | None | D*F | NC | | D** | NC
| | | | | | | | D**
MacLeod, 1998 | Rat, adult, ventricular | 5 min Free | EPA (11–14) | STD (11–14) | 1–7.5uM | Ambient | None | | | | I^ND^dd
| | | EPA (11–14) | STD (11–14) | >10uM | Ambient | None | | | | D^ND^dd
| | | DHA (6–8) | STD (6–8) | 1–7.5uM | Ambient | None | | | | I^ND^
| | | DHA (11–14) | STD (11–14) | >10uM | Ambient | None | | | | D^ND^dd
Durot, 1997 | Rat, neonatal, ventricular | 4 d Bound | SM3 (9) | SM6 (9) | 25uM EPA+25uM DHA-Al | Ambient | None | NC | NC | NC | NC | I* | NC | NC
| | | SM3 (5) | SM6 (5) | 25uM EPA+25uM DHA-Al | Hypoxia | None | NC | D* | D** | D* | NC | NC
| | | SM3 (5) | SM6 (5) | 25uM EPA+25uM DHA-Al | Reoxy | None | NC | NC | NC | NC | NC | Im
Fournier, 1995 | Rat, neonatal, ventricular | 4 d Bound | EPA (11) | DHA (11) | 100uM | Ambient | None | NC | I* | NC | NC | NC | NC | I*
Grynberg, 1988 | Rat, neonatal, ventricular | 24 h Bound | SM3 (11) | SM6 (11) | 57%ALA+ 7%LA+ +0.2% AA- Na-Al | Ambient | None | NC | NC | NC | NC | NC | NC | NC
| | | SM3 (11) | SM6 (11) | 57%ALA+7% LA+ +0.2% AA- Na-Al | Hypoxia | None | NC | D** | NC | NC | NC | NC | D*
| | | SM3 (11) | SM6 (11) | 57%ALA+ 7% LA +0.2% AA- Na-Al | Reoxy | None | NC | I** | NC | NC | NC | NC | I*
Grynberg, 1996 | Rat, neonatal, ventricular | 4 d Bound | EPA-Al (10) | DHA-Al (10) | 0.1mM | Ambient | None | | I* | | NC | NC | NC | I*
Reithman, 1996 | Rat, neonatal, cardiac | 3 d Bound | DHA (28–29) | STD (28–29) | 60uM | Ambient | None | NC | I*
| | | DHA (14–19) | STD (14–19) | 60uM | Ambient | NA+TIM | D*
| | | DHA (10–11) | STD (10–11) | 60uM | Ambient | ISO | D*
| | | DHA (4) | STD (4) | 60uM | Ambient | OUA | D*
GUINEA PIG
MacLeod, 1998 | Guinea pig, adult, ventricular | 5 min Free | EPA (12–16) | STD (12–16) | 1–20uM | Ambient | None | | | | D^ND^ dd
| | | DHA (12–16) | STD (12–16) | 1–20uM | Ambient | None | | | | D^ND^ dd
CAT
Bayer, 1979 | Cat, adult, heart in situ | 5 min Free IV | ALA-Na (7) | STD (7) | 2mg/kg/ min | Ambient | INDO | | | | | | | | NC _AC_
| | | | | | | | | | | | | | | NC _AVC_
| | | | | | | | | | | | | | | NC _ARP_
| | | | | | | | | | | | | | | NC
| | | | | | | | | | | | | | | AVRP

NC = no change; AP=action potential rate; APA= action potential amplitude; APD40= action potential duration at 40% depolarization; APD 80= action potential duration at 80% depolarization; Vmax= maximum rate of depolarization; MDP= maximum diastolic potential; OS= overshoot; I = increase; NC = no change; ND= no data;

* = p<0.05

** = p<0.01;

*** = p<0.001

AA =arachidonic acid

AC =intra-atrial conduction time

ALA = alpha linoleic acid

ARP =functional refractory period of the atrium

AVC =atrioventricular conductance time

AVRP =functional refractory period of atrioventricular conducting system

D = decrease

dd = dose dependent

DHA =decosahexaenoic acid

F =frequency

I =increased

INDO =indomethacin

ISO= isoproteronol

LA =linoleic acid

MDP= maximum diastolic potential

N-6 =omega 6

ND =no data

OS= overshoot

SM3=synthesized medium for omega-3 group

SM6 = synthesized medium for omega-6 group

STD = standard chow

SR =sarcoplasmic reticulum

uM =micromoles

Summary Table 3-28. Effects of Omega-3 Fatty Acids on lon Pumps and lon Movement in Isolated Organ and Cell Culture Studies

Summary Table 3-28. Effects of Omega-3 Fatty Acids on lon Pumps and lon Movement in Isolated Organ and Cell Culture Studies

Author, Year | Model [Animal, Type, Age] | Exposure Duration | Comparison Groups | | Amount of Omega-3 | Experimental Condition | Agent | Pump Activity | Cys. Ca^2+^ influx | Cys. Ca^2+^ efflux | Cys Ca^2+^ Content | SR Ca^2+^ Content | SR Ca^2+^ Uptake | SR Ca^2+^ Release | Exchanger | Other
| | | Omega-3 Fatty Acid (n) | Control (n)
RAT
Kang & Leaf, 1996 | Rat, neonatal, cardiac | 7min Free | EPA (6) | STD (6) | 10–15uM | Ambient | None | | | | NCs_ys_
| | | | | | | | | | | NC_dia_
| | | EPA (6) | STD (6) | 10–15uM | Ambient | LPC | | | | T_CaFlu_
Negretti, 2000 | Rat, ND ventricular | ND Free | EPA (46) | STD (46) | 10uM | Ambient | Ca^2+^ | | | | D***
| | | | | | | | | | | Bas
| | | EPA (4) | STD (4) | 5uM | Ambient | Caff | | | | | I*
| | | DHA (3) | STD (3) | 5uM | Ambient | Caff | | | | | I*
O'Neill, 2002 | Rat, ND ventricular | ND Free | EPA (46) | STD (46) | 10uM | Ambient | Ca^2+^ | | D* | NC | D^ND^Bas
| | | EPA (12) | STD (12) | 10uM | Ambient | Caff | | | NC
Pepe, 1994 | Rat, young adult, cardiac | 4 min Free | DHA (6) | STD (6) | 5uM | Ambient | None | | | | NC
| | | DHA (6) | STD (6) | 5uM | Ambient | NIT | | B* | | B*
| | | DHA (6) | STD (6) | 5uM | Ambient | BAY | | B* | | B*
| | | DHA (6) | STD (6) | 5uM | Ambient | ISO | | | | NC
Rinaldi, 2002 | Rat, adult, ventricular | 20 min vs 3 d Free | DHA+KCl (9) | DHA+KCL (9) | 10uM | Ambient | KCl | | | | D*mag of I
| | | DHA (9) | DHA (9) | 10uM | Ambient | KCl | | | | D** mag of I
| | | DHA (9) | DHA (9) | 10uM | Anoxia | None | | | | D**
| | | DHA (9) | DHA (9) | 10uM | Anoxia | KCl | | | | D**
| | | DHA (9) | DHA (9) | 10uM | Anoxia | ET-1 | | | | D**
| | 20 min free | DHA+ ET-1 (9) | STD (9) | 10uM | Ambient | ET-1 | | | | I**
| | | DHA (9) | STD (9) | 10uM | Ambient | ET-1 | | | | D**mag of I
| | | DHA (9) | STD (9) | 10uM | Ambient | None | | | | NC_bas_
| | | DHA +KCl (9) | STD (9) | 10uM | Ambient | KCl | | | | I***
| | | DHA (9) | STD (9) | 10uM | Ambient | KCl | | | | D**mag of I
| | | DHA+ET-1 (9) | STD (9) | 10uM | Ambient | ET-1 | | | | D**mag of I
| | | DHA (9) | STD (9) | 10uM | Ambient | ET-1 | | | | D**mag of I
| | | DHA (9) | STD (9) | 10uM | Anoxia | None | | | | D**mag of I
| | | DHA (9) | STD (9) | 10uM | Anoxia | KCl | | | | D**
| | | DHA (9) | STD (9) | 10uM | Anoxia | ET-1 | | | | D**
| | 3 d Free | DHA (9) | STD (9) | 10uM | Ambient | None | | | | NC_bas_
| | | DHA+KCl (9) | STD (9) | 10uM | Ambient | KCl | | | | I***
| | | DHA (9) | STD (9) | 10uM | Ambient | KCl | | | | D**mag of I
| | | DHA (9) | STD (9) | 10uM | Anoxia | None | | | | D**
| | | DHA (9) | STD (9) | 10uM | Anoxia | KCl | | | | D**
| | | DHA (9) | STD (9) | 10uM | Anoxia | ET-1 | | | | D**
Rodrigo, 1999 | Rat, adult, SSP ventricular | 10 min Free | EPA (5) | STD (5) | 5uM | Ambient | Ca^2+^ | | | | | | | D*
| | | EPA (5) | STD (5) | 10uM | Ambient | Ca^2+^ | | | | | | | D*
Vitelli, 2002 | Rat, adult, ventricular | 20 min Free | DHA (ND) | STD (ND) | 10uM | Ambient | Ca^2+^ free KRB | | | | NC_bas_
| | | DHA (ND) | STD (ND) | 10uM | Ambient | CaCl2 KRB | | | | NC_bas_
| | | DHA+ DXR (ND) | STD+ DXR (ND) | 10uM | Ambient | DXR+ Ca^2+^ free KRB | | | | D** | | | I*
| | | DHA+ DXR (ND) | STD (ND) | 10uM | Ambient | DXR+ Ca^2+^ free KRB | | | | NC
| | | DHA+ DXR (ND) | DHA (ND) | 10uM | Ambient | DXR+ Ca^2+^ free KRB | | | | NC
| | | DHA+ DXR (9) | STD+ DXR (9) | 10uM | Ambient | DXR+ CaCl2 KRB | | | | D** | | | I*
| | | DHA+ DXR (9) | STD (9) | 10uM | Ambient | DXR+ CaCl2 KRB | | | | NC
| | | DHA+ DXR (9) | DHA (9) | 10uM | Ambient | DXR+ CaCl2 KRB | | | | NC
| | | DHA (9) | STD (9) | 10uM | Ambient | Caff+ CaCl2 free KRB | | | | D** | | | I*
| | | DHA+ DXR (9) | STD (9) | 10uM | Ambient | Caff+CaCl2 free KRB | | | | NC
| | | DHA (9) | STD (9) | 10uM | Ambient | Caff+ CaCl2 KRB | | | | D** | | | I*
| | | DHA+ DXR (9) | STD (9) | 10uM | Ambient | Caff+CaCl2 KRB | | | | NC
Xiao, 1997 | Rat, adult ventricular | ND Free | EPA (ND) | STD (ND) | 1.5uM | Ambient | None | | | | | | | | | D**_calcium transients_
| | | EPA (ND) | STD (ND) | 15uM | Ambient | None | | | | | | | | | D**_calcium transients_
Hallaq, 1990 | Rat, neonatal, cardiac | 3–5d Boudn | EPA (8) | STD (8) | 5uM | Ambient | None | | | | NC
| | 3–5d Bound | EPA (3) | STD (3) | 5uM | Ambient | OUA (1um) | | | | NC
| | 3–5d Bound | EPA (5) | STD (5) | 5uM | Ambient | OUA (0.1m M) | | | | D***
| | 3–5d Bound | EPA (10) | STD (10) | 5uM | Ambient | OUA (0.1m M) | NC NaK
| | 3–5d Bound | EPA (11) | STD (11) | 5uM | Ambient | BUME | NC NaK
| | 3–5d Bound | EPA (8) | STD (8) | 5uM | Ambient | OUA+ BUME | NC NaK
| Rat, neonatal, ventricular | 4d Bound | DHA (4–11) | STD (4–11) | 5uM | Ambient | OUA | | B* I
| | 4d Bound | DHA (5–14) | STD (5–14) | 5uM | Ambient | NIT | | B^ND^D
| | 4d Bound | DHA+NIT (5–14) | DHA (5–14) | 5uM | Ambient | NIT | | NC
| | 4d Bound | DHA (5–14) | STD (5–14) | 5uM | Ambient | BAY | | B^ND^I
| | 4d Bound | DHA+ BAY (5–14) | DHA (5–14) | 5uM | Ambient | BAY | | NC
| | 4d Bound | DHA (5–14) | STD (5–14) | 5uM | Ambient | OUA + NIT | | B^ND^ D
| | 4d Bound | DHA +OUA + NIT (5–14) | DHA (5–14) | 5uM | Ambient | OUA + NIT | | NC
| | 4d Bound | DHA+Bay+NIT (5–14) | STD+Bay+NIT | 5uM | Ambient | BAY + NIT | | B^ND^
| | 4d Bound | DHA+Bay+NIT (5–14) | DHA (5–14) | 5uM | Ambient | BAY + NIT | | NC
| | 4d Bound | EPA (5–14) | STD (5–14) | 5uM | Ambient | NIT | | B^ND^
| | 4d Bound | EPA+NIT (5–14) | EPA (5–14) | 5uM | Ambient | NIT | | NC
| | 4d Bound | EPA (5–14) | STD (5–14) | 5uM | Ambient | BAY | | B^ND^ I
| | 4d Bound | EPA+BAY (5–14) | EPA (5–14) | 5uM | Ambient | BAY | | NC
| | 4d Bound | EPA (5–14) | STD (5–14) | 5uM | Ambient | OUA + NIT | | B^ND^ D
| | 4d Bound | EPA +OUA + NIT (5–14) | EPA (5–14) | 5uM | Ambient | OUA + NIT | | NC
| | 4d Bound | EPA+Bay+NIT (5–14) | STD+Bay+NiIT | 5uM | Ambient | BAY + NIT | | B^ND^ D
| | 4d Bound | EPA+Bay+NIT (5–14) | EPA (5–14) | 5uM | Ambient | BAY + NIT | | NC
Rodrigo, 1999 | Guinea pig, adult, SSP ventricular | 10 min Free | EPA (5) | STD (5) | 5uM | Ambient | Ca^2+^ | | | | | | | D*
DOG
Philipson, 1985 | Dog, adult, ventricular SR vesicles | 1.5 sec Free | ALA (9) | STD (9) | 30uM | Ambient | Ca^2+^ | | | | | | | | I*_NaCa exchange_
| | 2 min Free | ALA (3) | STD (3) | 20uM | Ambient | Pre-loaded Ca^2+^ | | | | | | | | | I* _SL pass Ca efflux_
Philipson, 1987 | Dog, adult, ventricular SR vesicles | 1.5 sec Free | ALA (3) | STD (3) | 60uM | Ambient | Ca^2+^ | | | | | | | | I*_NaCa exchange_
| | 2 min Free | ALA (4) | STD (4) | 30uM | Ambient | Pre-loaded Ca^2+^ | | | | | | | | | I* _SL pass Ca efflux_
Goel, 2002 | Pig, adult ventricular SR vesicles | 90+/-30s Free | ALA (3–5) | STD (3–5) | 50uM | Ambient | None | | | | | | | | NC_Na/H exchange_
| | | DHA (3–5) | STD (3–4) | 50uM | Ambient | Na^+^ | | | | | | | | D*_Na/H exchange_
| | | EPA (3–5) | STD (3–5) | 10uM | Ambient | None | | | | | | | | NC_Na/H exchange_
| | | EPA (3–5) | STD (3–5) | 25uM | Ambient | None | | | | | | | | NC_Na/H exchange_
| | | EPA (3–6) | STD (3–6) | 50uM | Ambient | None | | | | | | | | D*_Na/H exchaange_ | NC_pass NA efflux_
| | | EPA (3–5) | STD (3–5) | 100uM | Ambient | None | | | | | | | | D*_Na/H exchaange_
| | | DHA (3–5) | STD (3–5) | 10uM | Ambient | None | | | | | | | | NC_Na/H exchange_
| | | DHA (3–5) | STD (3–5) | 25uM | Ambient | None | | | | | | | | D*_Na/H exchange_
| | | DHA (3–5) | STD (3–5) | 50uM | Ambient | None | | | | | | | | D*_Na/H exchange_ | NC_pass NA efflux_
| | | DHA (3–5) | STD (3–5) | 100uM | Ambient | None | | | | | | | | D*_Na/H exchange_

Cys=cytopsolic; SR=sarcoplasmic reticulum; D=decrease; I=increase; NC=no change; ND=no data;

* =p<0.05;

** =p<0.01;

*** =p<0.001

ALA=alpha linoleric acud

B=blocked

Bas=baseline

BAY=Bay K8644

BUME=bumetamide

Caff=caffeine

D=decrease

DHA=decosahexaenoic acid

DXR=dexorubicin

EPA=eicosapentaenoic acid

ET-1=endothelin-1

I=increased

ISO=isoproteronol

KCI=potassium chloride

KRB=Krebs Ringer bicarbonate

LPC=lysophosphatidylcholine

Na=sodium

Na/K=sodium/potassium

NC=no change

ND=no data

NIT=nitrendipine

OUA-ouabain

SL=sarcolemma

SR=sarcoplasmic reticulum

STD=standard chow

uM=micromoles

Summary Table 3-29. Effects of Omega-3 Fatty Acids on Ion Currents in Isolated Organ and Cell Culture Studies

Summary Table 3-29. Effects of Omega-3 Fatty Acids on Ion Currents in Isolated Organ and Cell Culture Studies

Author, Year | Model [Animal, Type, Age] | Exposure Duration | Comparison Groups | | Amount of Omega-3 | Experi-mental Condition | Agent | I_Na_ | I_to_ | I_Ca.L_ | I_K_ | I_KI_ | I_KUR_
| | | Omega-3 Fatty Acid (n) | Control (n)
MOUSE
Honore, 1994 | Mouse, neonatal, ventricular | ND Free | DHA (9) | STD (9) | 30uM | Ambient | None | | | | | NC | D*
RAT
Bogdanov, 1998 | Rat, adult ventricular | 3–12 min Free | EPA (4) | STD (4) | 5–10uM | Ambient | None | | | | | | NC
| | | EPA (4) | STD (4) | 20uM | Ambient | None | | | | | | D*
| | | EPA (4) | STD (4) | 50uM | Ambient | None | | D* | | | NC | D*
| | | DHA (ND) | STD (ND) | 5uM | Ambient | None | | D^ND^
| | | | | | | | | D^ND^ A
| | | | | | | | | I^ND^ delay
| | | | | | | | | D** t
| | | DHA (ND) | STD (ND) | 5uM | Ambient | INDO | | D^ND^
| | | | | | | | | D^ND^ A
| | | | | | | | | I^ND^ delay
| | | | | | | | | D** t
| | | DHA (ND) | STD (ND) | 50uM | Ambient | None | | | | | NC | D^ND^
Leifert, 1999 | Rat, adult ventricular | 4 min Free | ALA (6) | STD (6) | 25uM | Ambient | None | +ve Ac***
| | | | | | | None | -ve InAc**
| | | EPA (10) | STD (10) | 25uM | Ambient | None | +ve Ac***
| | | | | | | | -ve InAc**
| | | DHA (7) | STD (7) | 25uM | Ambient | None | D^ND^ A
| | | | | | | | +ve Ac**
| | | | | | | | -ve InAc**
Macleod, 1998 | Rat, adult ventricular | 5 min Free | EPA (6–8) | STD (6–8) | 5,10,20uM | Ambient | None | D^ND^ A dd | | D^ND^ dd
| | | EPA (5–8) | STD (5–8) | 0.1–10uM | Ambient | None | | D^ND^ dd
| | | EPA (ND) | STD (ND) | 2uM | Ambient | None | | | | D^ND^ | D^ND^
| | | EPA (ND) | STD (ND) | 5uM | Ambient | None | | | | D^ND^ | D^ND^
| | | DHA (6–8) | STD (6–8) | 5,10,20uM | Ambient | None | D^ND^ A dd
| | | DHA (5–8) | STD (5–8) | 5,7.5,10uM | Ambient | None | | | D^ND^ dd
| | | DHA (5–8) | STD (5–8) | 0.1–10uM | Ambient | None | | D^ND^ dd
Negretti, 2000 | Rat, adult, ventricular | 3 min Free | EPA (5) | STD (5) | 10uM | Ambient | None | | | D* A
| | | DHA (5) | STD (5) | 10uM | Ambient | None | | | D* A
O'Neill, 2002 | Rat, ND ventricular | ND Free | EPA (6) | STD (6) | 10uM | Ambient | Ca^2+^ | | D***F
| | | | | | | | | I***A
Pepe, 1994 | Rat, adult, cardiac | 4 min Free | DHA (6/gp) | STD (6/gp) | 5uM | Ambient | None | | | NC A
| | | DHA (6/gp) | STD (6/gp) | 5uM | Ambient | NIT | | | I* A
| | | DHA (6/gp) | STD (6/gp) | 5uM | Ambient | BAY | | | B* A
| | | DHA (6/gp) | STD (6/gp) | 5uM | Ambient | ISO | | | NC A
Rodrigo, 1999 | Rat, adult ventricular | 10 min Free | EPA (8) | STD (8) | 5uM | Ambient | None | | | D***
Xiao, 1995 | Rat, neonatal, ventricular | ND Free | ALA (5) | STD (5) | 10uM | Ambient | None | D*
| | | EPA (6–10) | STD (6–10) | 5–10uM | Ambient | None | D*
| | | | | | | | NC IVC
| | | | | | | | NC Ac
| | | | | | | | NC InAc
| | | EPA (4–10) | STD (4–10) | 10–40uM | Ambient | None | D* dd
| | | EPA (10) | STD (10) | 5–10uM | Ambient | None | D** tdv dependent
| | | EPA (21) | STD (21) | 10uM | Ambient | None | D***
| | | DHA (7) | STD (7) | 10uM | Ambient | None | D*
| | | DHA (7) | STD (7) | 5uM | Ambient | None | D**
Xiao, 1997 | Rat, neonatal, ventricular | ND Free | ALA (5) | STD (5) | 5uM | Ambient | None | | | D**
| | | | | | | | | | -ve IAC
| | ND Free | EPA (ND) | STD (ND) | 0.1–40uM | Ambient | None | | | D* dd tdv dependent
| | ND Free | EPA (5) | STD (5) | 5uM | Ambient | None | | | D**
| | | | | | | | | | -ve IAC
| | ND Free | DHA (6) | STD (6) | 5uM | Ambient | None | | | D**
| | | | | | | | | | -ve IAC
| | ND Free | EPA (11) | STD (11) | 1.5uM | Ambient | None | | | D*
| | | | | | | | | | NC IVC
| | | | | | | | | | -ve Shift
| | | | | | | | | | IAC
| | ND Free | EPA (5) | STD (5) | 1uM | Ambient | None | | | D**
| | ND Free | EPA (8) | STD (8) | 5uM | Ambient | None | | | D**
GUINEA PIG
Ferrier, 2002 | Guinea pig, adult, ventricular | 20 min Free | DHAm.e (18–24) | STD (18–24) | 10uM | Ambient | None | | | I**
Macleod, 1998 | Guinea pig adult, ventricular | 5 min Free | EPA (8–10) | STD (8–10) | 5,10,20uM | Ambient | None | D^ND^ A dd
| | | EPA (5–8) | STD (5–8) | 2, 5uM | Ambient | None | | | | D^ND^ | D^ND^
| | | EPA (5–8) | STD (5–8) | 5,7.5,10uM | Ambient | None | | | D^ND^ A dd
| | | DHA (8–10) | STD (8–10) | 5,10,20uM | Ambient | None | D^ND^ A dd
| | | DHA (6–10) | STD (6–10) | 5, 7.5, 10uM | Ambient | None | | | D^ND^ dd
Rodrigo, 1999 | Guinea pig, adult, ventricular | 10 min Free | EPA (11) | STD (11) | 5uM | Ambient | None | | | D***
FERRET
Xiao, 2002 | Ferret, adult, ventricular | ND Free | ALA (7) | STD (7) | 5uM | Ambient | None | | | | D**
| | | ALA (4–8) | STD (4–8) | 10uM | Ambient | None | | D* | | D*** | NC
| | | EPA (6) | STD (6) | 5uM | Ambient | None | | | | D*
| | | EPA (4–8) | STD (4–8) | 10uM | Ambient | None | | D** | | D*** | NC
| | | DHA (7–12) | STD (7–12) | 10uM | Ambient | None | | | | D*
| | | DHA (6) | STD (6) | 0.2–50uM | Ambient | None | | | | D*dd
| | | DHA (6–12) | STD (12) | 5uM | Ambient | None | | | | D* | NC
| | | DHA (5–8) | STD (5–8) | 10uM | Ambient | None | | D*** | | D* | NC
| | | DHA (5) | STD (5) | 10uM | Ambient | Sta | | | | D*
| | | DHA (2–6) | STD (2–6) | 20uM | Ambient | None | | | | D** | NC
| | | DHA (11) | STD (11) | 50uM | Ambient | None | | | | D***

INA= sodium current; ITO= transient K+ outward current or initial outward current; ICA.L= voltage dependent L-type calcium current/inward calcium current/calcium sparks; IK=delayed rectifier K+ current; IKl= inward recitifer K+ current or tail current; IKUR= ultra rapid K+ current; D = decrease; I = increase; NC = no change; ND= no data;

* = p<0.05

** = p<0.01;

*** = p<0.001

A =amplitude

Ac =activation parameter

ALA =alpha linoleic acid

BAY =Bay K8644

D =decrease

dd =dose dependent

DHA =decosahexaenoic acid

nd D =

EPA =eicosapentaenoic acid

F =frequency

I =increased

IAC =

InAc =inactivation parameter

nd I =

INDO =indomethacin

ISO =isoproteronol

IVC =

NC =no change

ND =no data

NIT =no data

Sta =standard

STD =standard chow

tdv =

uM =micromoles

Summary Table 3-30. Effects of Omega-3 Fatty Acids on Ion Channels in Isolated Organ and Cell Culture Studies

Summary Table 3-30. Effects of Omega-3 Fatty Acids on Ion Channels in Isolated Organ and Cell Culture Studies

Author, Year | Model [Animal, Age, Type] | Exposure Duration: Free or Bound | Omega-3 Fatty Acid (n) | Control (n) | Amount of Omega-3 | Experimental Condition | Agent | Na^+^ Channel | Cloned Kv1.5 K+ channels | Nitrendipine Binding To Putative Dihydropyridine Sensitive Ca2+ Channels
MOUSE
Honore, 1994 | Mouse, neonatal, ventricular | ND Free | DHA (5–11) | STD (5–11) | 30uM | Ambient | None | | B* activity
| | | ALA (ND) | STD (ND) | ND | Ambient | None | | NC activity
RAT
Hallaq, 1992 | Rat, neonatal, ventricular | 4 d Bound | EPA (5–10) | STD (5–10) | 5uM | Ambient | NIT | | | D* High Affinity K_d_
| | | | | | | | | | D** High Affinity B_max_
| | | | | | | | | | D** Low Affinity K_d_
| | | | | | | | | | D* Low Affinity B_max_
| | | DHA (5–10) | STD (5–10) | 5uM | Ambient | NIT | | | D** High Affinity K_d_
| | | | | | | | | | D* High Affinity B_max_
| | | | | | | | | | D** Low Affinity K_d_
| | | | | | | | | | D* Low Affinity B_max_
Kang, 1997 | Rat, neonatal cardiac | 2–3 d Bound | EPA (4) | STD (4) | 20uM | Ambient | None | NC in number
| | | EPA (4) | STD (4) | 20uM | Ambient | MEX | D* in number
| | | | | | | | B* increase in expression

B= Block; STD=Control; D=decrease; d=days; I= Increase; NC=No change; ND=No data; NIT= Nitrendipine; MEX= Mexiletine; D = decrease; I = increase; NC = no change; ND= no data;

* = p<0.05

** = p<0.01;

*** = p<0.001

B =blocked

Bmax =binding capacity

D = decrease

DHA =decosahexaenoic acid

EPA =eicosapantaenoic acid

Kd =affinity

NC =no change

ND =no data

NIT =nitrendipine

MEX =mexiletine

uM =micromoles

STD =standard

Summary Table 3-31. Comparison of IC50 or Ec50 Values in Isolated Organ and Cell Culture Studies

Summary Table 3-31. Comparison of IC50 or Ec50 Values in Isolated Organ and Cell Culture Studies

Author, year | Model [Animal, Age, Type] | Exposure Duration | Omega-3 Fatty Acid (n) | Control (n) | Experimental Condition | Agent | I_Na_ | I_to_ | I_CaL_ | I_K_ | TS
Leifert, 1999 | Rat, adult, ventricular | 4 mins Free | DHA | STD | Ambient | None | 6.0 ± 1.2 μM
| | | EPA | STD | Ambient | None | 16.2 ± 1.3 μM
| | | ALA | STD | Ambient | None | 26.6 ± 1.3 μM
Macleod, 1998 | Rat, adult, ventricular | 5 mins Free | DHA | STD | Ambient | None | 12.8 ± 0.8 μM | 2.6 ± 0.7 μM | 27.9 ± 2.5 μM | | 63 ± 8.3 μM
| | | EPA | STD | Ambient | None | 7.9 ± 0.6 μM | 1.9 ± 0.3 μM | 9.4 ± 0.8 μM | | 51 ± 5.0 μM
| Guinea pig, adult, ventricular | 5 mins Free | DHA | STD | Ambient | None | 15.7 ± 0.9 μM | 34.7 ± 2.6 μM | | | 8.5 ± 1.1 μM
| | | EPA | STD | Ambient | None | 8.9 ± 0.5 μM | 8.6 ± 1.5 μM | | | 6.7 ± 2.2 μM
Xiao, 1997 | Rat, adult, ventricular | ND Free | EPA | STD | Ambient | None | | | 2.1 μM
| Rat, neonatal, ventricular | ND Free | EPA | STD | Ambient | None | | | 0.8 μM
Xiao, 2002 | Ferret,adult, ventricular | 3min Free | DHA | STD | Ambient | None | | 7.5 μM | | 20 μM

D = decrease; I = increase; NC = no change; ND= no data;

* = p<0.05

** = p<0.01;

*** = p<0.001

DHA = decosahexaenoic acid

EPA = eicosapantaenoic acid

ND = no data

STD = standard chow

TS =twitch size

uM =micromoles