# Listing of Excluded Studies

Animal and isolated organ and cell culture rejected articles

### 1. No omega-3 fatty-acid treatment or inntervention (30 articles)

Abeywardena MY; McMurchie EJ;Russell GR; Charnock JS. Species variation in the ouabain sensitivity of cardiac Na+/K+-ATPase. A possible role for membrane lipids, Biochemical Pharmacology, 11/15/84, 33, 22
Abeywardena MY; McMurchie EJ; Russell GR; Sawyer WH; Charnock JS. Response of rat heart membranes and associated ion-transporting ATPases to dietary lipid, Biochimica et Biophysica Acta, 9/1/84, 776, 1
Alam SQ; Mannino SJ; Alam BS; McDonough K. Effect of essential fatty acid deficiency on forskolin binding sites, adenylate cyclase and cyclic AMP-dependent protein kinase activity, the levels of G proteins and ventricular function in rat heart, Journal of Molecular & Cellular Cardiology, 8/1/95, 27,
Bachmann E; Weber E. Effects of corn oil addition to the diet on the energy metabolism of heart, liver and kidney of female rats, Pharmacology & Toxicology, 7/1/90, 67, 1
Benediktsdottir VE; Curvers J; Gudbjarnason S. Time course of alterations in phospholipid fatty acids and number of beta-adrenoceptors in the rat heart during adrenergic stimulation in vivo, Journal of Molecular & Cellular Cardiology, 5/1/99, 31, 5
Benediktsdottir VE; Skuladottir GV; Gudbjarnason S. Effects of ageing and adrenergic stimulation on alpha 1- and beta-adrenoceptors and phospholipid fatty acids in rat heart, European Journal of Pharmacology, 5/26/95, 289, 3
Bhatnagar MK; Yamashiro S. Res Vet Sci 1979; 26(2):183–188
Charnock JS; Abeywardena MY; McMurchie EJ; Russell GR. The composition of cardiac phospholipids in rats fed different lipid supplements, Lipids, 3/1/84, 19, 3
Charnock JS; McLennan PL; Abeywardena MY; Russell GR. Altered levels of n-6/n-3 fatty acids in rat heart and storage fat following variable dietary intake of linoleic acid, Annals of Nutrition & Metabolism, 1/1/85, 29, 5
Horackova M; Murphy MG. Effects of chronic diabetes mellitus on the electrical and contractile activities, 45Ca2+ transport, fatty acid profiles and ultrastructure of isolated rat ventricular myocytes, Pflugers Archiv - European Journal of Physiology, 5/1/88, 411, 5
Kako KJ; Vasdev SC; Narbaitz R. Lipid metabolism, contractility, and ultrastructure of hearts of rats fed a mustard seed oil diet, Advances in Myocardiology, 1/1/80, 2
Katzeff I; Levin G; Hurwitz ML; Rosendorff C. Dietary fatty acid saturation affects coconary vascular resistance and beta-adrenoceptors in the rat heart, Progress in Lipid Research, 1/1/86, 25, 479–483; 10 ref.
Kim RS; LaBella FS. The effect of linoleic and arachidonic acid derivatives on calcium transport in vesicles from cardiac sarcoplasmic reticulum, Journal of Molecular & Cellular Cardiology, 2/1/88, 20, 2
Kim RS; Sukhu B; LaBella FS. Lipoxygenase-induced lipid peroxidation of isolated cardiac microsomes modulates their calcium-transporting function, Biochimica et Biophysica Acta, 7/22/88, 961, 2
Lepran I; Nemecz G; Koltai M, et al. J Cardiovasc Pharmacol 1981; 3(4):847–853
Mentz P; Forster W. The influence of unsaturated fatty acids on prostaglandin-release in isolated perfused guinea-pig hearts, Prostaglandins, 7/1/77, 14, 1
Nakajima T; Kurachi Y; Ito H; Takikawa R; Sugimoto T. Anti-cholinergic effects of quinidine, disopyramide, and procainamide in isolated atrial myocytes: mediation by different molecular mechanisms, Circulation Research, 2/1/89, 64, 2
Nakao S; Ebata H; Hamamoto T; Kagawa Y; Hirata H. Solubilization and reconstitution of voltage-dependent calcium channel from bovine cardiac muscle. Ca2+ influx assay using the fluorescent dye Quin2, Biochimica et Biophysica Acta, 10/20/88, 944, 3
Navarro MD; Periago JL; Pita ML; Hortelano P. The n-3 polyunsaturated fatty acid levels in rat tissue lipids increase in response to dietary olive oil relative to sunflower oil, Lipids, 12/1/94, 29, 12
Oddis CV; Mayer OH; Finkel MS. Prostaglandins Leukotrienes & Essential Fatty Acids 1996; 54(3):223–228
Phillis JW; Diaz FG; O'Regan MH; Pilitsis JG. Effects of immunosuppressants, calcineurin inhibition, and blockade of endoplasmic reticulum calcium channels on free fatty acid efflux from the ischemic/reperfused rat cerebral cortex, Brain Research, 12/6/02, 957, 1
Phylactos AC; Harbige LS; Crawford MA. Essential fatty acids alter the activity of manganese-superoxide dismutase in rat heart, Lipids, 2/1/94, 29, 2
Sexton PT; Sinclair AJ; O' Dea K; Sanigorski AJ; Walsh J. The relationship between linoleic acid level in serum, adipose tissue and myocardium in humans, Asia Pacific Journal of Clinical Nutrition, 4/1/95, 4, 3
Skuladottir GV; Schioth HB; Gudbjarnason S. Polyunsaturated fatty acids in heart muscle and alpha 1-adrenoceptor binding properties, Biochimica et Biophysica Acta, 7/28/93, 1178, 1
Starkopf J; Andreasen TV; Bugge E; Ytrehus K. Lipid peroxidation, arachidonic acid and products of the lipoxygenase pathway in ischaemic preconditioning of rat heart, Cardiovascular Research, 1/1/98, 37, 1
Sugiyama S; Miyazaki Y; Kotaka K. Mechanism of free fatty acid-induced arrhythmias, Journal of Electrocardiology, 1/1/82, 15, 3
Wahle KW; Milne L; McIntosh G. Regulation of polyunsaturated fatty acid metabolism in tissue phospholipids of obese (fa/fa) and lean (Fa/-) Zucker rats. 1. Effect of dietary lipids on cardiac tissue, Lipids, 1/1/91, 26, 1
Wallert MA; Ackerman MJ; Kim D; Clapham DE. Two novel cardiac atrial K+ channels, I(K.AA) and I(K.PC), Journal of General Physiology, 1/1/91, 98, 5
Wallukat G; Morwinski R; Kuhn H. Modulation of the beta-adrenergic response of cardiomyocytes by specific lipoxygenase products involves their incorporation into phosphatidylinositol and activation of protein kinase C, Journal of Biological Chemistry, 11/18/94, 269, 46
Ziemlanski S; Rosnowski A; Opuszynska FT. Acta Medica Polona 1973; 14(4):279–290

### 2. Not cardiac cells (4 articles)

MacLeod DC. Effect of Dietary Polyunsaturated Fatty Acids on Contraction and Relaxation of Rat Femoral Resistance Arteries, Journal of Cardiovascular Pharmacology, 1/1/94, 23, 1
Sawazaki S; Nakamura N; Hamazaki T; Yamazaki K; Urakaze M; Yano S. Intravenous infusion of trieicosapentaenoyl-glycerol and LTB4 and LTB5 production by leukocytes of rabbits, American Journal of Physiology - Heart & Circulatory Physiology, 1/1/92, 262, 6 31–6
Wang DW; Zhao HY. Prevention of atherosclerotic arterial stenosis and restenosis after angioplasty with Andrographis paniculata nees and fish oil. Experimental studies of effects and mechanisms, Chinese Medical Journal, 6/1/94, 107, 6
Yong L; Watkins BA; Yong L. Conjugated linoleic acids alter bone fatty acid composition and reduce ex vivo prostaglandin E2 biosynthesis in rats fed n-6 or n-3 fatty acids, Lipids, 3/1/98, 33, 4

### 3. Fatty acid compositions or metabolic products only (33 articles)

Abeywardena MY; McLennan PL; Charnock JS. Differential effects of dietary fish oil on myocardial prostaglandin I2 and thromboxane A2 production, American Journal of Physiology, 2/1/91, 260, 2 Pt 2
Bell JG; Dick JR; Sargent JR; McVicar AH. Dietary linoleic acid affects phospholipid fatty acid composition in heart and eicosanoid production by cardiomyocetes from Atlantic salmon (Salmo salar), Comparative Biochemistry & Physiology, 1/1/92, A, Physiology. 103, 2
Berlin E; Kim CS; McClure D; Banks MA; Peters RC. Brain and heart membrane fatty acid composition in miniature swine fed diets containing corn and menhaden oils, Nutrition Research, 1/1/98, 18, 4
Charnock JS; Abeywardena MY; Tan D; McLennan PL. Omega-3 and omega-6 PUFA's have different effects on the phospholipid fatty acid composition of rat myocardial muscle when added to a saturated fatty acid dietary supplement, Nutrition Research, 1/1/91, 11, 9
Charnock JS; Dryden WF; McMurchie EJ; Abeywardena MY; Russell GR. Differences in the fatty acid composition of atrial and ventricular phospholipids of rat heart following standard and lipid-supplemented diets, Comparative Biochemistry & Physiology - B: Comparative Biochemistry, 1/1/83, 75, 1
Hooper L. Dietary fat intake and prevention of cardiovascular disease: Systematic review, British Medical Journal, 7/1/01, [print] 322, 7289
Innis SM; Clandinin MT. Dynamic modulation of mitochondrial inner-membrane lipids in rat heart by dietary fat, Biochemical Journal, 1/1/81, 193, 1
Lee CR; Beattie OP; Hamm MW. Saturated, n-6, or n-3 fatty acids and cholesterol supplementation: differential effects on liver and heart lipid composition, Nutrition Research, 9/1/89, 9,
Loo G; Berlin E; Peters RC; Kliman PG; Wong HYC. Effect of dietary corn, coconut, and menhaden oils on lipoprotein, liver, and heart membrane composition in the hypercholesterolemic rabbit, Journal of Nutritional Biochemistry, 2/1/91, 2, 11
Lu GP; Surette ME; Whelan J; Kinsella JE. Dietary n-3 polyunsaturated fatty acids alter cardiac lipids in hamsters, Nutrition Research, 1/1/93, 13, 7
McGee CD; Lieberman P; Greenwood CE. Dietary fatty acid composition induces comparable changes in cardiolipin fatty acid profile of heart and brain mitochondria, Lipids, 1/1/96, 31, 6
McHowat J; Creer MH; Hicks KK; Jones JH; McCrory R; Kennedy RH. Induction of Ca-independent PLA(2) and conservation of plasmalogen polyunsaturated fatty acids in diabetic heart, American Journal of Physiology - Endocrinology & Metabolism, 7/1/00, 279, 1
McMurchie EJ; Burnard SL; Rinaldi JA; Patten GS; Neumann M; Gibson RA. Cardiac membrane lipid composition and adenylate cyclase activity following dietary eicosapentaenoic acid supplementation in the marmoset monkey, Journal of Nutritional Biochemistry, 3/1/92, 3, 1
McMurchie EJ; Patten GS; McLennan PL; Charnock JS; Nestel PJ. The influence of dietary lipid supplementation on cardiac beta-adrenergic receptor adenylate cyclase activity in the marmoset monkey, Biochimica et Biophysica Acta, 1/22/88, 937, 2
Meij JT; Bordoni A; Dekkers DH; Guarnieri C; Lamers JM. Alterations in polyunsaturated fatty acid composition of cardiac membrane phospholipids and alpha 1 adrenoceptor mediated phosphatidylinositol turnover, Cardiovascular Research, 2/1/90, 24, 2
Montfoort A; Rutten-van Beysterveld CC; Wortelboer MR. Molecular species of diacylphosphatidylethanolamine in rat and mouse heart given the same diet, Biochemistry International, 5/1/83, 6, 5
Nada MA; Abdel-Aleem S; Schulz H. On the rate-limiting step in the beta-oxidation of polyunsaturated fatty acids in the heart, Biochimica et Biophysica Acta, 4/6/95, 1255, 3
Nair SS; Leitch J; Garg ML. Suppression of inositol phosphate release by cardiac myocytes isolated from fish oil-fed pigs, Molecular & Cellular Biochemistry, 12/1/00, 215, 1–2
Nair SSD; Leitch J; Garg ML. N-3 polyunsaturated fatty acid supplementation alters inositol phosphate metabolism and protein kinase C activity in adult porcine cardiac myocytes, Journal of Nutritional Biochemistry, 1/1/01, 12, 1
Nalbone G; Grynberg A; Chevalier A; Leonardi J; Termine E;Lafont H. Phospholipase A activity of cultured rat ventricular myocyte is affected by the nature of cellular polyunsaturated fatty acids, Lipids, 6/1/90, 25, 6
Navarro MD; Hortelano P; Periago JL; Pita ML. Effect of dietary olive and sunflower oils on the lipid composition of the aorta and platelets and on blood eicosanoids in rats, Arteriosclerosis & Thrombosis, 1/1/92, 12, 7
Otten W; Iaizzo PA; Eichinger HM. Effects of a high n-3 fatty acid diet on membrane lipid composition of heart and skeletal muscle in normal swine and in swine with the genetic mutation for malignant hyperthermia, Journal of Lipid Research, 10/1/97, 38, 10
Pehowich DJ. Hypothyroid state and membrane fatty acid composition influence cardiac mitochondrial pyruvate oxidation, Biochimica et Biophysica Acta - Biomembranes, Vol 1235(2) (pp 231–238), 1995, 1/1/95
Robblee NM; Clandinin MT. Effect of dietary fat level and polyunsaturated fatty acid content on the phospholipid composition of rat cardiac mitochondrial membranes and mitochondrial ATPase activity, Journal of Nutrition, 1/1/84, 114, 2
Shu GC; Hatch GM. Stimulation of phosphatidylglycerolphosphate phosphatase activity by unsaturated fatty acids in rat heart, Lipids, 1/1/94, 29, 7
Steel MS. Arachidonic acid supplementation dose-dependently reverses the effects of a butter-enriched diets in rats, Prostaglandins Leukotrienes & Essential Fatty Acids, 1/1/93, 48, 3
Tahin QS; Blum M; Carafoli E. The fatty acid composition of subcellular membranes of rat liver, heart, and brain: diet-induced modifications, European Journal of Biochemistry, 12/1/81, 121, 1
Takeo S; Nasa Y; Tanonaka K; Yabe K; Nojiri M; Hayashi M; Sasaki H; Ida K; Yanai K. Effects of long-term treatment with eicosapentaenoic acid on the heart subjected to ischemia/reperfusion and hypoxia/reoxygenation in rats, Molecular & Cellular Biochemistry, 11/1/98, 188, 1–2
Watkins SM; Lin TY; Davis RM; Ching JR; DePeters EJ; Halpern GM; Walzem RL; German JB. Unique phospholipid metabolism in mouse heart in response to dietary docosahexaenoic or alpha-linolenic acids, Lipids, 3/1/01, 36,
Weber N; Mukherjee KD. Steep rise of docosahexaenoic acid in phosphatidylethanolamines of heart and liver of rats fed native olive oil or rapeseed oil, Nutrition Research, 1/1/98, 18, 5

### 4. Not specific to arrhythmia or no outcomes of interests (31 articles)

Adan Y; Shibata K; Sato M; Ikeda I; Imaizumi K. Effects of docosahexaenoic and eicosapentaenoic acid on lipid metabolism, eicosanoid production, platelet aggregation and atherosclerosis in hypercholesterolemic rats, Bioscience, Biotechnology & Biochemistry, 1/1/99, 63, 1
Barbosa AM; Mandarim-de-Lacerda CA. Virchows Archiv 1999; 434(5):451–453
Benediktsdottir VE; Gudbjarnason S. Modification of the fatty acid composition of rat heart sarcolemma with dietary cod liver oil, corn oil or butter, Journal of Molecular & Cellular Cardiology, 2/1/88, 20,
Biagi P; Bordoni A; Lorenzini A, et al. Mechanisms of Ageing & Development 1999; 107(2):181–195
Black KL; Culp B; Madison D. The protective effects of dietary fish oil on focal cerebral infarction, Prostaglandins and Medicine, Vol 3(5) (pp 257–268), 1979, 6/1/80
Bodak A; Hatt PY. Myocardial lesions induced by rapeseed oil-rich diet in the rat: ultrastructural aspects, Recent Advances in Studies on Cardiac Structure & Metabolism, 1/1/75, 6
Bolton HS; Chanderbhan R; Bryant RW; Bailey JM; Weglicki WB; Vahouny GV. Prostaglandin synthesis by adult heart myocytes, Journal of Molecular & Cellular Cardiology, 11/1/80, 12, 11
De Craemer D. Peroxisomes in liver, heart, and kidney of mice fed a commercial fish oil preparation: Original data and review on peroxisomal changes induced by high-fat diets, Journal of Lipid Research, 1/1/94, 35,
Forsyth GW; Carter KE; Loew FM; Ackman RG. Heart mitochondrial metabolism after feeding herring oil to rats and monkeys, Lipids, 12/1/77, 12, 10
Gerbi A; Barbey O; Raccah D; Coste T; Jamme I; Nouvelot A; Ouafik L; Levy S; Vague P; Maixent JM. Alteration of Na,K-ATPase isoenzymes in diabetic cardiomyopathy: effect of dietary supplementation with fish oil (n-3 fatty acids) in rats, Diabetologia, 5/1/97, 40,
Gunther J; Kutscherskij E. Adv Myocardiol 1982; 3:329–334
Grynberg A; Astorg PO; Lherminier J. Statistical analysis of the size of heart mitochondria in rats fed sunflower oil, primor oil or rapeseed oil, Biological Structures & Morphogenesis, 1/1/88, 1, 2
Hartog JM; Verdouw PD; Klompe M; Lamers JM. Dietary mackerel oil in pigs: effect on plasma lipids, cardiac sarcolemmal phospholipids and cardiovascular parameters, Journal of Nutrition, 8/1/87, 117, 8
Kang JX; Leaf A. Evidence that free polyunsaturated fatty acids modify Na+ channels by directly binding to the channel proteins, Proceedings of the National Academy of Sciences of the United States of America, 4/16/96, 93, 8
Kramer JK. Comparative studies on composition of cardiac phospholipids in rats fed different vegetable oils, Lipids, 9/1/80, 15, 9
Malecki EA; Greger JL. Manganese protects against heart mitochondrial lipid peroxidation in rats fed high levels of polyunsaturated fatty acids, Journal of Nutrition, 1/1/96, 126, 1
Manas M; Mataix J; Quiles JL; Huertas JR; Battino M. Tissue specific interactions of exercise, dietary fatty acids, and vitamin e in lipid peroxidation, Free Radical Biology & Medicine, 1/1/98, 24, 4
McMillin JB; Bick RJ; Benedict CR. Influence of dietary fish oil on mitochondrial function and response to ischemia, American Journal of Physiology, 11/1/92, 263, 5 Pt 2
Mills DE; Ward RP. Effects of essential fatty acid administration on cardiovascular responses to stress in the rat, Lipids, 2/1/86, 21, 2
Mills DE; Ward RP. Effects of eicosapentaenoic acid (20:5 omega 3) on stress reactivity in rats, Proceedings of the Society for Experimental Biology & Medicine, 5/1/86, 182, 1
Needleman P; Wyche A; Sprecher H; Elliott WJ; Evers A. A unique cardiac cytosolic acyltransferase with preferential selectivity for fatty acids that form cyclooxygenase/lipoxygenase metabolites and reverse essential fatty acid deficiency, Biochimica et Biophysica Acta, 9/11/85, 836, 2
Nishimura M; Nanbu A; Komori T; Ohtsuka K; Takahashi H; Yoshimura M. Eicosapentaenoic acid stimulates nitric oxide production and decreases cardiac noradrenaline in diabetic rats, Clinical & Experimental Pharmacology & Physiology, 8/1/00, 27, 8
Pakala R. Vascular smooth muscle cells preloaded with eicosapentaenoic acid and docosahexaenoic acid fail to respond to serotonin stimulation, Atherosclerosis, 4/1/00, [print] 153, 1
Pehowich DJ; Awumey EMK. Influence of hypothyroid state on cardiac sarcolemmal incorporation of dietary omega-6 and omega-3 fatty acids, Nutrition Research, 1/1/95, 15, 8
Power GW; Newsholme EA. Dietary fatty acids influence the activity and metabolic control of mitochondrial carnitine palmitoyltransferase I in rat heart and skeletal muscle, Journal of Nutrition, 12/1/97, 127, 11
Totland GK; Madsen L; Klementsen B; Vaagenes H; Kryvi H; Froyland L; Hexeberg S; Berge RK. Proliferation of mitochondria and gene expression of carnitine palmitoyltransferase and fatty acyl-CoA oxidase in rat skeletal muscle, heart and liver by hypolipidemic fatty acids, Biology of the Cell, 8/1/00, 92, 5
Vamecq J; Vallee L; de la Porte PL; Fontaine M; de Craemer D; van den BC; Lafont H; Grataroli R; Nalbone G. Effect of various n-3/n-6 fatty acid ratio contents of high fat diets on rat liver and heart peroxisomal and mitochondrial beta-oxidation, Biochimica et Biophysica Acta, 10/13/93, 1170,
Yamaoka S; Urade R; Kito M. Cardiolipin molecular species in rat heart mitochondria are sensitive to essential fatty acid-deficient dietary lipids, Journal of Nutrition, 1/1/90, 120, 5
Yamashiro S; Clandinin MT. Myocardial ultrastructure of rats fed high and low erucic acid rapeseed oils, Experimental & Molecular Pathology, 1/1/80, 33, 1
Yun KL; Fann JI; Sokoloff MH; Fong LG; Sarris GE; Billingham ME; Miller DC. Dose response of fish oil versus safflower oil on graft arteriosclerosis in rabbit heterotopic cardiac allografts, Annals of Surgery, 8/1/91, 214, 2

### 5. Other reasons and articles about other parameters not sufficiently relevant (90 articles)

Abeywardena MY; McLennan PL; Charnock JS. Differences between in vivo and in vitro production of eicosanoids following long-term dietary fish oil supplementation in the rat, Prostaglandins Leukotrienes & Essential Fatty Acids, 3/1/91, 42, 3
Abeywardena MY; McLennan PL; Charnock JS. Long-term saturated fat feeding induced changes in rat myocardial phospholipid fatty acids are reversed by cross-over to polyunsaturated diets: Differences between n-3 and n-6 lipid supplements, Nutrition Research, 1/1/87, 7, 7
Abeywardena MY; McLennan PL; Charnock JS. Changes in myocardial eicosanoid production following long-term dietary lipid supplementation in rats, American Journal of Clinical Nutrition, 4/1/91, 53, 4 Suppl
Agren JJ. Effect of moderate freshwater fish diet on erythrocyte ghost phospholipid fatty acids, Annals of Medicine, 1/1/91, 23, 3
al Makdessi S; Sweidan H; Jacob R. n-3 versus n-6 fatty acid incorporation into the phospholipids of rat heart sarcolemma. A comparative study of four different oil diets, Journal of Molecular & Cellular Cardiology, 1/1/94, 26, 1
Alam SQ;Ren YF;Alam BS;, [3H]forskolin- and [3H]dihydroalprenolol-binding sites and adenylate cyclase activity in heart of rats fed diets containing different oils, Lipids, 3/1/88, 23, 3
Asano M; Nakajima T; Hazama H; Iwasawa K; Tomaru T; Omata M; Soma M; Asakura Y; Mizutani M; Suzuki S; Yamashita K; Okuda Y. Influence of cellular incorporation of n-3 eicosapentaenoic acid on intracellular Ca2+ concentration and membrane potential in vascular smooth muscle cells, Atherosclerosis, 1/1/98, 138, 1
Asano M; Nakajima T; Iwasawa K; Asakura Y; Morita T; Nakamura F; Tomaru T; Wang Y; Goto A; Toyo-oka T; Soma M; Suzuki S; Okuda Y. Eicosapentaenoic acid inhibits vasopressin-activated Ca2+ influx and cell proliferation in rat aortic smooth muscle cell lines, European Journal of Pharmacology, 8/27/99, 379, 2–3
Asano M; Nakajima T; Iwasawa K; Hazama H; Omata M; Soma M; Yamashita K; Okuda Y. Inhibitory effects of omega-3 polyunsaturated fatty acids on receptor-mediated non-selective cation currents in rat A7r5 vascular smooth muscle cells, British Journal of Pharmacology, 4/1/97, 120, 7
Awumey EM; Paton DM; Pehowich DJ. Thyroid status and dietary fatty acids affect beta-adrenoceptor agonist stimulation of tension development in rat myocardium, Journal of Autonomic Pharmacology, 4/1/95, 15, 2
Barzanti V; Battino M; Baracca A, et al. Br J Nutr 1994; 71(2):193–202
Berlin E; McClure D; Banks MA; Peters RC. Heart and liver fatty acid composition and vitamin E content in miniature swine fed diets containing corn and menhaden oils, Comparative Biochemistry & Physiology, 9/1/94, Physiology. 109, 1
Billman GE; Kang JX; Leaf A. Lipids. 3/1/1997
Black SC; Katz S; McNeill JH. Influence of omega-3 fatty acid treatment on cardiac phospholipid composition and coronary flow of streptozocin-diabetic rats, Metabolism: Clinical & Experimental, 3/1/93, 42, 3
Bordoni A; Biagi PL; Turchetto E; Rossi CA; Hrelia S. Cardioscience. 12/1/1992
Bordoni A; Tantini B; Clo C; Turchetto E. Influence of docosahexaenoic acid on phosphatidylinositol metabolism in cultured cardiomyocytes, Cardioscience, 12/1/90, 1, 4
Bouroudian M; Nalbone G; Grynberg A; Leonardi J; Lafont H. In vitro study of docosahexaenoic acid incorporation into phosphatidylcholine by enzymes of rat heart, Molecular & Cellular Biochemistry, 3/27/90, 93, 2
Chardigny JM; Moreau D. Effects of dietary fats on cardiac performance and substrate utilization in isolated perfused rat hearts, Nutrition Research, 11/1/91, 11, 2–3
Charnock JS; Abeywardena MY; McLennan PL. Comparative changes in the fatty-acid composition of rat cardiac phospholipids after long-term feeding of sunflower seed oil- or tuna fish oil-supplemented diets, Annals of Nutrition & Metabolism, 1/1/86, 30, 6
Charnock JS; Abeywardena MY; McLennan PL. The effect of different dietary lipid supplements on the non-esterified fatty acid composition of normoxic rat hearts: A link between nutrition and cardiac arrhythmia, Nutrition Research, 1/1/92, 12, 12
Chen MF; Lee YT; Hsu HC et al. Int J Cardiol 1992; 36(3):297–304
Delerive P; Oudot F; Ponsard B; Talpin S; Sergiel JP; Cordelet C; Athias P; Grynberg A. Hypoxia-reoxygenation and polyunsaturated fatty acids modulate adrenergic functions in cultured cardiomyocytes, Journal of Molecular & Cellular Cardiology, 2/1/99, 31, 2
Demaison L; Grynberg A. Reprod Nutr Dev 1991; 31(1):37–45
Demaison L, Moreau D, Vergely-Vandriesse C, et al. Effects of dietary polyunsaturated fatty acids and hepatic steatosis on the functioning of isolated working rat heart under normoxic conditions and during post-ischemic reperfusion. Mol Cell Biochem. 2001;224:103-116. [pmid: 11693187].
Demaison L; Sergiel JP; Moreau D; Grynberg A. Influence of the phospholipid n-6/n-3 polyunsaturated fatty acid ratio on the mitochondrial oxidative metabolism before and after myocardial ischemia, Biochimica et Biophysica Acta, 10/21/94, 1227, 1–2
Denson DD; Wang X; Worrell RT; Eaton DC. Effects of fatty acids on BK channels in GH(3) cells, American Journal of Physiology - Cell Physiology, 10/1/00, 279, 4
Diaz O; Berquand A; Dubois M, et al. Journal of Biological Chemistry 2002; 277(42):39368–39378
Djemli-Shipkolye AR. Differential Effect of w3 PUFA Supplementations on Na,K-ATPase and Mg-ATPase Activities: Possible Role of the Membrane w6/w3 Ratio, Journal of Membrane Biology, 1/1/03, 191, 1
Du XJ;Dart AM;Riemersma RA;, Lack of modulation by dietary unsaturated fats on sympathetic neurotransmission in rat hearts, American Journal of Physiology, 9/1/93, 265, 3 Pt 2
Dubois M; Croset M; Nemoz G; Lagarde M; Prigent AF. Modulation of cyclic nucleotide phosphodiesterase by dietary fats in rat heart, Lipids, 10/1/92, 27, 10
Finkel MS; Romeo RC; Hartsell TL, et al. J Cardiovasc Pharmacol 1992;20(4):563–571
Forster W; Mentz P; Blass KE; Mest HJ. Antiarrhythmic effects of arachidonic, linoleic, linolenic, and oleic acid, and the influence of indomethacin and polyphloretinephosphate, Advances in Prostaglandin & Thromboxane Research, 1/1/76, 1
Garratt JC; McEvoy MP; Owen DG. Blockade of two voltage-dependent potassium channels, mKv1.1 and mKv1.2, by docosahexaenoic acid, European Journal of Pharmacology, 10/31/96, 314, 3
Germain E; Bonnet P; Aubourg L; Grangeponte MC; Chajes V; Bougnoux P. Anthracycline-induced cardiac toxicity is not increased by dietary omega-3 fatty acids, Pharmacological Research, 1/1/03, 47, 2
Grynberg A; Degois M; Rocquelin G. Succinate dehydrogenase activity in relation with cardiac morphology in rats fed low erucic acid rapeseed oil, Archives d' Anatomie Microscopique et de Morphologie Experimentale, 1/1/84, 73, 4
Grynberg A; Nalbone G; Leonardi J; Lafont H; Athias P. Eicosapentaenoic and docosahexaenoic acids in cultured rat ventricular myocytes and hypoxia-induced alterations of phospholipase-A activity, Molecular & Cellular Biochemistry, 10/21/92, 116, 1–2
Hartog JM; Lamers JM; Montfoort A; Becker AE; Klompe M; Morse H; ten Cate FJ; van der WL; Hulsmann WC; Hugenholtz PG. Comparison of mackerel-oil and lard-fat enriched diets on plasma lipids, cardiac membrane phospholipids, cardiovascular performance, and morphology in young pigs, American Journal of Clinical Nutrition, 8/1/87, 46, 2
Hasin Y; Sarel O; Shefer A; Raz S; Gotsman MS. Dietary lipid intake and myocardial electrophysiology, Israel Journal of Medical Sciences, 12/1/87, 23, 12
Hazama H; Nakajima T; Asano M; Iwasawa K; Morita T; Igarashi K; Nagata T; Horiuchi T; Suzuki J; Soma M;Okuda Y. Omega-3 polyunsaturated fatty acids--modulation of voltage-dependent L-type Ca2+ current in guinea-pig tracheal smooth muscle cells, European Journal of Pharmacology, 8/21/98, 355, 2–3
Hirafuji M; Ebihara T; Kawahara F; Hamaue N; Endo T; Minami M. Inhibition by docosahexaenoic acid of receptor-mediated Ca<sup>2+</sup> influx in rat vascular smooth muscle cells stimulated with 5-hydroxytryptamine, European Journal of Pharmacology, 1/1/01, 427, 3
Hirafuji M; Ebihara T; Kawahara F;Nezu A; Taminura A; Saito H; Minami M. Effect of docosahexaenoic acid on intracellular calcium dynamics in vascular smooth muscle cells from normotensive and genetically hypertensive rats, Research Communications in Molecular Pathology & Pharmacology, 10/1/98, 102, 1
Honen BN; Saint DA. Polyunsaturated dietary fats change the properties of calcium sparks in adult rat atrial myocytes, Journal of Nutritional Biochemistry, 1/1/02, 13, 6
Hong MY; Chapkin RS; Barhoumi R et al. Carcinogenesis 2002; 23(11):1919–1925
Kakar SS; Huang WH; Askari A. Control of cardiac sodium pump by long-chain acyl coenzymes A, Journal of Biological Chemistry, 1/5/87, 262, 1
Karanian JW. Inhibitory effects of n-6 and n-3 hydroxy fatty acids on thromboxane (U46619)-induced smooth muscle contraction, Journal of Pharmacology & Experimental Therapeutics, 1/1/94, 270, 3
Kearns RJ; Hayek MG; Turek JJ et al. Veterinary Immunology & Immunopathology 1999; 69(2–4):165–183
Kim D; Sladek CD; Aguado-Velasco C; Mathiasen JR. Arachidonic acid activation of a new family of K+ channels in cultured rat neuronal cells, Journal of Physiology, 5/1/95, 484, Pt 3
Kohno M; Ohmori K; Wada Y; Kondo I; Noma T; Fujita N; Mizushige K; Mandal AK. Inhibition by eicosapentaenoic acid of oxidized-LDL- and lysophosphatidylcholine-induced human coronary artery smooth muscle cell production of endothelin, Journal of Vascular Research, 7/1/01, 38, 4
Ku K; Nosaka S; Hashimoto M et al. Transplantation 1996; 62(6):735–742
Lauritzen I; Blondeau N; Heurteaux C; Widmann C; Romey G; Lazdunski M. Polyunsaturated fatty acids are potent neuroprotectors, EMBO Journal, 4/17/00, 19, 8
Lee SH; Clandinin MT;, Effect of dietary fat on the utilization of fatty acids by myocardial tissue in the rat, Journal of Nutrition, 11/1/86, 116, 11
Lehr HA; Hubner C; Nolte D; Kohlschutter A; Messmer K. Dietary fish oil blocks the microcirculatory manifestations of ischemia-reperfusion injury in striated muscle in hamsters, Proceedings of the National Academy of Sciences of the United States of America, 8/1/91, 88, 15
Locher R; Sachinidis A; Brunner C; Vetter W. Scandinavian Journal of Clinical & Laboratory Investigation. 1991
Luostarinen R; Wallin R;Saldeen T. Dietary (n-3) fatty acids increase superoxide dismutase activity and decrease thromboxane production in the rat heart, Nutrition Research, 1/1/97, 17, 1
Matsui H; Morishima I; Hayashi K; Kamiya H; Saburi Y; Okumura K. Dietary fish oil does not prevent doxorubicin-induced cardiomyopathy in rats, Canadian Journal of Cardiology, 3/1/02, 18, 3
Mayol V; Duran MJ; Dignat-George F; Levy S; Sampol J, et al. Atherosclerosis. 1998
McMurchie EJ; Patten GS; Charnock JS; McLennan PL. The interaction of dietary fatty acid and cholesterol on catecholamine-stimulated adenylate cyclase activity in the rat heart, Biochimica et Biophysica Acta, 4/9/87, 898, 2
Mest HJ; Blass KE; Forter W. Effects of arachidonic, linoleic, linolenic and oleic acid on experimental arrhythmias in cats, rabbits and guinea-pigs, Prostaglandins, 7/1/77, 14, 1
Nair SS; Leitch J; Garg ML. Specific modifications of phosphatidylinositol and nonesterified fatty acid fractions in cultured porcine cardiomyocytes supplemented with n-3 polyunsaturated fatty acids, Lipids, 7/1/99, 34, 7
Nakao F; Kobayashi S; Mogami K; Mizukami Y; Shirao S; Miwa S; Todoroki-Ikeda N; Ito M;Matsuzaki M. Involvement of Src family protein tyrosine kinases In reply to: Ca2+ sensitization of coronary artery contraction mediated by a sphingosylphosphorylcholine-Rho-kinase pathway, Circulation Research, 1/1/02, 91, 10
Okuda Y. Life Sciences 1994; 55(1)
Okuda Y; Ezure M; Tsukahara K; Sawada T; Mizutani M; Katori T; Bannai C; Yamashita K. Eicosapentaenoic acid enhances intracellular free calcium in cultured human endothelial cells, Biochemical Medicine & Metabolic Biology, 4/1/94, 51, 2
Oudot F; Grynberg A; Sergiel JP. Eicosanoid synthesis in cardiomyocytes: influence of hypoxia, reoxygenation, and polyunsaturated fatty acids, American Journal of Physiology, 1/1/95, 268, 1 Pt 2
Paige JA; Liao R; Hajjar RJ; Foisy RL; Cory CR; O'Brien PJ; Gwathmey JK. Effect of a high omega-3 fatty acid diet on cardiac contractile performance in Oncorhynchus mykiss, Cardiovascular Research, 2/1/96, 31, 2
Patten GS; Rinaldi JA; McMurchie EJ. Effects of dietary eicosapentaenoate (20:5 n-3) on cardiac beta-adrenergic receptor activity in the marmoset monkey, Biochemical & Biophysical Research Communications, 7/31/89, 162, 2
Paulson DJ; Smith JM; Zhao J; Bowman J. Effects of dietary fish oil on myocardial ischemic/reperfusion injury of Wistar Kyoto and stroke-prone spontaneously hypertensive rats, Metabolism: Clinical & Experimental, 5/1/92, 41, 5
Pehowich DJ. Dietary n-3 fatty acids alter angiotensin-induced contraction and 1,2- diacylglycerol fatty acid composition in thoracic aortas from diabetic rats, Prostaglandins Leukotrienes and Essential Fatty Acids, Vol 58(4) (pp 301–309), 1998, 1/1/98
Pepe S; McLennan PL. Cardiac membrane fatty acid composition modulates myocardial oxygen consumption and postischemic recovery of contractile function, Circulation, 5/14/02, 105, 19
Poling JS; Karanian JW; Salem N; Vicini S. Time- and voltage-dependent block of delayed rectifier potassium channels by docosahexaenoic acid, Molecular Pharmacology, 2/1/95, 47,
Poling JS; Vicini S; Rogawski MA; Salem N. Docosahexaenoic acid block of neuronal voltage-gated K+ channels: subunit selective antagonism by zinc, Neuropharmacology, 1/1/96, 35, 7
Pound EM; Kang JX; Leaf A. Journal of Lipid Research 2001; 42:346–351
Quaggiotto P; Leitch JW; Falconer J; Murdoch RN; Garg ML. Plasma F(2alpha)-isoprostane levels are lowered in pigs fed an (n-3) polyunsaturated fatty acid supplemented diet following occlusion of the left anterior descending coronary artery, Nutrition Research, 1/1/00, 20, 5
Reibel DK; Holahan MA; Hock CE. Effects of dietary fish oil on cardiac responsiveness to adrenoceptor stimulation, American Journal of Physiology, 3/1/88, 254, 3 Pt 2
Roche H. International Journal for Vitamin & Nutrition Research 1994; 64(3)
Seebungkert B; Lynch JW. Effects of polyunsaturated fatty acids on voltage-gated K+ and Na+ channels in rat olfactory receptor neurons, European Journal of Neuroscience, 12/1/02, 16, 11
Sergiel JP; Martine L; Raederstorff D; Grynberg A; Demaison L. Individual effects of dietary EPA and DHA on the functioning of the isolated working rat heart, Canadian Journal of Physiology & Pharmacology, 7/1/98, 76, 7–8
Singleton CB; Valenzuela SM; Walker BD; Tie H; Wyse KR; Bursill JA; Qiu MR; Breit SN; Campbell TJ. Blockade by N-3 polyunsaturated fatty acid of the Kv4.3 current stably expressed in Chinese hamster ovary cells, British Journal of Pharmacology, 6/1/99, 127, 4
Skuladottir GV; Johannsson M. Pharmacology & Toxicology. 2/1/1997
Smith JM. Effects of dietary fish oil on cardiovascular responsiveness to adrenergic agonists in spontaneously hypertensive rat, Canadian Journal of Physiology & Pharmacology, 1/1/93, 71, 7
Su MJ; Nieh YC; Lin FY; Lo HM; Tseng YZ. Electrophysiological effects of linolenic acid on rat ventricular cardiomyocytes, Asia Pacific Journal of Pharmacology, 1/1/94, 9, 1
Voskuyl RA; Vreugdenhil M; Kang JX; Leaf A. Anticonvulsant effect of polyunsaturated fatty acids in rats, using the cortical stimulation model, European Journal of Pharmacology, 1/12/98, 341, 2–3
Vreugdenhil M; Bruehl C; Voskuyl RA; Kang JX; Leaf A; Wadman WJ. Polyunsaturated fatty acids modulate sodium and calcium currents in CA1 neurons, Proceedings of the National Academy of Sciences of the United States of America, 10/29/96, 93, 22
Wood DA; Riemersma RA; Butler S; Thomson M; Macintyre C; Elton RA; Oliver MF. Linoleic and eicosapentaenoic acids in adipose tissue and platelets and risk of coronary heart disease, Lancet, 1/1/87, i, 8526
Xiao Y; Li X. Polyunsaturated fatty acids modify mouse hippocampal neuronal excitability during excitotoxic or convulsant stimulation, Brain Research, 10/30/99, 846, 1
Xiao YF; Ke Q; Wang SY, et al. Proceedings of the National Academy of Sciences of the United States of America 2001; 98(6):3606–3611
Xiao YF; Wright SN; Wang GK; et al. Am J of Physiology-Heart & Circulatory Physiology 2000; 279(1):H35–H46
Xiao YF; Wright SN; Wang GK; Morgan JP; Leaf A. American Journal of Physiology-Heart & Circulatory Physiology. 1998
Xiao YF; Wright SN; Wang GK; Morgan JP; Leaf A. Proceedings of the National Academy of Sciences of the United States of America. 1998
Yanagisawa A; Lefer AM. Vasoactive effects of eicosapentaenoic acid on isolated vascular smooth muscle, Basic Research in Cardiology, 3/1/87, 82, 2
Yang B; Saldeen TG; Nichols WW; Mehta JL. Dietary fish oil supplementation attenuates myocardial dysfunction and injury caused by global ischemia and reperfusion in isolated rat hearts, Journal of Nutrition, 12/1/93, 123, 12