# References and Included Studies

1 USDA. Individual Fatty Acid Intakes: Results from the 1995 Continuing Survey of Food Intakes by Individuals (data table set 4). Available online at <http://www.barc.usda.gov/bhnrc/foodsurvey/home.htm>.
2 Institute of Medicine. Dietary Reference Intakes: Energy, Carbohydrate, Fiber, Fat, Fatty Acids, Cholesterol, Protein, and Amino Acids (Macronutrition). 2002. The National Academy Press.
3 Simopoulos A P. Evolutionary aspects of omega-3 fatty acids in the food supply. Prostaglandins Leukotrienes and Essential Fatty Acids. 1999;60(56):421-429.
4 Fallon S, Enig MG. Tripping Lightly Down the Prostaglandin Pathways.The Price-Pottenger Nutrition Foundation. Avaliable online at <http://www.price-pottenger.org/Articles/Prostaglandin.htm>. 2001.
5 Nair S S, Leitch J W, Falconer J, Garg M L. Prevention of cardiac arrhythmia by dietary (n-3) polyunsaturated fatty acids and their mechanism of action. [Review] [93 refs]. Journal of Nutrition. 1997;127(3):383-393. [pmid: 9082021].
6 James M J, Gibson R A, Cleland L G. Dietary polyunsaturated fatty acids and inflammatory mediator production. Am J Clin Nutr. 2000;71(1 SUPPL.):343S-348S. [pmid: 10617994].
7 Krummel D. Nutrition in Cardiovascular Disease. In: Mahan LK, Escot-Stump S, editors. Krause's Food, Nutrition, and Diet Therapy. W.B. Saunder Company, 1996.
8 Hornstra G. Omega-3 long-chain polyunsaturated fatty acids and health benefits. Amended and updated version of the English translation of <<Oméga-3 et bénéfice santé>>, initially published by Catherine Anselmino, Centre d'Etude et d'Information sur les Vitamines, Roche Vitamines France, Neuilly-sur-Seine (NutriScience). Available online: <http://www.vita-web.com/whatsnew/Omega 3.pdf>. Catherine Anselmino, Centre d'Etude et d'Information sur les Vitamines, Roche Vitamines France, Neuilly-sur-Seine (NutriScience).
9 Mohrman D, Heller L. Cardiovascular Physiology. 5th ed. New York: Lange Medical Books/McGraw-Hill, 2003.
10 Heart and Stroke Statistical Update for 2003. Website . 2003.
11 Grynberg A, Fournier A, Sergiel J P, Athias P. Membrane docosahexaenoic acid vs. eicosapentaenoic acid and the beating function of the cardiomyocyte and its regulation through the adrenergic receptors. Lipids. 1996;31(Suppl):S205-S210. [pmid: 8729120].
12 Nair S S, Leitch J W, Falconer J, Garg M L. Prevention of cardiac arrhythmia by dietary (n-3) polyunsaturated fatty acids and their mechanism of action. [Review] [93 refs]. Journal of Nutrition. 1997;127(3):383-393. [pmid: 9082021].
13 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
14 Walker M J, Curtis M J, Hearse D J, et al. The Lambeth Conventions: guidelines for the study of arrhythmias in ischaemia infarction, and reperfusion. Cardiovascular Research. 1988;22(7):447-455. [pmid: 3252968].
15 Curtis M J, Macleod B A, Walker M J. Models for the study of arrhythmias in myocardial ischaemia and infarction: the use of the rat. [Review] [141 refs]. Journal of Molecular & Cellular Cardiology. 1987;19(4):399-419. [pmid: 3302278].
16 McLennan P L, Abeywardena M Y, Charnock J S. Dietary fish oil prevents ventricular fibrillation following coronary artery occlusion and reperfusion. Am Heart J. 1988;116(3):709-717. [pmid: 3414486].
17 Hock C E, Holahan M A, Reibel D K. Effect of dietary fish oil on myocardial phospholipids and myocardial ischemic damage. American Journal of Physiology. 1987;252(3:Pt 2):t-60.
18 McLennan P, Dallimore J. Dietary canola oil modifie myocardial fatty acids and inhibits cardiac arrhythmias in rats. Journal of Nutrition 125, 1003–1009. 1995.
19 McLennan P L. Relative effects of dietary saturated, monounsaturated, and polyunsaturated fatty acids on cardiac arrhythmias in rats. American Journal of Clinical Nutrition. 1993;57(2):207-212. [pmid: 8424390].
20 Hock C E, Beck L D, Bodine R C, Reibel D K. Influence of dietary n-3 fatty acids on myocardial ischemia and reperfusion. American Journal of Physiology. 1990;259(5:Pt 2):t-26.
21 Anderson K E, Du X J, Sinclair A J, Woodcock E A, Dart A M. Dietary fish oil prevents reperfusion Ins(1,4,5)P3 release in rat heart: possible antiarrhythmic mechanism. Am J Physiol. 1996;271(4 Pt 2):H1483-H1490. [pmid: 8897943].
22 Charnock J S, Abeywardena M Y, Tan D, McLennan P L. Omega-3 and omega-6 PUFA's have different effects on the phospholipid fatty acid composition of rat myocardial muscle when added to a saturated fatty acid dietary supplement. Nutrition Research. 1991;11(9):1013-1024.
23 Abeywardena M Y, Charnock J S. Dietary lipid modification of myocardial eicosanoids following ischemia and reperfusion in the rat. Lipids. 1995;30(12):1151-1156. [pmid: 8614306].
24 McLennan P L, Bridle T M, Abeywardena M Y, Charnock J S. Dietary lipid modulation of ventricular fibrillation threshold in the marmoset monkey. American Heart Journal. 1992;123(6):1555-1561. [pmid: 1595535].
25 McLennan P L, Bridle T M, Abeywardena M Y, Charnock J S. Comparative efficacy of n-3 and n-6 polyunsaturated fatty acids in modulating ventricular fibrillation threshold in marmoset monkeys. Am J Clin Nutr. 1993;58(5):666-669. [pmid: 8237873].
26 Charnock J S, McLennan P L, Abeywardena M Y. Dietary modulation of lipid metabolism and mechanical performance of the heart. Molecular and Cellular Biochemistry. 1992;116(12):19-25. [pmid: 1480148].
27 Isensee H, Jacob R. Differential effects of various oil diets on the risk of cardiac arrhythmias in rats. Journal of Cardiovascular Risk. 1994;1(4):353-359. [pmid: 7542556].
28 McLennan P L, Abeywardena M Y, Charnock J S. Reversal of the arrhythmogenic effects of long-term saturated fatty acid intake by dietary n-3 and n-6 polyunsaturated fatty acids. American Journal of Clinical Nutrition. 1990;51(1):53-58. [pmid: 2296929].
29 McLennan P, Howe P, Abeywardena M, et al. The cardiovascular protective role of docosahexaenoic acid. Eur J Pharmacol. 1996;300(12):83-89. [pmid: 8741170].
30 Hartog J M, Lamers J M, Achterberg P W, et al. The effects of dietary mackerel oil on the recovery of cardiac function after acute ischaemic events in the pig. Basic Res Cardiol. 1987;82(Suppl 1):223-234. [pmid: 3663006].
31 al Makdessi S, Brandle M, Ehrt M, Sweidan H, Jacob R. Myocardial protection by ischemic preconditioning: the influence of the composition of myocardial phospholipids. Molecular & Cellular Biochemistry. 1995;145(1):69-73. [pmid: 7659079].
32 Pepe S, Tsuchiya N, Lakatta E G, Hansford R G. PUFA and aging modulate cardiac mitochondrial membrane lipid composition and Ca2+ activation of PDH. Am J Physiol Heart Circ Physiol. 1999;276(1 45-1):H149-H158.
33 Chen M F, Hsu H C, Lee Y T. Effects of fish oil supplementation on the changes in myocardial cyclic adenosine monophosphate, inositol 1,4,5-triphosphate and mitochondrial calcium levels during acute coronary occlusion-reperfusion in cholesterol-fed rabbits. Int J Cardiol. 1994;46(1):23-31. [pmid: 7960272].
34 Yang B C, Saldeen T G, Bryant J L, Nichols W W, Mehta J L. Long-term dietary fish oil supplementation protects against ischemia-reperfusion-induced myocardial dysfunction in isolated rat hearts. American Heart Journal. 1993;126(6):1287-1292. [pmid: 8249783].
35 Pepe S, McLennan P L. Dietary fish oil confers direct antiarrhythmic properties on the myocardium of rats. Journal of Nutrition. 1996;126(1):34-42. [pmid: 8558320].
36 Culp B R, Lands W E, Lucches B R, Pitt B, Romson J. The effect of dietary supplementation of fish oil on experimental myocardial infarction. Prostaglandins. 1980;20(6):1021-1031. [pmid: 7208950].
37 Oskarsson H J, Godwin J, Gunnar R M, Thomas J X Jr. Dietary fish oil supplementation reduces myocardial infarct size in a canine model of ischemia and reperfusion. J Am Coll Cardiol. 1993;21(5):1280-1285. [pmid: 8459088].
38 Kinoshita I, Itoh K, Nishida-Nakai M, et al. Antiarrhythmic effects of eicosapentaenoic acid during myocardial infarction--enhanced cardiac microsomal (Ca(2+)-Mg2+)-ATPase activity. Jpn Circ J. 1994;58(12):903-912. [pmid: 7699737].
39 Otsuji S, Shibata N, Hirota H, Akagami H, Wada A. Highly purified eicosapentaenoic acid attenuates tissue damage in experimental myocardial infarction. Jpn Circ J. 1993;57(4):335-343. [pmid: 8388522].
40 Lo H M, Lin F Y, Huang T S, et al. Effects of linolenic acid on the canine heart. J Formos Med Assoc. 1991;90(6):536-540. [pmid: 1680997].
41 Billman G E, Hallaq H, Leaf A. Prevention of ischemia-induced ventricular fibrillation by omega 3 fatty acids. Proceedings of the National Academy of Sciences of the United States of America. 1994;91(10):4427-4430. [pmcid: 43798]. [pmid: 8183925].
42 Billman G E, Kang J X, Leaf A. Prevention of sudden cardiac death by dietary pure omega-3 polyunsaturated fatty acids in dogs. Circulation. 1999;99(18):2452-2457. [pmid: 10318669].
43 Heard S O, McGuire K, Haw M P, et al. Dietary enrichment with omega-3 fatty acids partially protects against lipopolysaccharide-induced atrial depression in rats. Circ Shock. 1992;36(2):140-146. [pmid: 1582005].
44 Ku K, Oku H, Alam M S, et al. Influences of dietary omega-3 polyunsaturated fatty acids on the recovery of cardiac and renal functions after preservation in hyperlipidemic rats. Transplantation. 1997;64(3):399-404. [pmid: 9275102].
45 Reig J. Rat myocardial tissue lipids and their effect on ventricular electrical activity: Influence on dietary lipids. Cardiovasc Res 1993; 27(3).
46 Laustiola K, Salo M K, Metsa-Ketela T. Altered physiological responsiveness and decreased cyclic AMP levels in rat atria after dietary cod liver oil supplementation and its possible association with an increased membrane phospholipid n-3/n-6 fatty acid ratio. Biochim Biophys Acta. 1986;889(1):95-102. [pmid: 3021239].
47 Leifert W R, Dorian C L, Jahangiri A, McMurchie E J. Dietary fish oil prevents asynchronous contractility and alters Ca<sup>2+</sup> handling in adult rat cardiomyocytes. Journal of Nutritional Biochemistry. 2001;12(6):365-376. [pmid: 11516641].
48 Leifert W R, Jahangiri A, Saint D A, McMurchie E J. Effects of dietary n-3 fatty acids on contractility, Na+ and K+ currents in a rat cardiomyocyte model of arrhythmia. Journal of Nutritional Biochemistry. 2000;11(78):382-392. [pmid: 11044633].
49 Chemla D, Javouhey-Donzel A, Suard I, et al. Influence of dietary polyunsaturated fatty acids on contractility, lusitropy and compliance of isolated rat myocardium. J Mol Cell Cardiol. 1995;27(8):1745-1755. [pmid: 8523435].
50 Demaison L, Bouveret P, Grynberg A. Polyunsaturated fatty acid composition and lipid metabolism in cultured cardiomyocyte and isolated working rat heart. Nutrition Research. 1993;13(9):1003-1015.
51 Karmazyn M, Horackova M, Murphy M G. Effects of dietary cod liver oil on fatty-acid composition and calcium transport in isolated adult rat ventricular myocytes and on the response of isolated hearts to ischemia and reperfusion. Can J Physiol Pharmacol. 1987;65(2):201-209. [pmid: 3567734].
52 Gillis A M, Keashly R, Watson P A, Mathison H J, Parsons H G. Influence of dietary fat on the pharmacodynamics of propafenone in isolated, perfused rabbit hearts. Circulation. 1992;85(4):1501-1509. [pmid: 1555290].
53 Croset M, Black J M, Swanson J E, Kinsella J E. Effects of dietary n-3 polyunsaturated fatty acids on phospholipid composition and calcium transport in mouse cardiac sarcoplasmic reticulum. Lipids. 1989;24(4):278-285. [pmid: 2526915].
54 Swanson J E, Lokesh B R, Kinsella J E. Ca2+-Mg2+ ATPase of mouse cardiac sarcoplasmic reticulum is affected by membrane n-6 and n-3 polyunsaturated fatty acid content. J Nutr. 1989;119(3):364-372. [pmid: 2522149].
55 Croset M, Kinsella J E. Changes in phospholipid fatty acid composition of mouse cardiac organelles after feeding graded amounts of docosahexaenoate in presence of high levels of linoleate. Effect on cardiac ATPase activities. Ann Nutr Metab. 1989;33(3):125-142. [pmid: 2529810].
56 Taffet G E, Pham T T, Bick D L, et al. The calcium uptake of the rat heart sarcoplasmic reticulum is altered by dietary lipid. J Membr Biol. 1993;131(1):35-42. [pmid: 8381872].
57 Maixent J M, Gerbi A, Barbey O, et al. Dietary fish oil promotes positive inotropy of ouabain in the rat heart. Am J Physiol Heart Circ Physiol. 1999;277(6 46-6):H2290-H2297.
58 Benediktsdottir V E, Gudbjarnason S. Modification of the fatty acid composition of rat heart sarcolemma with dietary cod liver oil, corn oil or butter. J Mol Cell Cardiol. 1988;20(2):141-147. [pmid: 2840513].
59 Lamers J M, Hartog J M, Guarnieri C, et al. Lipid peroxidation in normoxic and ischaemic-reperfused hearts of fish oil and lard fat fed pigs. J Mol Cell Cardiol. 1988;20(7):605-615. [pmid: 3172249].
60 Honen B N, Saint D A. Polyunsaturated dietary fats change the properties of calcium sparks in adult rat atrial myocytes. Journal of Nutritional Biochemistry. 2002;13(6):322-329. [pmid: 12088797].
61 Pepe S, Bogdanov K, Hallaq H, et al. Omega 3 polyunsaturated fatty acid modulates dihydropyridine effects on L-type Ca2+ channels, cytosolic Ca2+, and contraction in adult rat cardiac myocytes. Proc Natl Acad Sci U S A. 1994;91(19):8832-8836. [pmcid: 44700]. [pmid: 7522322].
62 Black S C, Katz S, McNeill J H. Cardiac performance and plasma lipids of omega-3 fatty acid-treated streptozocin-induced diabetic rats. Diabetes. 1989;38(8):969-974. [pmid: 2526764].
63 Minarovic I, Vojtko R, Sebokova E, Klimes I, Zahradnik I. Effect of the high-fat diet on the calcium channels in rat myocardium. Annals of the New York Academy of Sciences, Vol 827 (pp 550–555), 1997 1997.
64 Gudmundsdottir E, Benediktsdottir V E, Gudbjarnason S. Combined effects of age and dietary fat on beta 1-receptors and Ca2+ channels in rat hearts. Am J Physiol. 1991;260(1 Pt 2):H66-H72. [pmid: 1847019].
65 Hallaq H, Smith T W, Leaf A. Modulation of dihydropyridine-sensitive calcium channels in heart cells by fish oil fatty acids. Proc Natl Acad Sci U S A. 1992;89(5):1760-1764. [pmcid: 48532]. [pmid: 1371883].
66 Kang JX, Leaf A. Effects of long-chain polyunsaturated fatty acids on the contraction of neonatal rat cardiac myocytes. Proceedings of the National Academy of Sciences of the United States of America, Vol 91(21) (pp 9886–9890), 1994 1994.
67 Li Y, Kang J X, Leaf A. Differential effects of various eicosanoids on the production or prevention of arrhythmias in cultured neonatal rat cardiac myocytes. Prostaglandins. 1997;54(2):511-530. [pmid: 9380795].
68 Kang J X, Leaf A. Prevention and termination of beta-adrenergic agonist-induced arrhythmias by free polyunsaturated fatty acids in neonatal rat cardiac myocytes. Biochem Biophys Res Commun. 1995;208(2):629-636. [pmid: 7695617].
69 Weylandt K H, Kang J X, Leaf A. Polyunsaturated fatty acids exert antiarrhythmic actions as free acids rather than in phospholipids. Lipids. 1996;31(9):977-982. [pmid: 8882978].
70 Reithmann C, Scheininger C, Bulgan T, Werdan K. Exposure to the n-3 polyunsaturated fatty acid docosahexaenoic acid impairs alpha 1-adrenoceptor-mediated contractile responses and inositol phosphate formation in rat cardiomyocytes. Naunyn-Schmiedebergs Archives of Pharmacology. 1996;354(2):109-119.
71 Juan H, Peskar B A, Simmet T. Effect of exogenous 5,8,11,14,17-eicosapentaenoic acid on cardiac anaphylaxis. Br J Pharmacol. 1987;90(2):315-325. [pmid: 2881590]. [pmcid: 1916950].
72 Hallaq H, Sellmayer A, Smith T W, Leaf A. Protective effect of eicosapentaenoic acid on ouabain toxicity in neonatal rat cardiac myocytes. Proc Natl Acad Sci U S A. 1990;87(20):7834-7838. [pmcid: 54844]. [pmid: 2172965].
73 Courtois M, Khatami S, Fantini E, et al. Polyunsaturated fatty acids in cultured cardiomyocytes: effect on physiology and beta-adrenoceptor function. American Journal of Physiology. 1992;262(2:Pt 2):t-6.
74 Negretti N, Perez M R, Walker D, O'Neill S C. Inhibition of sarcoplasmic reticulum function by polyunsaturated fatty acids in intact, isolated myocytes from rat ventricular muscle. J Physiol (Lond ). 2000;523(2):367-375. [pmid: 10699081].
75 de Jonge H W, Dekkers D H, Bastiaanse E M, et al. Eicosapentaenoic acid incorporation in membrane phospholipids modulates receptor-mediated phospholipase C and membrane fluidity in rat ventricular myocytes in culture. J Mol Cell Cardiol. 1996;28(5):1097-1108. [pmid: 8762046].
76 Jahangiri A, Leifert W R, Patten G S, McMurchie E J. Termination of asynchronous contractile activity in rat atrial myocytes by n-3 polyunsaturated fatty acids. Molecular & Cellular Biochemistry. 2000;206(12):33-41. [pmid: 10839192].
77 Rodrigo G C, Dhanapala S, Macknight A D. Effects of eicosapentaenoic acid on the contraction of intact, and spontaneous contraction of chemically permeabilized mammalian ventricular myocytes. J Mol Cell Cardiol. 1999;31(4):733-743. [pmid: 10329201].
78 Kang J X, Leaf A. Protective effects of free polyunsaturated fatty acids on arrhythmias induced by lysophosphatidylcholine or palmitoylcarnitine in neonatal rat cardiac myocytes. Eur J Pharmacol. 1996;297(12):97-106. [pmid: 8851173].
79 Leifert W R, Jahangiri A, McMurchie E J. Membrane fluidity changes are associated with the antiarrhythmic effects of docosahexaenoic acid in adult rat cardiomyocytes. Journal of Nutritional Biochemistry. 2000;11(1):38-44. [pmid: 15539341].
80 Ponsard B, Durot I, Delerive P, et al. Cross-influence of membrane polyunsaturated fatty acids and hypoxia-reoxygenation on alpha- and beta-adrenergic function of rat cardiomyocytes. Lipids. 1999;34(5):457-466. [pmid: 10380117].
81 Grynberg A, Fournier A, Sergiel J P, Athias P. Effect of docosahexaenoic acid and eicosapentaenoic acid in the phospholipids of rat heart muscle cells on adrenoceptor responsiveness and mechanism. J Mol Cell Cardiol. 1995;27(11):2507-2520. [pmid: 8596201].
82 Ferrier G R, Redondo I, Zhu J, Murphy M G. Differential effects of docosahexaenoic acid on contractions and L-type Ca2+ current in adult cardiac myocytes. Cardiovasc Res. 2002;54(3):601-610. [pmid: 12031706].
83 Macleod J C, Macknight A D, Rodrigo G C. The electrical and mechanical response of adult guinea pig and rat ventricular myocytes to omega3 polyunsaturated fatty acids. Eur J Pharmacol. 1998;356(23):261-270. [pmid: 9774258].
84 Grynberg A, Fantini E, Athias P, et al. Modification of the n-6/n-3 fatty acid ratio in the phospholipids of rat ventricular myocytes in culture by the use of synthetic media: functional and biochemical consequences in normoxic and hypoxic conditions. J Mol Cell Cardiol. 1988;20(10):863-874. [pmid: 3216398].
85 Durot I, Athias P, Oudot F, Grynberg A. Influence of phospholipid long chain polyunsaturated fatty acid composition on neonatal rat cardiomyocyte function in physiological conditions and during glucose-free hypoxia-reoxygenation. Molecular & Cellular Biochemistry. 1997;175(12):253-262. [pmid: 9350058].
86 Fournier A, Fantini E, Sergiel J P, Athias P, Grynberg A. Influence of the phospholipid content in docosahexaenoic acid on electrophysiology and contraction of rat heart muscle cells. Cardioscience. 1995;6(1):71-78. [pmid: 7605899].
87 Bayer B L, Forster W. Actions of prostaglandin precursors and other unsaturated fatty acids on conduction time and refractory period in the cat heart in situ. Br J Pharmacol. 1979;66(2):191-195. [pmid: 465869]. [pmcid: 2043625].
88 Bogdanov K Y, Spurgeon H A, Vinogradova T M, Lakatta E G. Modulation of the transient outward current in adult rat ventricular myocytes by polyunsaturated fatty acids. Am J Physiol. 1998;274(2 Pt 2):H571-H579. [pmid: 9486261].
89 Kang J X, Xiao Y F, Leaf A. Free, long-chain, polyunsaturated fatty acids reduce membrane electrical excitability in neonatal rat cardiac myocytes. Proc Natl Acad Sci U S A. 1995;92(9):3997-4001. [pmcid: 42089]. [pmid: 7732020].
90 O'Neill S C, Perez M R, Hammond K E, Sheader E A, Negretti N. Direct and indirect modulation of rat cardiac sarcoplasmic reticulum function by n-3 polyunsaturated fatty acids. J Physiol (Lond ). 2002;538(Pt 1):179-184. [pmid: 11773326].
91 Rinaldi B, Di Pierro P, Vitelli M R, et al. Effects of docosahexaenoic acid on calcium pathway in adult rat cardiomyocytes. Life Sci. 2002;71(9):993-1004. [pmid: 12088759].
92 Vitelli M R, Filippelli A, Rinaldi B, et al. Effects of docosahexaenoic acid on [Ca<sup>2+</sup>]<inf>i</inf> increase induced by doxorubicin in ventricular rat cardiomyocytes. Life Sci. 2002;71(16):1905-1916. [pmid: 12175705].
93 Philipson K D, Ward R. Effects of fatty acids on Na+-Ca2+ exchange and Ca2+ permeability of cardiac sarcolemmal vesicles. J Biol Chem. 1985;260(17):9666-9671. [pmid: 2991257].
94 Philipson K D, Ward R. Modulation of Na+-Ca2+ exchange and Ca2+ permeability in cardiac sarcolemmal vesicles by doxylstearic acids. Biochim Biophys Acta. 1987;897(1):152-158. [pmid: 3099842].
95 Xiao Y F, Gomez A M, Morgan J P, Lederer W J, Leaf A. Suppression of voltage-gated L-type Ca2+ currents by polyunsaturated fatty acids in adult and neonatal rat ventricular myocytes. Proc Natl Acad Sci U S A. 1997;94(8):4182-4187. [pmcid: 20596]. [pmid: 9108126].
96 Goel D P, Maddaford T G, Pierce G N. Effects of omega-3 polyunsaturated fatty acids on cardiac sarcolemmal Na(+)/H(+) exchange. Am J Physiol Heart Circ Physiol. 2002;283(4):H1688-H1694. [pmid: 12234824].
97 Leifert W R, McMurchie E J, Saint D A. Inhibition of cardiac sodium currents in adult rat myocytes by n-3 polyunsaturated fatty acids. J Physiol (Lond ). 1999;520(Pt 3):671-679. [pmid: 10545135].
98 Xiao Y F, Kang J X, Morgan J P, Leaf A. Blocking effects of polyunsaturated fatty acids on Na+ channels of neonatal rat ventricular myocytes. Proc Natl Acad Sci U S A. 1995;92(24):11000-11004. [pmcid: 40558]. [pmid: 7479925].
99 Xiao Y F, Morgan J P, Leaf A. Effects of polyunsaturated fatty acids on cardiac voltage-activated K(+) currents in adult ferret cardiomyocytes. Sheng Li Hsueh Pao - Acta Physiologica Sinica. 2002;54(4):271-281.
100 Honore E, Barhanin J, Attali B, Lesage F, Lazdunski M. External blockade of the major cardiac delayed-rectifier K+ channel (Kv1.5) by polyunsaturated fatty acids. Proceedings of the National Academy of Sciences of the United States of America. 1994;91(5):1937-1941. [pmcid: 43279]. [pmid: 8127910].
101 Kang J X, Li Y, Leaf A. Regulation of sodium channel gene expression by class I antiarrhythmic drugs and n - 3 polyunsaturated fatty acids in cultured neonatal rat cardiac myocytes. Proc Natl Acad Sci U S A. 1997;94(6):2724-2728. [pmcid: 20157]. [pmid: 9122264].
102 Riemersma R A, Sargent C A. Dietary fish oil and ischaemic arrhythmias. Journal of Internal Medicine Supplement. 1989;225(731):111-116. [pmid: 2706038].
103 Fay M P, Graubard B I, Freedman L S, Midthune D N. Conditional logistic regression with sandwich estimators: application to a meta-analysis. Biometrics. 1998;54(1):195-208. [pmid: 9544516].
104 Fay M P, Freedman L S. Meta-analyses of dietary fats and mammary neoplasms in rodent experiments. Breast Cancer Research & Treatment. 1997;46(23):215-223. [pmid: 9478276].
105 Fay M P, Freedman L S, Clifford C K, Midthune D N. Effect of different types and amounts of fat on the development of mammary tumors in rodents: a review. Cancer Research. 1997;57(18):3979-3988. [pmid: 9307282].