# Appendix D Peer Reviewers

We gratefully acknowledge the following individuals who reviewed the initial draft of this Report and provided us with constructive feedback. Acknowledgments are made with the explicit statement that this does not constitute endorsement of the report.

## American College of Physicians

- Katherine D. Sherif, MD
- Director, Center for Women's Health
- Medical College of Pennsylvania Hospital
- 3300 Henry Avenue
- Drexel University College of Medicine
- Philadelphia, PA 19129-1191

## Agency for Healthcare Research and Quality

- David Atkins, MD. MPH
- Chief Medical Officer
- Center for Outcomes and Evidence
- Agency for Healthcare Research and Quality
- 540 Gaither Road
- Rockville, MD 20850

## Other Reviewers

### National Heart, Lung, Blood Institute

- David A. Lathrop, PhD
- Assistant Director
- Clinical and Molecular Medicine Program
- Division of Heart and Vascular Diseases
- National Heart, Lung, and Blood Institute
- National Institutes of Health
- U.S. Department of Health & Human Services
- 6701 Rockledge Drive, Room 8136
- Bethesda, MD 20892-7936

### Office of Dietary Supplements, National Institutes of Health

- Anne Thurn, PhD
- Director
- Evidence-Based Review Program
- Office of Dietary Supplements
- National Institutes of Health
- Bldg. 31, Room 1B29
- Bethesda, MD 20892-2086