# Appendix C

Evidence Table 1: Whole Animal Studies Part 1

Table 1 Evidence Table: Whole Animal Studies Part 1

Author, yr | Study Characteristics | Animal Model | Exposure Duration | Ref. Diet | Dietary Characteristics
| | | | | Groups | Total Fat | % of Total Fatty Acids | | | | | Other
| | | | | | | ALA | E+D | n-6 | SFA | MUFA
Abeywardena, 1995 | Country: Australia | Mean age: ND | 9 months | Standard rat chow (Milling Industries, Adelaide, Australia) | SSO | 15* %w/w or 32* %kcal | 0.9 | 0 | 59* | 13* | 22*
| Animal: Wistar rats | Age grp: ND | | | SBO | | 2.8 | 0 | 44* | 21* | 25*
| Funding: Industry | Sex: Males | | | FO (MaxEPA) | | 1.4 | 22 | 7* | 28* | 15*
al Makdessi, 1995 | Country: Germany | Mean age: ND | 10 weeks | Low-fat (<1% w/w) standard chow from (Altromin GmbH & Co.) | FO (sardine oil) | 10% w/w | 1.3 | 29 | ND | 31* | ND
| Animal: Wistar rats | Age grp: Young | | | Coconut oil | | 0.9 | 0 | ND | >60* | ND
| Funding: ND | Sex: Males
Anderson, 1996 | Country: Australia | Mean age: ND | 8 weeks | Total fat: 3.5% | FO (MaxEPA) | Initially given at 0.6 ml and + 0.1 ml/wk up to 1.0 ml w/ increasing body weight | ND | ND | 0 | 10 | 28 | Total n3 = 41%
| Animal: Sprague-Dawley rats | Age grp: Adult | | | Safflower oil | | 0 | 0 | 75 | 25 | 15
| Funding: Government | Sex: Males
Billman, 1994 | Country: US | Mean age: ND | Infusion study | ND | Saline (n=3) or I.V. infusion (n=5) | 100 ml of Intralipid, a 10% lipid emulsion | 7 | 0 | ND | ND | ND
| Animal: Mongrel dogs | Age grp: ND | | | Emulsion of fish oil | 10 ml FO concentrate (n=4)5 ml same FO concentrate + 5 ml TG concentrate (n=4) | ND | 70 | ND | ND | ND
| Funding: Government | Sex: ND | | | | | ND | 65 | ND | ND | ND
Billman, 1999 | Country: US | Mean age: ND | Infusion study | ND | SBO lipid emulsion (n=7) or saline (n=7) | ND | 7~8 in SBO | 0 | ND | ND | ND
| Animal: Mongrel dogs | Age grp: ND | | | EPA | | 0 | E=98 | ND | ND | ND
| Funding: Government | Sex: ND | | | | | | D=1
| | | | | DHA | | 0 | E=1 | ND | ND | ND
| | | | | | | | D=91
| | | | | ALA | | >99 | 0
Charnock, 1992 | Country: Australia | Mean age: > 3 years old | 30 months | ND | SSO | 12* %w/w or 28 %kcal | 1.1 | 0 | ND | 23* | 23* | N3/n6 = 0.02= 2.0
| Animal: Wistar rats | Age grp: Adult | | | FO | | 1.4 | 20 | ND | 29* | 26*
| Funding: ND | Sex: ND
Charnock, 1991 | Country: Australia | Mean age: near 1 yr old | 12 months | NDMilling Industries Australia. Total fat: 3 %w/w | SF/SSO | 16* %w/w or 35 %kcal | ND | ND | 19 | 45 | 29 | TT n-3 = 1.1
| Animal: Wistar rats | Age grp: Adult | | | | | | | | | | TT n6 = 19
| Funding: ND | Sex: males | | | SF/FO | | ND | ND | 12 | 41 | 29 | TT n-3 = 13
| | | | | | | | | | | | TT n6 = 12
Chen, 1994 | Country: Taiwan | Mean age: ND | 2 weeks. | Standard rabbit chow (Purina 5321, St. Louis, MO, USA) | HC (1% CHOL-enriched diet) | 40 %kcal (1% chol) | ND | ND | ND | ND | ND
| Animal: rabbits | Age grp: ND | | | HCF (1% CHOL and 10% FO) | 40% energy (1% chol +10% fish oil) | ND | 52 | ND | ND | ND
| Funding: Government | Sex Males
Culp, 1980 | Country: US | Mean age: ND | 36 to 45 days | Standard dog chow (Friskies Dinner) | Standard dog chow | ND | ND | 0.1 | ND | 32 | 34
| Animal: Mongrel dogs | Age grp: ND | | | FO (Menhaden) | +25 %kcal | ND | 13 | ND | 32 | 20
| Funding: Government | Sex: ND
Germain, 2003 | Country: France | Mean age: ND | >= 3 weeks | APAE, Jouy en Josas, France. | Palm oil | +15% of total fat | ND | ND | ND | high MUFA level | ND
| Animal: Sprague-Dawley rats | Age grp: ND | | | DHASCO (DHA fom purified TGs) | | ND | ND | ND | ND | ND
| Funding: Government | Sex: Females
Hartog JM 1987 | Country: Netherlands | Mean age: 5 weeks | 16 weeks | ND | Lard fat (9% w/w) | ND | 1 | 0 | ND | 36 | ND
| Animal: Yorkshire piglets | Age grp: Unclear | | | ML (4.5% mackerel oil + 4.5% lard fat) | | 1 | 13 | ND | 32 | ND
| Funding: Dutch Heart Foundation | Sex: ND
Hock, 1990 | Country: US | Mean age: ND | 4 weeks | Fat-free purified diet | CO (corn oil) | 12 %kcal or 5 %w/w | 1 | 0 | 59 | 14* | 25* | n3/n6= 0.02
| Animal: Sprague-Dawley rats | Age grp: Weanling | | | MO (Menhaden oil) | | 2 | 20 | 5 | 33* | 27* | =6.06
| Funding: Government | Sex: ND
Hock, 1987 | Country: US | Mean age: ND | 4 weeks | Fat-free purified diet | CO (corn oil) | 12 %kcal or 5 %w/w | 1 | 0 | 59 | 14* | 25* | n3/n6= 0.02
| Animal: Sprague-Dawley rats | Age grp: Adult | | | MO (Menhaden oil) | | 2 | 21 | 4 | 31* | 27* | =7.99
| Funding: Government | Sex: Males
Isensee H 1994 | Country: Germany | Mean age: 2 months | 10 weeks | Low-fat (<1 %w/w ) basic diet (Altromin GmbH, Lage, Germany) | CO | 10 %w/w | 1 | 0 | 50 | 16 | 31
| Animal: Wistar rats | Age grp: Young | | | LO (Linseed oil) | | 52 | 0 | 20 | 9 | 16
| Design: A | Sex: Males | | | FO | | 0.3 | 29 | 12 | 31 | 26
| Funding: Alfred Teufel-Stiftung research foundation
Kinoshita, 1994 | Country: Japan | Mean age: ND | 8 weeks | Standard diet (Oriental Yeast Co.) | Standard diet | ND | ND | ND | ND | ND | ND
| Animal: Mongrel dogs | Age grp: Adult | | | EPA ester | Mochida Pharmaceutical Co | ND | 100 mg/kg BW/d | ND | ND | ND
| Diseased: Funding: ND | Sex: ND
Lo, 1991 | Country: Taiwan | Mean age: ND | Infusion study | Same dogs were infused control buffer or different dosages of ALA. | Control buffer | ND | ND | ND | ND | ND | ND
| Animal: Mongrel dogs | Age grp: ND | | | ALA infusion | | 1, 5, 10, 20, 30, or 60 mg/kg | ND | ND | ND | ND
| Funding: ND | Sex: MixSex : “either sex”
McLennan, 1996 | Country: Australia, Switzerland | Mean age: ND | 5 weeks | ND | Olive oil | 5% w/w from olive oil | ND | ND | ND | ND | ND
| Animal: spontaneously hypertensive Wistar rats | Age grp: ND | | | EPA | 0.5% from n-3; 4.5% from olive oil | ND | E:0.5 w/w | ND | ND | ND
| Funding: ND | Sex: Males | | | DHA | | ND | D:0.5w/w | ND | ND | ND
| | | | | EPA+DHA | | ND | ND | ND | ND | ND
McLennan, 1995 | Country: Australia | Mean age: 12 weeks | 12 weeks | Nonpurified lab rat diet. Total fat = 4% w/w | CAN | 15 %w/w or 32 %kcal | 8 | 0 | 21 | 12 | 60 | N3/n6 = 0.37
| Animal: Sprague-Dawley rats | Age grp: Adult | | | SBO | | 7 | 0 | 52 | 19 | 22 | = 0.14
| Funding: ND | Sex: Males | | | SSO | | 5 | 0 | 64 | 12 | 23 | =0.008
McLennan, Bridle, 1993 | Country: Australia | Mean age: ND | 16 weeks | Low-fat marmoset diet (Milling Industries, Adelaide, Australia) Total fat = 6% w/w | SF/SSO (8% sheep perirenal fat + 2% SSO) | 16 %w/w | 0.8 | 1 | 20 | 48 | ND | N3/n6 = 0.12
| Animal: Marmoset monkeys | Age grp: Old | | | SF/FO (7% SF + 3% FO) | | 0.8 | 11 | 10 | 47 | ND | =1.25
| Funding: Government | Sex: 50% Males
McLennan, 1993 | Country: Australia | Mean age: 30 weeks | 12 weeks | Basic laboratory diet (Milling Industries, Adelaide, Australia) Total fat = 4% w/w | SSO | 15 %w/w or 32 %kcal | ND | ND | 56 | 15 | 25 | Total n3 = 4%
| Animal: Sprague-Dawley rats | Age grp: Old | | | FO | | ND | ND | 8 | 40 | 25 | =17%
| Funding: International Olive Oil Council | Sex: ND
McLennan, 1992 | Country: Australia | Mean age: 2 years | 30 months | Total fat: 4 %w/w SFA: 37.3%MUFA: NDPUFA: 18.3% | SSO | 12 %w/w or 29 %kcal | ND | ND | 54 | 23 | ND | ND
| Animal: Marmoset monkeys | Age grp: Unclear | | | TFO (tuna fish oil) | | ND | ND | 11 | 29 | ND | Total n3 = 23%
| Funding: ND | Sex: breeding pairs
McLennan, 1990 | Country: Australia | Mean age: 2 months | 18 months | Standard lab rat diet. Total fat = 4% w/w | SF+SSO | 16 %w/w or 35 %kcal | 0 | 0 | 58 | 16 | ND
| Animal: Sprague-Dawley rats | Age grp: Adult | | | SF+TFO | | ND | 23 | 9 | 31 | ND
| Funding: Government | Sex: Males
McLennan, 1988 | Country: Australia | Mean age: “age-matched” | 12 months | Standard lab rat diet. Total fat = 4% w/w | SSO | 16 %w/wor 35 %kcal | ND | 0 | 58 | ND | ND
| Animal: Wistar rats | Age grp: Unclear | | | TFO | | ND | 23 | 9 | ND | ND
| Funding: Government | Sex: Males
Oskarsson, 1993 | Country: US | Mean age: ND | 6 weeks | ND | No fish oil Rx | ND | ND | ND | ND | ND | ND
| Animal: Mongrel dogs | Age grp: ND | | | MaxEPA | | ND | 0.1 g/kg/d | ND | ND | ND
| Funding: ND | Sex: “Mixed Sex”
Otsuji, 1993 | Country: Japan | Mean age: ND | 8 weeks | Standard diet prepared by Oriental Yeast Co. | Standard dog chow | 30 g/kg BW /day | ND | ND | ND | ND | ND
| Animal: Mongrel dogs | Age grp: Adult | | | EPA ester | 100 mg/kg BW/day | ND | ND | ND | ND | ND
| Funding: ND | Sex: MixSex : No data on the distribution
Pepe, 1996 | Country: Australia | Mean age: 16 weeks | 16 weeks | Nonpurified diet fed to all rats (Milling Industries, Adelaide, Australia).Total fat = 7.6% | SAT (sheep perirenal fat) | 15.3% w/w | 1.5 | 1 | 8 | 55 | ND
| Animal: Wistar rats | Age grp: Young | | | FO | | 1.2 | 36 | 8 | 25 | ND
| Funding: ND | Sex: Males
Yang, 1993 | Country: US | Mean age: ND | 5 days | Standard rat nonpurified diet (Purina Mills, St. Louis, MO)Total fat = 5 %kcal | Butter | 17 %kcal | ND | ND | ND | ND | ND
| Animal: Sprague-Dawley rats | Age grp: ND | | | FO (fish oil rich pellets | | ND | 32 | 23 | 25 | 15
| Funding: Government | Sex: Males

* estimated values, not reported in original paper

Types of study design:

A = N-3 PUFAs vs. n-6 PUFAs

B = N-3 PUFAs vs. MUFAs

C = N-3 PUFAs vs. SFAs

D = N-3 PUFAs vs. Standard chows

Evidence Table 1: Whole Animal Studies Part 2

Table 1 Evidence Table: Whole Animal Studies Part 2

Author, yr | Outcomes | Experimental Protocols | Results | Comment/ Biases/ Limitations
Abeywardena, 1995 | VPB | Myocardial ischemia and reperfusion model. | VPB/10 min | Sex diff? No
| VT (%) | 5-min regional myocardial ischemia. Arrhythmias induced by reperfusion were assessed during a 10-min period after releasing the occlusion and restoring blood flow. | [SBO vs. SSO] n=18 vs. 18, p>0.05 Increased +176% Estimated | Age diff? ND
| VF (%) | | [FO vs. SSO] n= 18 vs. 18, p>0.05 Decrease -13% Estimated | BW diff? No
| AS | | [FO vs. SBO] n= 18 vs. 18, Decrease -68% Estimated | No statistics were performed for FO vs. SBO comparison in the original study
| Deaths | | VT (%) during reperfusion
| | | [SBO vs. SSO] n=18 vs. 18, Increased 76%/39% Reported
| | | [FO vs. SSO] n=18 vs. 18, Decrease 22%/39% Reported
| | | VF (%) during reperfusion
| | | [SBO vs. SSO ] n= 18 vs. 18, Increased 23%/11% Reported
| | | [FO vs. SSO] n= 18 vs. 18, Decrease 5%/11% Estimated
| | | AS (severity of arrhythmia) during reperfusion
| | | [SBO vs. SSO] n= 18 vs. 18, p<0.05 Increase (sig.), +107% Estimated
| | | [FO vs. SSO] n= 18 vs. 18, p>0.05 Decrease, -40% Estimated
| | | [FO vs. SBO] n= 18 vs. 18, Decrease -71% Estimated
| | | Total Deaths
| | | [SBO vs. SSO] n= 18 vs. 18, No change 2/18 vs. 1/18 Reported
| | | [FO vs. SSO] n= 18 vs. 18, Decrease 0/18 vs. 1/18 Reported
| | | VT (%) during ischemia
| | | [SBO vs. SSO] n=: 18 vs. 18, No change 44%/39% Reported
| | | [FO vs. SSO] n=: 18 vs. 18, Decrease 6%/39% Reported
al Makdessi, 1995 | AR (%) | Arrhythima (AR) was defined as salves of extrasystoles and/or ventricular flutter and fibrillation. | [FO vs. HCO] (results in figure) | Sex diff? No
| SIZ (%) | The preconditioning = in situ by means of 2 cycles of 3 min left anterior descending coronary artery occlusion - 10 min reperfusion. | AR (%): n= 8 vs. 5, Decrease | Age diff? No
| | | AR (%) w/ precondition: n= 8 vs. 6, No change | BW diff? ND
| | | SIZ (%): n= 8 vs. 5, No change | No statistics were done for FO vs. HCO comparisons in the original study.
| | | SIZ (%) w/ precondition: n= 8 vs. 6, No change
Anderson, 1996 | VPB | Myocardial ischemia and reperfusion model. | Hearts that experienced instability (VPB, VT, and/or VF) during the equilibration period or sustained VT and/or VF during the last 30 s of the occlusion period were excluded from analysis of reperfusion-induced arrhythmias. | Sex diff? No.
| VT (%) | 20-min regional myocardial ischemia. Arrhythmias induced by reperfusion were assessed during reperfusion. | [FO vs. SO in reperfusion] | Age diff? ND
| VF (%) | | VPB: n= 8 vs. 6, p>0.05 No change -31% Estimated | BW diff? ND
| AS | | VT (%): n= 8 vs. 6, p>0.05, 38%/50% Reported | Sustained VT and/or VF were excluded from the analyses
| | | VF (%): n= 8 vs. 6, p>0.05, 13%/33% Reported
| | | AS: n= 8 vs. 6, p>0.05 Decrease, -54% Estimated
Billman, 1994 | VF (%) | Exercise-plus-ischemia (2-min occlusion) test. | Ctrl: saline or I.V. infusion | Sex diff? ND
| | VF was induced in one additional animal by the combination of cocain (1.0 mg/kg i.v.) and the exercise-plus-ischemia test. | VF (%) | Age diff? ND
| | | Ventricular flutter (which degenerates to VF) was reproducibly induced with each presentation of the control (both saline and Intralipid infusions) exercise-plus-ischemia tests. The cocaine exercise-plus-ischemia test induced a similar response. Data for all animals that developed VF have therefore been combined. | BW diff? ND
| | | [FO infusion vs. Ctrl] n= 8 vs. 8, p<0.005 Decrease (sig.) 12.5%/100% (4 ctrl animals developed VF shortly after the treadmill stopped, whereas 4 animals developed malignant arrhythmias while running) Reported.
Billman, 1999 | VF (%) | Exercise-plus-ischemia (2-min occlusion) test. | Ctrl: Soybean oil lipid emulsion (containing 7%~8% ALA) | Sex diff? ND
| | | VF (%). | Age diff? ND
| | | [EPA infusion vs. Ctrl] n= 7 vs. 7, P=0.0105 Decrease (sig.), 2/7 vs. 7/7 Reported | BW diff? ND
| | | [DHA infusion vs. Ctrl] n= 8 vs. 7, P=0.0035 Decrease (sig.), 2/8 vs. 7/7 Reported
| | | [ALA infusion vs. Ctrl] n= 8 vs. 7, P=0.0035 Decrease (sig.), 2/8 vs. 7/7 Reported
Charnock, 1992 | VFT | Arrhythmias were induced by electrical stimulation protocol in normoxic and ischemic hearts. | VFT | Sex diff? ND
| Sustaned | | [FO vs. SSO in normoxic)] n=ND, No change | Age diff? ND
| VF (%) | | [FO vs. SSO in ischemia)] n=ND, No change | BW diff? ND
| | | Sustained VF (%) | The procedures for induced-arrhythmias were not reported in the study, but presumably same as McLennan, 1992 & McLennan, Bridle, 1993.
| | | [FO vs. SSO in normoxic)] n=ND, Decrease 8%/13% Reported
| | | [FO vs. SSO in ischemia)] n=ND, Decrease 0%/13% Reported
Charnock, 1991 | VT (%) | 15-min ischemia model | [SF/FO vs. SSO] | Sex diff? No
| VF (%) | | VT (%) in ischemia: n=10 vs. 10, p>0.05 No Change 70%/100% Reported | Age diff? No
| VPB/15 min | | VF (%) in ischemia: n=10 vs. 10, p<0.05 Decreased (sig.) 0%/60% Reported | BW diff? No
| AS | | VPB/15 min in ischemia: n=10 vs. 10, p<0.05 Decreased (sig.) -72% Estimated
| | | AS in ischemia: n=10 vs. 10, p<0.05 Decreased (sig.) -59% Estimated
Chen, 1994 | VPB Deaths | In the short-term ischemia study, the ligation was maintained for 10 min in each rabbit and was followed by a reperfusion for 1 hr. | VT/VF Deaths (%) during ischemia | Sex diff? No
| | In the long-term ischemia study, the ligation was maintained for 1 hr in each rabbit and was followed by a reperfusion for 4 hr. | [HCF vs. HC (short term study)] n= 12 vs. 14, p>0.05 Decrease 8%/21% Reported | Age diff? ND
| | | [HCF vs. HC (long term study)] n= 14 vs. 15, p>0.05 No change 21%/27% Reported | BW diff? ND
| | | VPB (%) during ischemia
| | | [HCF vs. HC (short term study)] n= 11 vs. 11, p>0.05 Decrease 18%/36% Reported
| | | [HCF vs. HC (long term study)] n= 11 vs. 11, p>0.05 No change 36%/55% Reported
| | | VT/VF Deaths (%) during reperfusion
| | | [HCF vs. HC (short term study)] n= 11 vs. 11, p>0.05 No change 0%/0% Reported
| | | [HCF vs. HC (long term study)] n= 11 vs. 11, p>0.05 No change 0%/0% Reported
| | | VPB (%) during reperfusion
| | | [HCF vs. HC (short term study)] n= 11 vs. 11, p>0.05 No change 18%/18% Reported
| | | [HCF vs. HC (long term study)] n= 11 vs. 11, p>0.05 No change 27%/36% Reported
Culp, 1980 | Sudden death | Coronary artery thrombosis induced by electrical stimulations. | Ctrl: standard dog chow | Sex diff? ND
| Infarct size (%) | | [FO vs. Ctrl] n= 10 vs. 17 | Age diff? ND
| VPB | | Sudden death (%): No change 30%/29% Reported | BW diff? No
| | | Infarct size (%): P=0.08 Decrease -52% Estimated
| | | Frequency of ectopic beats rose from < 10% at the beginning of the experiment to about 80% after 19 to 247 hrs of stimulation among controls. In contrast, the fish-oil-fed dogs maintained a more normal ECG pattern, showing less than 30% ectopic beats after 19 hours.
Hartog JM 1987 | VPB | Myocardial ischemia and reperfusion models: | Ctrl: Lard fat (9% w/w) | Sex diff? ND
| VT (%) | 5-min ischemia; | [ML vs. Ctrl] | Age diff? No
| VF (%) | 10-min reperfusion. | VPB during occlusion: n= 7 vs. 6, p>0.05 No change, +53% Estimated | BW diff? ND
| Death | | VPB during reperfusion: n= 7 vs. 6, p<0.05 Decrease (sig.) -65% Estimated
| | | VT (%) n= 7 vs. 6, No change 29%/17% Reported (all events were occurred during ischemia)
| | | VF (%) n= 7 vs. 6, Increased 3/7 vs. 0/6 Reported
| | | Of the three animals in ML group had VF, defibrillation was unsuccessful in one animal, which died of ventricular systole during the fifth reperfusion.
Hock, 1990 | VF (%) | Myocardial ischemia and reperfusion models: | [MO vs. CO] | Sex diff? ND
| AS | 15-min ischemia; | VF (%) in 6-hr model: n= 7 vs. 10, p<0.02 Decrease (sig.) 14%/91% Reported | Age diff? ND
| Deaths | 6-hr and 24-hr reperfusion. | AS in 6-hr model: n= 7 vs. 10 p<0.01 Decrease (sig.) -77% Estimated | BW diff? No
| | | Total Deaths (%) in 24-hr model: n= 21 vs. 22, p<0.05 Decrease (sig.) 24%/69% Reported
Hock, 1987 | VPB | Ischemia model. | [MO vs. CO] | Sex diff? No
| Deaths | “Acute” left main coronary artery ligation was performed. | Arrhythmia death (%): n= 13 vs. 14, No change 2/13 vs. 2/14 Reported | Age diff? ND
| | Arrhythima outcomes were observed 15 min after the acute ligation. | VPB: n= 11 vs. 12, p>0.05 No change | BW diff? No
Isensee H 1994 | Time in normal sinus rhythm | Myocardial ischemia and reperfusion models: | VT (%) during ischemia | Sex diff? No
| VF (%) | 20-min ischemia; | [FO vs. CO] n= 9~10/grp, Decrease (sig.) 0% vs. 44% Reported | Age diff? No
| VT (%) | 20-min reperfusion | [LO vs. CO] n= 9~10/grp, No change 60%/40% Reported | BW diff? ND
| SIZ (%) | | [FO vs. LO] n= 9~10/grp, p<0.05 Decrease (sig.) 0%/60% Reported
| | | VF (%) during ischemia (results in figure)
| | | [FO vs. CO] n= 9~10/grp, p<0.05 Decrease (sig.) 10% vs. (about 45%) Reported
| | | [FO vs. CO w/ Aspirin during ischemia] n= 9~10/grp, p>0.05 No change
| | | [LO vs. CO] n= 9~10/grp, p>0.05 No change
| | | [LO vs. CO w/ Aspirin during ischemia] n= 9~10/grp, p>0.05 No change
| | | [FO vs. LO] n= 9~10/grp, p<0.05 Decrease (sig.) 10% vs. (about 40%) Reported
| | | [FO vs. LO w/ Aspirin during ischemia] n= ND, p>0.05 No change
| | | VF (%) during reperfusion
| | | [FO vs. CO] n= 9~10/grp, p>0.05 No change 40%/67% Reported
| | | [LO vs. CO] n= 9~10/grp, No change 60%/67% Reported
| | | [FO vs. LO] n= 9~10/grp, No change 40%/60% Reported
| | | SIZ (%) at end of ischemia (results in figure)
| | | [FO vs. CO] n= 9~10/grp, No change
| | | [FO vs. CO w/ Aspirin during ischemia] n= 9~10/grp, p>0.05 No change
| | | [LO vs. CO] n= 9~10/grp, p>0.05 No change
| | | [LO vs. CO w/ Aspirin during ischemia] n= 9~10/grp, p>0.05 No change
| | | [FO vs. LO] n= 9~10/grp, p>0.05 No change
| | | [FO vs. LO w/ Aspirin during ischemia] n= 9~10/grp, p>0.05 No change
| | | Length of time in normal sinus rhythm after occlusion (results in figure)
| | | [FO vs. CO] n= 9~10/grp, p<0.05 Increase (sig.)
| | | [FO vs. CO w/ Aspirin during ischemia] n= 9~10/grp, p>0.05 No change
| | | [LO vs. CO] n= 9~10/grp, p>0.05 No change
| | | [LO vs. CO w/ Aspirin during ischemia] n= 9~10/grp, p>0.05 No change
| | | [FO vs. LO] n= 9~10/grp, p<0.05 Increase (sig.)
| | | [FO vs. LO w/ Aspirin during ischemia] n= 9~10/grp, p>0.05 No change
| | | The length of time in normal sinus rhythm after occlusion was sig. longer, VF incidence was sig. higher, and the size of the ischemic zone was sig. larger when no Aspirin added during ischemia among the FO group.
| | | The length of time in normal sinus rhythm after occlusion was sig. longer, VF incidence was sig. higher, and the size of the ischemic zone was sig. larger when no Aspirin added during ischemia among the LO group.
Kinoshita, 1994 | VF (%) | Ischemia model: 3-hr coronary ligation | Ctrl: Standard diet | Sex diff? ND
| VT (%) | Digitalis-induced arrhythmia model: Digoxin (0.025 mg/kg/min) was administrated intravenously over a 60 sec period to 5 dogs in each group immediately after ischemia | [EPA vs. Ctrl] | Age diff? ND
| AS | | Ventricular extra beats (VEBs) in ischemia: n=10 vs. 10, p<0.05 Decrease (sig.) -44% Estimated | BW diff? ND
| VPB | | VF (%) in ischemia: n=10 vs. 10, p>0.05 No change 2/10 vs. 2/10 Reported
| | | AS in ischemia: n= 10 vs. 10, p<0.05 Decrease (sig.) -55% Estimated
| | | Time in developing digitalis-induced VT or VF: n= 5 vs. 5, Increased >25 min vs. 10–15 min Reported
Lo, 1991 | VT (%) | Normal conditions. | No events of VT or VPB were observed when infusing control buffer, ALA=1, 5, or 10 mg/kg (n=8, same dogs for all groups) | Sex diff? No
| VPB | | [ALA vs. Ctrl buffer n=8, same dogs for all groups] | Age diff? ND
| | | VT (%) | BW diff? ND
| | | ALA=20, or 30 mg/kg, p>0.05 Increased 13%, or 38% respectively Reported | Injections of ALA invariably result in acute pulmonary edema within 5 minutes (unpublished observation). Thus, whether or not the observed CVD effect was due to the direct effect of ALA was questionable.
| | | ALA=60 mg//kg, p=0.013 Increase (sig.) 63% Reported | Possibly cumulative effect should be considered because various testing doses were repeatedly given in each dog.
| | | VPB (%)
| | | ALA=20 mg/kg, p>0.05 Increased 25% Reported
| | | ALA=30 mg/kg, p=0.003 Increase (sig.) 75%
| | | ALA=60 mg/kg, p=0.0007 Increase (sig.) 88% Reported
| | | All ventricular arrhythmia occurred within 3 seconds after injection and recovered spontaneously within 5 minutes.
| | | A significant depression of myocardial contractility (the change in maximal left ventricular dp/dt during systole) was noted at a dose of 5 mg/kg. When the dose of ALA was increased, a more prominent myocardial depression was observed. In contract, and injection of the control buffer solution did not alter left ventricular dp/dt.
McLennan, 1996 | VF (%) | Ischemia model | Ctrl: Olive oil | Sex diff? No
| AS | | AS (results in figure) | Age diff? ND
| | | [EPADHA vs. Ctrl] n= “n=10”, p<0.02 Decrease (sig.) | BW diff? ND
| | | [EPA vs. Ctrl] n=ND, p>0.05 No change | No statistics were performed for these comparisons in the original study.
| | | [DHA vs. Ctrl] n= “n=10”, p<0.02 Decrease (sig.)
| | | VF (%)
| | | [EPADHA vs. Ctrl] n=ND p<0.01 Inhibitory effects 10%/80% Reported
| | | [EPA vs. Ctrl] n=ND, p>0.05 No change 70%/80% Reported
| | | [DHA vs. Ctrl] n=ND", p<0.03 Inhibitory effects 20%/80% Reported
McLennan, 1995 | VPB | Myocardial ischemia and reperfusion models: | 15-min ischemia; 10-min reperfusion model: | Sex diff? No
| VT (%) | 15-min ischemia; 10-min reperfusion. | VPB | Age diff? No
| VF (%) | 5-min ischemia; 10-min reperfusion. | [CAN vs. SSO in ischemia] n= 16 vs. 14, No change -13% Estimated | BW diff? ND
| AS | | [SBO vs. SSO in ischemia] n= 13 vs. 14, No change -14% Estimated
| Deaths | | [CAN vs. SSO in reperfusion] n= 13 vs. 13, No change -43% Estimated
| | | [SBO vs. SSO in reperfusion] n= 11 vs. 13, No change -2% Estimated
| | | VT (%)
| | | [CAN vs. SSO in ischemia] n= 16 vs. 14, No change 75%/93% Reported
| | | [SBO vs. SSO in ischemia] n= 13 vs. 14, No change 62%/93% Reported
| | | [CAN vs. SSO in reperfusion] n= 13 vs. 13, No change 31%/69% Reported
| | | [SBO vs. SSO in reperfusion] n= 11 vs. 13, No change 3%/69% Reported
| | | VF (%)
| | | [CAN vs. SSO in ischemia] n= 16 vs. 14, No change 43%/43% Reported
| | | [SBO vs. SSO in ischemia] n= 13 vs. 14, No change 38%/43% Reported
| | | [CAN vs. SSO in reperfusion] n= 13 vs. 13, Decrease (sig.) 0%/23% Reported
| | | [SBO vs. SSO in reperfusion] n= 11 vs. 13, No change 27%/23% Reported
| | | VF Deaths
| | | [CAN vs. SSO in ischemia] n= 16 vs. 14, Increased 19%/7% Reported
| | | [SBO vs. SSO in ischemia] n= 13 vs. 14, Increased 15%/7% Reported
| | | [CAN vs. SSO in reperfusion] n= 13 vs. 13, Decrease (sig.) 0%/8% Reported
| | | [SBO vs. SSO in reperfusion] n= 11 vs. 13, Decrease (sig.) 0%/8% Reported
| | | AS
| | | [CAN vs. SSO in ischemia] n= 16 vs. 14, No change -11% Estimated
| | | [SBO vs. SSO in ischemia] n= 13 vs. 14, No change -18% Estimated
| | | [CAN vs. SSO in reperfusion] n= 13 vs. 13, No change -64% Estimated
| | | [SBO vs. SSO in reperfusion] n= 11 vs. 13, No change -12% Estimated
| | | 5-min ischemia; 10-min reperfusion model:
| | | VPB
| | | [CAN vs. SSO in reperfusion] n= 10 vs. 10, p>0.05 No change
| | | [SBO vs. SSO in reperfusion] n= 10 vs. 10, p>0.05 No change
| | | VT (%)
| | | [CAN vs. SSO in reperfusion] n= 10 vs. 10, No change 70%/70% Reported
| | | [SBO vs. SSO in reperfusion] n= 10 vs. 10, No change 90%/70% Reported
| | | VF (%)
| | | [CAN vs. SSO in reperfusion] n= 10 vs. 10, No change 10%/50% Reported
| | | [SBO vs. SSO in reperfusion] n= 10 vs. 10, No change 50%/50% Reported
| | | VF Deaths
| | | [CAN vs. SSO in reperfusion] n= 10 vs. 10, 0%/20% Reported
| | | [SBO vs. SSO in reperfusion] n= 10 vs. 10, No change 30%/20% Reported
| | | AS
| | | [CAN vs. SSO in reperfusion] n= 10 vs. 10, p<0.05 Decreased (sig.) –41% Reported
| | | [SBO vs. SSO in reperfusion] n= 10 vs. 10, p>0.05 No changes
McLennan, Bridle, 1993 | VFT | Ischemia was induced by 15-min coronary artery occlusion. | Ctrl: SF/SSO (8% sheep perirenal fat+2% sunflower-seed oil) | Sex diff? No
| VF (%) | Isoproterenol (ISO) was injected in 0.5 ug/kg BW/min. | [SF/FO vs. Ctrl] | Age diff? ND
| | Arrhythmias were induced by electrical stimulation protocol in control, 5 min after ischemia, and 30 min after restoration of coronary blood flow during the infusion of isoproterenol. | VF (%) in control condition: n=10 vs. 9, No Change 60%/60% Reported | BW diff? No
| | | VF (%) in ischemia: n=10 vs. 9, No Change 100%/100% Reported
| | | VF (%) in ISO (0.5 ug/kg body wt/min): n= 10 vs. 9, p<0.05 Decrease (sig.) 3/10 vs. 7/9 Reported. The other 2 out of the 10 animal in FO group developed VT.
| | | VF (%) in ISO (2.0 ug/kg body wt/min): n=: 10 vs. 9, p=0.033 Decrease (sig.) 5/10 vs. 9/9 Reported
| | | Among susceptible animals:
| | | VFT in control condition: n= 6 vs. 6, p<0.05 Increase (sig.) +133% Estimated
| | | VFT in ischemia: n= 10 vs. 10, p<0.05 Increase (sig.) +79% Estimated
| | | VFT in ISO (0.5 ug/kg body wt/min): n= 5 (VF+VT) vs. 7, p<0.05 Increased +55% Estimated
| | | VFT in ISO (2.0 ug/kg body wt/min): n= 5 vs. 9, p>0.05 Increased +75% Estimated
McLennan, 1993 | Time in normal sinus rhythm | Myocardial ischemia and reperfusion models: | 15-min ischemia; 5-min reperfusion model: | Age diff? No
| VPB | 15-min ischemia; 5-min reperfusion. | VPB | BW diff? No
| VT (%) | 5-min ischemia; 5-min reperfusion. | [FO vs. SSO in ischemia] n= 14 vs. 13, No change -10% Estimated | No statistics were performed for FO vs. SSO comparisons in the original study.
| VF (%) | | [FO vs. SSO in reperfusion] n= 14 vs. 12, No change -31% Estimated
| AS | | VT (%)
| Deaths | | [FO vs. SSO in ischemia] n= 14 vs. 13, Decrease 35%/92% Reported
| | | [FO vs. SSO in reperfusion] n= 14 vs. 12, p<0.05 Decrease (sig.) 21%/67% Reported
| | | VF (%)
| | | [FO vs. SSO in ischemia] n= 14 vs. 13, Decrease (sig.) 0%/38% Reported
| | | [FO vs. SSO in reperfusion] n= 14 vs. 12, p>0.05 No Change, 0%/8% Reported
| | | Time in sinus rhythm
| | | [FO vs. SSO in ischemia] n= 14 vs. 13, No change +12%
| | | [FO vs. SSO in reperfusion] n= 14 vs. 12, p>0.05 No Change
| | | Deaths
| | | [FO vs. SSO in ischemia] n= 14 vs. 13, Decrease (sig.) 0%/8% Reported
| | | [FO vs. SSO in reperfusion] n= 14 vs. 12, No change 0%/0% Reported
| | | AS
| | | [FO vs. SSO in ischemia] n= 14 vs. 13, , p<0.05 Decrease (sig.) -41% Estimated
| | | [FO vs. SSO in reperfusion] n= 14 vs. 12, p<0.05 Decrease (sig.) 63% Estimated
| | | 5-min ischemia; 5-min reperfusion model
| | | VPB
| | | [FO vs. SSO in reperfusion n= 10 vs. 12, No change -27% Estimated
| | | VT (%)
| | | [FO vs. SSO in reperfusion] n= 10 vs. 12, No change 60%/80% Reported
| | | VF (%)
| | | [FO vs. SSO in reperfusion] n= 10 vs. 12, Decrease 10%/25% Reported
| | | Time in sinus rhythm
| | | [FO vs. SSO in reperfusion] n= 10 vs. 12, No change +16% Estimated
| | | Deaths
| | | [FO vs. SSO in reperfusion] n= 10 vs. 12, Decrease (sig.) 0%/8% Reported
| | | AS
| | | [FO vs. SSO in reperfusion] n= 10 vs. 12, Decrease -48% Estimated
McLennan, 1992 | VFT | Ischemia was induced by 15-min coronary artery occlusion.. | VF (%) | Sex diff? ND
| VF (%) | Isoproterenol (ISO) was injected in 0.5 ug/kg BW/min. | [TFO vs. SSO in control condition] n= 16 vs. 13, No change 10/16 vs. 8/13 Estimated from graph | Age diff? No
| Deaths | Arrhythmias were induced by electrical stimulation protocol in control, 5 min after ischemia, and 30 min after restoration of coronary blood flow during the infusion of isoproterenol | [TFO vs. SSO in ischemia] n= 16 vs. 13 No change 12/16 vs. 8/13 Estimated from graph | BW diff? No
| | | [TFO vs. SSO in ISO] n= 16 vs. 13 No change 7/16 vs. 10/13 Estimated from graph | Isoproterenal induced a sig. increase in the proportion of inducible animals having sustained episodes of VF in all dietary groups; as well as a sig. proportion of animals suffering fatal VF and cardiac arrest compared to the control condition.
| | | In TFO fed animals, 80% of VF episodes were of less than 5 seconds' duration compared with only 25% of SSO (p=0.054 n.s.) animals
| | | VFT in susceptible marmosets (results in figure)
| | | [TFO vs. SSO in control condition] n= 10 vs. 8, p>0.05 No change
| | | [TFO vs. SSO in ischemia] n= 12 vs. 8, p>0.05 No change
| | | [TFO vs. SSO in ISO] n= 7 vs. 10, >0.05 No change
| | | Total VF Deaths, combining the Deaths in control condition, ischemia, and isoproterenol models.
| | | [TFO vs. SSO] n= 16 vs. 13, Decrease (sig.) 0/16 vs. 3/13 Reported
McLennan, 1990 | Time in normal sinus rhythm | Myocardial ischemia and reperfusion models: | VPB | Sex diff? No
| VPB | 15-min ischemia; 10-min reperfusion. | [SF/TFO vs. SF/SSO in ischemia] n= 7 vs. 7, p>0.05 No change | Age diff? No
| VT (%) | | [SF/TFO vs. SF/SSO in perfusion] n= 7 vs. 7, p<0.05 Decrease (sig.) -24% Estimated | BW diff? Yes
| VF (%) | | VT (%) | SSO group had significant lower body weight after 18 months
| AS | | [SF/TFO vs. SF/SSO in ischemia] n= 7 vs. 7, p>0.05 No change 57%/57% Reported
| Deaths | | [SF/TFO vs. SF/SSO in perfusion] n= 7 vs. 7, p>0.05 No change 71%/86% Reported
| | | VF (%)
| | | [SF/TFO vs. SF/SSO in ischemia] n= 7 vs. 7, p>0.05 No change 14%/29% Reported
| | | [SF/TFO vs. SF/SSO in perfusion] n= 7 vs. 7, p>0.05 No change 29%/29% Reported
| | | Time in sinus rhythm
| | | [SF/TFO vs. SF/SSO in ischemia] n= 7 vs. 7, p>0.05 No change
| | | [SF/TFO vs. SF/SSO in perfusion] n= 7 vs. 7, p>0.05 No change
| | | VT/VF Deaths
| | | [SF/TFO vs. SF/SSO in ischemia] n= 7 vs. 7, No change 0%/0% Reported
| | | [SF/TFO vs. SF/SSO in perfusion] n= 7 vs. 7, No change 0%/0% Reported
| | | AS (results in figure
| | | [SF/TFO vs. SF/SSO in ischemia] n= 7 vs. 7, p>0.05 No change
| | | [SF/TFO vs. SF/SSO in perfusion] n= 7 vs. 7, p>0.05 No change
McLennan PL 1988 | VT (%) | Myocardial ischemia and reperfusion models:. | VT (%) | Sex diff? No
| VF (%) | 15-min ischemia, followed by reperfusion | [TFO vs. SSO in ischemia] n= 10 vs. 10, p<0.01 Decrease (sig.) 37% vs. 77%* Reported | Age diff? No
| AS | | [TFO vs. SSO in reperfusion] n= 10 vs. 10, p<0.05 Decrease (sig.) 50%* vs. 80%* Estimated | BW diff? Yes
| Ischemic region (%) | | VF (%) | SSO=512 gm; TFO=566 gm
| | | [TFO vs. SSO in ischemia] n= 10 vs. 10, p<0.01 Decrease (sig.) 0% vs. 10%* Reported
| | | [TFO vs. SSO in reperfusion] n= 10 vs. 10, p<0.05 Decrease (sig.) 0% vs. 30% Estimated
| | | AS (results in figure)
| | | [TFO vs. SSO in ischemia] n= 10 vs. 10, p>0.05 No change
| | | [TFO vs. SSO in reperfusion] n= 10 vs. 10, p<0.05 Decrease (sig) -44% Estimated
| | | IS
| | | [TFO vs. SSO] n= 10 vs. 10, No change +7% Estimated
| | | No animal died in TFO and SSO groups.
Oskarsson, 1993 | SIZ (%) | Myocardial ischemia and reperfusion models:. | Ctrl: No fish oil Rx | Sex diff? ND
| | 90-min ischemia; | [MaxEPA vs. Ctrl] | Age diff? ND
| | 30-min reperfusion | Myocardial infarct size (%): n= 10 vs. 12, p<0.05 Decrease (sig.) 13%/29% Reported | BW diff? No
| | | Amount of myocardium at risk for severe ischemia (%): n= 10 vs. 12, p>0.05 No change 41.2%/39.3% Reported
Otsuji, 1993 | Deaths | Coronary artery occlusion (ischemia model) | Ctrl: Standard dog chow | Sex diff? ND
| Infracted area | | [EPA-ester vs. Ctrl] | Age diff? ND
| Size of the area at risk (%) | | VF Deaths: n= 10 vs. 15, p<0.05 Decrease (sig.) 0%/33% Reported | BW diff? ND
| | | Ultimate size of the infarcted area: n= 10 vs. 10, p<0.01 Decrease (sig.) 17.6%/29.2% Reported
| | | Size of the area at risk (%): n= 10 vs. 10, p>0.05 No change
Pepe, 1996 | VPB | Myocardial ischemia and reperfusion models: | [FO vs. SAT] | Sex diff? No
| VT (%) | 15-min ischemia; | Ischemia-reperfusion model: | Age diff? No
| VF (%) | 10-min reperfusion. | VPB during ischemia: n= 20 vs. 20, p<0.05 Decrease (sig.) -73% Estimated | BW diff? ND
| VFT | | VT (%) after ischemia-reperfution: n= 20 vs. 20, p<0.05 Decrease (sig.) 10%/70% Reported
| | Electrical Stimulation (independent of myocardial ischemia model) | VF (%) after ischemia-reperfution: n= 20 vs. 20, p<0.05 Decrease (sig.) 0%/80% Reported
| | | Electrical Stinulation:
| | | The threshold current for VF induction was reduced in all dietary groups n ischemia but remained significantly higher in the mackerel-oil-fed group than in the saturated-fat-fed group (n=10 per group).
Yang, 1993 | VF (%) or VF (%) | Myocardial ischemia and reperfusion models: | [FO vs. Butter] | Sex diff? No
| | 15-min ischemia; 10-min reperfusion. | VT (%) or VF (%): n= 8 vs. 9, p<0.05 Decrease (sig.) 3/8 vs. 7/9 Reported | Age diff? ND
| | | | BW diff? ND

Evidence Table 2. Whole-Animal Isolated Organ and Cell Studies Part 1

Table 2 Evidence Table. Whole-Animal Isolated Organ and Cell Studies Part 1

Author, yr | Country Funding | Species Stage Sex | Exp-osure Duration (weeks) | Group [Sample Size] | Total Fat (omega-3 fatty acids) | Unit | SFA | MUFA | PUFA | ALA | EPA | DHA | Other omega-3 fatty acids
Benediktsdottir, 1988 | Iceland U | Rats | 16 | Corn oil (CO) [ND] | 10 %w | % total fatty acids | 14.5 | 24.5 | 57.8 | ND | 0.0 | 0.0 | 0.0^3^
| | Adult
| | Male | | Cod-liver oil (CLO) [ND] | 10 %w | | 22.0 | 47.0 | 27.2 | ND | 6.9 | 7.2 | 0.9^3^
Black, 1989 | Canada G | Rats | 4 | STD [6] | | ND | ND | ND | ND | ND | ND | ND
| | Adult
| | Male | | STD+FO [6] | 0.5ml/kg/day | ND | ND | ND | ND | ND | ND | ND
Chemla, 1995 | France G | Rats | 4 | N-3 [15] | 15%w | %TFA | 20.0 | 57.7 | 11.4 | 0.8 | 4.3 | 4.1
| | Adult
| | Male | | N-6 [15] | 15%w | | 19.8 | 58.9 | 20.7 | 0.5 | 0.0 | 0.0
Chen, 1994 | Taiwan G | Rabbits | 2 | High cholesterol (HC) [11–15] | 40 %kcal | % w/w | ND | ND | ND | ND | ND | ND
| | Adult | | | 40 %kcal (10 %kcal from fish oil)
| | Male | | HC+FO [11–12] | | | ND | ND | ND | ND | 30.2 | 21.5
Croset, 1989a | USA G^1^ | Mouse | 2 | STD [10] | 0 %w | Mol% | 11.8 | 31.7 | 56.1 | 0.0 | ND | 0.0
| | Weanling | | STD+0.4 %w/w DHAe[10] | 10 %w/w | | 11.7 | 28.8 | 59.1 | 0.0 | ND | 0.1
| | Male | | STD+0.8 %w/w DHAe[10] | 10%w/w | | 11.5 | 25.7 | 61.6 | 0.0 | ND | 0.2
| | | | STD+ 4%w/w DHAe [10] | 10 %w /w | | 5.3 | 9.3 | 85.3 | 0.0 | ND | 0.8
Croset, 1989b | USA | Mouse | 2 | OO+ALA e [6] | 1.5+0.5%w | Mol% | 27.6 | 44.5 | 27.9 | 20.5 | 0.2 | 0.1
| | Weanling | | OO+EPA e [6] | 1.5+0.5%w | | 30.3 | 49.8 | 19.9 | 1.0 | 8.1 | 1.9
| | Male | | OO+DHA e [6] | 1.5+0.5%w | | 27.5 | 47.3 | 25.1 | 0.5 | 0.9 | 16.5
Demaison, 1993 | France G | Rats | 8 | SF [32] | 100g/Kg | % TFA | 11.8 | 16.2 | 71.7 | 0.2 | ND | ND
| | Weanling | | LIN [29] | 100g/kg | | 8.7 | 20.3 | 71.0 | 53.5 | ND | ND
| | Male
Gillis, 1992 | Canada G | Rabbits | 6 | SAF (9) | 10%w | %w | 9.6 | 13.1 | 77.3 | 0.0 | 0.0 | 0.0 | 0.0^3^
| | Weanling | | FO (9) | 10%w | | 23.5 | 29.2 | 47.3 | 1.4 | 26.5 | 8.6 | 2.3^3^
| | ND
Gudmundsdottir, 1991 | Iceland U | Rats | 20 | CO [5] | 10%w | %w | 13.6 | 24.6 | 58.6 | 2.6 | 0.0 | 0.0
| | Adult | | CLO (4) | 10%w | | 18.1 | 51.0 | 27.7 | 0.0 | 7.1 | 8.1
| | Male
| | Rats | 88 | CO [5] | 10%w | %w | 13.6 | 24.6 | 58.6 | 2.6 | 0.0 | 0.0
| | Aged | | CLO (4) | 10%w | | 18.1 | 51.0 | 27.7 | 0.0 | 7.1 | 8.1
| | Male
Heard, 1992 | USA U | Rats | 4 | SAF [18] | 20%w | ND | ND | ND | ND | ND | ND | ND
| | Adult | | MenO+SAF [18] | 19.5%+0.5%w | | ND | ND | ND | ND | ND | ND
| | Male
Honen, 2002 | Australia G | Rats | 3 | Canola oil (6) | 3ml/d | % TFA | 6.2 | 60.0 | 33.8 | 12.1 | 0 | 0
| | Adult | | FO(6) G | 3ml/d | | 1.7 | 15.8 | 77.7 | 0.5 | 48.0 | 26.2
| | Male
Karmazyn, 1987 | Canada G | Rats | 12 | STD [14] | 10%w | ND | ND | ND | ND | ND | ND | ND
| | Weanling | | STD+Cod liver oil (CLO) [14] | | | ND | ND | ND | ND | ND | ND
| | Male/ Female
Kinoshita, 1994 | Japan U | Dogs | 8 | STD (15) | 100mg/kg | mg/k | ND | ND | ND | ND | ND | ND
| | Adult | | STD+EPAe (15) | | g/d | ND | ND | ND | ND | 100 | ND
| | ND
Ku, 1997 | Japan G | Rats | 12 | HC (5) | 5.1%w | ND | ND | ND | ND | ND | ND | ND
| | Aged | | HC+EPA (5) | 5.1%w (300mg/kg) | | ND | ND | ND | ND | ND | ND
| | Female | | HC+DHA (5) | 5.1%w (300mg/kg) | | ND | ND | ND | ND | ND | ND
Lamers, 1988 | Neth.; Italy G | Pigs | 8 | LARD [8] | 9%w | %TFA | 36 | 46 | 15 | 1 | 0 | 0
| | Weanling
| | Male/ Female | | FO +LARD [8] | 4.5% +4.5%w | | 32 | 40 | 11 | 1 | 8 | 5
Laustiola, 1986 | Finland U | Rats | 16 | STD [20] | | % TFA | 26.2 | 23.6 | 49.7 | 5.3 | 1.3 | 2.7 | 0.2^3^
| | Weanling | | | 10%na | | | | | | | | 2.7^4^
| | Male | | STD+CLO [33] | | | 22.8 | 46.5 | 28.6 | 1.7 | 6.4 | 8.2 | 0.7^3^
| | | | | | | | | | | | | 8.2^4^
Leifert, 2000a | Australia G | Rats | 3 | LARD [6–8] | 29% E (74kJ fat/d) | % w | 58.0 | 39.4 | 2.6 | 0.7 | 0.1 | 0.0 | 0.0^3^
| | Young | | FO [6–8] G5 | 29% E (74kJ fat/d) | | 27.3 | 28.2 | 44.6 | 1.1 | 24.3 | 12.1 | 2.3^3^
| | Adult
| | Male
Leifert, 2001 | Australia I+NP | Rats | 3 | SF (6) | 17%w (10%w) | %w | 36.4 | 55.1 | 8.5 | 1.2 | 0 | 0 | 0.0^3^
| | Adult | | FO (6) | 17%w (10%w) | | 18.6 | 44.0 | 37.4 | 0.9 | 17.8 | 8.9 | 1.7^3^
| | Male
Maixent, 1999 | France G+NPl | Rats | 8 | STD [11] | 0.5g of oil/kg | mg/g of oil | ND | ND | ND | ND | ND | ND
| | Adult | | STD+FO [10] | | | ND | ND | ND | ND | 180 | 120
| | Male
Minaro-vic, 1997 | Slovak G | Rats | 2 | HF [10] | 300g/kg | % w | 47.0 | 39.7 | 13.3 | ND | ND | ND
| | Young | | FO [10] | 100g/kg | | 13.0 | 29.4 | 57.6 | ND | ND | ND
| | Adult
| | Male
Pepe, 1999 | USA U | Rats | 6 | N-6 (6) | 15.6% w (11.7%w) | ND | ND | ND | ND | ND | ND | ND | ND
| | Young | | FO (5) | 15.6%w (11.7%w) | | ND | ND | ND | ND | ND | ND | ND
| | Adult
| | Male
Reig, 1993 | Spain U | Rats | 5 | HF (20) | 37%w | %TFA | 36.7 | 40.0 | 19.4 | 2.2 | 0.0 | 0.0 | 0.0^3^
| | Young | | HF+FO (20) | 31%+6%w | | 30.0 | 33.0 | 37.1 | 3.4 | 4.6 | 3.4 | 1.0^3^
| | Adult
| | Male
Swan-son, 1989 | USA G | Mouse | 2 | SAF+CO (9) | 12%w (2%+10%w) | %w | 14.5 | 24.2 | 60.9 | 1.0 | 0.0 | 0.0 | 0.0^3^
| | Weanling | | SAF+MenO (9) | 12%w (2%+10%w) | | 28.5 | 26.1 | 44.7 | 1.8 | 12.9 | 9.1 | 2.0^3^
| | Male
Taffet, 1993 | USA G | Rats | 3 | CO [11] | 20%w | Mol % | 14.3 | 26.3 | 59.3 | 0.0 | 0.0 | ND
| | Young | | CO+MenO [12] | 3%+17%w | | 39.9 | 28.3 | 31.9 | 1.3 | 16.5 | ND
| | Adult
| | Female

Evidence Table 2. Whole-Animal Isolated Organ and Cell Studies Part 2

Table 2 Evidence Table. Whole-Animal Isolated Organ and Cell Studies Part 2

Author, yr | Outcome Category | Cell or Tissue | Expt Condition | Agent | Change in Membrane Composition | Results (n=cells)
Benediktsdottir, 1988 | IPIM | Sarcolemma | Ambient | None | Yes | CLO vs. CO
| | | | | | - NC in Na^+^K^+^ ATPase (n=ND; p>0.05)
Black, 1989 | IPIM | Sarcoplasmic reticulum | Ambient | None | ND | STD+FO vs. STD
| | | | | | - NC in sarcoplasmic reticulum calcium transport activity (n=6;p>0.05)
Chemla, 1995 | CP | Myocardium | Ambient | None | ND | N-3 vs. N-6
| | | | | | - NC in force-velocity relationship characteristics (n=15; p>0.05)
Chen, 1994 | IPIM | Myocardial mitochondria | Sham ischemic | None | ND | HC+FO vs. HC
| | | | | | - NC in mitochondrial calcium concentrations (n=5/group; p>0.05)
| | | Short-term Ischemia (Occl-10min Rep-1hr) | None | ND | HC+FO vs. HC
| | | Long-term Ischemia (Occl-1hr Rep-4hr) | | | - NC in mitochondrial calcium concentrations after short or long term ischemia (n=11/group; p>0.05)
Croset, 1989a | IPIM^1^ | SR vessicles^2^ | Ambient | None | Yes | All DHA diets vs. STD
| | | | | | - NC in maximum velocity of SR Ca2+, Mg2+-ATPase with incremental levels of DHA (n=10/group; p>0.05)
| | Myocardial mitochodria | Ambient | 0.15 uM oligomycin | Yes | STD+0.4%DHAe. vs. STD
| | | | | | - Increased maximum velocity of mitochondrial oligomycin-sensitive ATPase (%=ND)(n=10/grp, p<0.02)
| | | | | | STD+0.8%DHAe. vs. STD
| | | | | | - Increased maximum velocity of mitochondrial oligomycin-sensitive ATPase (%=ND)(n=10/grp, p<0.05)
| | | | | | STD+4%DHAe. vs. STD
| | | | | | - NC in maximum velocity of mitochondrial oligomycin-sensitive ATPase (n=10/grp, p>0.05)
Croset, 1989b | IPIM | SR vesicles | Ambient | None | Yes | OO+ALAe. vs. Safflower oil
| | | | | | - Decreased Ca^2+^ transport measured a maximum rate of Ca^2+^ accumulation in cardiac SR vesicles (%=ND) (n=3; p<0.05)
| | | | | | OO+EPAe. vs. Safflower oil
| | | | | | - Decreased Ca^2+^ transport measured a maximum rate of Ca^2+^ accumulation in cardiac SR vesicles (%=ND) (n=3; p<0.04)
| | | | | | OO+DHAe. vs. O Safflower oil
| | | | | | - Decreased Ca^2+^ transport measured a maximum rate of Ca^2+^ accumulation in cardiac SR vesicles (%=ND) (n=3; p<0.03)
| | | | | | OO+ALAe. vs. OO+EPAe
| | | | | | - Decreased Ca^2+^ transport measured a maximum rate of Ca^2+^ accumulation in cardiac SR vesicles (%=ND) (n=3; p=ND)
| | | | | | OO+ALAe. vs. OO+DHAe.
| | | | | | - Decreased Ca^2+^ transport measured a maximum rate of Ca^2+^ accumulation in cardiac SR vesicles (%=ND) (n=3; p=ND)
| | | | | | OO+EPAe. vs. OO+DHAe.
| | | | | | - Decreased Ca^2+^ transport measured a maximum rate of Ca^2+^ accumulation in cardiac SR vesicles (%=ND) (n=3; p=ND)
| | | | | | OO+EPAe. vs. OO+SA
| | | | | | - NC in maximum specific activity (V_max_) and affinity for Ca^2+^ and ATP of Ca^2+^Mg^2+^ ATPase associated with CA2+ uptake (n=3;p>0.05)
| | | | | | OO+DHAe. vs. OO+SA
| | | | | | - NC in maximum specific activity (V_max_) and affinity for Ca^2+^ and ATP of Ca^2+^Mg^2+^ ATPase associated with CA2+ uptake (n=3;p>0.05)
Demaison, 1993 | CP | Isolated Working heart | Ambient (Perfusion) | None | Yes | LIN vs. SF
| | | | | | - NC in contractility (n=29–32; p>0.05)
Gillis, 1992 | BEP | SR vesicles | Ambient | None | Yes | FO vs. SAF
| | | | | | - NC in mean baseline QRS (n=9; p>0.05)
| | | | | | - NC in mean baseline QT interval duration (n=9; p>0.05)
| | | Electrical | None | Yes | FO vs. SAF
| | | | | | - NC in mean baseline left ventricular effective refractory period (VERP) (n=9; p>0.05)
| | | | | | - NC in mean baseline epicardial MAP duration (n=9; p>0.05)
| | | | | | - NC in mean baseline endocardial MAP duration (n=9; p>0.05)
| | | | | | - NC in strength - interval relations (mean threshold current at each coupling interval) (n=9; p>0.05)
| | | Electrical | None | Yes | FO vs. SAF
| | | | | | - NC in mean diastolic threshold (n=9; p>0.05)
| | | | | | - NC in absolute refractory period (n=9; p>0.05)
| | | | | | - NC in relative refractory period (n=9; p>0.05)
Gudmundsdottir, 1991 | ICH | Sarcolemma | Ambient | NIT | Yes | CLO vs. CO at 20 weeks
| | | | | | - NC in the affinity (1/K_d_) and binding (B_max_) of slow Ca2+ channels for [3H NIT] (n=4–5;p>0.05)
| | | | | | CLO vs. CO at 88 weeks
| | | | | | - Decreased the affinity (1/K) and binding (B_max_)of slow Ca2+ channels for [3H NIT] (n=4–5;p<0.05)
Heard, 1992 | CP | Atrial tissue | Ambient | Saline | ND | FO+SAF vs. SAF
| | | | | | - NC in force of contraction indexed to body weight (FOC/BW) (n=6; p>0.05)
| | | | | | - NC in maximum rate of rise of contraction (dF/dt) (n=6; p>0.05)
| | | | | | - NC in maximum rate of relaxation (-dF/dt) (n=6; p>0.05)
| | | | | | - NC in atrial rate (beats/min) (n=6; p>0.05)
| CP | Atrial tissue | Ambient | LPS (20mg/kg) | ND | FO+SAF vs. SAF
| | | | | | - Increased force of contraction indexed to body weight (FOC/BW) (n=11; p<0.05)
| | | | | | - Increased maximum rate of rise of contraction (dF/dt) (n=11; p<0.05)
| | | | | | - Increased maximum rate of relaxation (-dF/dt) (n=11; p<0.05)
| | | | | | - Decreased atrial rate (beats/min) (n=ND; p<0.05)
| CP | Atrial tissue | Ambient | ISO (0.1, 0.5, 1.0 and 5.0uM) | ND | FO+SAF vs. SAF
| | | | | | - NC in atrial force of contraction indexed to body weight (FOC/BW) as a function of Iso concentration (n=ND; p>0.05)
Honen, 2002 | IPIM | Atrial myocytes | Ambient | None | Yes | FO vs. RO
| | | | | | - NC in mean area of Ca2+ sparks n=5; p>0.05)
| | | | | | - NC in mean duration of Ca2+ sparks (n=5; p>0.05)
| | | | | | - NC in mean frequency of Ca2+sparks (n=5; p>0.05)
| | | | | | - Increased the proportion of “ideal” sparks (rapid rise and exponential fall by 9.1% (n=5; p<0.05)
| | | | | | - NC in proportion of “very slow rise and fall sparks” (n=5; p>0.05)
| | | | | | - Decreased the proportion of “marked step/plateau in the decay phase” sparks by 63% (n=5; p<0.05)
Karmazyn, 1987 | IPIM | Ventricular myocytes | Ischemia-Reperfusion | None | Yes | STD+CLO vs STD
| | | | | | - Time dependent (10–80mins) increase in Ca^2+^ uptake by 135–159% (n=5–9; p<0.01)
| | | | | | - NC in Ca^2+^ efflux (n=5–9; p>0.05)
| BEP | Ventricular myocytes | Ischemia-Reperfusion | None | Yes | STD+CLO vs STD
| | | | | | - NC in developed or resting tension (n=5–9; p>0.05)
Kinoshita, 1994 | IPIM | Myocardial microsomal vesicles | Ambient (non-infarct) | None | Yes | STD+EPAe. vs. STD
| | | | | | - Increased Ca^2+^-Mg^2+^ATPase V_max_ by 48% (n=6; p<0.01)
| | | | | | - NC in Km (n=6; p>0.05)
| | Myocardial microsomal vesicles | Ischemia | None | Yes | STD+EPAe. vs. STD
| | | | | | - Increased Ca^2+^-Mg^2+^ ATPase V_max_ by 45% (n=6; p<0.01)
| | | | | | - NC in Km (n=6; p>0.05)
| | Myocardial microsomal vesicles | Ambient (non-infarct) | Oua | Yes | STD+EPAe. vs. STD
| | | | | | - NC in Na^2+^-K^2+^ ATPase V_max_ (n=6; p>0.01)
| | | | | | - NC in the amount of ouabain needed to induce 50% inhibition (IC_50_) of Na^2+^-K^2+^ ATPase activity.(n=6; p>0.05)
| | Myocardial microsomal vesicles | Ischemia | Oua | Yes | STD+EPAe. vs. STD
| | | | | | - NC in Na^2+^-K^2+^ ATPase V_max_ (n=6; p>0.01)
| | | | | | - NC in the amount of ouabain needed to induce 50% inhibition (IC_50_) of Na^2+^-K^2+^ ATPase activity.(n=6; p>0.05)
Ku, 1997 | CP | Isolated Heart | Ambient | None | Yes | HC+EPA vs. HC
| | | | | | - NC in recovery of heart rate (n=5; p>0.05)
| | | Ambient | None | Yes | HC+DHA vs. HC
| | | | | | - NC in recovery of heart rate (n=5; p>0.05)
| | | Ambient | None | Yes | HC+DHA vs HC+EPA
| | | | | | - NC in recovery of heart rate (n=5; p>0.05)
Lamers, 1988 | IPIM | Sarcolemma | Ambient | Ca^2+^ | Yes | FO+LARD vs LARD
| | | | | | - Increased Ca^2+^ pumping ATPase activity by 68% (n= 6; p< 0.05)
| | | Ischemia (5 min) | Ca^2+^ | Yes | FO+LARD vs LARD
| | | Reperfusion (10 min) | | | - Increased Ca^2+^ pumping ATPase activity by 43% (n=6; p< 0.05)
Laustiola, 1986 | CP | Atrial myocytes | High O2 | None | Yes | STD+CLO vs STD
| | | | | | - Decreased contraction amplitude by 25% (n=7–11; p<0.001)
| | | | | | - Decreased heart rate by 24% (n=7–11; p<0.001)
| | | High O2 | NA(1×10^-6^/90sec) | Yes | STD+CLO vs STD
| | | | | | - NC in contraction amplitude (n=4–11; p>0.05)
| | | | | | - NC in heart rate (n=4–11; p>0.05)
| | | Hypoxia | NA(1×10^-6^/90sec) | Yes | STD+CLO vs STD
| | | | | | - Decreased contraction amplitude by 58% (n=4–11; p<0.001)
| | | | | | - Decreased heart rate by 13% (n=4–11; p<0.001)
| | | Reoxy O2 5min | NA (1×10^-6^/90sec) | Yes | STD+CLO vs STD
| | | | | | - NC in contraction amplitude (n=4–11; p>0.05)
| | | | | | - NC in heart rate (n=4–11; p>0.05)
Leifert, 2000a | CP | Ventricular myocytes | Ambient | | Yes | FO vs. LARD
| | | | | | - NC in resting or diastolic cell length (voltage required to stimulate 90% of cells to contract) (n=29–36; p>0.05)
| | | | | | - NC in systolic cell length (peak cell shortening during steady state) (n=29–36; p>0.05)
| | | | | | - NC in percent cell length (systolic-diastolic/diastolic*100) (n=29–36; p>0.05)
| | | | | | - NC in post-rest potentiation (post rest contraction length/steady state contraction length*100) (n=29–36; p>0.05)
| | | Ambient | ISO (0.01–3uM/3min) | Yes | FO vs. LARD
| | | | | | - Decrease and delay in the development of ISO induced asynchronous contractile activity (n=6 animals/gr; p<0.05)
| | | | | | - EC_50_ values were 892 ± 130nM and 347 ± 91 nM for FO and LARD, respectively.
| | | Ambient | FRGS (2.3mM purine; 7mU/ml xanthine oxidase/20mins) | Yes | FO vs. LARD
| | | | | | - Decreased development of FRGS induced asynchronous contractions over the entire time course (3–20mins) (n=6–9 animals/gp; p<0.01)
| | | | | | - Increased the time taken until 50% of cardiomyocytes contracted in an asynchronous manner (30%) (n=6–9animals/gp; p<0.01)
| | | Ambient | None | Yes | FO vs. LARD
| | | | | | - NC in voltage dependence of Na^+^ current activation parameters G_max_; V_50_; E_rev_ or K (n=28; p>0.05)
| | | | | | - NC in voltage dependence of Na^+^ current inactivation parameters I_max_ and K (n=28; p>0.05)
| | | | | | - More negative V_50_ for the voltage dependence of Na^+^ current inactivation (n=28; p<0.05)
| | | Ambient | None | Yes | FO vs. LARD
| | | | | | - NC in I_to_ current activation parameters I_max_; V_50_ or K (n=17–28; p>0.05)
| | | | | | - NC in I_to_ current inactivation parameters I_max_; V_50_ or K (n=17–28; p>0.05)
Leifert, 2001 | CP | Cardio-myocytes | Ambient | ISO (0.1–3uM) | Yes | FO vs. SF
| | | | | | - Decreased the time of onset of asynchronous contractile activity (%=ND)(n=6 animals; p<0.001)
| | | | | | - No change in the number of asynchronously contracting myocytes (n= 29–32; p>0.05)
| | | | | | - Prevented asynchronously contraction during Ca2+ transient measurements (n= 29–32; p<0.05)
| IPIM | | Ambient | None | Yes | FO vs. SF
| | | | | | - NC in SR Ca2+ transient under steady state conditions and after 30sec rest period (n=8/grp; p>0.05)
| | | Ambient | Caffeine (20mM) -induced SR Ca2+ release | Yes | FO vs. SF
| | | | | | - NC in SR Ca2+ content (n=8/grp; p>0.05)
| | | Ambient | DBHQ (10uM/4m): SR Ca2+ ATPase inhibitor | Yes | FO vs. SF
| | | | | | - NC in value of the peak Ca2+ transient (n=32; p>0.05)
| | | | | | - Increased the time constant of decay (tau) of the Ca2+ transient (%=ND) (n=8/grp; p<0.05), indicating a more rapid Ca2+ efflux via sarcolemmal Ca2+ exchangers in the SF group.
| | | Ambient | None | Yes | FO vs. SF
| | | | | | - Increased the time constant of the decay phase of the Ca2+ transient (%=ND) (n=8/grp; p<0.05)
| | | | | | - NC in end-diastolic Ca2+ concentration (n=8/grp; p>0.05)
| | | | | | - NC in systolic peak Ca2+ concentration (n=8/grp; p>0.05)
| | | | | | - NC in developed Ca2+ concentration (systolic-end diastolic) (n=8/grp; p>0.05)
| | | Ambient | ISO (0.5uM): increase the cellular Ca2+ load | Yes | FO vs. SF
| | | | | | - Increased the time constant of the decay phase of the Ca2+ transient by 13% (n=8/grp; p<0.01), indicating a more rapid Ca2+ efflux via SR and/or sarcolemmal Ca2+ exchangers in the SF group.
| | | | | | - NC in end-diastolic Ca2+ concentration (n=8/grp; p>0.05)
| | | | | | - NC in systolic peak Ca2+ concentration (n=8/grp; p>0.05)
| | | | | | - NC in developed Ca2+ concentration (systolic-end diastolic) (n=8/grp; p>0.05)
Maixent, 1999 | IPIM | Myocardial microsomal vesicles | Ambient | OUA (10^-7^ to 10^-4^M) | Yes | STD+FO vs. STD
| | | | | | - NC in ouabain-sensitive Na^+^K^+^ATPase activity (n=4; p>0.05)
| | | | | | - NC in relative contribution of Na^+^K^+^ATPase a2 isoform (high affinity)
| | | | | | - NC in relative contribution of Na^+^K^+^ATPase a1 isoform (low affinity)
| | | | | | - NC in IC_50_ value of Na^+^K^+^ATPase a2 isoform (high affinity)
| | | | | | - Lower IC_50_ value of Na^+^K^+^ATPase a1 isoform (low affinity)
Minarovic, 1997 | ICU | Ventricular myocytes | Ambient | None | Yes | FO vs. HF
| | | | | | - NC in rates of activation and the fast component of inactivation of the Ca^2+^ current (n=ND; p>0.05)
| | | | | | - More negative half-inactivation potential (n=5–8;p<0.05) suggesting that these channels are less prone to inactivation
| | | | | | - NC in voltage dependence of the peak I_Ca_ amplitude (n=ND; p>0.05)
| | | Ambient | Verapamil (ND) | Yes | FO vs. HF
| | | | | | - No effect on the binding characteristics of the calcium channel blockers or the parameters of the I_Ca_-V curves (n=ND; p>0.05)
| | | Ambient | Diltiazem: (ND) | Yes | FO vs. HF
| | | | | | - No effect on the binding characteristics characteristics of the calcium channel blockers or the parameters of the I_Ca_-V curves (n=ND; p>0.05)
Reig, 1993 | BEP | Ventricular Tissue | Ambient | None | Yes | HF+FO vs. HF
| | | | | | - Decreased ventricular refractory period by 14% (n=5 animals;p<0.05)
| CP | Ventricular Tissue | Ambient | None | Yes | HF+FO vs. HF
| | | | | | - No change in proportion of animals with heart rate >750 beats/min by 50% (n=10animals;p>0.05)
Pepe, 1999 | IPIM | Myocardial mitochondria | Ambient | None | Yes | FO vs. N-6 in young animals
| | | | | | - NC in response of mitochondrial Ca2+concentration (n=5–6; p>0.05)
| | | | | | FO vs. N-6 in aged animals
| | | | | | - NC in response of Ca2+concentration (n=5–6; p>0.05)
| | | | | | FO vs. FO (aged vs. young)
| | | | | | - NC in response of Ca2+concentration (n=5–6; p>0.05)
| | | Ambient | Norepinephrine (10^-7^ M): ß-adrenergic receptor stimulation | Yes | FO vs. N-6 in young animals
| | | | | | - Decreased response of Ca2+concentration by 32% (n=5–6; p<0.05)
| | | | | | FO vs. N-6 in aged animals
| | | | | | - Decreased response of Ca2+concentration by 35% (n=5–6; p<0.05)
| | | | | | FO vs. FO (aged vs. young)
| | | | | | - NC in response of Ca2+concentration (n=5–6; p>0.05)
| | | 15-min low-flow ischemia, and 5-min reperfusion | None | | FO vs. N-6 in young animals
| | | | | | - Decreased response of Ca2+concentration (n=6; p<0.0001)
| | | | | | FO vs. N-6 in aged animals
| | | | | | - Decreased response of Ca2+concentration (n=6; p<0.05)
Swanson, 1989 | IPIM | SR vesicles | Ambient | None | Yes | SAF+MenO vs SAF+CO
| | | | | | - Decreased relative activity of Ca2+-Mg2+ ATPase activity by 86% (n= 3 pools of 3 hearts per replicate; p<0.05)
| | | | | | SAF+MenO vs SAF+CO
| | | | | | - Decreased the initial (0–5 min) calcium transport rate by 60% (n= 3 pools of 3 hearts per replicate; p<0.05)
| | | | | | SAF+MenO vs SAF+CO
| | | | | | - Decreased maximum sarcoplasmic reticulum calcium uptake by 62% (n= 3 pools of 3 hearts per replicate; p<0.01)
Taffet, 1993 | IPIM | Ventricular SR vesicle | Ambient | None | Yes | CO+FO vs. CO
| | | | | | - Decreased oxalate facilitated ATP dependent SR Ca2+ uptake by 30% (n=11–12; p<0.05)
| | | Ambient | Calcium 40uM +ATP 50um | Yes | CO+FO vs. CO
| | | | | | - Decreased Ca^2+^Mg^2+^ ATPase activity by 25% (n=11–12; p<0.05)
| | | | | | - Decreased Ca^2+^ATPase activity (independent of Mg-ATPase activity) by -27% (n=11–12; p<0.05)
| | | Ambient | Calcium 40uM +ATP 50um +Ionomycin (800mM) | Yes | CO+FO vs. CO
| | | | | | - Decreased Ca^2+^Mg^2+^ATPase activity by 27% (n=11–12; p<0.05)
| | | | | | - Decreased Ca^2+^Mg^2+^ ATPase activity (independent of Mg^2+^ATPase activity) by 27% (n=11–12; p<0.05)
| | | | | | - NC in Mg-ATPase activity (independent of Ca^2+^ATPase activity) (n=11–12; p>0.05)
| | | Ambient | 40uM calcium+ 1mM ATP +Ionomycin (800mM) | Yes | CO+FO vs. CO
| | | | | | - Decreased Ca^2+^Mg^2+^ATPase activity by 23% (n=11–12; p<0.05)
| | | | | | - Decreased Ca^2+^ATPase activity (independent of Mg^2+^ATPase activity) by 23% (n=11–12; p<0.05)
| | | | | | - Decreased Mg^2+^ATPase activity (independent of Ca^2+^ATPase activity (%=ND); (n=11–12; p<0.05)
| | | | | | - Decreased calcium accumulation by isolated SR by 27% (n=11–12; p<0.05)
| | | | | | - NC in iononycin stimulation (n=11–12; p>0.05)
| | | | | | - NC in acylphosphate (EP) (n=4; p>0.05)
| | | | | | - Decreased turnover (Ca-ATPase/total EP) by 24% (n=11–12; p<0.05)
| | | | | | - Decreased turnover (Ca-ATPase/CaEP) by 17% (n=11–12; p<0.05)
| | | | | | - NC in coupling (ATP/Ca uptake) (n=11–12; p<0.05)

Evidence Table 3. Isolated Organ And Cell Culture Studies

Table 3 Evidence Table. Isolated Organ And Cell Culture Studies

Author, yr | Study Characteristics | Cells | Fatty Acid | Incubation/ Exposure Duration | Outcome Category | Experimental Condition | Agent [Amt] | Results
| [Country: Funding:] | [Animal: Age: Type:] | [N3: Dose: Form:]
Bayer, 1979 | Germany, U | Cat | ALA-Na 2mg/kg/min | 5 min | BEP | Ambient | INDO | ALA vs. Ctrl
| | Adult heart in situ | Free IV | | | | | - No change in intra-atrial conduction time
| | | | | | | | - No change in atrioventricular conduction time
| | | | | | | | - No change in functional refractory period of the atrium
| | | | | | | | - No change in functional refractory period of atrio-ventricular conducting system
Bogdanov, 1998 | Russia/USA | Rat | DHA | 3–12 mins | ICU | Ambient | None | DHA vs. Ctrl
| U | Adult | 5μM | | | | | - Decreased I_to_ by 40% (n=ND; p=ND) which were not observed when 4-AP (5μM/ND) was present in the bath medium
| | Ventricular | Free | | | | | - Decreased I_to_ amplitude by 60% (n=ND; p=ND)
| | | | | | | | - Increased I_to_ delay (n=ND; p=ND)
| | | | | | | | - Decreased time constant of I_to_ inactivation (t) evoked by a voltage step from -70 to +60MV by 33% within 3mins (n=4; p<0.02).
| | | | | | | | - Effects were reversible by BSA
| | | DHA | 3–12 mins | ICU | Ambient | INDO (10μM) Added with FA | DHA+INDO vs. Ctrl+INDO
| | | 5μM | | | | | - Presence of INDO did not modify effects on I_to_ indicating that effects of DHA were not related to its cyclooxygenase products (n=ND; p>0.05)
| | | Free
| | | DHA | 3–12 mins | ICU | Ambient | None | DHA vs. Ctrl
| | | 50μM | | | | | - Decreased I_SUS_ by 32% (n=ND; p=ND)
| | | Free | | | | | - No change in I_KI_ at voltages between -120 to -80mV (n=5; p>0.05)
| | | EPA | 3–12 mins | ICU | Ambient | None | EPA vs. Ctrl
| | | 5–10μM | | | | | - No change in of I_SUS_ (n=4; p>0.05)
| | | Free
| | | EPA | 3–12 mins | ICU | Ambient | None | EPA vs. Ctrl
| | | 20μM | | | | | - Decreased I_SUS_ by 16% (n=4; p<0.05)
| | | Free
| | | EPA | 3–12 mins | ICU | Ambient | None | EPA vs. Ctrl
| | | 50μM | | | | | - Decreased I_to_ by 73% (n=4; p<0.05)
| | | Free | | | | | - Decreased I_SUS_ by 56% (n=4; p<0.05)
| | | | | | | | - No change in I_KI_ at voltages between -120 to -80mV (n=5; p>0.05)
| | | EPA | 10–15 mins | BEP | Ambient | None | EPA vs. Ctrl
| | | 5–10μm | | | | | - Increased AP (% in fig) (n=ND; p=ND)
| | | Free | | | | | - No change in APA (n=ND; p>0.05)
| | | EPA | 10–15 mins | BEP | Ambient | None | EPA vs. Ctrl
| | | 20μM | | | | | - Increased APD (% in fig) (n=ND; p=ND)
| | | Free | | | | | - Decreased APA (% in fig) (n=ND; p<0.05)
| | | | | | | | - Decreased V_max_ (% in fig) (n=ND; p=ND)
| | | DHA | 10–15 mins | BEP | Ambient | None | DHA vs. Ctrl
| | | 10–50μM | | | | | - Similar effects as EPA on APD, APA and V_max_ (data not shown)
| | | Free
Courtois, 1992 | France | Rat | SM3-Na-BSA | 24 hour s | CP | Ambient | None | SM3 vs. Ctrl
| G | Neonatal | (ALA+EPA) 28.3+29.9% of total FA's Bound | | | | | - No change in contraction rate (n=5; p>0.05)
| | Ventricular | | | | | | - No change in CD_80_ (n=5; p>0.05)
| | | | | | | | - No change +C_max_ (n=5; p>0.05)
| | | | | | | | - No change in -C_max_ (n=5; p>0.05)
| | | | | | | | SM3 vs. SM6
| | | | | | | | - No change in contraction rate (n=5; p>0.05)
| | | | | | | | - No change in CD_80_ (n=5; p>0.05)
| | | | | | | | - Increased +C_max_ (n=5; p<0.01)
| | | | | | | | - No change in -C_max_ (n=5; p>0.05)
| | | SM3-Na-BSA | 24 hour s | CP | Ambient | ISO (10^-7^ M) Added after FA | SM3+ISO vs. Ctrl+ISO
| | | (ALA+EPA) 28.3+29.9% of total FA's Bound | | | | | - Decreased contraction rate by10% (n=5; p<0.05)
| | | | | | | | - No change in CD_80_ (n=5; p>0.05)
| | | | | | | | - No change in +C_max_ (n=5; p>0.5)
| | | | | | | | - No change in -C_max_ (n=5; p>0.05)
| | | | | | | | SM3+ISO vs. SM6+ISO
| | | | | | | | - No change in contraction rate (n=5;p>0.05)
| | | | | | | | - No change in CD_80_ (n=5; p>0.05)
| | | | | | | | - No change in +C_max_ (n=5; p>0.05)
| | | | | | | | - No change in -C_max_ (n=5; p>0.05)
| | | | | | | | SM3+Iso vs. SM3
| | | | | | | | - Increased contraction rate by 18% (n=5; p<0.01)
| | | | | | | | - Decreased CD_80_ by -12% (n=5; p<0.01)
| | | | | | | | - No change +C_max_ (n=5; p>0.05)
| | | | | | | | - Decreased -C_max_ by 13% (n=5; p<0.01)
de Jonge, 1996 | Netherlands | Rat | EPA | 4–5 days | CP | Ambient | None | EPA vs. Ctrl
| G | Neonatal | 214μM | | | | | - Decreased irregularity of spontaneous contractions (n=4; p<0.05)
| | Ventricular | Bound
Durot, 1997 | France | Rat | SM3 media containing 25μM EPA-Al + 25μM | 4 days | BEP | Ambient | None | SM3 vs. SM6
| G | Neonatal | DHA-Al Bound | | | | | - Increased V_max_ by 16% (n=9; p<0.05)
| | Ventricular | | | | | | - No change in MDP (n=9; p>0.05)
| | | | | | | | - No change in OS (n=9; p>0.05)
| | | | | | | | - No change in AP (n=9; p>0.05)
| | | | | | | | - No change in APA (n=9; p>0.05)
| | | | | | | | - No change in APD_40_ (n=9; p>0.05)
| | | | | | | | - No change in APD_80_ (n=9; p>0.05)
| | | SM3 media containing 25μM EPA-Al + 25μM | 4 days | BEP | Hypoxia (N_2_) | None | SM3 vs. SM6
| | | DHA-Al Bound | | | | | - Decreased APA (% in fig)(n=5; p<0.05)
| | | | | | | | - Decreased APD_40_ (% in fig) (n=5; p<0.01)
| | | | | | | | - Decreased APD_80_ (% in fig)(n=5; p<0.05)
| | | | | | | | - No change in MDP (n=5; p>0.05)
| | | | | | | | - No change in AP (n=5; p>0.05)
| | | | | | | | - No change in upstroke velocity (n=5; p>0.05)
| | | | | | | | - No change in V_max_ (n=5; p>0.05)
Durot, 1997 | France | Rat | SM3 media containing 25μM EPA-Al + 25μM | 4 days | BEP | Reoxy (O_2_ for 1.5 hrs) | None | SM3 vs. SM6
| G | Neonatal | DHA-Al Bound | | | | | - No change in APA (n=5; p>0.05)
| | Ventricular | | | | | | - No change in APD_40_ (n=5; p>0.05)
| | | | | | | | - No change in APD_80_ (n=5; p<0.05 )
| | | | | | | | - Recovery of MDP was significantly increased i.e. improvement (n=5, p<0.01)
| | | | | | | | - No change in V_max_ (n=5; p>0.05)
| | | SM3 media containing 25μM EPA-Al + 25μM | 4 days | CP | Ambient | None | SM3 vs. SM6
| | | DHA-Al Bound | | | | | - No change in tC_20_ (n=6, p>0.05)
| | | | | | | | - No change in CD_20_ (n=6, p>0.05)
| | | | | | | | - No change in CD_80_ (n=6, p>0.05)
| | | | | | | | - No change in +C_max_, (n=6, p>0.05)
| | | | | | | | - No change in +C_max_ (n=6, p>0.05)
| | | SM3 media containing 25μM EPA-Al + 25μM | 4 days | CP | Hypoxia (N_2_) | None | SM3 vs. SM6
| | | DHA-Al Bound | | | | | - No change in tC_20_ (n=6, p>0.05)
| | | | | | | | - No change in CD_20_ (n=6, p>0.05)
| | | | | | | | - No change in CD_80_ (n=6, p>0.05)
| | | | | | | | - No change in +C_max_ (n=6, p>0.05)
| | | | | | | | - No change in -C_max_ (n=6, p>0.05)
| | | SM3 media containing 25μM EPA-Al + 25μM | 4 days | CP | Reoxy (O_2_ for 1.5 hrs) | None | SM3 vs. SM6
| | | DHA-Al Bound | | | | | - No change in tC_20_ (n=6, p>0.05)
| | | | | | | | - No change in CD_20_ (n=6, p>0.05)
| | | | | | | | - No change in CD_80_ (n=6, p>0.05)
| | | | | | | | - No change in +C_max_ (n=6, p>0.05)
| | | | | | | | - No change in -C_max_ (n=6, p>0.05)
Ferrier, 2002 | Canada | Guinea Pig | DHAm.e. | 20 mins | ICU | Ambient | None | DHAm.e. vs. Ctrl
| G | Adult | 10μM | | | | | - Inhibition in the magnitude of the peak I_ca.L_ by 85% (n=18–24; p<0.001)
| | Ventricular | Free
| | | DHAm.e. | 20 mins | CP | Ambient | None | DHAm.e. vs. Ctrl
| | | 10μM | | | | | - Decreased amplitude of CICR induced contractions by 93% (n=18–24; p<0.001)
| | | Free | | | | | - No change in VSRM induced contractions (n=18–24; p>0.05)
Fournier, 1995 | France | Rat | EPA 100μM Bound | 4 days | CP | Ambient | None | EPA vs. DHA
| G/ NP | Neonatal | DHA 100μM Bound | | | | | - No change in tC_20_ (n=11; p>0.05)
| | Ventricular | | | | | | - No change in CD_20_ (n=11; p>0.05)
| | | | | | | | - No change in CD_80_ (n=11; p>0.05)
| | | | | | | | - No change in +C_max_ (n=11; p>0.05)
| | | | | | | | - No change in -C_max_ (n=11; p>0.05)
Fournier, 1995 | France | Rat | EPA 100μM Bound | 4 days | BEP | Ambient | None | EPA vs. DHA
| G/ NP | Neonatal | DHA 100μM Bound | | | | | - Increased APA due to a higher plateau phase (%in fig) (n=11; p<0.05
| | Ventricular | | | | | | - Increased OS (% in fig) (n=11; p<0.05)
| | | | | | | | - No change in MDP (n=11; p>0.05)
| | | | | | | | - No change in ADP_40_ (n=11; p>0.05)
| | | | | | | | - No change in ADP_80_ (n=11; p>0.05)
| | | | | | | | - No change in AP (n=11; p>0.05)
| | | | | | | | - No change in V_max_ (n=11; p>0.05)
Goel, 2002 | Canada | Pig | EPA | 90+/- 30s | IPIM | Ambient | None | EPA vs. Ctrl
| G/NP | Adult | 10μM | | | | | - No change in H^+^ dependent Na^+^ uptake (Na^+^/H^+^ exchange) (n=3–5; p>0.05)
| | Ventricular | Free
| | SL vesicles
| | | EPA | 90+/- 30s | IPIM | Ambient | None | EPA vs. Ctrl
| | | 25μM | | | | | - No change in H^+^ dependent Na^+^ uptake (Na^+^/H^+^ exchange) (n=3–5; p>0.05)
| | | Free
| | | EPA | 90+/- 30s | IPIM | Ambient | None | EPA vs. Ctrl
| | | 50μM | | | | | - Decreased H^+^ dependent Na^+^ uptake by 24% (Na^+^/H^+^ exchange) (n=3–5; p<0.05) which occurred at all reaction times (2–60 secs) and at all extravesicular pH values except pH 6
| | | Free | | | | | - No change in passive Na^+^ efflux (n=6; p>0.05)
| | | EPA | 90+/- 30s | IPIM | Ambient | None | EPA vs. Ctrl
| | | 100μM | | | | | - Decreased H^+^ dependent Na^+^ uptake (Na^+^/H^+^ exchange) (% in fig) (n=3–5; p<0.05) which occurred at all reaction times (2–60 secs) and at all extravesicular pH values except pH 6
| | | Free
| | | DHA | 90+/- 30s | IPIM | Ambient | None | DHA vs. Ctrl
| | | 10μM | | | | | - No change in H^+^ dependent Na^+^ uptake (Na^+^/H^+^ exchange) (n=3–5; p>0.05)
| | | Free
| | | DHA | 90+/- 30s | IPIM | Ambient | None | DHA vs. Ctrl
| | | 25μM | | | | | - Decreased H^+^ dependent Na^+^ uptake (Na^+^/H^+^ exchange) (% in fig) (n=3–5; p<0.05)
| | | Free
| | | DHA | 90+/- 30s | IPIM | Ambient | None | DHA vs. Ctrl
| | | 50μM | | | | | - Decreased H^+^ dependent Na^+^ uptake (Na^+^/H^+^ exchange) by 34% (n=3–5; p<0.05)
| | | Free | | | | | - No change in passive Na^+^ efflux (n=6; p>0.05)
| | | DHA | 90+/- 30s | IPIM | Ambient | None | DHA vs. Ctrl
| | | 100μM | | | | | - Decreased H^+^ dependent Na^+^ uptake (Na^+^/H^+^ exchange) (% in fig) (n=3–5; p<0.05)
| | | Free
| | | ALA | 90+/- 30s | IPIM | Ambient | None | ALA vs. Ctrl
| | | 50μM | | | | | - No change in H^+^ dependent Na^+^ uptake (Na^+^/H^+^ exchange) (n=3–5; p>0.05)
| | | Free
| | | DHA | 90+/- 30s | IPIM | Ambient | Na^+^ (0.05, 2.5 or 10mM) | DHA vs. Ctrl
| | | 50μM | | | | | - Decreasd H^+^ dependent Na^+^ uptake (Na^+^/H^+^ exchange) as a function of Na^+^ by 30–40% (n=3–4; p<0.05)
| | | Free
Grynberg, 1988 | France | Rats | SM3 media containing 57% ALA+7%LA +0.2% AA as Na-Al | 24 hours | BEP | Ambient | None | SM3 vs. SM6
| G | Neonatal | | | | | | - No change in AP (n=11, p>0.05)
| | Ventricular | | | | | | - No change in APA (n=11, p>0.05)
| | | | | | | | - No change in APD_40_ (n=11, p>0.05)
| | | | | | | | - No change in APD_80_ (n=11, p>0.05)
| | | | | | | | - No change in MDP (n=11, p>0.05)
| | | | | | | | - No change in OS (n=11, p>0.05)
| | | | | | | | - No change in V_max_ (n=11, p>0.05)
| | | SM3 media containing 57% ALA+7%LA +0.2% AA as Na-Al | 24 hours | BEP | Hypoxia(N_2_) | None | SM3 vs. SM6
| | | | | | | | - No change in AP (n=11; p>0.05)
| | | | | | | | - Decreased APA (n=11, p<0.01).
| | | | | | | | - No change in APD_40_ (n=11, p>0.05)
| | | | | | | | - No change in APD_80_ (n=11, p>0.05)
| | | | | | | | - No change in MDP (n=11, p>0.05)
| | | | | | | | - Decreased OS (n=11, p<0.05)
| | | | | | | | - No change in V_max_ (n=11, p>0.05)
| | | SM3 media containing 57% ALA+7%LA +0.2% AA as Na-Al | 24 hours | BEP | Reoxy (O_2_) | None | SM3 vs. SM6
| | | | | | | | - No change in AP (n=11, p>0.05)
| | | | | | | | - No change in AP (n=11, p>0.05)
| | | | | | | | - Increased APA (n=11, p<0.01)
| | | | | | | | - No change in APD_40_ (n=11, p>0.05)
| | | | | | | | - No change in APD_80_ (n=11, p>0.05)
| | | | | | | | - No change in MDP (n=11, p>0.05)
| | | | | | | | - Increased OS (n=11, p<0.05)
| | | | | | | | - No change in V_max_ (n=11, p>0.05)
| | | SM3 media containing 57% ALA+7%LA +0.2% AA as Na-Al | 24 hours | CP | Ambient | None | SM3 vs. SM6
| | | | | | | | - No change in tC_20_ (n=11, p>0.05)
| | | | | | | | - No change in CD_80_ (n=11, p>0.05)
| | | SM3 media containing 57% ALA+7%LA +0.2% AA as Na-Al | 24 hours | CP | Hypoxia (N_2_) | None | SM3 vs. SM6
| | | | | | | | - No change in tC_20_ (n=11, p>0.05)
| | | | | | | | - No change in CD_80_ (n=11, p>0.05)
| | | SM3 media containing 57% ALA+7%LA +0.2% AA as Na-Al | 24 hours | CP | Reoxy (O_2_) | None | SM3 vs. SM6
| | | | | | | | - No change in tC_20_ (n=11, p>0.05)
| | | | | | | | - No change in CD_80_ (n=11, p>0.05)
Grynberg, 1995 | France | Rat | EPA-Na-BSA | 4 days | CP | Ambient | None | EPA vs. DHA
| G/NP | Neonatal | 100μM | | | | | - No change in spontaneous beating frequency (n=12; p>0.05)
| | Ventricular | DHA-Na-BSA | | | | | - No change in CD_20_ (n=12; p>0.05)
| | | 100μM | | | | | - No change in CD_80_ (n=12; p>0.05)
| | | Bound | | | | | - No change in +C_max_ (n=12; p>0.05)
| | | | | | | | - No change in -C_max_ (n=12; p>0.05)
| | | EPA-Na-BSA | 4 days | CP | Ambient | ISO (10^-7^ M) Added after FA | EPA+ISO vs. DHA+ISO
| | | 100μM | | | | | - Decreased spontaneous beating frequency by 40% (n=6; p<0.05)
| | | DHA-Na-BSA | | | | | - No change in normalized CD_80_ (n=6; p>0.05)
| | | 100μM | | | | | EPA+ISO vs. EPA
| | | Bound | | | | | - Increased spontaneous beating frequency by 30% (n=6; p<0.05)
| | | | | | | | DHA+ISO vs. DHA
| | | | | | | | - Increased spontaneous beating frequency by 50% (n=6; p<0.05)
| | | EPA-Na-BSA | 4 days | CP | Ambient | Phe (3 ×10^-6^ M) Added after FA | EPA+Phe vs. DHA+Phe
| | | 100μM | | | | | - No change in spontaneous beating rate (n=6; p>0.05)
| | | DHA-Na-BSA | | | | | - No change in CD_80_ (n=6; p>0.05)
| | | 100μM
| | | Bound
| | | EPA-Na-BSA | 4 days | CP | Ambient | dBcAMP (10^-73^M) Added after FA | EPA+dBcAMP vs. DHA+dBcAMP
| | | 100μM | | | | | - Decreased spontaneous beating rate (% in fig) (n=6; p<0.05)
| | | DHA-Na-BSA | | | | | EPA+dBcAMP vs. EPA
| | | 100μM | | | | | - Increased spontaneous beating rate by 40% (n=6; p=ND)
| | | Bound | | | | | DHA+dBcAMP vs. DHA
| | | | | | | | - Increased spontaneous beating rate by 60% (n=6; p=ND)
Grynberg, 1996 | France | Rat | EPA-Albumin | 4 days | CP | Ambient | None | - EPA vs. DHA
| U | Neonatal | 0.1mM | | | | | - No change in spontaneous rate (n=10; p>0.05)
| | Ventricular | Bound | | | | | - No change in CD_20_ (n=10; p>0.05)
| | | DHA-Albumin | | | | | - No change in CD_80_ (n=10; p>0.05)
| | | 0.1mM | | | | | - No change in +C_max_ (n=10; p>0.05)
| | | Bound | | | | | - No change in -C_max_ (n=10; p>0.05)
| | | EPA-Albumin | 4 days | CP | Ambient | Phe (3×10^-6^M) | EPA+Phe vs. DHPA+Phe
| | | 0.1mM | | | | | - No change in contraction rate (n=10; p>0.05)
| | | Bound
Grynberg, 1996 | France | Rat | EPA-Albumin | 4 days | CP | Ambient | ISO (10^-6^M) | EPA+ISO vs. DHA+ISO
| U | Neonatal | 0.1mM | | | | | - Decreased contraction rate (% in fig) (n=10; p<0.01)
| | Ventricular | Bound
| | | DHA-Albumin
| | | 0.1mM
| | | Bound
| | | EPA-Albumin | 4 days | CP | Ambient | dBcAMP (10^-3^M) | EPA+dBcAMP vs. DHA+dBcAMP
| | | 0.1mM | | | | | - Decreased contraction rate (% in fig) (n=10; p<0.01)
| | | Bound
| | | DHA-Albumin
| | | 0.1mM
| | | Bound
| | | EPA-Albumin | 4 days | BEP | Ambient | None | EPA vs..DHA
| | | 0.1mM | | | | | - Increased APA by 3% (n=10; p<0.05)
| | | Bound | | | | | - Increased OS by 13% (n=10; p0<0.05)
| | | DHA-Albumin | | | | | - No change in MDP (n=10; p>0.05)
| | | 0.1mM | | | | | - No change in APD_80_ (n=10; p>0.05)
| | | Bound | | | | | - No change in V_max_ (n=10; p>0.05)
Hallaq,1990 | USA/Germany | Rat | EPA | 3–5 days | CP | Ambient | None | EPA vs. Ctrl
| G | Neonatal | 5μM | | | | | - No change in amplitude of contraction (n=6; p>0.05)
| | Ventricular | Bound | | | | | - No change in beats/min (n=6; p>0.05)
| | | EPA | 3–5 days | CP | Ambient | OUA (0.1mM) Added after FA | EPA+OUA vs. Ctrl+OUA
| | | 5μM | | | | | - Increased amplitude of contraction by 156% (n=6; p<0.001)
| | | Bound | | | | | - Decreased beats/min by 67% (n=6; p<0.001)
| | | | | | | | EPA vs. EPA+OUA
| | | | | | | | - Increased amplitude of contraction by 33% (n=6; p<0.001)
| | | | | | | | - Decreased beats/min by 31% (n=6; p<0.001)
| | | EPA | 3–5 days | IPIM | Ambient | None | EPA vs. Ctrl
| | | 5μM | | | | | - No change in cytosolic free Ca^2+^ (n=8; p>0.05)
| | | Bound
| | | EPA | 3–5 days | IPIM | Ambient | OUA (1μM) Added after FA | EPA+OUA vs. Ctrl+OUA
| | | 5μM | | | | | - No change in time averaged cytosolic free Ca^2+^ induced by OUA (n=3; p>0.05)
| | | Bound
| | | EPA | 3–5 days | IPIM | Ambient | OUA (0.1mM) Added after FA | EPA+OUA vs. Ctrl+OUA
| | | 5μM | | | | | - Decreased time averaged cytosolic free Ca^2+^ induced by OUA by 75% (n=5; p<0.001)
| | | Bound
Hallaq, 1990 | USA/Germany | Rat | EPA | 3–5 days | IPIM | Ambient | OUA (0.1mM) Added after FA | EPA+OUA vs. Ctrl+OUA
| G | Neonatal | 5μM | | | | | - No change in OUA sensitive Na, K-ATPase (pump activity) measured as the rate of influx of ^86^Rb into myocytes (n=10; p>0.05)
| | Ventricular | Bound | | | | | - No change in OUA sensitive Na, K-ATPase (pump activity) measured using NADH-coupled enzyme assay to determine rate of ATP hydrolysis by Na, K-ATPase (n=3; p>0.05)
| | | EPA | 3–5 days | IPIM | Ambient | BUME (10μM) Added after FA | EPA+BUME vs. Ctrl+BUME
| | | 5μM | | | | | - No change in BUME sensitive Na, K-ATPase (pump activity) measured as the rate of influx of ^86^Rb into myocytes which also indicates that the facilitated cotransport pathway for Na^+^, K^+^ and 2Cl^-^ is not affected by EPA (n=11; p>0.05)
| | | Bound
| | | EPA | 3–5 days | IPIM | Ambient | OUA+BUME (0.1mM+10 μM) Added after FA | EPA+OUA+BUME vs. Ctrl+OUA+BUME
| | | 5μM | | | | | - No change in total Na, K-ATPase (pump activity) measured as the rate of influx of ^86^Rb into myocytes (n=11; p>0.05)
| | | Bound
Hallaq, 1992 | USA | Rat | DHA | 1–2 mins | CP | Ambient | None | DHA vs. Ctrl
| G | Neonatal | 5μM | | | | | - No change in contractility (n=6; p>0.05)
| | Ventricular | Free
| | | DHA | 1–2 mins | CP | Ambient | OUA (0.1mM) Added before or after FA | DHA+OUA vs. Ctrl+OUA
| | | 5μM | | | | | - Prevented or Terminated arrhythmia's (n=10; p<0.05)
| | | Free
| | | DHA | 1–2 mins | CP | Ambient | NIT (0.5nM) Added with FA | DHA+NIT vs. NIT
| | | 5μM | | | | | - Prevented the inhibitory effect of NIT on contractility (n=6; p<0.05)
| | | Free
| | | DHA | 1–2 mins | CP | Ambient | BAY (0.1μM) Added after FA | DHA+BAY vs. Ctrl+BAY
| | | 5μM | | | | | - Prevented the inhibitory effects of BAY on contractility (n=4; p<0.05)
| | | Free
| | | DHA | 1–2 mins | CP | Ambient | VER (10μM) or DIL (1μM) Added with FA | DHA+VER or DIL vs. Ctrl+VER or DIL
| | | 5μM | | | | | - Did not prevent the inhibitory effects of VER or DIL on contractility (n=3–4; p=ND)
| | | Free
| | | EPA | 1–2 mins | CP | Ambient | OUA (0.1mM) Added after FA | EPA+OUA vs. Ctrl+OUA
| | | 5μM | | | | | - Prevented arrhythmia (n=ND; p<0.05)
| | | Free
| | | EPA | 4 days | ICH | Ambient | NIT (0.03^-10^ nM) Added after FA | EPA vs. Ctrl
| | | 5μM | | | | | - Noncompetitive inhibition of the specific binding of NIT by reducing the maximal binding of [^3^H] NIT
| | | Bound | | | | | - Decreased K_d_ value of high affinity binding site by 97% (n=5–10; p<0.05)
| | | | | | | | - Decreased the number of high affinity binding sites (B_MAX_) by -90% (n=5–10; p<0.01)
| | | | | | | | - Decreased K_d_ value of low affinity binding site by 74% (n=5–10; p<0.01)
| | | | | | | | - Decreased the number of low affinity binding sites (B_MAX_) by 60% (n=5–10; p<0.05)
Hallaq, 1992 | USA | Rat | DHA | 4 days | ICH | Ambient | NIT (0.03^-10^ nM) Added after FA | DHA vs. Ctrl
| G | Neonatal | 5μM | | | | | - K_d_ value of high affinity binding site was non detectable due to suppression by DHA (n=5–10; p<0.001)
| | Ventricular | Bound | | | | | - Number of high affinity binding sites (B_MAX_) was non detectable due to suppression by DHA (n=5–10; p<0.001)
| | | | | | | | - Decreased K_d_ value of low affinity binding site by 78% (n=5–10; p<0.01)
| | | | | | | | - Decreased the number of low affinity binding sites (B_MAX_) by 64% (n=5–10; p<0.05)
| | | DHA | 4 days | IPIM | Ambient | OUA (0.1mM) ^45^Ca2^+^ | DHA+OUA vs. OUA
| | | 5uM | | | | | - Decreased ^45^Ca^2+^ uptake (Ca^2+^ influx) by 29% (n=4–11; p<0.025)
| | | Bound
| | | DHA | 4 days | IPIM | Ambient | NIT (0.5nM) Added after FA | DHA+NIT vs. Ctrl+NIT
| | | 5μM | | | | | - Increased ^45^Ca^2+^ uptake (Ca^2+^ influx) by 28% (n=5–14; p=ND)
| | | Bound | | | | | DHA+NIT vs. DHA
| | | | | | | | - No change in ^45^Ca^2+^ uptake (Ca^2+^ influx) (n=5–14; p>0.05)
| | | DHA | 4 days | IPIM | Ambient | BAY (0.1μM) Added after FA | DHA+BAY vs. Ctrl+BAY
| | | 5μM | | | | | - Decreased ^45^Ca^2+^ uptake (Ca^2+^ influx) by 32% (n=5–14; p=ND)
| | | Bound | | | | | DHA+BAY vs. DHA
| | | | | | | | - No change in ^45^Ca^2+^ uptake (Ca^2+^ influx) (n=5–14; p>0.05)
| | | DHA | 4 days | IPIM | Ambient | OUA+ NIT (0.1mM+0.5 nM) Added after FA | DHA+OUA+NIT vs. Ctrl+OUA+NIT
| | | 5μM | | | | | - Increased ^45^Ca^2+^ uptake (Ca^2+^ influx) by 13% (n=5–14; p=ND)
| | | Bound | | | | | DHA+OUA+NIT vs. DHA
| | | | | | | | - No change in ^45^Ca^2+^ uptake (Ca^2+^ influx) (n=5–14; p>0.05)
| | | DHA | 4 days | IPIM | Ambient | BAY+ NIT (0.1μM+ 0.5 nM) Added after FA | DHA+BAY+NIT vs. Ctrl+BAY+NIT
| | | 5μM | | | | | - Increased ^45^Ca^2+^ uptake (Ca^2+^ influx) by 55% (n=5–14; p=ND)
| | | Bound | | | | | DHA+Bay+NIT vs. DHA
| | | | | | | | - No change in ^45^Ca^2+^ uptake (Ca^2+^ influx) (n=5–14; p>0.05)
| | | EPA | 4 days | IPIM | Ambient | NIT (0.5nM) Added after FA | EPA+NIT vs. Ctrl+NIT
| | | 5μM | | | | | - Increased ^45^Ca^2+^ uptake (Ca^2+^ influx) by 34% (n=5–14; p=ND)
| | | Bound | | | | | EPA+NIT vs. EPA
| | | | | | | | - No change in ^45^Ca^2+^ uptake (Ca^2+^ influx) (n=5–14; p>0.05)
| | | EPA | 4 days | IPIM | Ambient | BAY (0.1μM) Added after FA | EPA+BAY vs. Ctrl+BAY
| | | 5μM | | | | | - Decreased ^45^Ca^2+^ uptake (Ca^2+^ influx) by 30% (n=5–14; p=ND)
| | | Bound | | | | | EPA+BAY vs. EPA
| | | | | | | | - No change in ^45^Ca^2+^ uptake (Ca^2+^ influx) (n=5–14; p>0.05)
| | | EPA | 4 days | IPIM | Ambient | OUA+ NIT (0.1mM+0.5 nM) Added after FA | EPA+OUA+NIT vs. Ctrl+OUA+NIT
| | | 5μM | | | | | - Increased ^45^Ca^2+^ uptake (Ca^2+^ influx) by 20% (n=5–14; p=ND)
| | | Bound | | | | | EPA+OUA+NIT vs. EPA
| | | | | | | | - No change in ^45^Ca^2+^ uptake (Ca^2+^ influx) (n=5–14; p>0.05)
| | | EPA | 4 days | IPIM | Ambient | BAY+ NIT (0.1μM+0.5 nM) Added after FA | EPA+BAY+NIT vs. Ctrl+BAY+NIT
| | | 5μM | | | | | - Increased ^45^Ca^2+^ uptake (Ca^2+^ influx) by 39% (n=5–14; p=ND)
| | | Bound | | | | | EPA+BAY+NIT vs. EPA
| | | | | | | | - No change in ^45^Ca^2+^ uptake (Ca^2+^ influx) (n=5–14; p>0.05)
Honore, 1994 | France | Mouse | DHA | ND | ICH | Ambient | None | DHA vs. Ctrl
| G/NP | Neonatal | 30μM | | | | | - Blocked delayed rectifier K^+^ channel (Kv1.5) activity (% in fig) (n=5–11; p<0.05)
| | Ventricular | Free
| | | ALA | ND | ICH | Ambient | None | ALA vs. Ctrl
| | | ND | | | | | - No change in delayed rectifier K^+^ channel (Kv1.5) activity (n=ND; p>0.05)
| | | ND
| | | DHA | ND | ICU | Ambient | None | DHA vs. Ctrl
| | | 30μM | | | | | - Intracellular DHA included in the pipette medium did not alter the Kv1.5 current (n=9; p>0.05)
| | | Free | | | | | - Addition of DHA to the external medium inhibited the Kv1.5 current within 20 seconds indicating that binding occurs on an external site (n=9; p<0.05)
| | | DHA | ND | ICU | Ambient | None | DHA vs. Ctrl
| | | 30μM | | | | | - No change in inward rectifier K^+^ current (n=4; p>0.05)
| | | Free | | | | | - Decreased ultra rapid K^+^ current (I_KUR_) measured at +30mV by 52% (n=4; p<0.05)
Jahangiri, 2000 | Australia | Rat | EPA | 7 mins | CP | Ambient | ISO (10μM) | EPA+ISO vs. Ctrl+ISO
| U | Adult | 10μM | | | | Added with FA | - Decreased the number of asynchronously contracting atrial myocytes by 76% (n=107/7hearts; p<0.01)
| | Atrial | Free
| | | DHA | 7 mins | CPr | Ambient | ISO (10μM) | DHA+ISO vs. Ctrl+ISO
| | | 10μM | | | | Added with FA | - Decreased the number of asynchronously contracting atrial myocytes by 69% (n=101/5 hearts; p<0.05)
| | | Free
| | | DHA m.e | 7 mins | CP | Ambient | ISO (10μM) | DHA m.e+ISO vs. Ctrl+ISO
| | | 10μM | | | | Added with FA | - No change in the number of asynchronously contracting atrial myocytes (n=71/4 hearts; p>0.05)
| | | Free
Juan, 1987 | Austria | Guinea Pigs | EPA-Na | 30mins | CP | Ambient | Antigen-ovalbumin (1mg/0.1ml) | EPA+Antigen vs. Ctrl+Antigen
| U | Adult | 6×10 ^-8^mol/min | | | | Added before FA | - No change in duration of arrhythmia (n=8; p>0.05)
| | Isolated heart | Free
| | | EPA-Na | 30mins | CP | Ambient | Antigen-ovalbumin (1mg/0.1ml) | EPA+antigen vs. Ctrl+Antigen
| | | 15×10^-8^mol/min | | | | Antioxidant-esculetin (1×10^-7^mol) | - Decreased duration of arrhythmia by 56% (n=8; p<0.05)
| | | Free | | | | Added before FA | EPA+Antioxidant+Antigen vs. Ctrl+Antigen
| | | | | | | | - Decreased duration of arrhythmia by 52% (n=5; p<0.05)
Kang, 1994 | USA | Rat | EPA | 3 mins | CP | Ambient | None | EPA vs. Ctrl
| G | Neonatal | 5–10μM | | | | | - Decreased contraction rate by 50 to 80% within 2 mins (n=46; p<0.05) and effects were reversed by BSA
| | Cardiac | Free | | | | | - No change in amplitude of contraction (n=ND; p>0.05)
| | | DHA | 3 mins | CP | Ambient | None | DHA vs. Ctrl
| | | 5–10μM | | | | | - Decreased contraction rate by 50 to 80% within 2 mins (n=32; p<0.05) and effects were reversed by BSA
| | | Free | | | | | - No change in amplitude of contraction (n=ND; p>0.05)
Kang, 1994 | USA | Rat | EPA | 3 mins | CP | Ambient | INDO (10–20μM/) | EPA+agents vs. Ctrl+agents
| G | Neonatal | 5–10μM | | | | BW755c (20μM) | - No change in EPA induced reductions in beating rate (n=ND; p>0.05)
| | Cardiac | Free | | | | BHT (0.005%/ Vitamin E (0.5uNIT/ml) and ETYA (ND)
| | | | | | | Added with FA
| | | EPA | 3 mins | CP | Ambient | Ca^2+^(7–10μM) | EPA+Ca^2+^ vs. Ctrl+Ca^2+^
| | | 5–10μM | | | | Added before or after FA | - Prevented or Terminated arrhythmia (n=ND; p<0.05) and the effects were reversible by BSA
| | | Free
| | | DHA | 3 mins | CP | Ambient | Ca^2+^ (7–10μM) | DHA+Ca^2+^ vs. Ctrl+Ca^2+^
| | | 5–10μM | | | | Added before or after FA | - Prevented or Terminated arrhythmia (n=ND; p<0.05) and the effects were reversible by BSA
| | | Free
| | | EPA | 3 mins | CP | Ambient | OUA (0.1mM) | EPA+OUA vs. Ctrl+OUA
| | | 5–10μM | | | | Added before FA | - Terminated contractures/fibrillations (n=ND; p<0.05) and the effects were reversible by BSA
| | | Free
| | | DHA | 3 mins | CP | Ambient | OUA (0.1mM) | DHA+OUA vs. Ctrl+OUA
| | | 5–10μM | | | | Added before FA | - Terminated contractures/fibrillation (n=ND; p<0.05) and the effects were reversible by BSA
| | | Free
| | | ALA | 3 mins | CP | Ambient | None | ALA vs. Ctrl
| | | 5–10μM | | | | | - Decreased beating rate by 40% (mean of the range (n=5; p<0.05) and the effects were reversible by BSA
| | | Free
| | | EPA e.e | 3 mins | CP | Ambient | None | EPAe.e vs. Ctrl
| | | 5–10μM | | | | | - No change in beating rate (n=3; p>0.05)
| | | Free
Kang, 1995a | USA | Rats | EPA | 2–5 mins | BEP | Ambient | None | EPA vs. Ctrl
| G | Neonatal | 10μM | | | | | - Hyperpolarizing RMP by 5±1 mV (n=8, p<0.05). The effect was reversible by BSA (2mg/ml).
| | Ventricular | Free | | | | | - Depolarizing APT by 9±3 mV (n=8, p<0.05). The effect was reversible by BSA (2mg/ml).
| | | | | | | | - Decreased APD_75_ by 21% (n=8, p<0.01)
| | | | | | | | - No change in APA (n=8, p>0.05)
| | | | | | | | - No change in V_max_ (n=8, p>0.05)
| | | | | | | | - Decreased action-potential frequency by 50% after 3 minutes EPA addition (n=8, p<0.05)
| | | | | | | | - Increased the stimulation strengths required to initiate action potentials by 49% (n=ND, p<0.01) Effect was reversible by BSA
Kang, 1995b | USA | Rat | EPA | 5mins | CP | Ambient | ISO (3uM) | EPA+ISO vs. ISO
| G/NP | Neonatal | 5–10μM | | | | Added before or after FA | - Prevented or Terminated arrhythmia within 2–3 mins (n=8; p<0.05)
| | Cardiac | Free | | | | | - Decreased contraction rate (%=ND) (n=5; p=ND)
| | | | | | | | - Effects were reversible by BSA.
Kang, 1995b | USA | Rat | EPA | 5 mins | CP | Ambient | ISO (3uM)+ | EPA+ISO+INDO+BW vs. Ctrl+ISO+INDO+BW
| G/NP | Neonatal | 5–10μM | | | | INDO (20 uM/)+ BW (ND) | - Prevented arrhythmia (n=3; p<0.05)
| | Cardiac | Free | | | | Added before FA
| | | DHA | 5 mins | CP | Ambient | ISO (3uM)+ | DHA+ISO+INDO+BW vs. Ctrl+ISO+INDO+BW
| | | 5–10μM | | | | INDO (20 uM/)+ | - Prevented arrhythmia (n=3; p<0.05)
| | | Free | | | | BW (ND)
| | | | | | | Added before FA
| | | EPA | 5 mins | CP | Ambient | cAMP (250uM) | EPA+cAMP vs. Ctrl+cAMP
| | | 5–10μM | | | | Added after FA | - Terminated arrhythmias w/in 3–5min (n=5; p<0.05)
| | | Free
| | | EPA | 5 mins | CP | Ambient | Cholera toxin | EPA+Cholera toxin vs. Cholera toxin
| | | 8μM | | | | (2ug/ml) (Gs protein activator) | - Decreased beating rate (%=ND) (n=4; p=ND)
| | | Free | | | | | - Effects were reversed by BSA
Kang , 1996 | USA | Rat | EPA | 3–7 mins | CP | Ambient | LPC (5–10 μM) | EPA+LPC vs. Ctrl+LPC
| G | Neonatal | 10–15μM | | | | Added before or 3–5 mins after FA | - Prevented tachycardia and slowed beating rate with 2–3 mins and also terminated arrhythmia (n=5; p<0.05)
| | Cardiac | Free | | | | | - Effects were reversible by BSA
| | | DHA | 3–7 mins | CP | Ambient | LPC (5–10 μM) | DHA+LPC vs. Ctrl+LPC
| | | 10–15μM | | | | Added before FA | - Prevented tachycardia and slowed beating rate with 2–3 mins (n=5; p<0.05)
| | | Free | | | | | - Effects were reversible by BSA
| | | ALA | 3–7 mins | CP | Ambient | LPC (5–10 μM) | ALA+LPC vs. Ctrl+LPC
| | | 10–15μM | | | | Added before FA | - Prevented tachycardia and slowed beating rate with 2–3 mins (n=5; p<0.05)
| | | Free | | | | | - Effects were reversible by BSA
| | | EPA | 3–7 mins | CP | Ambient | PTC (2–10 μM) | EPA+PTC vs. Ctrl+LPC
| | | 10–15μM | | | | Added before or after FA | - Prevented or Terminated occurrence of arrhythmia (n=5;p<0.05)
| | | Free | | | | | - Effects were reversible by BSA
| | | DHA | 3–7 mins | CP | Ambient | PTC (2–10 μM) | DHA+PTC vs. Ctrl+LPC
| | | 10–15μM | | | | Added before or after FA | - Prevented or Terminated occurrence of arrhythmia (n=5;p<0.05)
| | | Free
| | | ALA | 3–7 mins | CP | Ambient | PTC (2–10 μM) | ALA+PTC vs. Ctrl+LPC
| | | 10–15μM | | | | Added before or after FA | - Prevented or Terminated occurrence of arrhythmia (n=5;p<0.05)
| | | Free
| | | EPA | 7mins | CP | Ambient | Ca^2+^ ionophore (5μM) | EPA+ Ca^2+^ vs. Ctrl+ Ca^2+^
| | | 10–15μM | | | | Added before FA | - Prevented or Terminated occurrence of arrhythmia (n=5;p<0.05)
| | | Free
| | | EPA | 3–5mins | CP | Ambient | Electrical pacing (15V) | EPA vs. Ctrl
| | | 15μM | | | | | - Decreased electrical automaticity/ excitability of the cardiac myocyte by 50% (n=7; p<0.01)
| | | Free
Kang , 1996 | USA | Rat | EPA | 7mins | IPIM | Ambient | None | EPA vs. Ctrl
| G | Neonatal | 10–15μM | | | | | - No change in systolic and diastolic (cytosolic) Ca^2+^ (n=6; p>0.05)
| | Cardiac | Free
| | | EPA | 7mins | IPIM | Arr | LPC (5–10 μM) | EPA+LPC vs. Ctrl+LPC
| | | 10–15μM | | | | Added before FA | - Terminated intermittent fluctuation of Ca^2+^ (n=6; p<0.05)
| | | Free
Kang, 1997 | USA | Rats | EPA | 3–4 days | ICH | Ambient | None | EPA vs. Ctrl
| G | Neonatal | 20μM | | | | | - No change in the number of Na+ channels per 10^6^ cell, measured by the binding of [^3^H] BTXB (n=4, p>0.05)
| | Cardiac | Bound
| | | EPA | 3–4 days | ICH | Ambient | MEX (20 uM) | EPA+MEX vs. Ctrl+ MEX
| | | 20μM | | | | | - Decreased the number of Na+ channels per 10^6^ cell by 40% to 50% (n=4, p<0.05)
| | | Bound | | | | | - Decreased the MEX induced increase in cardiac Na^+^ channel expression
Leifert, 1999 | Australia | Rat | DHA | 4 mins | ICU | Ambient | None | DHA vs. Ctrl
| U | Adult | 25μM | | | | | - Decreased INa peak current amplitude by 42% (n=7; p=ND)
| | Ventricular | Free
| | | DHA | 4 mins | ICU | Ambient | None | DHA vs. Ctrl
| | | 25μM | | | | | - Shifted the voltage dependence of I_Na_ activation to more positive potentials as indicated by a decrease in G_mas_ by 35% and a shift of V' to a more positive potentialby 21% (n=5; p<0.01)
| | | Free | | | | | - Shifted the voltage dependence of of I_Na_ inactivation to more negative potentials as indicated by a decrease in I_max_ by 36% and a shift of V' to more hyperpolarized potentials by 30% (n=5; p<0.01)
| | | EPA | 4 mins | ICU | Ambient | None | EPA vs. Ctrl
| | | 25μM | | | | | - Shifted the voltage dependence of I_Na_ activation to more positive potentials as indicated by a decrease in G_mas_ by-30% and a shift of V' to a more positive potential by 26% (n=10; p<0.001)
| | | Free | | | | | - Shifted the voltage dependence of of I_Na_ inactivation to more negative potentials as indicated by a decrease in I_max_ by 35% and a shift of V' to more hyperpolarized potentials by 25% (n=10; p<0.01)
| | | ALA | 4 mins | ICU | Ambient | None | ALA vs. Ctrl
| | | 25μM | | | | | - Shifted the voltage dependence of I_Na_ activation to more positive potentials as indicated by a decrease in G_mas_ by 18% and a shift of V' to a more positive potential by 25% (n=6; p<0.001)
| | | Free | | | | | - Shifted the voltage dependence of of I_Na_ inactivation to more negative potentials as indicated by a decrease in I_max_ by 25% and a shift of V' to more hyperpolarized potentials by 30% (n=6; p<0.01)
Leifert, 2000b | Australia | Rat | DHA | ND | CP | Ambient | ISO (10um) | DHA+ISO vs. Docasanoic Acid+ISO
| U | Adult | 10μM | | | | Added 5 mins after FA | - Decreased spontaneous contractions by 85% (n=5; p<0.01)
| | Ventricular | Free
| | | DHA | ND | CP | Ambient | LPC (10um) | DHA+LPC vs. Stearic Acid+LPC
| | | 10μM | | | | Added 5 mins after FA | - Decrease in spontaneous contractions by 77% (n=4; p<0.01)
| | | Free
Leifert, 2000b | Australia | Rat | DHA | ND | CP | Ambient | Electrical | DHA vs. Stearic Acid
| U | Adult | 10μM | | | | Stimulation (1Hz at 25 V) | - Decrease in asynchronous contractions by 61% (n=4; p<0.05)
| | Ventricular | Free
Li, 1997 | USA | Rat | EPA | ND | CP | Ambient | Eicosanoids | EPA vs. Ctrl
| G | Neonatal | 10μM | | | | PGD2+PGE2+P | - Terminated the arrhythmias and contractures within 2–3 minutes (n=ND, p<0.05), followed by a slow beating rate.
| | Cardiac | Free | | | | GF2 +U46619 (3μm-0.5μM)
Macleod, 1998 | New Zealand | Rat | EPA | 5 mins | CP | Ambient | None | EPA vs. Ctrl
| G/NP | Adult | 1–7.5uM | | | | | - Increased (prolonged) twitch size (%=ND) (n=6–8; p=ND)
| | Ventricular | Free
| | | DHA | 5 mins | CP | Ambient | None | DHA vs. Ctrl
| | | 1–7.5uM | | | | | - Increased (prolonged) twitch size (%=ND) (n=6–8; p=ND)
| | | Free
| | | EPA | 5 mins | CP | Ambient | None | EPA vs. Ctrl
| | | >10M | | | | | - Decreased twitch size (%=ND) (n=6–8; p=ND)
| | | Free
| | | DHA | 5 mins | CP | Ambient | None | DHA vs. Ctrl
| | | >10M | | | | | - Decreased twitch size (%=ND) (n=6–8; p=ND)
| | | Free
| | | EPA | 5 mins | BEP | Ambient | None | EPA vs. Ctrl
| | | 1–7.5uM | | | | | - Dose dependant increase (lengthening of early plateau potential) in ADP_80_ (%=ND) (n=11–14; p=ND)
| | | Free
| | | DHA | 5 mins | BEP | Ambient | None | DHA vs. Ctrl
| | | 1–7.5uM | | | | | - Dose dependant increase (lengthening of early plateau potential) in ADP_80_ (%=ND) (n=11–14; p=ND)
| | | Free
| | | EPA | 5 mins | BEP | Ambient | None | EPA vs. Ctrl
| | | >10M | | | | | - Dose dependant decrease in ADP_80_ (%=ND) (n=11–14; p=ND)
| | | Free
| | | DHA | 5 mins | BEP | Ambient | None | DHA vs. Ctrl
| | | >10M | | | | | - Dose dependant decrease in ADP_80_ (%=ND) (n=11–14; p=ND)
| | | Free
| | | EPA | 5 mins | ICU | Ambient | None | EPA vs. Ctrl
| | | 5,10 or 20uM | | | | | - Dose dependant decrease of the peak amplitude of the I_Na_ (%=ND) (n=6–8; p=ND)
| | | Free
| | | DHA | 5 mins | ICU | Ambient | None | DHA vs. Ctrl
| | | 5,10 or 20uM | | | | | - Dose dependant decrease of the peak amplitude of the I_Na_ (%=ND) (n=6–8; p=ND)
| | | Free
| | | EPA | 5 mins | ICU | Ambient | None | EPA vs. Ctrl
| | | 5,7.5 or 10uM | | | | | - Dose dependant decrease of the peak I_Ca.L_ (%=ND) (n=5–8; p=ND)
| | | Free
Macleod, 1998 | New Zealand | Rat | DHA | 5 mins | ICU | Ambient | None | DHA vs. Ctrl
| G/NP | Adult | 5,7.5 or 10uM | | | | | - Dose dependant decrease of the peak I_Ca.L_ (%=ND) (n=5–8; p=ND)
| | Ventricular | Free
| | | EPA | 5 mins | ICU | Ambient | None | EPA vs. Ctrl
| | | 0.1–10uM | | | | | - Dose dependant decrease of I_to_ (%=ND) (n=5–8; p=ND)
| | | Free
| | | DHA | 5 mins | ICU | Ambient | None | DHA vs. Ctrl
| | | 0.1–10uM | | | | | - Dose dependant decrease of I_to_ (%=ND) (n=5–8; p=ND)
| | | Free
| | | EPA | 5 mins | ICU | Ambient | None | EPA vs. Ctrl
| | | 2um | | | | | - Decreased I_K_ and I_KI_ by 30–40%(n=ND; p=ND)
| | | Free
| | | EPA | 5 mins | ICU | Ambient | None | EPA vs. Ctrl
| | | 5um | | | | | - Decreased I_K_ and I_KI_ by 50–60% (n=ND; p=ND)
| | | Free
| | Guinea Pig | EPA | 5 mins | CP | Ambient | None | EPA vs. Ctrl
| | Adult | 5–20μM | | | | | - Dose dependant decrease in twitch size (%=ND) (n=6–8; p=ND)
| | Ventricular | Free
| | | DHA | 5 mins | CP | Ambient | None | DHA vs. Ctrl
| | | 5–20μM | | | | | - Dose dependant decrease in twitch size (%=ND) (n=6–8; p=ND)
| | | Free
| | | EPA | 5 mins | BEP | Ambient | None | EPA vs. Ctrl
| | | 1–20μM | | | | | - Dose dependant reduction in ADP_80_ (%=ND) (n=12–16; p=ND)
| | | Free
| | | DHA | 5 mins | BEP | Ambient | None | DHA vs. Ctrl
| | | 1–20μM | | | | | - Dose dependant reduction in ADP_80_ (%=ND) (n=12–16; p=ND)
| | | Free
| | | EPA | 5 mins | ICU | Ambient | None | EPA vs. Ctrl
| | | 5,10 or 20μM | | | | | - Dose dependant decrease of the peak amplitude of I_Na_ (%=ND) (n=8–10; p=ND)
| | | Free
| | | DHA | 5 mins | ICU | Ambient | None | DHA vs. Ctrl
| | | 5,10 or 20μM | | | | | - Dose dependant decrease of the peak amplitude of I_Na_ (%=ND) (n=8–10; p=ND)
| | | Free
| | | EPA | 5 mins | ICU | Ambient | None | EPA vs. Ctrl
| | | 5,7.5 or 10μM | | | | | - Dose dependant decrease of the peak I_Ca.L_ (%=ND) (n=6–10; p=ND)
| | | Free
Macleod, 1998 | New Zealand | Guinea Pig | DHA | 5 mins | ICU | Ambient | None | DHA vs. Ctrl
| G/NP | Adult | 5,7.5 or 10μM | | | | | - Dose dependant decrease of the peak I_Ca.L_ (%=ND) (n=6–10; p=ND)
| | Ventricular | Free
| | | EPA | 5 mins | ICU | Ambient | None | EPA vs. Ctrl
| | | 2um | | | | | - Decreased I_K_ and I_KI_ by 10% (n=5–8; p=ND)
| | | Free
| | | EPA | 5 mins | ICU | Ambient | None | EPA vs. Ctrl
| | | 5um | | | | | - Decreased I_K_ and I_KI_ by 30–40% (n=5–8; p=ND)
| | | Free
Negretti, 2000 | Venezuela | Rat | EPA | 3 mins | CP | Ambient | None | EPA vs. Ctrl
| G/NP | Adult | 10μM | | | | | - Increased resting cell length by 2% (n=6, p<0.001).
| | Ventricular | Free | | | | | - Decreased the spontaneous contraction frequency (n=47 out of 57; p<0.001)
| | | | | | | | - Effects were reversible by BSA
| | | EPA | 3 mins | IPIM | Ambient | None | EPA vs. Ctrl
| | | 10μM | | | | | - Decreased the frequency of spontaneous waves of calcium release (n=47 out of 57; p<0.001)
| | | Free | | | | | - Decreased the amplitude of the wave by 16% (n=41, p<0.001)
| | | | | | | | - Effects were reversible by BSA
| | | EPA | 3 mins | IPIM | Ambient | Ca^2+^ (10uM) | EPA vs. Ctrl
| | | 10μM | | | | | - Decreased the basal level of [Ca2+] by 6% (n=46, p<0.005). The effect was reversible by BSA.
| | | Free
| | | EPA | 3 mins | IPIM | Ambient | Caffeine (10mM) | EPA vs. Ctrl
| | | 5μM | | | | | - Increased the SR calcium content indicated by an increase in the caffeine induced Na^+-^Ca^2+^ exchange current by 41% (n=4, p<0.05).
| | | Free
| | | DHA | 3 mins | IPIM | Ambient | Caffeine (10mM) | DHA vs. Ctrl
| | | 5μM | | | | | - Increased the SR calcium content indicated by an increase in the caffeine induced Na^+-^Ca^2+^ exchange current by 41% (n=4, p<0.05).
| | | Free
| | | EPA | 3 mins | ICU | Ambient | None | EPA vs. Ctrl
| | | 10μM | | | | | - Decreased the amplitude of I_Ca.L_ (n=5; p<0.05)
| | | Free
| | | DHA | 3 mins | ICU | Ambient | None | DHA vs. Ctrl
| | | 10μM | | | | | - Decreased the amplitude of I_Ca.L_ (n=5; p<0.05)
| | | Free
O'Neill, 2002 | UK/Venezuela | Rat | EPA | ND | ICU | Ambient | None | EPA vs. Ctrl
| G/NP | ND | 10uM | | | | | - Decreased frequency of transient inward currents that accompany spontaneous waves of CICR by 33% (n=6; p<0.05)
| | Ventricular | Free | | | | | - Increased amplitude of currents activated by each wave by 29% (n-6; p<0.05)
| | | EPA | ND | IPIM | Ambient | None | EPA vs. Ctrl
| | | 10uM | | | | | - Decreased resting cytosolic Ca^2+^ due to decrease Ca^2+^ influx across surface membrane and not due to increased activation of efflux pathways(n=6; p<0.05)
| | | Free
O'Neill, 2002 | UK/Venezuela | Rat | EPA | ND | IPIM | Ambient | None | EPA vs. Ctrl
| G/NP | ND | 10uM | | | | | - Decreased wave frequency activated by Ca2+ efflux (% in fig) (n=6; p<0.01)
| | Ventricular | Free | | | | | - Increased efflux of Ca2+ activated by individual waves by 12% (n=6; p<0.05)
| | | | | | | | - Decreased wave generated efflux per unit time by 19% (n=6; p<0.01)
| | | | | | | | - Decreased total efflux (% in fig) (n=6; p<0.01)
| | | EPA | ND | IPIM | Ambient | Caffeine (10mM/ND) | EPA+Caffeine vs. Ctrl+Caffeine
| | | 10uM | | | | | - No change in surface membrane Ca2+ efflux pathway (n=12; p>0.1)
| | | Free
Pepe, 1994 | USA | Rat | DHA | 4 mins | CP | Ambient | None | DHA vs. Ctrl
| G | Young Adult | 5μM | | | | | - No change in DL (n=6, p>0.05)
| | Cardiac | Free | | | | | - No change in TA_t50_ (n=6, p>0.05)
| | | | | | | | - No change in VS/DL (n=6; p>0.05)
| | | DHA | 4 mins | CP | Ambient | NIT (10nM) | DHA+NIT vs. Ctrl+NIT
| | | 5μM | | | | | - Blocked NIT effect on TA (n=6, p<0.05)
| | | Free | | | | | - Blocked NIT effect on VS/DL (n=6; p<0.05)
| | | | | | | | - Effects were reversible by BSA
| | | DHA | 4 mins | CP | Ambient | BAY (10nM) | DHA+BAY vs. Ctrl+BAY
| | | 5μM | | | | | - Blocked NIT effect on TA (n=6, p<0.05)
| | | Free | | | | | - Blocked NIT effect on VS/DL (n=6; p<0.05)
| | | | | | | | - Effects were reversible by BSA
| | | DHA | 4 mins | CP | Ambient | ISO (0.1–1uM) | DHA+ISO vs. Ctrl+ISO
| | | 5μM | | | | | - No change in TA (n=6, p>0.05)
| | | Free | | | | | - No change in DL (n=6; p>0.05)
| | | | | | | | - Effects were reversible by BSA
| | | DHA | 4 mins | ICU | Ambient | None | DHA vs. Ctrl
| | | 5μM | | | | | - No change in peak I_Ca.L_ amplitude (n=6; p>0.05)
| | | Free
| | | DHA | 4 mins | ICU | Ambient | NIT (10nM) | DHA+NIT vs. Ctrl+NIT
| | | 5μM | | | | | - Increased peak I_Ca.L_ amplitude by 50% (n=6; p<0.05)
| | | Free | | | | | Effects were reversible by BSA
| | | DHA | 4 mins | ICU | Ambient | BAY (10nM) | DHA+BAY vs. Ctrl+BAY
| | | 5μM | | | | | - Blocked the BAY induced increase in peak I_Ca.L_ amplitude (n=6; p<0.05)
| | | Free | | | | | - Effects were reversible by BSA
| | | DHA | 4 mins | ICU | Ambient | ISO (0.1–1uM) | DHA+ISO vs. Ctrl+ISO
| | | 5μM | | | | | - No change in peak I_Ca.L_ amplitude (n=6; p>0.05)
| | | Free
| | | DHA | 4 mins | IPIM | Ambient | None | DHA vs. Ctrl
| | | 5μM | | | | | - No change in IFTA_dias_ and IFR _t50_ indicating no change in cytosolic Ca^2+^ and Cai^2+^ transient amplitude (n=6; p>0.05)
| | | Free
| | | DHA | 4 mins | IPIM | Ambient | NIT (10nM) | DHA+NIT vs. Ctrl+NIT
| | | 5μM | | | | | - Inhibited NIT blockage of the L-type calcium channel influx (n=6; p<0.05)
| | | Free | | | | | - Blocked NIT effect on IFTA_dias_ (n=6; p<0.05)
| | | | | | | | - Effects were reversible by BSA
Pepe, 1994 | USA | Rat | DHA | 4 mins | IPIM | Ambient | BAY (10nM) | DHA+BAY vs. Ctrl+BAY
| G | Young Adult | 5μM | | | | | - Inhibited BAY induced potentiation of L-type calcium channel influx (n=6; p<0.05)
| | Cardiac | Free | | | | | - Blocked BAY effect on IFTA_dias_ (n=6; p<0.05)
| | | | | | | | - Effects were reversible by BSA
| | | DHA | 4 mins | IPIM | Ambient | ISO (0.1–1uM) | DHA+ISO vs. Ctrl+ISO
| | | 5μM | | | | | - No change in ISO induced increase in cytosolic calcium content (n=6; p>0.05)
| | | Free
Phiipson, 1985 | USA | Dog | ALA | 1.5 sec | IPIM | Ambient | Ca^2+^ (10uM) Added before FA | ALA vs. Ctrl
| G | Adult | 30μM | | | | | - Increased Na^+^-Ca^2+^ exchange measured as Na^+^ dependent Ca^2+^ uptake by 112% (n=9, p<0.05)
| | Ventricular | Free | | | | | - Preincubation with ALA to ensure complete incorporation resulted in the maximal stimulation of Na+ dependent Ca2+ influx being about 40% less than when the vesicles were only briefly exposed to ALA.
| | SL vesicles
| | | ALA | 2 mins | IPIM | Ambient | Preloaded Ca^2+^ (47.9 nMl) | ALA vs. Ctrl
| | | 20μM | | | | | - Increased passive Ca2+ efflux by 147% (n=3, p<0.05)
| | | Free
Phiipson, 1987 | USA | Dog | ALA | 1.5 sec | IPIM | Ambient | Ca^2+^ (10uM) | ALA vs. Ctrl
| G | Adult | 60μM | | | | | - Increased Na^+^-Ca^2+^ exchange measured as Na^+^ dependent Ca^2+^ uptake by 87% (n=3, p<0.05)
| | Ventricular | Free
| | SL vesicles
| | | ALA | 2 minutes | IPIM | Ambient | Preloaded Ca^2+^ (52.3 nM) | ALA vs. Ctrl
| | | 30μM | | | | | - Increased passive Ca2+ efflux by 170% (n=4, p<0.05)
| | | Free
Ponsard, 1999 | France | Rat | EPA+DHA-Albumin | 4 days | CP | Ambient | None | EPA+DHA vs. Ctrl
| NP | Neonatal | 4.6+6.5% | | | | | - No change in CR (n=13; p>0.05)
| | Ventricular | Bound | | | | | - No change in CD_20_ (n=13; p>0.05)
| | | | | | | | - No change in CD_80_ (n=13; p>0.05)
| | | | | | | | - No change in +C_max_ (n=13; p>0.05)
| | | | | | | | - No change in -C_max_ (n=13; p>0.05)
| | | EPA+DHA-Albumin | 4 days | CP | Ambient | ISO (10^-7^M) | EPA+DHA+ISO vs. N-6+ISO
| | | 4.6+6.5% | | | | | - Increased CR by 66% (n=7; p<0.05)
| | | Bound | | | | | - No change in CD_20_ (n=7; p>0.05)
| | | | | | | | - No change in CD_80_ (n=7; p>0.05)
| | | | | | | | - No change in +C_max_ (n=7; p>0.05)
| | | | | | | | - No change in -C_max_ (n=7; p>0.05)
| | | EPA+DHA-Albumin | 4 days | CP | Ambient | PHE (10^-6^M) | EPA+DHA+PHE vs. N-6+PHE
| | | 4.6+6.5% | | | | | - Increased CR by 115% (n=6; p<0.05)
| | | Bound | | | | | - No change in CD_20_ (n=6; p>0.05)
| | | | | | | | - No change in CD_80_ (n=6; p>0.05)
| | | | | | | | - No change in +C_max_ (n=6; p>0.05)
| | | | | | | | - No change in -C_max_ (n=6; p>0.05)
Ponsard, 1999 | France | Rat | EPA+DHA-Albumin | 4 days | CP | Normoxia-Posthypoxic Reoxy | ISO (10^-7^M) | EPA+DHA+ISO in Hypoxia vs. EPA+DHA+ISO in Normoxia
| NP | Neonatal | 4.6+6.5% | | | | | - Increased CR (% in fig) (n=6; p<0.001)
| | Ventricular | Bound | | | | | - No change in CD_20_ (n=6; p>0.05)
| | | | | | | | - No change in CD_80_ (n=6; p>0.05)
| | | | | | | | - Increased +C_max_ (%=ND) (n=6; p<0.05)
| | | | | | | | - No change in -C_max_ (n=6; p>0.05)
| | | EPA+DHA-Albumin | 4 days | CP | Normoxia-Posthypoxic Reoxy | PHE (10^-6^M) | EPA+DHA+PHE in Hypoxia vs. EPA+DHA+PHE in Normoxia
| | | 4.6+6.5% | | | | | - No change (n=6; p>0.05)
| | | Bound | | | | | - No change in CD_20_ (n=6; p>0.05)
| | | | | | | | - No change in CD_80_ (n=6; p>0.05)
| | | | | | | | - No change in +C_max_ (n=6; p>0.05)
| | | | | | | | - No change in -C _ax_ (n=6; p>0.05)
Reithman, 1996 | Germany | Rat | DHA | 3 days | BEP | Ambient | None | DHA vs. Ctrl
| U | Neonatal | 60μM | | | | | - Increased amplitude by 20% (n=28–29; p<0.05)
| | Cardiac | Bound | | | | | - No change in APR (n=14–19; p>0.05)
| | | DHA | 3 days | BEP | Ambient | NA + TIM (100μmol/L+10 μmol/L) | DHA+NA+TIM vs. Ctrl+NA+TIM
| | | 60μM | | | | | - Decreased APR by 28% (n=14–19; p<0.05)
| | | Bound
| | | DHA | 3 days | CP | Ambient | NA + TIM (100μmol/L+10 μmol/L) | DHA+NA+TIM vs. Ctrl+NA+TIM
| | | 60μM | | | | | - Decreased arrhythmias by 84% (n=15–28; p<0.01)
| | | Bound
| | | DHA | 3 days | BEP | Ambient | Isoprenaline (10 μmol/L) | DHA+Isoprenaline vs. Ctrl+Isoprenaline
| | | 60μM | | | | | - Decreased APR by 26% (n=10–11; p<0.05)
| | | Bound
| | | DHA | 3 days | BEP | Ambient | OUA (10 μmol/L) | DHA+OUA vs. Ctrl+OUA
| | | 60μM | | | | | - Decreased APR by 16% (n=4 ; p<.05)
| | | Bound
Rinaldi, 2002 | Italy | Rat | DHA | 20 minutes (acute) | IPIM | Ambient | None | DHA vs. Ctrl
| NP | Adult | 10μM | | | | | - No change in basal cytosolic Ca^2+^ levels (n=9; p>0.5)
| | Ventricular | Free
| | | DHA | 3 days (chronic) | IPIM | Ambient | None | DHA vs. Ctrl
| | | 10μM | | | | | - No change in cytosolic Ca^2+^ levels (n=9; p>0.5)
| | | Free
| | | DHA | 20 minutes (acute) | IPIM | Ambient | ET-1 (100nM) | DHA+ET-1 vs. Ctrl
| | | 10μM | | | | | - Increased ET-1 induced cytosolic Ca^2+^ levels by 128% (n=9; p<0.01)
| | | Free
| | | DHA | 3 days (chronic) | IPIM | Ambient | ET-1 (100nM) | DHA+ET-1 vs. Ctrl
| | | 10μM | | | | | - Increased ET-1 induced cytosolic Ca^2+^ by 148% (n=9; p<0.01)
| | | Free
| | | DHA | 20 minutes (acute) | IPIM | Ambient | KCl (50mM) | DHA+KCl vs. Ctrl
| | | 10μM | | | | Added after FA | - Decreased Ca2+by 71% (n=9; p<0.01)
| | | Free
Rinaldi, 2002 | Italy | Rat | DHA | 3 days (chronic) | IPIM | Ambient | KCl (50mM) | DHA+KCl vs. Ctrl+KCl
| NP | Adult | 10μM | | | | Added after FA | - Decreased Ca^2+^ by 48% (n=9; p<0.01)
| | Ventricular | Free
| | | DHA | 20 minutes (acute) | IPIM | Ambient | KCl (50mM) | DHA+ET-1 (chronic) vs. DHA+ET-1 (acute)
| | | 10μM | 3 days (chronic) | | | Added after FA | - Decreased Ca^2+^ by 17% (n=9; p<0.01)
| | | Free
| | | DHA | 20 minutes (acute) | IPIM | Anoxia | 97%N_2_ and 3% CO_2_ | DHA+Anoxic Soln vs. Ctrl
| | | 10μM | | | | | - Decreased Ca^2+^ by 58% (n=9; p<0.01)
| | | Free
| | | DHA | 3 days (chronic) | IPIM | Anoxia | 97%N_2_ and 3% CO_2_ | DHA+Anoxic Soln vs. Ctrl
| | | 10μM | | | | | - Decreased Ca^2+^ by 83% (n=9; p<0.01)
| | | Free
| | | DHA | 20 minutes (acute) | IPIM | Anoxia | 97%N_2_ and 3% CO_2_ | DHA+Anoxic Soln (chronic) vs. DHA+Anoxic Soln (acute)
| | | 10μM | 3 days (chronic) | | | | - Decreased Ca^2+^ by 59% (n=9; p<0.01)
| | | Free
| | | DHA | 20 minutes (acute) | IPIM | Anoxia | 97%N_2_ and 3% CO_2_+ KCl (50mM) | DHA+Anoxic Soln+KCl vs. Ctrl
| | | 10μM | | | | | - Decreased Ca^2+^ (%=ND) (n=9; p<0.01)
| | | Free
| | | DHA | 3 days (chronic) | IPIM | Anoxia | 97%N_2_ and 3% CO_2_+ KCl (50mM) | DHA+Anoxic Soln+KCl vs. Ctrl
| | | 10μM | | | | | - Decreased Ca^2+^ (%=ND) (n=9; p<0.01)
| | | Free
| | | DHA | 20 minutes (acute) | IPIM | Anoxia | 97%N_2_ and 3% CO_2_+ KCl (50mM) | DHA+Anoxic Soln+KCl (chronic) vs. DHA+Anoxic Soln+KCl (acute)
| | | 10μM | 3 days (chronic) | | | | - Decreased Ca^2+^ by 70% (n=9; p<0.01)
| | | Free
| | | DHA | 20 minutes (acute) | IPIM | Anoxia | 97%N_2_ and 3% CO_2_+ ET-1 (100nM) | DHA+Anoxic Soln+ET-1 vs. Ctrl
| | | 10μM | | | | | - Decreased Ca^2+^ (%=ND) (n=9; p<0.01)
| | | Free
| | | DHA | 3 days (chronic) | IPIM | Anoxia | 97%N_2_ and 3% CO_2_+ ET-1 (100nM) | DHA+Anoxic Soln+ET-1 vs. Ctrl
| | | 10μM | | | | | - Decreased Ca^2+^ (%=ND) (n=9; p<0.01)
| | | Free
| | | DHA | 20 minutes (acute) | IPIM | Anoxia | 97%N_2_ and 3% CO_2_+ ET-1 (100nM) | DHA+Anoxic Soln+ET-1 (bound) vs. DHA+Anoxic Soln+ET-1 (free)
| | | 10μM | 3 days (chronic) | | | | - Decreased Ca^2+^ by 70% (n=9; p<0.01)
| | | Free
| | | ALA-Na | 5 mins | CP | Ambient | None | ALA-Na vs. Ctrl
| | | 2mg/kg/min | | | | | - No change in intra-atrial conduction time (AC) (n=7; p>0.05)
| | | Free as IV | | | | | - No change in atrio-ventricular conductance time (AVC) (n=7; p>0.05)
| | | | | | | | - No change in functional refractory period of the atrium (ARP) (n=7; p>0.05)
| | | | | | | | - No change in functional refractory period of atrio-ventricular conducting system (AVRP) (n=7; p>0.05)
Rodrigo, 1999 | New Zealand | Rat | EPA | 10 mins | CP | Ambient | None | EPA vs. Ctrl
| G/NP | Adult | 5μM | | | | | - Decreased twitch contraction size by 70 (n=8; p<0.001)
| | Ventricular | Free | | | | | - Effects were reversible by BSA
| | | EPA | 10 mins | ICU | Ambient | None | EPA vs. Ctrl
| | | 5μM | | | | | - Decreased I_Ca.L_ by 72% (n=8; p<0.001)
| | | Free | | | | | - Effects were reversible by BSA
| | Guinea Pig | EPA | 10 mins | CP | Ambient | None | EPA vs. Ctrl
| | Adult | 5μM | | | | | - Initial increase in twitch contraction size (% cell shortening) followed by a decrease in twitch contraction strength by -88% (n=7; p<0.001)
| | Ventricular | Free | | | | | - Effects were partially reversible by BSA
| | Guinea Pig | EPA | 10 mins | ICU | Ambient | None | EPA vs. Ctrl
| | Adult | 5μM | | | | | - Decreased I_Ca.L_ by 64% (n=11; p<0.001)
| | Ventricular | Free | | | | | - Effects were reversible by BSA
| | Rat | EPA | 10mins | CP + IPIM | Ambient | Ca^2+^ (133–267nM) | EPA+Ca^2+^ vs. Ctrl+Ca^2+^
| | Adult | 5uM | | | | Added before FA | - Decreased frequency of spontaneous contractions (%=ND) (n=5; p<0.05) due to an inhibition of SR Ca^2+^ release
| | Skinned/Saponin Permealized Ventricular | Free | | | | | - No change in degree of relaxation between spontaneous contractions (n=5; p>0.05)
| | | EPA | 10mins | CP+ IPIM | Ambient | Ca^2+^ (133–267nM) | EPA+Ca^2+^ vs. Ctrl+Ca^2+^
| | | 10μM | | | | Added before FA | - Decreased frequency of spontaneous contractions (%=ND) (n=5; p<0.05) due to an inhibition of SR Ca^2+^ release
| | | Free | | | | | - No change in degree of relaxation between spontaneous contractions (n=5; p>0.05)
| | Guinea Pig | EPA | 10 mins | CP | Ambient | Ca^2+^ (133–267nM) | EPA+Ca^2+^ vs. Ctrl+Ca^2+^
| | Adult | 5μM | | | | Added before FA | - Decreased frequency of spontaneous contractions (%=ND) (n=5; p<0.05) due to an inhibition of SR Ca^2+^ release
| | Adult Skinned/ Saponin Permealized Ventricular | Free | | | | | - No change in degree of relaxation between spontaneous contractions (n=5; p>0.05)
Vitelli, 2002 | Italy | Rat | DHA | 20 mins | IPIM | Ambient | Ca^2+^ free KRB (1.8mM) | DHA vs. Ctrl
| U | Adult | 10μM | | | | | - No change in basal level of cytosolic Ca2+ (n=ND; p>0.01)
| | Ventricular | Free
| | | DHA | 20 mins | IPIM | Ambient | CaCl_2_ KRB (1.8mM) | DHA vs. Ctrl
| | | 10μM | | | | | - No change in basal level of cytosolic Ca2+ (n=ND; p>0.01)
| | | Free
Vitelli, 2002 | Italy | Rat | DHA | 20 mins | IPIM | Ambient | DXR (100uM) | DHA+DXR vs. Ctrl+DXR
| U | Adult | 10μM | | | | Added after FA | - Decreased peak level of Ca^2+^ (n=ND; p<0.01)
| | Ventricular | Free | | | | Ca^2+^ free KRB (1.8mM) | DHA+DXR vs. Ctrl
| | | | | | | | - No change in peak level of Ca^2+^ (n=ND; p>0.05)
| | | | | | | | DHA+DXR vs. DHA
| | | | | | | | - No change in peak level of Ca^2+^ (n=ND; p>0.05)
| | | DHA | 20 mins | IPIM | Ambient | DXR (100uM) | DHA+DXR vx Ctrl+DXR
| | | 10μM | | | | Added after FA | - Decreased peak level of Ca^2+^ (n=9; p<0.01)
| | | Free | | | | CaCl_2_ KRB (1.8mM) | DHA+DXR vs. Ctrl
| | | | | | | | - No change in peak level of Ca^2+^ (n=9; p>0.05)
| | | | | | | | DHA+DXR vs. DHA
| | | | | | | | - No change in peak level of Ca^2+^ (n=9; p>0.05)
| | | DHA | 20 mins | IPIM | Ambient | Caff (10mM) | DHA+Caff vx Ctrl+Caff
| | | 10μM | | | | Added after FA | - Decreased peak level of Ca^2+^ (n=9; p<0.01)
| | | Free | | | | Ca^2+^ free KRB (1.8mM) | DHA+DXR vs. Ctrl
| | | | | | | | - No change in peak level of Ca^2+^ (n=9; p>0.05)
| | | DHA | 20 mins | IPIM | Ambient | Caff (10mM) | DHA+Caff vx Ctrl+Caff
| | | 10μM | | | | Added after FA | - Decreased peak level of Ca^2+^ (n=9; p<0.01)
| | | Free | | | | CaCl_2_ KRB (1.8mM) | DHA+DXR vs. Ctrl
| | | | | | | | - No change in peak level of Ca^2+^ (n=9; p>0.05)
Weylandt, 1996 | USA | Rat | EPA | 48 hrs | CP | Ambient | ISO (3–10uM) | EPA+ISO vs. Ctrl+ISO
| G | Neonatal | 15μM | | | | | - No change in arrhythmias (n=51–107; p=ND)
| | Cardiac | DHA | | | | | EPA+ISO vs. DHA+ISO
| | | 15μM | | | | | - No change in arrhythmias (n=51–107; p>0.1)
| | | Bound
| | | DHA | >48 hrs | CP | Ambient | ISO (3–10uM) | DHA+ISO vs. Ctrl+ISO
| | | 15μM | | | | | - No change in arrhythmias (n=13–51; p>0.1)
| | | Bound
| | | EPA | 48 hrs | CP | Ambient | Ca^2+^ (7mM) | EPA+ Ca^2+^ vs. Ctrl+ Ca^2+^
| | | 15μM | | | | | - No change in arrhythmias (n=14–20; p>0.1)
| | | DHA | | | | | EPA+Ca^2+^ vs.DHA+Ca^2+^
| | | 15μM | | | | | - No change in arrhythmias (n=6–14; p>0.1)
| | | Bound
| | | DHA | 48 hrs | CP | Ambient | Ca^2+^ (7mM) | DHA+Ca^2+^ vs. Ctrl+Ca^2+^
| | | 15μM | | | | | - No change in arrhythmias (n=6–20; p>0.1)
| | | Bound
| | | DHA | 3–12mins | CP | Ambient | ISO (3–10uM) | DHA+ISO vs. Ctrl+ISO
| | | 15μM | | | | Added before FA | - Terminated arrhythmias (n=8; p<0.05)
| | | Free
| | | EPA | 3–12mins | CP | Ambient | ISO (3–10uM) | EPA+ISO vs. Ctrl+ISO
| | | 15μM | | | | Added before FA | - Terminated arrhythmias (n=8; p<0.05)
| | | Free
Weylandt, 1996 | USA | Rat | DHA | 3–12mins | CP | Ambient | ISO (3–10uM) | DHA vs. DHA+ISO
| G | Neonatal | 15μM | 48 hrs | | | Added before FA | - Terminated arrhythmias (n=23; p<0.05)
| | Cardiac | Bound | | | | | EPA vs. EPA+ISO
| | | EPA | | | | | - Terminated arrhythmias (n=23; p<0.05)
| | | 15μM
| | | Free
| | | DHA or EPA | 3–12mins | CP | Ambient | Ca^2+^ (7mM)) | DHA+Ca^2+^ vs. Ctrl+Ca^2+^
| | | 15μM | | | | | - Decreased arrhythmias by -83% (n=12; p<0.05)
| | | Free | | | | | EPA vs. Ctrl+Ca^2+^
| | | | | | | | - Decreased arrhythmias by -83% (n=12; p<0.05)
| | | DHA or EPA | 3–12mins | CP | Ambient | Ca^2+^ (7mM) | DHA (free) vs. DHA (bound)+Ca^2+^
| | | 15μM | 48 hrs | | | | - Decrease in arrhythmias by -90% (n=10; p<0.05)
| | | Bound | | | | | EPA (free) vs. EPA (bound)+Ca^2+^
| | | DHA or EPA | | | | | - Decrease in arrhythmias by -90% (n=10; p<0.05)
| | | 15μM
| | | Free
Xiao, 1995 | USA | Rat | EPA | ND | ICU | Ambient | None | EPA vs. Ctrl
| G | Neonatal | 5–10μM | | | | | - Suppressed voltage activated Na^+^ currents within 2mins which was reversible by BSA (n=6; p<0.05)
| | Ventricular | Free | | | | | - No change in current-voltage relations or in the activation and inactivation time constants of Na^+^ current (n=10; p>0.05)
| | | EPA | ND | ICU | Ambient | None | EPA vs. Ctrl
| | | 10–40μM | | | | | - Suppressed Na^+^ current by 68% to 99% with 10um and 40um EPA respectively indicating a dose dependent effect (n=4–10; p<0.05)
| | | Free
| | | EPA | ND | ICU | Ambient | None | EPA vs..Ctrl
| | | 10μM | | | | | - Modified the voltage dependence of the steady state inactivation of I_Na_ (n=7; p<0.001). Inhibition of 83% at -80mV and 29% at -150mV indicating a voltage dependent effect. Application of a train of stimulating pulses at freq.l of 1.0, 0.2, 0.1, or 0.03 Hz had no effect on time required to attain same level of inhibition of I_Na_ independent of concentration (n=5; p>0.05) (time and dose but not use dependent effect)
| | | Free
| | | EPA | ND | ICU | Ambient | None | EPA vs. Ctrl
| | | 5μM | | | | | - Inhibition of I_Na_ by 51% (n=10; p<0.01)
| | | Free
| | | DHA | | | | | DHA vs. Ctrl
| | | 5μM | | | | | - Inhibition of I_Na_ by 52% (n=7; p<0.01)
| | | Free
| | | EPA | ND | ICU | Ambient | None | EPA vs. Ctrl
| | | 10μM | | | | | - Inhibition of I_Na_ by 64% (n=21; p<0.001)
| | | Free
Xiao, 1995 | USA | Rat | DHA | ND | ICU | Ambient | None | DHA vs. Ctrl
| G | Neonatal | 10μM | | | | | - Inhibition of I_Na_ by 66% (n=7; p<0.05)
| | Ventricular | Free
| | | ALA | ND | ICU | Ambient | None | ALA vs. Ctrl
| | | 10μM | | | | | - Inhibition of I_Na_ by 71% (n=5; p<0.05)
| | | Free
| | | EPA | ND | ICU | Ambient | None | EPA vs. Ctrl
| | | 15μM | | | | | - Decreased I_Ca,L_ by 50% (n=11; p<0.05) and effects were partially reversible by BSA
| | | Free | | | | | - No change in shape of current voltage relationship (n=11; p>0.05)
| | | | | | | | - Negative shift (3.33+/-0.4 mV) of the I_Ca,L_ inactivation curve (n=11; p<0.05) and effects were reversible by BSA
Xiao, 1997 | USA | Rat | EPA | ND | ICU | Ambient | None | EPA vs. Ctrl
| G | Neonatal | 0.1–40μM | | | | | - Time and dose dependant decrease in I_Ca,L_ within seconds (n=6; p<0.05)
| | Ventricular | Free | | | | | I_Ca,L_ was almost completely inhibited when the concentration of EPA was above 5 uM
| | | EPA | ND | ICU | Ambient | None | EPA vs. Ctrl
| | | 1μM | | | | | - Decreased I_Ca,L_ by 33% when elicited from the holding potential -40 to 0mV than from -80 to 0mV indicating a voltage dependent effect (n=6; p<0.05)
| | | Free | | | | | Effect was also time but not frequency or use-dependent (n=4; p>0.05)
| | | EPA | ND | ICU | Ambient | None | EPA vs. Ctrl
| | | 5μM | | | | | - Inhibition of I_Ca,L_ by 83% (n=5; p<0.01)
| | | Free | | | | | - EPA, DHA and ALA had similar effects on the steady-state inactivation of the calcium cannel (approx 3 to 5 mV shift to negative potentials a the V1/2 point)
| | | DHA | ND | ICU | Ambient | None | DHA vs. Ctrl
| | | 5μM | | | | | - Inhibition of I_Ca,L_ by 62% (n=6; p<0.01)
| | | Free
| | | ALA | ND | ICU | Ambient | None | ALA vs. Ctrl
| | | 5μM | | | | | - Inhibition of I_Ca,L_ by 77% (n=5; p<0.01)
| | | Free
| | | EPA | ND | ICU | Ambient | None | EPA vs. Ctrl
| | | 1μM | | | | | - Suppression of I_Ca,L_ by 57% (n=5; p<0.01)
| | | Free
| | | EPA | ND | ICU | Ambient | None | EPA vs.. Ctrl
| | | 5μM | | | | | - Suppression of I_Ca,L_ by 47% (n=8; p<0.01)
| | | Free
| | | EPA | ND | IPIM | Ambient | None | EPA vs. Ctrl
| | | 1.5μM | | | | | - Decreased the calcium transients induced by I_Ca,L_ (n=ND; p<0.01)
| | | Free
| | | EPA | ND | ICU | Ambient | None | EPA vs. Ctrl
| | | 15μM | | | | | - Decreased the calcium transients induced by I_Ca,L_ (n=ND; p<0.01)
| | | Free | | | | | - Decreased SR Ca^2+^ release (n=ND; p<0.05)
| | | | | | | | - No change in time constant of decay (tau) or temporal and spatial spread of the calcium sparks (n 33–46; p>0.05) indicating no direct action of EPA on SR Ca^2+^ release or re-uptake
Xiao, 2002 | USA | Ferret | DHA | ND | ICU | Ambient | None | DHA vs. Ctrl
| G/NP | Adult | 10μM | | | | | - Decreased I_k_ by 62%–69% (n=7–12; p<0.05)
| | Atrial | Free
| | Ferret | DHA | ND | ICU | Ambient | None | DHA vs. Ctrl
| | Adult | 0.2–50μM | | | | | - Dose dependant decrease in I_k_ (% in fig) (n=6; p<0.05)
| | Ventrlcular | Free
| | | DHA | ND | ICU | Ambient | None | DHA vs. Ctrl
| | | 5μM | | | | | - Decreased I_k_ by 31% (n=12; p<0.05)
| | | Free | | | | | - No change in I_KI_ (n=6; p>0.05)
| | | DHA | ND | ICU | Ambient | None | DHA vs. Ctrl
| | | 10μM | | | | | - Decreased I_k_ by 42% regardless of holding potential (n=8; p<0.05)
| | | Free | | | | | - Decreased I_to_ by 57% (n=7; p<0.001)
| | | | | | | | - No change in I_KI_ (n=5; p>0.05)
| | | DHA | ND | ICU | Ambient | None | DHA vs. Ctrl
| | | 20μM | | | | | - Decreased I_k_ by 50% (n=6; p<0.01)
| | | Free | | | | | No change in I_KI_ (n=2; p>0.05)
| | | DHA | ND | ICU | Ambient | None | DHA vs. Ctrl
| | | 50μM | | | | | - Decreased I_k_ by 61% (n=11; p<0.001)
| | | Free
| | | EPA | ND | ICU | Ambient | None | EPA vs. Ctrl
| | | 5μM | | | | | - Decreased I_k_ by 26% (n=6; p<0.05)
| | | Free
| | | EPA | ND | ICU | Ambient | None | EPA vs. Ctrl
| | | 10μM | | | | | - Decreased I_k_ by 40% (n=8; p<0.001)
| | | Free | | | | | - Decreased I_to_ by 67% (n=4; p<0.01)
| | | | | | | | - No change in I_KI_ (n=ND; p>0.05)
| | | ALA | ND | ICU | Ambient | None | ALA vs. Ctrl
| | | 5μM | | | | | - Decreased I_k_ by 22% (n=7; p<0.01)
| | | Free
| | | ALA | ND | ICU | Ambient | None | ALA vs. Ctrl
| | | 10μM | | | | | - Decreased I_k_ by 46% (n=8; p<0.001)
| | | Free | | | | | - Decreased I_to_ by 49% (n=4; p<0.05)
| | | | | | | | - No change in I_KI_ (n=ND; p>0.05)
| | | DHA | ND | ICU | Ambient | Sta (0.1μmol/L) | DHA+Sta vs. Ctrl+Sta
| | | 10μM | | | | Added before FA | - Decreased I_k_ by 65% (n=5; p<0.05)
| | | Free