# Appendixes

Appendix A

Appendix B

Appendix C

Appendix D Peer Reviewers