# Summary Matrix

Summary Matrix 1: Study quality and applicability of RCT evidence regarding respiratory outcomes*

Summary Matrix 1: Study quality and applicability of RCT evidence regarding respiratory outcomes*

| | Quality
| | A | | | B | | | C
Applicability | I | | | | Author | Year | N
| | | | | Kirsch | 1988 | 12
| II
| | Author | Year | N | Author | Year | N | Author | Year | N
| | Arm | 1988 | 25 | McDonald | 1991 | 15 | Okamoto | 2000a | 14
| III | Emelyanov | 2002 | 46 | Hodge^†^ | 1998 | 45 | Stenius-Aarniala | 1989 | 36
| | Nagakura^†^ | 2000 | 30
| | Thien | 1993 | 37

N = number of randomized participants;

* Dry, 1991 (total quality grade: C) not entered since received an “X” (insufficient information) for applicability;

† Pediatric trial

Summary Matrix 2: Study quality and applicability of evidence regarding respiratory outcomes from study designs other than an RCT

Summary Matrix 2: Study quality and applicability of evidence regarding respiratory outcomes from study designs other than an RCT

| | Quality
| | A | | | B | | | C
Applicability | I | | | | Author | Year | N
| | | | | Broughton | 1997 | 26
| II
| | Author | Year | N | Author | Year | N | Author | Year | N
| | Masuev | 1997b | 8 | Ashida | 1997 | 5 | Gorelova* | 1998 | 33
| III | Okamoto | 2000b | 26 | Hashimoto | 1977 | 8
| | Picado | 1988 | 10 | Machura | 1996 | 60
| | Villani | 1998 | 7

N = number of randomized participants;

* Pediatric trial

Summary Matrix 3: Study quality and applicability of RCT evidence regarding mediators of inflammation

Summary Matrix 3: Study quality and applicability of RCT evidence regarding mediators of inflammation

| | Quality
| | A | | | B | | | C
Applicability | I | | | | Author | Year | N
| | | | | Kirsch | 1988 | 12
| II
| | Author | Year | N | Author | Year | N | Author | Year | N
| III | Arm | 1988 | 25 | Hodge* | 1998 | 45 | Okamoto | 2000a | 14
| | | | | | | | Stenius-Aarniala | 1989 | 36

N = number of randomized participants;

* Pediatric trial

Summary Matrix 4: Study quality and applicability of evidence regarding mediators of inflammation from study designs other than an RCT

Summary Matrix 4: Study quality and applicability of evidence regarding mediators of inflammation from study designs other than an RCT

| | Quality
| | A | | | B | | | C
Applicability | I | | | | Author | Year | N
| | | | | Broughton | 1997 | 26
| II
| | Author | Year | N | Author | Year | N | Author | Year | N
| III | Okamoto | 2000b | 26 | Ashida | 1977 | 5 | Masuev | 1997a | 34
| | Picado | 1988 | 10 | Hashimoto | 1977 | 8

N = number of randomized participants

Summary Matrix 5: Study quality and applicability of observational study evidence regarding primary prevention

Summary Matrix 5: Study quality and applicability of observational study evidence regarding primary prevention

| | Quality
| | A | | | B | | | C
Applicability | I
| II | | | | Author | Year | N
| | | | | Troisi* | 1995 | 1446
| | Author | Year | N | Author | Year | N | Author | Year | N
| III | Satomi | 1994 | 706 | Huang | 2001a | 36 | Hodge | 1996 | 71
| | | | | Takemura | 2002 | 1673

N = number of randomized participants

* Adults (nurses) only