# Summary Tables

Summary Table 1: RCT evidence of omega-3 fatty acids to improve respiratory outcomes in asthma

Summary Table 1: RCT evidence of omega-3 fatty acids to improve respiratory outcomes in asthma

Author, Year, Location | Omega-3 Fatty Acid Arm/Phase | | Comparator Arm/Phase | | # of S Unique Results Favoring Omega-3 Fatty Acids | Jadad Total Quality / Allocation Concealment (Internal Validity) | Applicability (External Validity)
| n | Type & Dose/Day | n | Type & Dose/Day
ADULTS
Arm, 1988, England^56,^ ^57^ | NR | 3.2 g EPA + 2.2 g DHA | NR | Olive oil (NR) | 1/9 | 4 (Grade: A)/unclear | III
Emelyanov, 2002, Russia^69^ | 23 | 200 mg EPA+DHA + 400 mg olive oil | 23 | 600 mg olive oil | 4/7 | 5 (Grade: A)/ unclear | III
Kirsch, 1988, USA^54,^ ^55^ | 6 | 4.0 g EPA ethyl ester (trace DHA) | 6 | 0.1 g EPA ethyl ester (trace DHA) | 0/6 | 3 (Grade: B)/unclear | I
McDonald, 1991, Australia^58^* | 15 | 2.7 g EPA + 1.8 g DHA | 15 | 15 g olive oil | 0/4 | 3 (Grade: B)/unclear | III
Okamoto, 2000a, Japan^66^ | 7 | 10–20 g perilla seed oil (ALA: NR) | 7 | 10–20 g corn oil | 4/4 | 2 (Grade: C)/unclear | III
Stenius-Aarniala, 1989, Finland^68^* | 36 | 20 mL fish oil (EPA+DHA: NR) | 36 | (1) 20 mL olive oil | 0/2 | 2 (Grade: C)/unclear | III
| | | | (2) 20 mL evening primrose oil
Thien, 1993, England^67^ | NR | 3.2 g EPA + 2.2 g DHA | NR | Olive oil (NR) | 0/6 | 4 (Grade: A)/unclear | III
CHILDREN
Hodge, 1998, Australia^52^ | NR | 0.72 g EPA 0.48 g DHA + ALA (NR) via canola diet | NR | Omega-6 fatty acids: 1.8 g safflower oil + 1.8 g palm oil + 0.4 g olive oil + sunflower diet (NR) | 0/3 | 3 (Grade: B)/unclear | III
Nagakura, 2000, Japan^64^ | 15 | 17.0–26.8 mg/kg EPA; 7.3–11.5 mg/kg DHA (300 mg fish oil) | 15 | 300 mg olive oil | 2/2 | 4 (Grade: A)/unclear | III
NOT REPORTED
Dry, 1991, France^65^ | NR | 1.0 g EPA+DHA | NR | “Placebo” (NR) | 1/1 | 2 (Grade: C)/unclear | X

n = number of enrolled participants; NR = not reported; S = significant;

* Crossover trial

Summary Table 2: Evidence from other study designs of omega-3 fatty acids to improve respiratory outcomes in asthma

Summary Table 2: Evidence from other study designs of omega-3 fatty acids to improve respiratory outcomes in asthma

Author, Year, Location | Omega-3 Fatty Acid Cohort/Phase | | Comparator Cohart/Phase | | # of S Unique Results Favoring Omega-3 Fatty Acids | Total Quality (Internal Validity) | Applicability (External Validity)
| n | Type & Dose/Day | n | Type & Dose/Day
ADULTS
Ashida, 1997, Japan^59^ ^†^ | 5 | 15 g perilla seed oil (ALA: NR) | NA | NA | 3/3 | 3 (Grade: B) | III
Broughton, 1997, USA^73^ ^†^ | 26 | “Low” EPA + DHA intake: ~0.7 g (mean) | 26 | “High” EPA + DHA intake: ~3.3 g (mean) | 5/16 | 3 (Grade: B) | I
Hashimoto, 1997, Japan^62^ ^†^ | 8 | 1.8 g EPA | NA | NA | 5/7 | 3 (Grade: B) | III
Masuev, 1997b, Russia^61^ ^††^ | 5 | 6.0 g EPA+DHA | 3 | 6.0 g olive oil | 1/1 | 4 (Grade: A) | III
Okamoto, 2000b, Japan^71^ ^†^ | 26 | 10–20 g of perilla seed oil (ALA: NR) | NA | NA | 5/5 | 4 (Grade: A) | III
Picado, 1988, Spain^74^ ^†^ | 10 | 3.0 g EPA+DHA + eucaloric diet | 10 | 3.0 g lactose + eucaloric diet | 3/4 | 5 (Grade: A) | III
Villani, 1998, Italy^72^ ^†^ | 7 | 3.0 g EPA+DHA (1:1 ratio) | NA | NA | 3/7 | 4 (Grade: A) | III
CHILDREN
Gorelova, 1998, Russia^70^ ^††^ | 23 | 4.5 g fish oil (NR) + hypo-allergenic diet | 10 | Control (NR) + hypo-allergenic diet | 1/1 | 2 (Grade: C) | III
Machura, 1996, Poland^^63^††^ | 37 | 3.0 g EPA+DHA (15 mL fish oil) | 23 | 15 mL sunflower oil | 2/6 | 3 (Grade: B) | III

n = number of enrolled participants; NR = not reported; NA = not applicable; S = significant;

† Noncomparative case series;

†† non-RCT

Summary Table 3: An indirect assessment of the impact of effect modifiers on the value of omega-3 fatty acids to improve four respiratory outcomes in asthma, organized by research design

Summary Table 3: An indirect assessment of the impact of effect modifiers on the value of omega-3 fatty acids to improve four respiratory outcomes in asthma, organized by research design

| Omega-3 Fatty Acid Arm/Phase | | Comparator Arm/Phase
Author, Year, Location | n | Type & Dose/Day | n | Type & Dose/Day | Results Favoring Omega-3 Fatty Acids | Research Design | Applicability (External Validity)
ADULTS
Arm, 1988, England^56,^ ^57^ | NR | 3.2 g EPA + 2.2 g DHA | NR | Olive oil (NR) | NS: AM PEF | RCT | III
| | | | | NS: PM PEF
| | | | | NS: BDU
Dry, 1991, France^65^* | NR | 1.0 g EPA+DHA | NR | “Placebo” (NR) | S: FEV_1_ | RCT | X
Emelyanov, 2002, Russia^69^ | 23 | 200 mg EPA+DHA + 400 mg olive oil | 23 | 600 mg olive oil | S: AM PEF | RCT | III
| | | | | S: BDU
| | | | | NS: FEV_1_
| | | | | NS: PM PEF
Kirsch, 1988, USA^54,^ ^55^ | 6 | 4.0 g EPA ethyl ester (trace DHA) | 6 | 0.1 g EPA ethyl ester (trace DHA) | NS: FEV_1_ | RCT | I
McDonald, 1991, Australia^58^ | 15 | 2.7 g EPA + 1.8 g DHA | 15 | 15 g olive oil | NS: AM PEF | RCT, 2-phase crossover | III
| | | | | NS: PM PEF
| | | | | NS: BDU
Okamoto, 2000a, Japan^66^ | 7 | 10–20 g perilla seed oil (ALA: NR) | 7 | 10–20 g corn oil | S: FEV_1_ | RCT | III
| | | | | S: AM PEF
Stenius-Aarniala, 1989, Finland^68^ | 36 | 20 mL fish oil (EPA+DHA: NR) | 36 | (1) 20 mL olive oil | NS: AM PEF | RCT, 3-phase crossover | III
| | | | (2) 20 mL evening primrose oil | NS: PM PEF
Thien, 1993, England^67^ | NR | 3.2 g EPA + 2.2 g DHA | NR | Olive oil (NR) | NS: AM PEF | RCT | III
| | | | | NS: PM PEF
| | | | | NS: BDU
Ashida, 1997, Japan^59^ | 5 | 15 g perilla seed oil (ALA: NR) | NA | NA | S: AM PEF | Non-comparative case series | III
| | | | | S: PM PEF
Hashimoto, 1997, Japan^62^ | 8 | 1.8 g EPA | NA | NA | S: AM PEF | Non-comparative case series | III
Picado, 1988, Spain^74^ | 10 | 3.0 g EPA+DHA + eucaloric diet | 10 | 3.0 g lactose + eucaloric diet | S: AM PEF | Non-comparative case series (placebo, then fish oil) | III
| | | | | NS: BDU^†^
Villani, 1998, Italy^72^ | 7 | 3.0 g EPA+DHA (1:1 ratio) | NA | NA | NS: AM PEF | Non-comparative case series | III

n = number of enrolled/randomized participants; NR = not reported; NA = not applicable; S = significant; NS = nonsignificant; BDU = bronchodilator use;

* Age not reported

† S greater BDU in last 2 weeks within the omega-3 fatty acids phase

Summary Table 4: RCT evidence of omega-3 fatty acids to influence mediators of inflammation in asthma

Summary Table 4: RCT evidence of omega-3 fatty acids to influence mediators of inflammation in asthma

| Omega-3 Fatty Acid Arm/Phase | | Comparator Arm/Phase
Author, Year, Location | n | Type & Dose/Day | n | Type & Dose/Day | # of S Unique Results Favoring Omega-3 Fatty Acids | Jadad Total Quality/Allocation Concealment (Internal Validity) | Applicability (External Validity)
ADULTS
Arm, 1988, England^56,^ ^57^ | NR | 3.2 g EPA + 2.2 g DHA | NR | Olive oil (NR) | 3/5 | 4 (Grade: A)/unclear | III
Kirsch, 1988, USA^54,^ ^55^ | 6 | 4.0 g EPA ethyl ester (trace DHA) | 6 | 0.1 g EPA EPA ethyl ester (trace DHA) | 9/17 | 3 (Grade: B)/unclear | I
Okamoto, 2000a, Japan^66^ | 7 | 10–20 g perilla seed oil (ALA: NR) | 7 | 10–20 g corn oil | 2/2 | 2 (Grade: C)/ unclear | III
Stenius-Aarniala, 1989, Finland^68^* | 36 | 20 mL fish oil (EPA+DHA: NR) | 36 | (1) 20 mL olive oil | 2/8 | 2 (Grade: C)/unclear | III
| | | | (2) 20 mL evening primrose oil
CHILDREN
Hodge, 1998, Australia^52^ | NR | 0.72 g EPA 0.48 g DHA + ALA (NR) via canola diet | NR | Omega-6 fatty acids: 1.8 g safflower oil + 1.8 g palm oil + 0.4 g olive oil + sunflower oil diet (NR) | 0/1 | 3 (Grade: B)/unclear | III

N = number of randomized participants; NR = not reported; S = significant;

* Crossover trial

Summary Table 5: Evidence from other study designs of omega-3 fatty acids to influence mediators of inflammation in asthma

Summary Table 5: Evidence from other study designs of omega-3 fatty acids to influence mediators of inflammation in asthma

| Omega-3 Fatty Acid Cohort/Phase | | Comparator Cohort/Phase
Author, Year, Location | n | Type & Dose/Day | n | Type & Dose/Day | # of S Unique Results Favoring Omega-3 Fatty Acids | Total Quality (Internal Validity) | Applicability (External Validity)
Ashida, 1997, Japan^59^ ^†^ | 5 | 15 g perilla seed oil (ALA: NR) | NA | NA | 2/2 | 3 (Grade: B) | III
Broughton, 1997, USA^73^ ^†^ | 26 | “Low” EPA+ DHA intake: ~0.7 g (mean) | 26 | “High” EPA+ DHA intake: ~3.3 g (mean) | 4/7 | 3 (Grade: B) | I
Hashimoto, 1997, Japan^62^ ^†^ | 8 | 1.8 g EPA | NA | NA | 0/2 | 3 (Grade: B) | III
Masuev, 1997a, Russia^60^ ^††^ | 27 | 6.0 g eiconol: EPA+DHA (NR) | 7 | 6.0 g olive oil | 1/1 | 2 (Grade: C) | III
Okamoto, 2000b, Japan^71^ ^†^ | 26 | 10–20 g perilla seed oil (ALA: NR) | NA | NA | 1/1 | 4 (Grade: A) | III
Picado, 1988, Spain^74^ ^†^ | 10 | 3.0 g EPA+DHA + eucaloric diet | 10 | 3.0 g lactose + eucaloric diet | 1/1 | 5 (Grade: A) | III

n = number of enrolled participants; NR: not reported; NA = not applicable; S = significant;

† Noncomparative case series;

†† non-RCT

Summary Table 6: RCT evidence of omega-3 fatty acids to prevent asthma in children

Summary Table 6: RCT evidence of omega-3 fatty acids to prevent asthma in children

| Omega-3 Fatty Acid Group | | Comparator Group
Author, Year, Location | n | Type & Dose/Day | n | Type & Dose/Day | # of S Unique Results Favoring Omega-3 Fatty Acids | Jadad Total Quality/Allocation Concealment (Internal Validity) | Applicability (External Validity)
Mihrshahi, 2003, Australia^50,^ ^51^ | 312 | 0.8 mg EPA + 3.6 mg DHA per kg body weight (500 mg fish oil) + canola oil/margarine (ALA: NR) | 304 | 500 mg Sunola oil + PUFA oils/margarine | 2/10 | 2 (Grade:C)/adequate | III

n=number of randomized participants; S = significant; PUFA = polyunsaturated fatty acids

Summary Table 7: Observational study evidence of omega-3 fatty acids for primary prevention of asthma

Summary Table 7: Observational study evidence of omega-3 fatty acids for primary prevention of asthma

Author, Year, Location | Number with asthma | Types of Control (n) | Unadjusted or Adjusted Associations of Dietary Fish Intake and Asthma Prevalence | Study Quality (Internal Validity) | Applicability (External Validity)
ADULTS
Troisi, 1995, USA^75^ | 1446 | NA | • NS relationship between 6-y risk of asthma and frequency of intake of dark meat fish | 3 (Grade: B) | II
| | | • NS adjusted risk reduction associated with all levels of omega-3 fatty acid intake
ADOLESCENTS
Huang, 2001, Taiwan^48,^ ^49^ | 36 | • Allergic rhinitis (n=115) | • S association between higher frequencies of oily fish intake and asthma prevalence | 3 (Grade: B) | III
| | • No asthma or rhinitis (n=1,030)
ADOLESCENTS & CHILDREN
Takemura, 2002, Japan^76^ | 1673 | • Not currently asthmatic (n=22,109) | • S higher asthma prevalence (adjusted) for consumers of 1-2 fish meals/wk than for consumers of 1-2/mo (overall, and only in males) | 3 (Grade: B) | III
CHILDREN
Hodge, 1996, Australia^77^ | 71 | • Normal airways (n=263) | • S lower (unadjusted) risk of asthma in eaters of fresh fish and oily fresh fish | 2 (Grade: C) | III
| | • Airways hyper-responsiveness only (n=55) | • S lower (adjusted) risk of asthma in consumers of oily fish
| | • Wheeze only (n=79)
Satomi, 1994, Japan^78^ | 706 | • Not asthmatic (n=6,882) | • S negative correlation between asthma prevalence and frequency of fish consumption (e.g., reddish fish) | 4 (Grade: A) | III

n = number of evaluated participants; NA = not applicable; S = significant; NS = nonsignificant

Summary Table 8: Studies reporting adverse events, side effects, and counter-indications

Summary Table 8: Studies reporting adverse events, side effects, and counter-indications

| Omega-3 Fatty Acid Arm/Phase | | Comparator Arm/Phase
Author, Year, Location | n | Type & Dose/ Day | n | Type & Dose/Day | Safety data
ADULTS
Arm, 1988, England^56,^ ^57^ ^†^ | NR | 3.2 g EPA + 2.2 g DHA | NR | Olive oil (NR) | Withdrew (timing: NR): size & number of capsules not tolerable (n=3; arm: NR); Withdrew after 3 wk (omega-3 fatty acids): hospitalized for acute asthma (n=1)
Broughton, 1997, USA^73^ ^††^ | 26 | ‘Low’ EPA + DHA intake: ~0.7 g (mean) | 26 | ‘High’ EPA + DHA intake: ~3.3 g (mean) | Fishy hiccups (omega-3 fatty acids arm: NR); Occasional mild gastrointestinal discomfort (omega-3 fatty acids arm: NR); Exclusion criteria: history of bleeding disorder or delayed clotting time
Emelyanov, 2002, Russia^69^ ^†^ | 23 | 200 mg EPA+DHA + 400 mg olive oil | 23 | 600 mg olive oil | Skin itch (1 per study arm); Metallic taste (omega-3 fatty acids arm: 1; control arm: 2)
Kirsch, 1988, USA^54,^ ^55^ ^†^ | 6 | 4.0 g EPA ethyl ester (trace DHA) | 6 | 0.1 g EPA ethyl ester (trace DHA) | Adverse reactions to aspirin or NSAIDs in high (n=2) & low dose (n=1) arms
Masuev, 1997b, Russia^61^ ^†††^ | 5 | 6.0 g EPA+DHA | 3 | 6.0 g Olive oil | Withdrew (timing: NR) due to severe clinical apnea in response to repeated allergen challenge (n=1)
McDonald, 1991, Australia^58^ ^†^* | 15 | 2.7 g EPA + 1.8 g DHA | 15 | 15 g olive oil | Withdrew (timing: NR): problems swallowing capsules (n=2). Exclusion criteria: peptic ulcers, cardiovascular disease, other potential bleeding disorders
Stenius-Aarniala, 1989, Finland^68^ ^†^* | 36 | 20 mL fish oil (EPA+DHA: NR) | 36 | (1) 20 mL olive oil (2) 20 mL evening primrose oil | Withdrew (timing: NR): could not tolerate taste of oil, or, difficulty keeping diary (n=7; breakdowns: NR) Exclusion criteria: coagulation disorders & diabetes
Thien, 1993, England^67^ ^†^ | NR | 3.2 g EPA + 2.2 g DHA | NR | Olive oil (NR) | Withdrew in wk 1: nausea & vomiting after taking capsules (omega-3 fatty acids arm: n=1); withdrew after wk 1: size & number of capsules unmanageable (n=6; arm: NR); withdrew in first 2 wk: size & number of capsule unmanageable (n=4; arm: NR); withdrew (timing: NR): difficulty taking capsules & recording data (n=2; arm: NR)
CHILDREN
Hodge, 1998, Australia^53^ ^†^ | NR | 0.72 g EPA 0.48 g DHA + ALA (NR) via Canola diet | NR | ‘Omega-6 fatty acids:’ 1.8g Safflower oil + 1.8g Palm oil + 0.4g Olive oil + Sunflower diet (NR) | Discomfort after taking capsules: omega-3 fatty acids arm (n=1); omega-6 fatty acids arm (n=2)
Nagakura, 2000, Japan^64^ ^†^ | 15 | 17.0–26.8 mg/kg EPA; 7.3–11.5 mg/kg DHA (300 mg fish oil) | 15 | 300 mg olive oil | Dropped out: unable to swallow capsules at beginning of study (n=1; arm: control)

n = number of enrolled/randomized participants; NR = not reported; NA = not applicable;

† RCT;

†† Noncomparative case series

††† non-RCT

* Crossover trial