# Excluded Studies

Aguilaniu B, Flore P, Page E, et al. Effects of indomethacin and polyunsaturated fatty acid diet on exercise-induced hypoxaemia in master athletes. Eur J Appl Physiol. 1998;77(1-2):81-8. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 15338217].
Antova T, Pattenden S, Nikiforov B, et al. Nutrition and respiratory health in children in six Central and Eastern European countries. Thorax. 2003;58(3):231-6. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 12612301].
Arm J P, Lee T H. The use of fish oil in bronchial asthma. Allergy Proc. 1989;10(3):185-7. Not a primary study. [pmid: 2548925].
Asero R. Is walnut really a birch-pollen-related fruit?. Allergy. 1998;3(9):908-9. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 9788699].
Austen KF. The role of arachidonic acid metabolites in local and systemic inflammatory processes. Drugs 1987;33:Suppl-7. Not a primary study.
Bakos N, Szemere P. Immunopathologic disorders in atopic dermatitis. Orvosi Hetilap. 1997;138(10):587-92. (Hungarian). Not a primary study. [pmid: 9157334].
Bardin P G, Holgate S T. Present and future antiinflammatory strategies for the treatment of asthma. Drugs of Today. 1991;27(2):107-15. Not a primary study.
Barham J B, Edens M B, Fonteh A N, et al. Addition of eicosapentaenoic acid to gamma-linolenic acid-supplemented diets prevents serum arachidonic acid accumulation in humans. J Nutr. 2000;130(8):1925-31. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 10917903].
Beck M, Zelczak G, Lentze M J. Abnormal fatty acid composition in umbilical cord blood of infants at high risk of atopic disease. Acta Paediatrica. 2000;89(3):279-84. Does not involve omega-3 fatty acids as exposure/intervention. [pmid: 10772274].
Bischoff S C, Ockenga J, Manns M P. Artificial nutrition in internal intensive care medicine. Internist. 2000;41(10):1041-61. (German) Not a primary study. [pmid: 11084891].
Booyens J, Louwrens C C, Katzeff I E. The use of drugs for the inhibition of prostaglandin or leukotriene synthesis from arachidonic acid is theoretically hazardous. Med Hypotheses. 1985;17(4):321-7. Not a primary study. [pmid: 2995775].
Britton J. Nutrition and obstructive lung disease: Risk factors and treatments. European Respiratory Review. 2000;10(75):475-9. Not a primary study.
Calder PC, Yaqoob P, Thies F, et al. Fatty acids and lymphocyte functions. [Review] [109 refs]. Br J Nutr 2002;87:Suppl-48. Not a primary study.
Calder PC. Dietary fatty acids and the immune system. Lipids 1999;34(6 SUPPL.):S137-S40. Not a primary study.
Calder P C. n-3 polyunsaturated fatty acids as pharmacologic agents: A fishy tale?. Nutrition. 1997;13(11-12):1002-4. Not a primary study. [pmid: 9556358].
Calder P C. Polyunsaturated fatty acids, inflammation, and immunity. [Review] [165 refs]. Lipids. 2001;36(9):1007-24. Not a primary study. [pmid: 11724453].
Corburn J. Combining community-based research and local knowledge to confront asthma and subsistence-fishing hazards in Greenpoint/Williamsburg, Brooklyn, New York. Environ Health Perspect 2002;110:Suppl-8. Not a primary study.
Crawford MA, Costeloe K, Ghebremeskel K, et al. The inadequacy of the essential fatty acid content of present preterm feeds. [erratum appears in eur J Pediatr 1998 Feb;157(2):160.]. [Review] [28 refs] Eur J Pediatr 1998;157:Suppl-7. Not a primary study.
Dawson J K, Abernethy V E, Graham D R, et al. A woman who took cod-liver oil and smoked. Lancet. 1996;347(9018):1804. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 8667926].
Denzlinger C. [Leukotrienes promote inflammation and proliferation. Interaction with other mediator systems--modulation by therapeutic measures]. [German]. Fortschr Med. 1998;116(3):41. Not a primary study. [pmid: 9522548].
Denzlinger C. Biology and pathophysiology of leukotrienes. Crit Rev Oncol-Hematol. 1996;23(3):167-223. Not a primary study. [pmid: 8842590].
Ebden P, Bevan C, Banks J, et al. A study of evening primrose seed oil in atopic asthma. Prostaglandins Leukotrienes & Essential Fatty Acids. 1989;35(2):69-72. Does not involve omega-3 fatty acids as exposure/intervention.
Engstrom K, Luostarinen R, Saldeen T. Whole blood production of thromboxane, prostacyclin and leukotriene B4 after dietary fish oil supplementation in man: effect of vitamin E. Prostaglandins Leukot Essent Fatty Acids. 1996;54(6):419-25. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 8888353].
Engstrom K, Wallin R, Saldeen T. Effect of low-dose aspirin in combination with stable fish oil on whole blood production of eicosanoids. Prostaglandins Leukot Essent Fatty Acids. 2001;64(6):291-7. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 11427037].
Ergas D, Eilat E, Mendlovic S, et al. n-3 fatty acids and the immune system in autoimmunity. Isr Med Assoc J. 2002;4(1):34-8. Not a primary study. [pmid: 11802309].
Essential fatty acids, prostaglandins & leukotrienes. The Second International Congress. London, March 1985. Proceedings Progress in Lipid Research 1986 25(1-4) 1 693 Not a primary study. 3423087
Fish oil supplements. [Dutch]. Geneesmiddelenbulletin. 1999;33(4):37-42. Not a primary study.
Fluge O, Omenaas E, Eide G E, et al. Fish consumption and respiratory symptoms among young adults in a Norwegian community. Eur Respir J. 1998;12(2):336-40. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 9727781].
Friedman Z, Demers L M. Essential fatty acids, prostaglandins, and respiratory distress syndrome of the newborn. Pediatrics. 1978;1(3):341-7. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 643409].
Furst P, Kuhn K S. Fish oil emulsions: What benefits can they bring?. Clin Nutr. 2000;19(1):7-14. Not a primary study. [pmid: 10700528].
Gadek J E, DeMichele S J, Karlstad M D, et al. Effect of enteral feeding with eicosapentaenoic acid, gamma-linolenic acid, and antioxidants in patients with acute respiratory distress syndrome. Enteral Nutrition in ARDS Study Group. [see comments.]. Crit Care Med. 1999;27(8):1409-20. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 10470743].
Gil A. Polyunsaturated fatty acids and inflammatory diseases. Biomed Pharmacother. 2002;56(8):388-96. Not a primary study. [pmid: 12442911].
Godden D J, Devereux G S, Anderson W J. Environmental lung disease: The role of diet. Monaldi Arch Chest Dis. 1999;54(6):479-84. Not a primary study. [pmid: 10695315].
Griese M, Schur N, Laryea M D, et al. Fatty acid composition of phospholipids of plasma and of mononuclear blood cells in children with allergic asthma and the influence of glucocorticoids. Eur J Pediatr. 1990;149(7):508-12. Does not involve omega-3 fatty acids as exposure/intervention. [pmid: 2347346].
Grimble R F. Stress proteins in disease: Metabolism on a knife edge. Clin Nutr. 2001;20(6):469-76. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 11883994].
Grimminger F, Seeger W, Mayer K. Use of n-3 fatty acid-containing lipid emulsions in the intensive care unit environment: The clinician's view. Clin Nutr. 2002;21(Suppl 2):23-9. Not a primary study. [pmid: 12516603].
Haban P, Zidekova E, Klvanova J. Supplementation with long-chain n-3 fatty acids in non-insulin-dependent diabetes mellitus (NIDDM) patients leads to the lowering of oleic acid content in serum phospholipids. Eur J Nutr. 2000;39(5):201-6. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 11131366].
Haby M, Peat J, Marks G B. Asthma in preschool children: prevalence and risk factors. Thorax. 2001;56:589-95. Does not involve omega-3 fatty acids as exposure/intervention. [pmid: 11462059].
Hammarstrom S. Leukotrienes. [Review] [145 refs]. Ann Rev Biochem. 1983;52:355-77. Not a primary study. [pmid: 6311078].
Hamvas A, Patterson B W. Pulmonary dysfunction and the integrity of the pulmonary surfactant system. Nutrition. 2002;18(7-8):680-1. Not a primary study. [pmid: 12431723].
Hasselmann M, Kummerlen C. Lipids and lung in the intensive care unit. [French]. Reanimation Urgences. 2001;10(6):543-9. Not a primary study.
Hederos C A, Berg A. Epogam evening primrose oil treatment in atopic dermatitis and asthma. Arch Dis Child. 1996;75(6):494-7. Does not involve omega-3 fatty acids as exposure/intervention. [pmid: 9014601].
Henderson WR. Omega-3 supplementation in CF [abstract]. 6th North American Cystic Fibrosis Conference 1992. Purpose of exposure/intervention was not the treatment or prevention of asthma.
Higgs G A. The effects of dietary intake of essential fatty acids on prostaglandin and leukotriene synthesis. Proc Nutr Soc. 1985;44(2):181-7. Not a primary study. [pmid: 2996008].
Hinman J W, Weeks J R. The prostaglandins: biology and biochemistry. J Reprod Med. 1972;9(6):262-5. Not a primary study. [pmid: 4648905].
Hodge L, Peat J K, Salome C. Increased consumption of polyunsaturated oils may be a cause of increased prevalence of childhood asthma. [see comments.]. Aust N Z J Med. 1994;24(6):727. Not a primary study. [pmid: 7632224].
Horrobin D F. Low prevalences of coronary heart disease (CHD), psoriasis, asthma and rheumatoid arthritis in Eskimos: are they caused by high dietary intake of eicosapentaenoic acid (EPA), a genetic variation of essential fatty acid (EFA) metabolism or a combination of both?. Med Hypotheses. 1987;22(4):421-8. Not a primary study. [pmid: 3035353].
Hui K P, Barnes N C. Inhibition of leukotriene synthesis: New therapy in asthma?. Pulm Pharmacol. 1993;6(1):3-9. Not a primary study. [pmid: 8477153].
In't V, Sterk P J, Bel E H. Alternative strategies in the treatment of bronchial asthma. Clin Exp Allergy. 2000;30(1):16-33. Not a primary study. [pmid: 10606927].
Increasing fish oil intake - Any net benefits?. Drug Ther Bull. 1996;34(8):60-2. Not a primary study. [pmid: 8810128].
Kehn P, Fernandes G. The importance of omega-3 fatty acids in the attenuation of immune-mediated diseases. J Clin Immunol. 2001;21(2):99-101. Not a primary study. [pmid: 11332659].
Kelley D S. Modulation of human immune and inflammatory responses by dietary fatty acids. [Review] [51 refs]. Nutrition. 2001;17(7-8):669-73. Not a primary study. [pmid: 11775583].
Kelley D S, Taylor P C, Nelson G J, et al. Docosahexaenoic acid ingestion inhibits natural killer cell activity and production of inflammatory mediators in young healthy men. Lipids. 1999;34(4):317-24. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 10443964].
Kurlandsky L E, Bennink M R, Webb P M, et al. The absorption and effect of dietary supplementation with omega-3 fatty acids on serum leukotriene B4 in patients with cystic fibrosis. Pediatr Pulmonol. 1994;18(4):211-7. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 7838619].
Kurosawa M, Sunaga Y, Tanaka T. Antipyretic effect of Lumbricus spencer in acetylsalicylic acid-induced asthma. Arzneimittel-Forschung. 1996;46(2):172-4. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 8720308].
Lands W E M, Valagussa F, Marchioli R. Biochemistry and physiology of eicosanoid precursors in cell membranes. Evidence and perspectives on n-3 polyunsaturated fatty acids in cardiovascular disease 2001; biological background, and research priorities on n-3 fatty acids", Research Centre of the Italian National Association of Hospital Cardiologists (ANMCO), Florence, Italy, 17-19 February 2000. European-Heart-Journal-Supplements. 2001;3(D):D22-D25. Not a primary study. [pmcid: 31276].
Lawrence R, Sorrell T. Eicosapentaenoic acid in cystic fibrosis: evidence of a pathogenetic role for leukotriene B4. Lancet. 1993;342(8869):465-9. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 8102430].
Lee T H, Arm J P, Horton C E, et al. Effects of dietary fish oil lipids on allergic and inflammatory diseases. Allergy Proc. 1991;12(5):299-303. Not a primary study. [pmid: 1959766].
Lee T H, Arm J P. The effects of a fish oil enriched diet on experimentally-induced and clinical asthma. Adv Prostaglandin Thromboxane Leukot Res. 1989;19:606-9. Not a primary study. [pmid: 2546399].
Lee T H, Drazen J M, Lewis R A, et al. Substrate and regulatory functions of eicosapentaenoic and docosahexaenoic acids for the 5-lipoxygenase pathway. Implications for pulmonary responses. [Review] [80 refs]. Progress in Biochemical Pharmacology. 1985;20:1-17. Not a primary study. [pmid: 2581266].
Lehr M. Cytosolic phospholipase A2 as a target for drug design. Drugs of the Future. 2000;25(8):823-32. Not a primary study.
Leon F E. Salmon, ventilation, and mycotoxin inhalation. [letter; comment.]. Lancet. 1995;346(8991-8992):1707. Not a primary study. [pmid: 11660388].
Lizenko M V, Petrovskismall l, Bakhirev A M. [Relationship of the levels of arachidonic and eicosapentaenoic acid in blood serum and low density lipoproteins in patients with bronchial asthma and change in the value during restricted-diet therapy]. [Russian]. Vopr Med Khim. 1998;44(2):213-8. Does not involve omega-3 fatty acids as exposure/intervention. [pmid: 9634725].
Lossl K, Skou HA, Christensen JH, et al. The effect of n-3 fatty acids on leukotriene formation from neutrophils in patients on hemodialysis. Lipids 1999;34:Suppl. Purpose of exposure/intervention was not the treatment or prevention of asthma.
Mancuso P. Anti-inflammatory effects on n-3 and n-6 fatty acids in endotoxin-induced lung injury (respiratory distress, pulmonary edema). Dissertation Abstracts International 1996; ume:58-06. Does not involve human participants.
Mariethoz E, Lacroix J - S, Moeschler M B, et al. Meeting on Allergy and the Environment. Rev Environ Health. 1999;14(2):63-78. Not a primary study. [pmid: 10485130].
Mayer K, Grimm H, Grimminger F, et al. Parenteral nutrition with n-3 lipids in sepsis. [Review] [67 refs]. Br J Nutr 2002;87:Suppl-75. Not a primary study.
McCarty M F. The reported clinical utility of taurine in ischemic disorders may reflect a down-regulation of neutrophil activation and adhesion. Med Hypotheses. 1999;53(4):290-9. Not a primary study. [pmid: 10608263].
Meletis C D, Ballen K. Nutrient support to minimize the allergic cascade. Alternative & Complementary Therapies. 1999;5(2):102-5. Not a primary study.
Mermer C, Mercola J. Omega-3s and childhood asthma. Thorax. 2002;57(3):281. Not a primary study. [pmid: 11867839].
Miedema I, Feskens E J M, Heederik D, et al. Dietary determinants of long-term incidence of chronic nonspecific lung diseases: The Zutphen study. Am J Epidemiol. 1993;138(1):37-45. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 8333425].
Miller A L. The etiologies, pathophysiology, and alternative/complementary treatment of asthma. [Review] [204 refs]. Altern Med Rev. 2001;6(1):20-47. Not a primary study. [pmid: 11207455].
Mohan I K, Das U N. Oxidant stress, anti-oxidants, nitric oxide and essential fatty acids in bronchial asthma. Med Sci Res. 1997;25(5):307-9. Purpose of exposure/intervention was not the treatment or prevention of asthma.
Moncada S, Salmon J A. Leukocytes and tissue injury: The use of eicosapentaenoic acid in the control of white cell activation. Wien Klin Wochenschr. 1986;98(4):104-6. Not a primary study. [pmid: 3010576].
Morris A, Noakes M, Clifton P M. The role of n-6 polyunsaturated fat in stable asthmatics. J Asthma. 2001;38(4):311-9. Does not involve omega-3 fatty acids as exposure/intervention. [pmid: 11456384].
Munck A. Cystic fibrosis: Nutritional therapy against inflammation, oxidative stress, and infection. [French]. Nutrition Clinique et Metabolisme. 2000;14(3):201-5. Not a primary study.
Nakajima T, Azuma E, Hashimoto M, et al. [Factors aggravating bronchial asthma in urban children (II)--The involvement of atopy and serum fatty acids, and their interaction with urban living environment]. [Japanese].
Nippon Koshu Eisei Zasshi - Japanese Journal of Public Health 1998;45(5):423-36. Does not involve omega-3 fatty acids as exposure/intervention.
Norum K R, Drevon C A. Fats and health. Acta Med Scand. 1988;224(4):289-91. Not a primary study. [pmid: 3188979].
Omega-3 white book. Omega-3 polyunsaturated fatty acids and oleic monounsaturated acids: Their role in health. [Spanish]. Nutricion Clinica: Dietetica Hospitalaria. 2002;22(3):23-33. Not a primary study.
Peat J K, Allen J, Oddy W. Beyond breast-feeding. J Allergy Clin Immunol. 1999;104(3 Pt 1):526-9. Not a primary study. [pmid: 10589000].
Peat J K. Can asthma be prevented? Evidence from epidemiological studies of children in Australia and New Zealand in the last decade. Clin Exp Allergy. 1998;28(3):261-5. Not a primary study. [pmid: 9543073].
Pelton R. Nutrients can reduce asthma severity. American Druggist. 1998;215(5):34-6. Not a primary study.
Perdomo-Ponce D, Benarroch L, Gonzalez-Cerrutti R, et al. [Family education, a model for allergy prevention]. [Spanish]. Investigacion Clinica. 1996;37(4):221-45. Does not involve omega-3 fatty acids as exposure/intervention. [pmid: 9004851].
Piper P J. Release and metabolism of prostaglandins in lung tissue. Pol J Pharmacol Pharm. 1974;26(1):61-72. Does not involve human participants. [pmid: 4365044].
Planas M, Masclans J R, Iglesia R, et al. Eicosanoids and fat emulsions in acute respiratory distress syndrome patients. Nutrition. 1997;13(3):202-5. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 9131679].
Plata-Salaman C R. Tumor necrosis factor production in response to lipids: Immunomodulatory activity with clinical applicability?. Nutrition. 1994;10(2):179-80. Not a primary study. [pmid: 8025375].
Quirce S, Fernandez-Nieto M, Polo F, et al. Soybean trypsin inhibitor is an occupational inhalant allergen. J Allergy Clin Immunol. 2002;109(1):178. Does not involve omega-3 fatty acids as exposure/intervention. [pmid: 11799388].
Ramos L, Lopez C, Ramadan S, et al. [Contamination of soybean by environmental fungi]. [Spanish]. Medicina (Mex). 2001;61(2):249-50. Not a primary study. [pmcid: 198880]. [pmid: 15340893].
Ramwell P W, Foegh M, Loeb R, et al. Synthesis and metabolism of prostaglandins, prostacyclin, and thromboxanes: the arachidonic acid cascade. Semin Perinatol. 1980;4(1):3-13. Not a primary study. [pmid: 6247764].
Recently introduced products. Drug & Therapeutics Bulletin. 1991;29(5):17-9. Not a primary study. [pmid: 1935601].
Rijcken B, Britton J. Epidemiology of chronic obstructive pulmonary disease. European Respiratory Monograph. 1998;3(7):41-73. Not a primary study.
Sadikot S M. Omega-6 and omega-3 fatty acids in health and disease. Journal of the Diabetic Association of India. 1993;33(2):40-8. Not a primary study.
Sakai K, Okuyama H, Shimazaki H, et al. Fatty acid compositions of plasma lipids in atopic dermatitis/asthma patients. Arerugi - Japanese Journal of Allergology. 1994;43(1):37-43. Does not involve omega-3 fatty acids as exposure/intervention.
Salmon J A, Terano T. Supplementation of the diet with eicosapentaenoic acid: a possible approach to the treatment of thrombosis and inflammation. Proc Nutr Soc. 1985;44(3):385-9. Not a primary study. [pmid: 2999800].
Sampson M J, Davies I R, Brown J C, et al. n-3 polyunsaturated fatty acid supplementation, monocyte adhesion molecule expression and pro-inflammatory mediators in Type 2 diabetes mellitus. Diabetic Medicine. 2001;18(1):51-8. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 11168342].
Samuelsson B, Funk C D, Hoshiko S, et al. Molecular biology of leukotriene and lipoxin formation. Adv Prostaglandin Thromboxane Leukot Res. 1989;19:1-10. Does not involve human participants. [pmid: 2546377].
Schmidt E B, Varming K, Moller J M, et al. No effect of a very low dose of n-3 fatty acids on monocyte function in healthy humans. Scand J Clin Lab Invest. 1996;56(1):87-92. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 8850177].
Schwartz J, Weiss S T. Dietary factors and their relation to respiratory symptoms. The Second National Health and Nutrition Examination Survey. Am J Epidemiol. 1990;132(1):67-76. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 2356815].
Schwartz J, Weiss S T. The relationship of dietary fish intake to level of pulmonary function in the first National Health and Nutrition Survey (NHANES I). [see comments.]. Eur Respir J. 1994;7(10):1821-4. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 7828691].
Seaton A, Devereux G. Diet, infection and wheezy illness: lessons from adults. Pediatr Allergy Immunol. 2000;11(Suppl.13):37-40. Not a primary study. [pmid: 11198632].
Shahar E, Boland L L, Folsom A R, et al. Docosahexaenoic acid and smoking-related chronic obstructive pulmonary disease. The Atherosclerosis Risk in Communities Study Investigators. Am J Respir Crit Care Med. 1999;159(6):1780-5. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 10351918].
Shahar E, Folsom A R, Melnick S L, et al. Dietary n-3 polyunsaturated fatty acids and smoking-related chronic obstructive pulmonary disease. Atherosclerosis Risk in Communities Study Investigators. N Engl J Med. 1994;331(4):228-33. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 8015569].
Simopoulos A P. The importance of the ratio of omega-6/omega-3 essential fatty acids. Biomed Pharmacother. 2002;56(8):365-79. Not a primary study. [pmid: 12442909].
Suchner U, Katz D P, Furst P, et al. Impact of sepsis, lung injury, and the role of lipid infusion on circulating prostacyclin and thromboxane A(2). Intensive Care Med. 2002;28(2):122-9. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 11907654].
Terano T, Kojima T, Seya A, et al. The effect of highly purified eicosapentaenoic acid in patients with psoriasis. Adv Prostaglandin Thromboxane Leukot Res. 1989;19:610-3. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 2546400].
The 1988 report of the Joint National Committee on Detection, Evaluation, and Treatment of High Blood Pressure. [see comments]. Arch Intern Med. 1988;148(5):1023-38. Not a primary study. [pmid: 3365073].
Thien F, Woods R, Walters E H. Asthma spoils from polyunsaturated oils? [letter; comment]. Aust N Z J Med. 1995;25(1):63-4. Not a primary study. [pmid: 7786256].
Thies F, Miles E A, Nebe-von-Caron G, et al. Influence of dietary supplementation with long-chain n-3 or n-6 polyunsaturated fatty acids on blood inflammatory cell populations and functions and on plasma soluble adhesion molecules in healthy adults. Lipids. 2001;36(11):1183-93. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 11795850].
Truswell A S, Marks G B, Haby M M, et al. Polyunsaturated fats and asthma [2] (Multiple letters). Thorax. 2002;57(1):93-4. Not a primary study. [pmid: 11810000].
Varming K, Schmidt E B, Svaneborg N, et al. The effect of n-3 fatty acids on neutrophil chemiluminescence. Scand J Clin Lab Invest. 1995;55(1):47-52. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 7624736].
Vincent D. Relationship of dietary fish intake to level of pulmonary function. [letter; comment]. Eur Respir J. 1995;8(3):507. Not a primary study. [pmid: 7789504].
von Schacky C, Kiefl R, Jendraschak E, et al. n-3 fatty acids and cysteinyl-leukotriene formation in humans in vitro, ex vivo, and in vivo. J Lab Clin Med. 1993;121(2):302-9. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 8381847].
Weber P C, Fischer S, von Schacky C, et al. The conversion of dietary eicosapentaenoic acid to prostanoids and leukotrienes in man. Prog Lipid Res. 1986;25(1-4):273-6. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 3423091].
Weiland S K, von Mutius E, Husing A, et al. Intake of trans fatty acids and prevalence of childhood asthma and allergies in Europe. ISAAC Steering Committee. Lancet. 1999;353(9169):2040-1. Does not involve omega-3 fatty acids as exposure/intervention. [pmid: 10376626].
Westcott J Y. The measurement of leukotrienes in human fluids. Clin Rev Allergy Immunol. 1999;17(1-2):153-77. Not a primary study. [pmid: 10829818].
Wolfram G, Adam O. [Clinical significance of essential fatty acids (author's transl)]. [German]. MMW - Munchener Medizinische Wochenschrift. 1980;122(48):1721-4. Not a primary study. [pmid: 6779136].
Woods RK, Thien FC, Abramson MJ. Dietary marine fatty acids (fish oil) for asthma in adults and children. [update of Cochrane Database Syst Rev. 2000;(4):CD001283 ; 11034708.]. [Review] [23 refs]. Cochrane Database Syst Rev 2002;(3):CD001283. Not a primary study.
Xi G L, Guo X Y, Chen R L. [Studies on antiasthmatic agents. II. Synthesis of some omega-(3-hydroxy-1,4-naphthoquinonyl-2)-alkanoic acids and mannich bases of 2-hydroxy-1,4-naphthoquinone (author's transl)]. [Chinese]. Yao Hsueh Hsueh Pao - Acta Pharmaceutica Sinica. 1980;15(9):548-54. Does not involve human participants.
Yu G, Bjorksten B. Polyunsaturated fatty acids in school children in relation to allergy and serum IgE levels. Pediatr Allergy Immunol. 1998;9(3):133-8. Purpose of exposure/intervention was not the treatment or prevention of asthma. [pmid: 9814727].
Yuksel H, Coskun S, Onag A. Pumpkin seed aspiration into the middle of the trachea in a wheezy infant unresponsive to bronchodilators. Pediatr Emerg Care. 2001;17(4):312-3. Does not involve omega-3 fatty acids as exposure/intervention. [pmid: 11493839].
Ziboh V A. Prostaglandins and other Lipid Mediators: Foreword. Prostaglandins Other Lipid Mediat. 2000;63(1-2):1-2. Not a primary study. [pmid: 11104340].