# References and Included Studies

1 USDA. Individual fatty acid intakes: Results from the 1995 Continuing Survey of Food Intakes by Individuals (data table set 4). 1995.
2 Institute of Medicine. Dietary Reference Intakes: Energy, Carbohydrate, Fiber, Fat, Fatty Acids, Cholesterol, Protein, and Amino Acids (Macronutrition). The National Academies Press, 2002.
3 Simopoulos A P, Leaf A, Salem N Jr. Essentiality of and recommended dietary intakes for omega-6 and omega-3 fatty acids. Ann Nutr Metab. 1999;43(2):127-130. [pmid: 10436312].
4 Fallon S, Enig MG. “Tripping Lightly Down the Prostaglandin Pathways”. 2001. Price-Pottenger Nutrition Foundation.
5 Nair J, Vaca C E, Velic I, et al. High dietary omega-6 polyunsaturated fatty acids drastically increase the formation of etheno-DNA base adducts in white blood cells of female subjects. Cancer Epidemiol Biomarkers Prev. 1997;6(8):597-601. [pmid: 9264272].
6 James MJ, Gibson RA, Cleland LG. Dietary polyunsaturated fatty acids and inflammatory mediator production. [Review][33 refs]. Am J Clin Nutr 2000; 71(1:Suppl):Suppl-8S.
7 Krummel D. Nutrition in cardiovascular disease. In: Mahan LK, Escot-Sump S, editors. Krause's food, nutrition, and diet therapy. W.B. Saunder Company, 1966.
8 Omega-3 long-chain polyunsaturated fatty acids and health benefits. Catherine Anselmino, Centre d'Etude et d'Information sur les Vitamines, Roche Vitamines France, Neuilly-sur-Seine (Nutriscience), 2003.
9 Consensus workshop on dietary assessment: nutrition monitoring and tracking the year 2000 objectives. Hyattsville, MD: National Center for Health Statistics, 1994.
10 USDA National Nutrient Database for Standard Reference. [Release 16] Available at: http://www.nal.usda.gov/fnic/foodcomp; [underlined: Accessed November 3, 2003] 2003. US Department of Agriculture Agricultural Research Service.
11 National Heart Lung and Blood Institute. Expert Panel Report 2: Guidelines for the diagnosis and management of asthma. 1997. Bethesda MD, National Institutes of Health; NIH Publication No. 97–4051.
12 National Heart Lung and Blood Institute. Morbidity & Mortality: 2002 Chart Book on Cardiovascular, Lung, and Blood Diseases. 2002. National Institutes of Health.
13 American Lung Association. Trends in asthma management and mortality. 2003. Epidemiology & Statistics Unit, Research and Scientific Affairs.
14 National Asthma Education and Prevention Program. Expert Panel Report: Guidelines for the Diagnosis and Management of Asthma Update on Selected Topics--2002. J Allergy Clin Immunol. 2002;110(5 Suppl):S141-S219. [pmid: 12542074].
15 Global Strategy for Asthma Management and Prevention. National Institutes of Health. National Heart, Lung and Blood Institute. Revised 2002. Updated from: NHLBI/WHO Workshop Report: Global Strategy for Asthma Management and Prevention Issued January, 1995 NIH Publication No 02–3659. 2002.
16 Williams H, McNicol KN. Prevalence, natural history, and relationship of wheezy bronchitis and asthma in children. An epidemiological study. Br Med J. 1969;4(679):321-325. [pmid: 5386265]. [pmcid: 1629591].
17 Martin A J, McLennan L A, Landau L I, et al. The natural history of childhood asthma to adult life. Br Med J. 1980;280(6229):1397-1400. [pmid: 7427131]. [pmcid: 1601770].
18 Kelly W J, Hudson I, Phelan P D, et al. Childhood asthma in adult life: a further study at 28 years of age. Br Med J (Clin Res Ed). 1987;294(6579):1059-1062. [pmid: 11680484].
19 Oswald H, Phelan P D, Lanigan A, et al. Outcome of childhood asthma in mid-adult life. BMJ. 1994;309(6947):95-96. [pmid: 8038676].
20 Horak E, Lanigan A, Roberts M, et al. Longitudinal study of childhood wheezy bronchitis and asthma: outcome at age 42. BMJ. 2003;326(7386):422-423. [pmcid: 149441]. [pmid: 12595380].
21 Ulrik C S. Outcome of asthma: longitudinal changes in lung function. Eur Respir J. 1999;13(4):904-918. [pmid: 10362061].
22 Castro-Rodriguez J A, Holberg C J, Wright A L, et al. A clinical index to define risk of asthma in young children with recurrent wheezing. Am J Respir Crit Care Med. 2000;162(4 Pt 1):1403-1406. [pmid: 11029352].
23 Reed C E. The natural history of asthma in adults: the problem of irreversibility. J Allergy Clin Immunol. 1999;103(4):539-547. [pmid: 10199998].
24 Simopoulos A P. The importance of the ratio of omega-6/omega-3 essential fatty acids. Biomedicine & Pharmacotherapy. 2002;56(8):365-379.
25 Hamid Q, Tulic' M K, Liu M C, et al. Inflammatory cells in asthma: mechanisms and implications for therapy. J Allergy Clin Immunol. 2003;111(1 Suppl):S5-S12. [pmid: 12532083].
26 Roper R L, Phipps R P. Prostaglandin E2 and cAMP inhibit B lymphocyte activation and simultaneously promote IgE and IgG1 synthesis. J Immunol. 1992;149(9):2984-2991. [pmid: 1328389].
27 Roper R L, Brown D M, Phipps R P. Prostaglandin E2 promotes B lymphocyte Ig isotype switching to IgE. J Immunol. 1995;154(1):162-170. [pmid: 7995935].
28 Markham A, Faulds D. Theophylline. A review of its potential steroid sparing effects in asthma. Drugs. 1998;56(6):1081-1091. [pmid: 9878995].
29 Weinberger M, Hendeles L. Theophylline in asthma. N Engl J Med. 1996;334(21):1380-1388. [pmid: 8614425].
30 Black P N, Sharpe S. Dietary fat and asthma: is there a connection?. [Review] [72 refs]. Eur Respir J. 1997;10(1):6-12. [pmid: 9032484].
31 Roberts G, Lack G. Relevance of inhalational exposure to food allergens. Curr Opin Allergy Clin Immunol. 2003;3(3):211-215. [pmid: 12840705].
32 Bush R K. Environmental controls in the management of allergic asthma. Med Clin North Am. 2002;86(5):973-989. [pmid: 12428541].
33 Saglani S, McKenzie S A. Environmental factors relevant to difficult asthma. Paediatr Respir Rev. 2002;3(3):248-254. [pmid: 12376062].
34 Horrobin D F. Low prevalences of coronary heart disease (CHD), psoriasis, asthma and rheumatoid arthritis in Eskimos: are they caused by high dietary intake of eicosapentaenoic acid (EPA), a genetic variation of essential fatty acid (EFA) metabolism or a combination of both?. Med Hypotheses. 1987;22(4):421-428. [pmid: 3035353].
35 Woods RK, Thien FC, Abramson MJ. Dietary marine fatty acids (fish oil) for asthma in adults and children. [update of Cochrane Database Syst Rev. 2000;(4):CD001283 ; 11034708.]. [Review][23 refs]. Cochrane Database of Systematic Reviews 2002;(3):CD001283.
36 Moher D, Cook D J, Eastwood S, et al. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Quality of Reporting of Meta-analyses. Lancet. 1999;354(9193):1896-1900. [pmid: 10584742].
37 Berlin J A. Does blinding of readers affect the results of meta-analyses? University of Pennsylvania Meta-analysis Blinding Study Group. Lancet. 1997;350(9072):185-186. [pmid: 9250191].
38 Jadad A R, Moore R A, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
39 Schulz K F, Chalmers I, Hayes R J, et al. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273(5):408-412. [pmid: 7823387].
40 Downs S H, Black N. The feasibility of creating a checklist for the assessment of the methodological quality both of randomised and non-randomised studies of health care interventions. J Epidemiol Community Health. 1998;52(6):377-384. [pmid: 9764259].
41 Jadad AR. Randomised controlled trials. London: BMJ Publishing Group, 1998.
42 Romano L. Study on feasibility and results of mid-term dietary supplementation in omega-3 fatty acids [abstract]. 21st European Cystic Fibrosis Conference 1997.
43 Castillo Vizuete JA. ASMA BRONQUIAL SENSIBLE AL ACIDA ACETIL SALICILICO. Dissertation Abstracts International 1988; ume:51-01.
44 Helms P J. Pathophysiology and prevention of asthma. Annales Nestle [Fr]. 2002;60(2):66-73.
45 Levere X M, Mustafa I. From specific supports of organ failures to comprehensive understanding of metabolic response. Critical Care and Shock, Vol 6(1(pp 4–6), 2003. 2003;6(1):4-6. [pmcid: 108195]. [pmid: 356316].
46 Palat D, Rudolph D, Rothstein M. A trial of fish oil in asthma. Am Rev Respir Dis. 1988;137(Suppl 4 part 2):328.
47 Sakakibara H, Hirose K, Matsushita K, et al. [Effect of supplementation with eicosapentaenoic acid ethyl ester, MND-21, on generation of leukotrienes by calcium ionophore-activated leukocytes in bronchial asthma]. [Japanese]. Nihon Kyobu Shikkan Gakkai Zasshi. 1995;33(4):395-402. [pmid: 7791267].
48 Huang S L, Lin K C, Pan W H. Dietary factors associated with physician-diagnosed asthma and allergic rhinitis in teenagers: analyses of the first Nutrition and Health Survey in Taiwan. Clin Exp Allergy. 2001;31(2):259-264. [pmid: 11251627].
49 Huang S, Pan W, Huang S L, et al. Dietary fats and asthma in teenagers: analyses of the first Nutrition and Health Survey in Taiwan (NAHSIT). Clin Exp Allergy. 2001;31(12):1875-1880. [pmid: 11737039].
50 Mihrshahi S, Peat J K, Webb K, et al. The childhood asthma prevention study (CAPS): design and research protocol of a randomized trial for the primary prevention of asthma. Control Clin Trials. 2001;22(3):333-354. [pmid: 11384793].
51 Mihrshahi S, Peat J K, Marks G B, et al. Eighteen-month outcomes of house dust mite avoidance and dietary fatty acid modification in the Childhood Asthma Prevention Study (CAPS). J Allergy Clin Immunol. 2003;111(1):162-168. [pmid: 12532113].
52 Hodge L, Salome C M, Hughes J M, et al. Effect of dietary intake of omega-3 and omega-6 fatty acids on severity of asthma in children. Eur Respir J. 1998;11(2):361-365. [pmid: 9551739].
53 Hodge L. Effect of fish oil supplements on severity of asthma in children. Annu Sci Meet Thorac Soc Aust N Z 1997.
54 Kirsch C M, Payan D G, Wong M Y, et al. Effect of eicosapentaenoic acid in asthma. Clin Allergy. 1988;18(2):177-187. [pmid: 2835194].
55 Payan D G, Wong M Y, Chernov-Rogan T, et al. Alterations in human leukocyte function induced by ingestion of eicosapentaenoic acid. J Clin Immunol. 1986;6(5):402-410. [pmid: 3021806].
56 Arm J P, Horton C E, Spur B W, et al. The effects of dietary supplementation with fish oil lipids on the airways response to inhaled allergen in bronchial asthma. Am Rev Respir Dis. 1989;139(6):1395-1400. [pmid: 2543246].
57 Arm J P, Horton C E, Mencia-Huerta J M, et al. Effect of dietary supplementation with fish oil lipids on mild asthma. Thorax. 1988;43(2):84-92. [pmid: 3353893].
58 McDonald C V. Effect of fish-oil derived omega-3 fatty acid supplements on asthma control. Aust N Z J Med. 1990;20:526.
59 Ashida K, Mitsunobu F, Mifune T, et al. A pilot study: effects of dietary supplementation with a-linolenic acid-enriched perilla seed oil on bronchial asthma. Allergol Int. 1997;46:181-185.
60 Masuev K A. [The effect of polyunsaturated fatty acids on the biochemical indices of bronchial asthma patients]. Ter Arkh. 1997;69(3):33-35. [pmid: 9229825].
61 Masuev K A. [The effect of polyunsaturated fatty acids of the omega-3 class on the late phase of the allergic reaction in bronchial asthma patients]. Ter Arkh. 1997;69(3):31-33. [pmid: 9229824].
62 Hashimoto N, Majima T, Ichimura K, et al. [Effects of eicosapentaenoic acid in patients with bronchial asthma]. Nihon Kyobu Shikkan Gakkai Zasshi. 1997;35(6):634-640. [pmid: 9294297].
63 Machura E, Brus R, Kalacinnski W, et al. [The effect of dietary fish oil supplementation on the clinical course of asthma in children]. Pediatr Pol. 1996;71(2):97-102. [pmid: 8966087].
64 Nagakura T, Matsuda S, Shichijyo K, et al. Dietary supplementation with fish oil rich in omega-3 polyunsaturated fatty acids in children with bronchial asthma. Eur Respir J. 2000;16(5):861-865. [pmid: 11153584].
65 Dry J, Vincent D. Effect of a fish oil diet on asthma: results of a 1-year double-blind study. Int Arch Allergy Appl Immunol. 1991;95(23):156-157. [pmid: 1834587].
66 Okamoto M, Mitsunobu F, Ashida K, et al. Effects of dietary supplementation with n-3 fatty acids compared with n-6 fatty acids on bronchial asthma. Intern Med. 2000;39(2):107-111. [pmid: 10732825].
67 Thien F C, Mencia-Huerta J M, Lee T H. Dietary fish oil effects on seasonal hay fever and asthma in pollen-sensitive subjects. Am Rev Respir Dis. 1993;147(5):1138-1143. [pmid: 8484622].
68 Stenius-Aarniala B, Aro A, Hakulinen A, et al. Evening primose oil and fish oil are ineffective as supplementary treatment of bronchial asthma. Ann Allergy. 1989;62(6):534-537. [pmid: 2735560].
69 Emelyanov A F. Treatment of asthma with lipid extract of New Zealand green-lipped mussel: a randomised clinical trial. Eur Respir J. 2002;20(3):596-600. [pmid: 12358334].
70 Gorelova J Y, Semikina E M. The changes of lymphocyte membrane receptors in bronchial asthma and atopic dermatitis in pediatric patients receiving treatment with polyenic fatty acids. Z Ernahrungswiss. 1998;37(1):142-143. [pmid: 9558750].
71 Okamoto M, Mitsunobu F, Ashida K, et al. Effects of perilla seed oil supplementation on leukotriene generation by leucocytes in patients with asthma associated with lipometabolism. Int Arch Allergy Immunol. 2000;122(2):137-142. [pmid: 10878492].
72 Villani F, Comazzi R, De Maria P, et al. Effect of dietary supplementation with polyunsaturated fatty acids on bronchial hyperreactivity in subjects with seasonal asthma. Respiration. 1998;65(4):265-269. [pmid: 9730791].
73 Broughton K S, Johnson C S, Pace B K, et al. Reduced asthma symptoms with n-3 fatty acid ingestion are related to 5-series leukotriene production. Am J Clin Nutr. 1997;65(4):1011-1017. [pmid: 9094887].
74 Picado C, Castillo J A, Schinca N, et al. Effects of a fish oil enriched diet on aspirin intolerant asthmatic patients: a pilot study. Thorax. 1988;43(2):93-97. [pmid: 3353894].
75 Troisi R J, Willett W C, Weiss S T, et al. A prospective study of diet and adult-onset asthma. Am J Respir Crit Care Med. 1995;151(5):1401-1408. [pmid: 7735592].
76 Takemura Y, Sakurai Y, Honjo S, et al. The relationship between fish intake and the prevalence of asthma: the Tokorozawa childhood asthma and pollinosis study. Prev Med. 2002;34(2):221-225. [pmid: 11817918].
77 Hodge L, Salome C M, Peat J K, et al. Consumption of oily fish and childhood asthma risk. Med J Aust. 1996;164(3):137-140. [pmid: 8628130].
78 Satomi H, Minowa M, Hatano S, et al. An epidemiological study of the preventive effect of dietary fish on bronchial asthma. Koshu Eisei In Kenkyu Hokoku. 1994;43(3):305-314.
79 Thien F C, Woods R K, Walters E H. Oily fish and asthma--a fishy story? Further studies are required before claims can be made of a beneficial effect of oily fish consumption on asthma. [letter; comment.]. Med J Aust. 1996;164(3):135-136. [pmid: 8628129].
80 Follmann D, Elliott P, Suh I, et al. Variance imputation for overviews of clinical trials with continuous response. J Clin Epidemiol. 1992;45(7):769-773. [pmid: 1619456].
81 Simopoulos A P. Essential fatty acids in health and chronic disease. Am J Clin Nutr. 1999;70(3 Suppl):560S-569S. [pmid: 10479232].
82 Sugano M, Hirahara F. Polyunsaturated fatty acids in the food chain in Japan. Am J Clin Nutr. 2000;71(1 Suppl):189S-196S. [pmid: 10617970].
83 Kris-Etherton P M, Taylor D S, Yu-Poth S, et al. Polyunsaturated fatty acids in the food chain in the United States. Am J Clin Nutr. 2000;71(1 Suppl):179S-188S. [pmid: 10617969].
84 Mermer C, Mercola J. Omega-3s and childhood asthma. Thorax. 2002;57(3):281. [pmid: 11867839].
85 Gergen PJ, Weiss KB. Asthma and rhinitis. In: Busse WW, Holgate ST, editors. Epidemiology of asthma. Boston: Blackwell Scientific Publications, 1995.
86 Gil A. Polyunsaturated fatty acids and inflammatory diseases. Biomedicine & Pharmacotherapy. 2002;56(8):388-396.
87 Surette M E, Koumenis I L, Edens M B, et al. Inhibition of leukotriene biosynthesis by a novel dietary fatty acid formulation in patients with atopic asthma: a randomized, placebo-controlled, parallel-group, prospective trial. Clin Ther. 2003;25(3):972-979. [pmid: 12852711].
88 Nafstad P, Nystad W, Magnus P, et al. Asthma and allergic rhinitis at 4 years of age in relation to fish consumption in infancy. J Asthma. 2003;40(4):343-348. [pmid: 12870829].
89 Woods R K, Walters E H, Raven J M, et al. Food and nutrient intakes and asthma risk in young adults. Am J Clin Nutr. 2003;78(3):414-421. [pmid: 12936923].
90 Schwartz J, Weiss S T. Dietary factors and their relation to respiratory symptoms. The Second National Health and Nutrition Examination Survey. Am J Epidemiol. 1990;132(1):67-76. [pmid: 2356815].
91 Schwartz J, Weiss S T. The relationship of dietary fish intake to level of pulmonary function in the first National Health and Nutrition Survey (NHANES I). [see comments.]. Eur Respir J. 1994;7(10):1821-1824. [pmid: 7828691].
92 Antova T, Pattenden S, Nikiforov B, et al. Nutrition and respiratory health in children in six Central and Eastern European countries. Thorax. 2003;58(3):231-236. [pmid: 12612301].
93 Fluge O, Omenaas E, Eide G E, et al. Fish consumption and respiratory symptoms among young adults in a Norwegian community. Eur Respir J. 1998;12(2):336-340. [pmid: 9727781].
94 Peat J K, Salome C M, Woolcock A J. Factors associated with bronchial hyperresponsiveness in Australian adults and children. Eur Respir J. 1992;5(8):921-929. [pmid: 1426199].
95 Haby M, Peat J, Marks G B. Asthma in preschool children: prevalence and risk factors. Thorax. 2001;56:589-595. [pmid: 11462059].
96 Damico K E, Stoll A L, Marangell L B, et al. How blind is double-blind? A study of fish oil versus placebo. Prostaglandins Leukot Essent Fatty Acids. 2002;66(4):393-395. [pmid: 12054908].
97 Schwartz J, Gold D, Dockery D W, et al. Predictors of asthma and persistent wheeze in a national sample of children in the United States. Association with social class, perinatal events, and race. Am Rev Respir Dis. 1990;142(3):555-562. [pmid: 2389907].