# Acknowledgments

The authors would like to thank numerous individuals for their support of the present project: our collaborators at Southern California/RAND (SC-RAND) and Tufts-New England Medical Center (Tufts-NEMC) EPCs; Isabella Steffensen and Christine Murray for their ability to convey with words, tables and figures what it is we did and found; Vasil Mamaladze, Uwe Siebert, Marie Sirdevan, and Malgorzata Winiszewska for their expert and timely translation of articles; Jonathan Arm for taking the time to clarify the relationship of two, included reports on research in which he played a key role; Lillian Thompson for her words of wisdom regarding flaxseed; Herb Woolf for responding with substance to our request of industry for evidence; Peter O'Blenis for assuring that our software would adapt and grow as quickly as the project requirements shifted and expanded; Tammy Clifford for her thoughts on research design; Gabriela Lewin and Adrienne Showler for their ideas concerning the organization of the data; Nick Barrowman for his grounding on statistical matters; Isabelle French for coordinating our review team particularly in our interactions with our Technical Expert Panel, the Federal Partners, and AHRQ; Rosaly Correa-de-Araujo and Jacqueline Besteman who, as our Task Order Officers, provided the AHRQ structure affording our work; and, Anne Thurn of the Office of Dietary Supplements for her direction on behalf of the Federal Partners. Sections of Chapter 1 were developed in collaboration with Tufts-NEMC EPC, and, with contributions from SC-RAND EPC.