# Appendix F. Additional Acknowledgements

The UO-EPC gratefully acknowledges the following individuals who served on our Technical Expert Panel (TEP). Acknowledgement does not reflect endorsement of this report.

Ken Adams PhD

Section Chief

Asthma and Inflammation Section

Asthma, Allergy, and Inflammation Branch

National Institute of Allergy and Infectious Diseases

Bethesda, MD

Pierre Ernst MD MSc

Professor,

Department of Medicine

McGill University

Montreal, PQ

James Friel PhD

Professor,

Department of Human Nutritional Sciences

Faculty of Human Ecology

University of Manitoba

Winnipeg, MB

Bill Harris PhD

Co-director,

Lipid and Diabetes Research Center

Saint Luke's

Kansas City, MO

Bruce Holub PhD

Professor,

Department of Human Biology and Nutritional Sciences

University of Guelph

Guelph, ON

(Industry representative)

Monica Kraft MD

Director, Pulmonary Physiology Unit

National Jewish Medical and Research Center

Denver, CO

(American Thoracic Society representative)

The UO-EPC gratefully acknowledges the following individuals who reviewed the initial draft of this evidence report, and provided constructive feedback. Acknowledgement does not reflect endorsement of this report.

Kristan Aronson PhD

Associate Professor

Community Health and Epidemiology

Queen's University

Kingston, ON

David Atkins MD MPH

Chief Medical Officer

Center for Outcomes and Evidence

Agency for Healthcare Research and Quality

Rockville, MD

Philip Calder PhD DPhil

Professor of Nutritional Immunology

Institute of Human Nutrition

School of Medicine

University of Southampton

Southampton, UK

Daniel Hamilos MD

Associate Professor of Medicine

Washington University School of Medicine

Division of Allergy and Immunology

St. Louis, MO

L. John Hoffer MD

Lady Davis Institute for Medical Research

Sir Mortimer B. Davis Jewish General Hospital

Montreal QC

Patricia Kehn

Program Officer

Transplantation Immunobiology Section

Transplantation Immunobiology Branch

National Institute of Allergy and Infectious Diseases

Bethesda, MD

Seema Mihrshahi PhD

Project Coordinator

Childhood Asthma Prevention Study

Clinical Epidemiology Unit

Children's Hospital at Westmead

Westmead NSW

Malcolm Sears MRACP FRACP

Research Director,

Firestone Institute for Respiratory Health

Hamilton, ON

Anne Thurn PhD

Director,

Evidence-Based Review Program

Office of Dietary Supplements

Bethesda, MD