# Appendix E. Evidence Tables

Evidence Table 1. Randomized controlled trial evidence of health effects of omega-3 fatty acids on asthma

Author, Year, Location | Study Characteristics | Study Design & Duration | Eligibility Criteria | Asthma Description/Severity/Duration/Diagnostic Method/Pre-study Medication/Study Medication | Intervention/Exposure Definition (Omega-3 Fatty Acid Type(s)/Source/Delivery/Serving Size or Dose/ Length) & Number of Pts Enrolled/Completed | Comparator Definition (Control or Background Diet/Source/ Delivery/Serving Size or Dose/Length) & Number of Pts Enrolled/Completed | Results | Concurrent Conditions & Medications | Number (%) of & Reasons for Dropouts/Withdrawals(Per Study Arm) | Quality (Internal Validity) & Applicability (External Validity) | Funding Source
Arm,^56,^ ^57^ 1988, England | • Enrolled/evaluated: 25/20 | • Parallel RCT, double-blind | • Inclusion: NR | • NR, mild asthma, 22 atopic, none aspirin-sensitive, some exercise-induced asthma (6/12 MaxEPA; 5/8 control) | • 5.4 g/d from fish oil capsules (3.2 g/d EPA + 2.2 g/d DHA) | • Identical capsules containing olive oil (Seven Seas Ltd., Marfleet, Hull, UK) | • NS ? in AM PEF (L/min) in either study arm (p >.05)* or between study arms [mean difference: 5 (95% CI 26, -16)] | NR | • n=5, with no data regarding from which study arm 4 left | • Randomization: 1 | Asthma Research Council (UK) & International Association of Fish Meal Manufacturers
| • Age (mean & range): 27 (15–42) y• | • 12–14 wk (Run-in: 2–4 wk) | • Exclusion: NR | • Severity: mild (undefined) | • 18 MaxEPA® (Seven Seas Ltd., Marfleet, Hull, UK) capsules/d | • Capsules/d: NR, though likely matched | • NS ? in PM PEF (L/min) in either study arm (p>.05)* or between study arms [mean difference: -2 (95% CI 16, -19)] | | • after 3 wk of MaxEPA®, hospitalized for acute asthma, took oral corticosteroids & stopped MaxEPA® (n=1) | • Binding: 2
| • % Male: 40 | | | • Duration: NR | • MaxEPA® contains mainly triglycerides, with 34% of the total fatty acids & 86% of the polyunsaturated fatty acids consisting of EPA + DHA | • Usual diet unchanged | • NS ? in PEF lability (AM-PM difference as % of higher figure) in either study arm (p>.05) or between study arms [mean difference: -0.1 (95% CI 2.36, -2.6)] | | • found number & size of capsules unmanageable (n=3) | • Withdrawals/dropouts: 1
| • Race: NR, likely Caucasian/European | | | • Method: NR | • Usual diet unchanged | • 10 wk intervention | • NS ? in total symptoms score (nocturnal cough & wheeze; daytime wheeze; 0= asymptomatic; 3= severe) in either study arm (p>.05)* or between study arms [mean difference: 3.2 (95% CI 13, -6.7)] | | • personal reasons (n=1) | • Jadad total score: 4 (Grade: A)
| • Number of sites: 1 | | | • Pre-study: on regular inhaled corticosteroids (11/25); 1 on long-acting theophylline at night; all on inhaled beta-2 agonists as required; none on oral corticosteroids | • 10 wk intervention | • n=NR/8 (4 males, all atopic) | • NS ? in bronchodilator use (total doses) in either study arm (p>.05)* or between study arms [mean difference: 7.8 (95% CI 20, -4.4)] | | | • Allocation concealment: unclear
| | | | • Study: NR | • N=NR/12 (6 males, 10 atopic) | | • NS ? in airways histamine responsiveness (specific airways conductance: sGAW) in either study arm (p>.05)* | | | • Applicability. III
| | | | | | | • NS ? in maximal % decreases in sGAW as airways response to exercise challenge in either study arm (p>.05)*
| | | | | | | • NS ? in acute airways response to allergen challenge (sGAW) in either arm (p>.05)*
| | | | | | | • S suppression at 2 (p=.006)* & 3–7 h (p<.005)* on late airways response to allergen challenge (sGAW) only in omega-3 fatty acid arm
| | | | | | | • NS suppression in calcium ionophore induced generation of LTB4 (ng/2 × 10^6^ PMN) in either study arm (p>.05)*
| | | | | | | • no calcium ionophore induced generation of LTB_5_ (ng/2 × 10^6^ PMN) before either intervention or after control intervention; some generated after omega-3 fatty acid intervention (NR)*
| | | | | | | • S suppression of total LTB compounds generation (ng/2 × 10^6^ PMN) by ionophore stimulated neutrophils only in omega-3 fatty acid arm (p<.01)*
| | | | | | | • S suppression of neutrophil chemotaxis (# neutrophils per 5 high power fields) to fMLP (M) (p=.01)* & LTB4 (p=.04)* only in omega-3 fatty acid arm
Dry, 1991, France^65,^ | • Enrolled/evaluated: 12/12 | • Parallel RCT, double-blind | • Inclusion: NR | • NR, allergic asthmatics (definition: reversible airway obstruction & bronchopulmonary hyper-reactivity, likely due to airway inflammation via chemical mediators) | • Low dose omega-3 fatty acids | • ‘Placebo’ (undefined) | • At 9 mo, S greater increase in FEV_1_ (% predicted) in the omega-3 fatty acid arm (p<.005) | NR | n=10 | • Randomization: 1 | NR
| • Age (mean & range): NR (NR) | • 12 mo (Run-in: NR) | • Exclusion: NR | • Severity: NR | • 1 g/d EPA+DHA (relative amounts undefined; delivery method undefined, likely capsule); Liparmonyl® (Ponroy Laboratories, France) | • 12 mos intervention | • NB: no statistical test conducted at final follow-up at 12 mo, with FEV_1_ (% predicted) results continuing to diverge | | | • Blinding: 1
| • % Male: NR | | | • Duration: NR | • 12 mo intervention | • n=NR/100% | | | | • Withdrawals/dropouts: 0
| • Race: NR, but likely Caucasian/European | | | • Method: NR | • N=NR/100% | | | | | • Jadad total score: 2 (Grade: C)
| • Number of sites: NR | | | • Pre-study: routinely used salbutamol, inhaled corticosteroids & sodium nedocromil (no data) | | | | | | • Allocation concealment: unclear
| | | | • Study: NR | | | | | | • Applicability: X
Emelyanov, 2002, Russia^69^ | • Enrolled/evaluated: 46/46 | • Parallel RCT, double-blind | • Inclusion: NR, volunteers; recruited in outpatient hospital department | • Atopic asthma, all house-dust mite sensitive; | • Extract of New Zealand green-lipped mussel (Perna Canaliculus) | • 2 matching capsules (2 capsules, twice daily) each containing 150 mg of olive oil, for a total of 600 mg/d olive oil (manufacturer: NR) | • S greater decrease in daytime wheeze in omega-3 fatty acid arm (p=.026) | NR | • n=0 | • Randomization: 2 | NR
| • Age (mean & range): 39.1 (18–56) y | • 10 wk (Runin: 2 wk; regular treatment stopped, only short-acting beta-2 agonists allowed: salbutamol, terbutaline) | • Exclusion: use of inhaled corticosteroids within prior 4 wk, oral corticosteroid use within last 3 mo; current or ex-smoker; clinically S heart, renal, liver & intestinal disorders, women of childbearing potential not using adequate contraception; receiving inhaled corticosteroids or hospitalized for asthma during run-in period | • Severity: mild-to-moderate via NIH/WHO criteria (1995); mild (n=36) = symptoms ≤ twice a wk, FEV_1_≥80% of predicted, using inhaled short-acting beta-2 agonists; moderate (n=10) = daily symptoms & FEV1 60%–80% of predicted & used inhaled short-acting beta-2 agonists daily; | • 4 capsules (2 capsules, twice daily) of liquid extract Lyprinol® (Mac Lab, Melbourne, Australia), each containing 50 mg omega-3 fatty acids (EPA+DHA: undefined) & 100 mg olive oil), for total of 600 mg/d of oil, including 200 mg EPA+DHA/d & 400 mg/d olive oil/d | • 8 wk intervention | • NS between-arm difference in ? in night-time awakenings (p=.085) | | • 60 volunteers, 46 of which were randomized: 14 withdrew before randomization due to deterioration in asthma control (lower FEV1 than those randomized: p≤.001) = more severe asthmatics withdrew before randomization | • Blinding: 2
| • % Male: 26.1 | | | • Duration: 5.9y | • 8 wk intervention | • n=23/23 | • S greater decrease in use of inhaled beta-2 agonists (puffs/d) in omega-3 fatty acid arm (p=.022) | | • Compliance (self-recorded): 95% & 93% for omega-3 fatty acids & control group, respectively) | • Withdrawals/dropouts: 1
| • Race: NR, likely Caucasian/European | | | • Method: clinical history, reversibility of FEV1 of >15% & diurnal PEF variability of >20%; American Thoracic Society (1987) criteria; atopy via positive skin-prick test to common inhalant allergens (house-dust mite; animal; pollen); | • n=23/23 | | • NS between-arm difference in ? in FEV_1_ (% predicted) (p=.708) | | | • Jadad total score: 5 (Grade: A)
| • Number of sites: 1 | | | • Pre-study: NR | | | • S greater increase in AM PEF (L/min) in omega-3 fatty acid arm (p=.00001) | | | • Allocation concealment: unclear
| | | | • Study: only short-acting beta-agonists allowed (rescue) | | | • NS between-arm difference in ? in PM PEF (L/min) (p=.136) | | | • Applicability: III
| | | | | | | • S greater decrease in the concentration of exhaled hydrogen peroxide (H_2_O_2_) in expired breath condensate (marker of airway inflammation) in the omega-3 fatty acid arm (p=.0001)
Hodge, 1998,^52,^ ^53^ Australia | • Enrolled/ evaluated: 45/39 | • Parallel RCT, double-blind | • Inclusion: episodic wheeze in last 12 mo & airways hyperresponsiveness (no mention of how recruited) | • NR, with 19/20 & 17/19 atopic in omega-3 & omega-6 fatty acid groups, respectively | • Omega-3 fatty acid group: 1.22 g/d from fish oil capsules, plus omega-3 fatty acid diet (use only provided canola oils & margarines & salad dressings, from unmarked containers; plus, instructed to have a fish meal at least once per month) (diet manufacturer: Meadowlea Pty Ltd.) | • Omega-6 fatty acid group: matched capsules plus omega-6 fatty acid diet (use only provided sunflower oils & margarines & salad dressings & oils, from unmarked containers; plus, asked to refrain from eating fish) (diet manufacturer: Meadowlea Pty Ltd.) | • NS ? in FEV_1_ (% predicted) in either study arm (p=NR)* | NR | • n=6 (dropped out at baseline; no reasons reported, or which study arm they left) | • Randomization: 1 | Fisheries Research and Development Corporation of Australia, &, Asthma Foundation of New South Wales
| • Age (mean & range): 10.25 (8–12) y | • 26 wk (Run-in: 2 wk) | • Exclusion: other significant diseases; taking regular oral corticosteroids; known aspirin or dietary salicylate sensitivity | • Severity: NR (baseline scores reported per study arm, yet no interpretation of severity) | • 0.3 g MaxEPA® (RP Scherer, Melbourne, Australia) capsules (0.18 g EPA & 0.12 g DHA per capsule): 4 per day (total: 0.72 EPA g/d, 0.48 DHA g/d); ALA undefined | • Control capsules (0.45 g safflower oil, 0.45 g palm oil, & 0.1 g olive oil; no EPA or DHA): 4 per day, of safflower/palm/olive oil | • NS ? in asthma severity score (parental diary card: composite of daily diary data re AM expiratory flow rate, day & night symptoms, & medication use) in either study arm (p=NR)* | | | • Blinding: 1
| • % Male: 43.6 | | | • Duration: NR | • 6 mo intervention | • 6 mo intervention | • NS ? in dose response ratio to histamine challenge in either study arm (p=.10)* | | | • Withdrawals/dropouts: 1
| • Race: NR, but likely Caucasian/European | | | • Method: episodic wheeze in last 12 mo & airways hyperresponsiveness & FEV_1_ & FVC & allergen skin prick tests | • n=NR/20 | • n=NR/19 | • NS between-arm difference in ? in TNF-alpha production (p=.075) | | | • Jadad total score: 3 (Grade: B)
| • Number of sites: 1 | | | • Pre-study: numbers of pts using inhaled corticosteroids, beta-2 agonist use & disodium cromoglycate similar across study arms (13/20 & 13/19 & used inhaled corticosteroids in omega-3 & omega-6 fatty acids groups, respectively) | | | | | | • Allocation concealment: unclear
| | | | • Study: medication use did not change significantly throughout the study (no data) | | | | | | • Applicability: III
Kirsch, 1988, USA ^54,^ ^55^ | • Enrolled/evaluated: 12/12 | • Parallel RCT, double-blind (maintained via restricted discussion of side effects, adjusted steroid doses, & treatment of minor complications) | • Inclusion: asthma ≥3 y duration; reversible airway obstruction ≥50% of d in past y (no description of recruitment process) | • Asthmatic, 9/12 allergic rhinitis via history & pin-prick test (5 & 4 in Low & High dos e groups, respectively); | • High dose omega-3 fatty acids group: 4 total g/d EPA ethyl ester via gelatine capsules (92% pure; contained <2.5% DHA: Maruyasu Ltd, Osaka, Japan; checked by gas chromatography & high performance liquid chromatography): 2 capsules, 4 times/d, each capsule with 0.5 g & each dose with 1g | • Low dose omega-3 fatty acids group: 0.1 total g/d EPA via gelatine capsules (same assessment of purity): 2 capsules, 4 times/d, each capsule with 0.0125 g & each dose with 0.025 g | • NS ? in total lung capacity in either study arm (p>.18)* | NR | n=0 | • Randomization: 1 | NIH Grants AI-19784, HL-31809, & HL-24136, &, the Veteran's Administration
| • Age (mean & range): 58.2 (42–73) y | • 16 wk (Run-in: 6 wk; 2 wk close-out) | • Exclusion: status asthmaticus, pneumonitis, pneumothorax or other major lung disease in past year. | • Severity: moderate (self-reported, & physician/observer, ratings): similar across study arms | • 8 wk intervention | • 8 wk intervention | • NS ? in airflow resistance in either study arm (p>.18)* | | | • Blinding: 1
| • % Male: 25 | | | • Duration: 26.08 y | • n=6/6 | | • NS ? in FEV_1_ in either study arm (p>.18)* | | | • Withdrawals/dropouts: 1
| • Race: NR | | | • Method: standard clinical evaluations & pulmonary function tests | • n=6/6 | | • NS ? in FEF_25–75_ in either study arm (p>.18)* | | | • Jadad total score: 3 (Grade: B)
| • Number of sites: 1 | | | • Pre-study: NR | | | • NS ? in self-reported asthma severity ratings in either study arm (p>.10)* | | | • Allocation concealment: unclear
| | | | • Study: types & doses of all onstudy medication, except for oral corticosteroids, kept constant; therapist allowed to adjust oral predisone dose ≤ 5 mg/wk; 10/12, including 6/6 in High dose group, got predisone; 1 on inhaled corticosteroids in Low dose group; 2/6 not on oral predisone in Low dose group, neither of whom on inhaled corticosteroids as well; similar oral predisone doses across study arms; 6/6 and 4/6 of same participants in Low & High dose groups, respectively, on both theophylline-like drug & beta-2 agonists; 3/6 & 2/6 in Low & High dose groups on cromolyn. | | | • NS ? in observer-reported asthma severity ratings in either study arm (p>.10)* | | | • Applicability: I
| | | | | | | • NS ? in generation of PGE by 10^6^ PMN leukocytes in either study arm (p>0.5)*
| | | | | | | • NS ? in generation of PGE by mononuclear leukocytes in either study arm (p>.05)*
| | | | | | | • S decrease in generation of LTB4 by 10^6^ PMN leukocytes only in High dose study arm (p<.01)*
| | | | | | | • S increase in generation of LTB5 by 10^6^ PMN leukocytes in High dose (p<.01)* & Low dose study arms (p<.001)*
| | | | | | | • NS ? in generation of PGE by mononuclear leukocytes in either study arm (p>.05)*
| | | | | | | • S decrease in generation of LTB_4_ by mononuclear leukocytes only in the High dose arm (p<.01)*
| | | | | | | • S increase in generation of LTB_5_ by mononuclear leukocytes in High (p<.001)* and Low dose arms (p<.05)*
| | | | | | | • S suppression of PMN leukocyte chemotaxis to C5a, LTB_4_ (3ng/ml), LTB_4_ (30ng/mL), 10^-7^ fMLP (M), & 10^-6^ fMLP (M) only in High dose study arm (all: p<.01)*
| | | | | | | • NS ? in suppression of mononuclear leukocyte chemotaxis to C5a, LTB_4_ (3ng/ml), LTB_4_ (30ng/ml), 10^-7^ fMLP (M), & 10^-6^ fMLP (M) (all: p>.01)*
McDonald, 1991, Australia^58^ | • Enrolled/evaluated: 15/NR | • RCT, 2-phase crossover (no phase orders reported); | • Inclusion: NR (recruited from a Chest Clinic at hospital) | • NR, non-smoking asthmatics (at least 7 were ex-smokers: stopped 1–31 y before study, & smoked 3–50 y prior to cessation); | • Omega-3 fatty acid supplementation via fish oil (manufacturer: NR) | • Control supplementation via 15 control capsules (undefined), containing a total of 15 g/d of olive oil (manufacturer: NR) | • NS between-arm difference in ? in AM PEF^†^ | NR | • n=NR (≥5) | • Randomization: 1 | NR
| • Age (mean & range): NR (28–72) y | • 28 wk (Run-in: 2 wk; washout: 6 wk) | • Exclusion: peptic ulcers, cardiovascular disease, other potential bleeding disorders | • Severity: moderately severe (undefined) | • 15 Lipitac capsules/day: total of 2.7 g/d EPA & 1.8 g/d DHA | • On-study dietary fish intake to be kept constant | • NS between-arm difference in ? in PM PEF^†^ | | • Problems swallowing capsules (n=2) | • Blinding: 1
| • % Male: 13.3 | | | • Duration: NR | • On-study dietary fish intake to be kept constant | • 10 wk intervention | • NS between-arm difference in ? in bronchodilator use^†^ | | • Unrelated medical problem (n=3) | • Withdrawals/ dropouts: 1
| • Race: NR, likely Caucasian/ European | | | • Method: recurrent reversible symptoms | • 10 wk intervention | • n=see omega-3 fatty acids description | • NS between-arm difference in ? in asthma symptom scores (cough, wheeze, dyspnoea, night-time asthma)^†^ | | | • Jadad total score: 3 (Grade: B)
| • Number of Sites: NR | | | • Pre-study: NR | • n=15/≤10 | | ^†^no data or tests of significance reported | | | • Allocation concealment: unclear
| | | | • Study: NR | | | | | | • Applicability: III
Nagakura, 2000, Japan^64^ | • Enrolled/evaluated: 30/29 | • Parallel RCT, double-blind (stratified for weight, with block size of 4) | • Inclusion: NR (in-patients 85% of the time due to asthma) | • NR | • EPA+DHA from fish oil | • Visually identical olive oil capsules | • S decrease in observer-evaluated asthma symptom scores only in omega-3 fatty acid arm (p=.01)* | NR | • n=7 (23.3%: 3 were controls) | • Randomization: 1 | NR
| • Age (mean & range): 11.02 (4–17) y | • 12 mo (Run-in: 2 mo) | • Exclusion: NR | • Severity: NR | • Capsule: 300 mg, including 84 mg EPA & 36 mg DHA (Nippon Suisan Kaisha Ltd., Tokyo, Japan) | • Capsule: 300 mg olive oil (Nippon Suisan Kaisha Ltd., Tokyo, Japan) | • S decrease in bronchial hyper-responsiveness to acetylcholine challenge only in the omega-3 fatty acid arm (p=.001)* | | • unable to swallow capsules (n=1/control); | • Blinding: 2
| • % Male: 51.7 | | | • Duration: mean = 10.1 y | • 6–12 capsules/d based on body weight (17–26.8 mg/kg/d EPA & 7.3–11.5 mg/kg/d DHA); 18.8–24.2 kg = 6 capsules/d, (2, three times daily); 24.8–32.6 kg = 8/d (3/2/3); 34.0–41.1 kg = 10/d (3/3/4); 45.3–59.2 kg = 12/d (4, three times daily) | • 6–12 capsules/d based on body weight (see fish oil arm for regimen) | | | • after asthma improved at 6 mo, discharged at request of parents (n=2); | • Withdrawals/ dropouts: 1
| • Race: NR, but likely Asian | | | • Method: NR | • 10 mo intervention | • 10 mo intervention | | | • no reasons given for discharge (n=4) | • Jadad total score: 4 (Grade: A)
| • Number of sites: 1 | | | • Pre-study: oral corticosteroids; undefined numbers on daily doses (no data) of theophylline, salbutamol, disodium cromoglycate, & beclomethasone diproprionate (inhaled corticosteroids: 3 users/study arm; mean dose in fish oil group: 166.7 mg/d; mean dose in controls: 183.3 mg/d); rescue = inhaled beta-2 agonists with intravenous theophylline, with or without hydrocortisone. | • n=15/11 | • n=15/12 | | | | • Allocation concealment: unclear
| | | | • Study: study arms “differed significantly” in amount of medication for acute asthma attacks (no data) | | | | | | • Applicability: III
Okamoto, 2000a, Japan^66^ | • Enrolled/evaluated: 14/14 | • Parallel RCT, blinding (NR) | • Inclusion: NR (admitted to hospital for treatment of asthma) | • NR, although 7 atopic (baseline serum IgE observed) | • ALA from perilla seed oil-rich supplementation (manufacturer: NR) | • Corn oil-rich supplementation (self-identified as source of omega-6 fatty acids) (manufacturer: NR) | • S greater increase in FEV_1_ in the omega-3 fatty acid arm (p<.05) | NR | n=0 | • Randomization: 1 | NR
| • Age (mean & range): 58.9 (22–84) y | • 4 wk (Run-in: NR) | • Exclusion: NR | • Severity: moderate (undefined) | • Replacing other oils, used as salad dressing &/or mayonnaise: 10–20 g/d | • Replacing other oils, used as salad dressing &/or mayonnaise: 10–20 g/d | • S increase in AM PEF only in the omega-3 fatty acid arm (p<.05)* | | | • Blinding: 0
| • % Male: 42.9 | | | • Duration: mean = 15 y | • Other dietary components unchanged | • Other dietary components unchanged | • S greater increase in FVC in the omega-3 fatty acid arm (p<.05) | | | • Withdrawals/ dropouts: 1
| • Race: NR, but likely Asian | | | • Method: post-bronchodilator FEV_1_ & response to methacholine challenge & diurnal PEF variation & clinical diagnosis via International Consensus of Diagnosis and Management of Asthma criteria (airways inflammation, bronchial hyper-responsiveness to non-specific stimuli, episodic & reversible airflow obstruction) | • 4 wk intervention | • 4 wk intervention | • S increase in V_25_ only in the omega-3 fatty acid arm (p<.05)* | | | • Jadad total score: 2 (Grade: C)
| • Number of sites: 1 | | | • Pre-study: all regularly using long-acting oral theophylline, inhaled beta-2 agonists, &, beclomethasone dipropionate (inhaled corticosteroid; mean dose: 196.4±173.7 mg/d) | • n=7/7 | • n=7/7 | • S greater decrease in generation of LTB_4_ by peripheral leukocytes in the omega-3 fatty acid arm (p<.05)^†^ | | | • Allocation concealment: unclear
| | | | • Study: NR | | | • S greater decrease in generation of LTC_4_ by peripheral leukocytes in the omega-3 fatty acid arm (p<.05)^†^ | | | • Applicability: III
| | | | | | | ^†^no assessment of results at final 4-wk followup, with decreasing LTB_4_ & LTC_4_ generation in the control arm
Stenius-Aarniala, 1989, Finland^68^ | • Enrolled/evaluated: 36/29 | • RCT, 3-phase crossover (6 possible phase orders); double-blind | • Inclusion: NR | • Relatively stable asthma: 4 aspirin-sensitive; 4 skin-test positive; | • 20 mL daily of MaxEPA® fish oil (Seven Seas Health Care Ltd., Hull, UK): bottles concealed yet no attempt to conceal taste | • Control phase: 20 mL daily of olive oil (bottles concealed yet no attempt to conceal taste): 77% monoenoic acids (mainly oleic acid) (Seven Seas Health Care Ltd., Hull, UK) | • NS differences between the 3 phases for AM PEF (% predicted)^†^* | NR | • n=7 (could not tolerate taste of the oil, or difficulty keeping asthma diary: no breakdown for study phases by problem) | • Randomization: 1 | NR, with MaxEPA® provided by Orion Pharmaceuticals
| • Age (mean & range): 40 (19–61) y | • 32 wk (Run-in: 2 wk); no washout | • Exclusion: fish allergy, diabetes, or coagulation disorders | • Severity: moderate (= PEF variability >15%); 3/29 smokers; 12/29 ex-smokers (not in last 2 y); | • 18% EPA + 12% DHA (dose not given in g) | • Phase 3: 20 mL daily of Evening primrose oil: Naudicelle®: Bio-Oil Research Ltd., Crewe, UK) phase (bottles concealed yet no attempt to conceal taste): 72% cis-linoleic acid & 9% gammalinolenic acid (source of omega-6 fatty acids) | • NS differences between the 3 phases for PM PEF (% predicted)^†^* | | | • Blinding: 0
| • % Male: 52.6 | | NB: Excluded during run-in period because variations (undefined) in their diurnal PEF were too small (n=4) | • Duration: NR | • Self-delivery by 10 mL spoon | • Each preparation self-delivered by 10 mL spoon | • S higher plasma PGE_2_ levels in the fish oil phase than the other 2 phases (p<.05)* | | | • Withdrawals/ dropouts: 1
| • Race: NR, but likely Scandinavian | | | • Method: MD clinical diagnosis: all fulfilled American College of Chest Physicians & American Thoracic Society (1975) criteria; | • 10 wk intervention (per phase) | • 10 wk intervention (per phase) | • S lower plasma PGF_2-alpha_ levels in the control (olive oil) phase than the other 2 phases (p<.05)* | | | • Jadad total score: 2 (Grade: C)
| • Number of sites: 1 | | | • Pre-study: 29/29 on inhaled beta-2 agonists, 24 inhaled corticosteroids, 8 long-term oral corticosteroids, 2 disodium cromoglycate, 3 ipratropium bromide, 26 oral theophylline, 1 oral beta-2 agonists. | • n=36/29 | • n=see omega-3 fatty acids description | • NS between-phase differences in plasma levels of TxB_2_ (p>.05)* | | | • Allocation concealment: unclear
| | | | • Study: drug use unchanged during all phases (no data re how may have changed from pre-study) | | | • NS between-phase differences in plasma levels of 6-keto-PGF_1-alpha_ (p>.05)* | | | • Applicability: III
| | | | | | | • NS between-phase differences in urine levels of PGE_2_ (p>.05)*
| | | | | | | • NS between-phase differences in urine levels of PGF_2-alpha_ (p>.05)*
| | | | | | | • NS between-phase differences in urine levels of TxB_2_ (p>.05)*
| | | | | | | • NS between-phase differences in urine levels of 6-keto-PGF_1-alpha_ (p>.05)*
| | | | | | | ^†^no tests of significance reported
Thien, 1993, Engand^67^ | • Enrolled/evaluated: 37/25 | • Parallel RCT, double-blind (evaluated in and out of pollen season) | • Inclusion: grass pollen sensitive; hay fever symptoms associated with asthma during pollen season; (recruited from Hospital Allergy Clinic) | • NR, no aspirin sensitivity; all pollen-sensitive (positive skin-prick test) & hay fever; some sensitive to fungal spores yet assumed that equally distributed via randomization | • 5.4 g/d from fish oil capsules | • Visually identical olive oil capsules (no amount of oil reported) (Seven Seas Ltd, Marfleet, Hull, UK) | • NS between-arm difference in respiratory symptom score (diary card) in pollen season^†^* | NR | • n=12 (32%): (no indication of study arms from which 11/12 participants left): | • Randomization: 1 | British United Provident Association Medical Foundation (independent medical research charity), National Asthma Campaign (UK), &, Seven Seas, Marfleet, Hull (UK) for MaxEPA® & matched control capsules
| • Age (mean & range): NR (19–42) y (completers only) | • 26 wk (Run-in: 2 wk) | • Exclusion: NR | • Severity: NR | • MaxEPA® (Seven Seas, Ltd., Marfleet, Hull, UK) capsule (total: 3.2 g/d EPA + 2.2 g/d DHA): 18 capsules/d | • 6 mo intervention | • NS between-arm difference in total bronchodilator use (diary card) in pollen season^†^* | | • withdrew from EPA study arm in first wk when developed nausea & vomiting after taking capsules (n=1) | • Blinding: 2
| • % Male: 52 (completers only) | | | • Duration: NR | • 6 mo intervention | • n=NR/10 | • NS between-arm difference in AM PEF (% predicted) in pollen season^†^* | | • size & number of capsules found to be unmanageable, withdrew after first wk (n=2) | • Withdrawals/ dropouts: 1
| • Race: NR, but likely Caucasian/ European | | | • Method: NR (only histamine bronchial challenge) | • n=NR/15 | | • NS between-arm difference in PM PEF (% predicted) in pollen season^†^* | | • size & number of capsules found to be unmanageable, withdrew in first 2 wk (n=4) | • Jadad total score: 4 (Grade: A)
| • Number of sites: 1 | | | • Pre-study: no oral corticosteroids, sodium cromoglycate, nedocromil sodium, or theophylline; | | | • NS between-arm difference in diurnal PEF variability (% maximum) in pollen season^†^* | | • withdrew in first month when unable to perform daily peak flows & complete diary cards (n=2) | • Allocation concealment: unclear
| | | | • Study: asked to maintain constant inhaled corticosteroid dose (confirmed; no data), & 8/25 completers regularly used them (≤200 μg/d, 1 used 400 μg/d; 13/25 completers on salbutamol inhaler (EPA: 8; control: 5); 7 regular salbutamol (EPA: 3; control: 4); 5 regular salbutamol & beclomethasone dipropionate (inhaled corticosteroid) via inhaler (EPA: 4; control: 1); chlorpheniramine or terfenadine permitted for symptom relief; longer-acting anti-histamines (e.g., cetirizine, astemiozole) not permitted | | | • NS between-arm difference in histamine responsiveness (airways conductance: sGAW) in pollen season^†^* | | • difficulty taking capsules & recording daily peak flows & diary cards (n= 2) | • Applicability: III
| | | | | | | ^†^intervention began when started recording data using diary cards, suggesting that ‘pre-intervention’ data were influenced by intervention. | | • withdrew for personal reasons (n=1)

NR = not reported; NA = not applicable; ? = change; S = significant; NS = nonsignificant; pts = participants; n = number of participants; enrolled = n qualified; evaluated = n analyzed; completed = n completing the study; Note: superscripts refer to reference list in main report

* No reported statistical test of the between-arm difference in (%) ? in the outcome

Evidence Table 2. Evidence from other study designs regarding health effects of omega-3 fatty acids on asthma

Author, Year, Location | Study Characteristics | Study Design & Duration | Eligibility Criteria | Asthma Description/Severity/Duration/Diagnostic Method/Pre-study Medication/Study Medication | Intervention/Exposure Definition (Omega-3 Fatty Acid Type(s)/Source/Delivery/Serving Size or Dose/ Length) & Number of Pts Enrolled/Completed | Comparator Definition (Control or Background Diet/Source/ Delivery/Serving Size or Dose/Length) & Number of Pts Enrolled/Completed | Results | Concurrent Conditions & Medications | Number (%) of & Reasons for Dropouts/ Withdrawals (Per Study Arm) | Quality (Internal Validity) & Applicability (External Validity) | Funding Source
Ashida, 1997, Japan^59^ | • Enrolled/evaluated: 5/5 | • Non-comparative case series | • Inclusion: pts with asthma admitted to hospital for treatment | • Bronchial asthma (n=4), cough variant asthma (n=1) | • Perilla seed oil supplementation (ALA: undefined amount) | NA | • S decrease in asthma symptoms score (cough, wheeze, daytime activity, sputum volume, dyspnoea) (p<.05) | NR | n=0 | • Total quality score: 3 (Grade: B) | NR
| • Age (mean & range): 60.2 (51–72) y | • 2 wk (Run-in: NR) | • Exclusion: NR | • Severity: NR | • 15 g/d Perilla seed oil as replacement salad dressing &/or mayonnaise | | • S increase in AM PEF (p<.05) | | | • Applicability: III
| • % Male: 0 | | | • Duration: mean = 10.6 (4–19) y | • 2 wk exposure | | • S increase in PM PEF (p<.05)
| • Race: NR, likely Asian | | | • Method: NR | • Other diet unchanged | | • S decrease in generation of LTB_4_ by peripheral leukocytes (p<.05)
| • Number of sites: 1 | | | • Pre-study: all on oral long-acting theophylline (200–400 mg/d); inhaled beta-2 agonists; inhaled beclomethasone dipropionate (400–1200 μg/d), prednisolone 5 mg/d (n=2) | • n=5/5 | | • S decrease in generation of LTC_4_ by peripheral leukocytes (p<.05)
| | | | • Study: same as prestudy (doses of inhaled corticosteroid & oral theophylline constant during study)
Broughton, 1997, USA^73^ | • Enrolled/evaluated: 26/19 | • Non-comparative case series (2-phase): High ratio always followed by Low ratio exposure | • Inclusion: non-specific bronchial responsiveness to methacholine with FEV_1_>70%; non-smoking atopic asthmatic pts | • Non-smoking, atopic asthmatics; no upper respiratory tract infections or asthma exacerbations 6 wk prior to study | • Low fish oil supplementation^†^ | • High fish oil supplementation^†^ | • With low ratio exposure: S reduction from baseline of 51%, 89%, 65% & 92% in provocative methacholine dose to cause a 20% fall in FVC_1_, FEV_1_, PEF, FEF_25–75_, respectively (p<.05)* | NR | 7 (27%) dropouts; Reasons: NR | • Total quality score: 3 (Grade: B) | University of Wyoming Biomedical Research Support & Shaklee Corporation (Hayward, CA)
| • Age (mean & range): 22 (19–25) y | • 8 wk (Run-in: NR; no washout) | • Exclusion: use of fish oil supplements; >1 fish meal/wk; history of bleeding disorder or delayed clotting time | • Severity: NR | • Average dose: ~0.7 g/d EPA+DHA | • Average dose: ~3.3 g/d EPA+DHA | • With high ratio exposure: NS difference (p>.05)* from baseline in provocative methacholine dose to cause a 20% fall in each of FVC_1_, FEV_1_, PEF, FEF_25–75_ | | | • Applicability: I
| • % Male: NR | | | • Duration: NR | • Omega-6/omega-3 fatty acid ratio = 1:0.1 | • Omega-6/omega-3 fatty acid ratio = 1:0.5 | • With high ratio exposure: responders' (NS fall in respiratory measures with increased challenge) respiratory responses were never reduced by 20%, regardless of the methacholine dose (no data)
| • Race: NR | | | • Method: air flow obstruction; FEV_1_>70% of predicted with methacholine test | • Capsules of fish oil (Dose: NR; Shaklee Corporation) | • Capsules of fish oil (Dose: NR; Shaklee Corporation) | • With high ratio exposure: nonresponders (respiratory reductions with increased challenge) had significantly greater difficulty breathing at 1.375 units methacholine, & respiratory capacity hindered by high omega-3 fatty acid ratio for 3 of 4 respiratory outcomes (no data), with only FEF_25–75_ improved (no data)
| • Number of sites: 1 | | | • Pre-study: salbutamol, oral corticosteroids, oral theophylline, (doses: NR) | • 4 wk exposure (average increase in energy was <1.5%) | • 4 wk exposure (average increase in energy was <1.5%) | • S increase in urinary total LTE_4_ excretion associated with low ratio (p<.05)*
| | | | • Study: NR, no nonsteroidal anti-inflammatory drugs | • n=26/19 | • n=26/19 | • NS Δ in urinary LTE_5_ excretion associated with low ratio (p>.05)
| | | | | | | • NS Δ in urinary LTE_4_ excretion with high ratio for responders or nonresponders (p>.05)*
| | | | | | | • Significantly lower urinary LTE_4_ excretion with high ratio (p<.05)*
| | | | | | | • S increase in urinary LTE_5_ excretion with high ratio for responders & nonresponders (p<0.5)*
| | | | | | | • NS Δ in urinary LTE_4_ excretion in responders & nonresponders combined (p>.05)*
| | | | | | | • Significantly higher urinary LTE_5_ excretion for responders with high ratio (p<.05)*
Gorelova, 1998, Russia^70^ | • Enrolled/ evaluated: 33/NR | • Non-randomized controlled trial: matched for age, diagnosis & treatment (no data) | • Inclusion: NR | • Asthmatic pts with atopic dermatitis | • ‘Polyen’ supplementation & hypoallergenic diet (poorly defined) | • Hypoallergenic diet (poorly defined) | • Significantly lower bronchodilator use in the omega-3 fatty acids arm (p<.05)* | • Atopic dermatitis & NR | NR | • Total quality score: 2 (Grade: C) | NR
| • Age (mean & range): NR (1–12) y | • NR (Run-in: NR) | • Exclusion: NR | • Severity: NR | • Fish oil capsules from seafish bodies; 1 capsule = 0.3 g fish oil: total 4.5 g/d fish oil (omega-3 fatty acid content not <25%) (types & amounts not defined) | • Control (NR) | | | | • Applicability: III
| • % Male: NR | | | • Duration: NR | • Omega-6/omega-3 fatty acid ratio data contradictory | • Omega-6/omega-3 fatty acid ratio data contradictory
| • Race: NR | | | • Method: NR | • Length: NR | • Length: NR
| • Number of sites: 1 | | | • Pre-study: broncholytics, antihistamines and corticosteroids (undefined) | • n=23/NR | • n=10/NR
| | | | • Study: same drugs
Hashimoto, 1997, Japan^62^ | • Enrolled/ evaluated: 8/8 | • Non-comparative case series | • Inclusion: ambulatory pts with Total Cholesterol >220 mg/dL or triglycerides >170 mg/dL with pre-existing hyperlipidemia and mild to moderate asthma | • Mild to moderate asthmatic pts, allergic dermatitis (n=4), hyperlipidemia (n=8) | • EPA | NA | • S decrease in symptom score (undefined) (p<.05) | • Allergic dermatitis (n=4); Hyperlipidemia (n=8) | n=0 | • Total quality score: 3 (Grade: B) | NR
| • Age (mean & range): 61.6 (38–78) y | • 10 wk (Run-in: 2 wk) | • Exclusion: antihistamine <2 wk prior to study; >5 mg/d oral prednisone; long-term steroids (undefined) started <1 mo before study | • Duration: NR | • 1800 mg/d EPA | | • S decrease in asthma score (undefined) (p<.05) | | | • Applicability = III
| • % Male: 12.5 | | | • Severity: mild to moderate | • 8 wk exposure | | • S decrease in therapeutic score (undefined) (p<.05)
| • Race: NR, likely Asian | | | • Method: NR | • n=8/8 | | • NS Δ in sleep score (undefined) (p>.05)
| • Number of sites: 1 | | | • Pre-study: NR | | | • NS Δ in daily life score (undefined) (p>.05)
| | | | • Study: NR | | | • S % increase in AM PEF (p<.05)
| | | | | | | • S % increase in PM PEF (p<.05)
| | | | | | | • NS Δ in urinary LTB_4_ excretion (p>.05)
| | | | | | | • NS Δ in urinary LTE_4_ excretion (p>.05)
Machura, 1996, Poland^63^ | • Enrolled/ evaluated: 60/60 | • Non-randomized controlled trial | • Inclusion: NR | • Bronchial asthma: mild (n=21; 76% atopic); severe (n=16; 56% allergic asthma); controls (75% atopic) | • Fish oil supplementation | • Control: sunflower oil | • NS difference between mild asthma subgroup and controls in number of days with increased severity of asthma symptoms (p>.05)* & S difference between severe asthma subgroup and controls in number of days with increased severity of asthma symptoms (p=.05)* | NR | NR | • Total quality score: 3 (Grade: B) | NR
| • Age (mean & range): NR (7–17) y | • 12 wk (Run-in: NR) | • Exclusion: NR | • Severity: NR | • 5 mL oil at each of 3 main meals: total 15 mL fish oil/d, 3 g/d EPA | • 5 mL oil at each of 3 main meals: total 15 mL sunflower oil/d | • NS difference between either subgroup and controls in loss of asthma control (p>.05)* | | | • Applicability: III
| • % Male: NR | | | • Duration: mild (mean = 7.6 y); severe (mean = 9.25 y); controls (mean = 7.36 y) | • 12 wk exposure | • 12 wk exposure | • NS difference between either asthma subgroup and controls in PEF (p>.05)*
| • Race: NR, likely Caucasian/ European | | | • Method: NR | • n=37/37 | • n=23/23 | • Significantly higher FEF_25–75_ only in mild asthma subgroup relative to controls (p<.05)*
| • Number of sites: NR | | | • Pre-study: routine asthma treatment | | | • NS difference between either asthma subgroup and controls in FEV_1_ (p>.05)*
| | | | • Study: NR
Masuev, 1997a, Russia^60^ | • Enrolled/ evaluated: 34/NR | • Non-randomized controlled trial: matched for age, sex & asthma severity | • Inclusion: NR | • Bronchial asthma atopic (n=17); infection-dependent asthma (n=10) | • EPA+DHA (undefined amount) & vitamin E (undefined amount) | • Olive oil capsules: 6 g/d | • S decrease in 5-hydroxyeicosatetraenoic acid (5-HETE) production with omega-3 fatty acids exposure (p<.05)* | NR | NR | • Total quality score: 2 (Grade: C) | NR
| • Age (mean & range): 50.2 (NR) y | • 2 mo (Run-in: NR) | • Exclusion: NR | • Severity: NR | • ‘Eiconol’ capsules: 6 g/d | • 2 mo exposure | • ? in 5-hydroxyeicosapentaenoic acid (5-HEPE) with omega-3 fatty acids exposure (statistical test: NR)* | | | • Applicability: III
| • % Male: NR | | | • Duration: NR | • 2 mo exposure | • n=7/NR
| • Race: NR | | | • Method: NR | • n=27/NR
| • Number of sites: NR | | | • Pre-study: NR
| | | | • Study: NR
Masuev, 1997b, Russia^61^ | • Enrolled/evaluated: 8/8 | • Non-randomized controlled trial: identified those with both acute & late asthma reaction to allergen inhalation challenge, then divided them into 2 subgroups matched for age, sex, & duration of asthma | • Inclusion: selected on basis of positive skin prick test to house dust, & late asthmatic reaction to allergen inhalation challenge; test was positive if, after 4–8 h, PEF decreased by ≤35% | • Bronchial asthma (relative remission), & hyper-sensitive to house dust | • 6 g/d EPA+DHA | • Capsules of olive oil (6 g/d) not containing omega-3 fatty acids | • S increase in PEF (relative to pre-exposure) 4–8 h after allergen challenge (late response period) only in the omega-3 fatty acids subgroup (p<.05)* | NR | n=0 | • Total quality score: 4 (Grade: A) | NR
| • Age (mean & range): NR (17–40) y | • 8 wk (Run-in: NR) | • Exclusion: NR | • Severity: NR | • ‘Eiconol’ capsules | • 8 wk exposure | | | | • Applicability: III
| • % Male: NR | | | • Duration: mean = 3–12 y | • 8 wk exposure | • n=3/3
| • Race: NR, likely Caucasian/ European | | | • Method: NR | • n=5/5
| • Number of sites: NR | | | • Pre-study: not taking steroids (undefined)
| | | | • Study: NR
Okamoto, 2000b, Japan^71^ | • Enrolled/evaluated: 26/26 | • Non-comparative case series | • Inclusion: mild asthmatic pts | • Mild asthmatic pts: atopic (n=13) | • Perilla seed oil supplementation (ALA: undefined amount) | NA | • Identified responders (vs nonresponders) as participants with significantly decreased LTC_4_ generation by peripheral leukocytes (see below) | NR | n=0 | • Total quality score: 4 (Grade: A) | NR
| • Age (mean & range): 61 (30–84) y | • 4 wk (Run-in: NR) | • Exclusion: NR | • Duration: mean = 8.7 y | • 10–20 g/d as replacement salad dressing &/or mayonnaise (mean dose = 14.65 g/d) | | • While S increase in AM PEF for responders & nonresponders (p<.05), values significantly lower for responders during study (p<.05) | | | • Applicability: III
| • % Male: 38.5 | | | • Severity: mild | • 4 wk exposure | | • Significantly lower baseline FVC, FEV_1_ & V_25_ values for responders (p<.05)
| • Race: NR, likely Asian | | | • Method: according to criteria of the International Consensus on Diagnosis and Treatment of Asthma: symptoms, FEV_1_, PEF variability, or methacholine test | • Diet unchanged | | • S increases in FVC & FEV_1_ from exposure only for responders (p<.05)
| • Number of sites: 1 | | | • Pre-study: long-acting oral theophylline, inhaled beta-2 agonists, inhaled corticosteroids (mean dose = 305.8 μg/d) | • n=26/26 | | • S differences between responders & nonresponders in FVC & FEV_1_ at final follow-up (p<.05)
| | | | • Study: NR | | | • LTC_4_ generation by peripheral leukocytes decreased and increased significantly for responders & nonresponders, respectively (p<.05)
| | | | | | | • At final follow-up, LTC_4_ levels differed significantly for responders & nonresponders (p<.05)
Picado, 1988, Spain^74^ | • Enrolled/evaluated: 10/10 | • Non-comparative case series (2-phase): first placebo, then fish oil | • Inclusion: aspirin-intolerant asthmatic pts | • Aspirin-intolerant asthmatic pts, nasal polyps (n=5) | • Experimental diet: MaxEPA® & sardine oil | • Placebo (lactose) | • NS ? in pulmonary symptom score (cough/dyspnoea) with either exposure (p>0.05)* | NR | n=0 | • Total quality score: 5 (Grade: A) | Sociedad Española Patologia Respiratoria
| • Age (mean & range): 52 (31–65) y | • 14 wk (single blind) (Run-in: 2 wk; no washout) | • Exclusion: NR | • Severity: NR | • 18.4% EPA + 10.5% DHA | • 12 capsules/d & eucaloric diet (including 32% fat) | • S decrease in PEF only with fish oil exposure (p<.05)* & S difference in PEF between fish oil and control at final followup (p<.05)* | | | • Applicability: III
| • % Male: 30 | | | • Duration: mean = 24.7 (4–56) y | • 3 g/d of omega-3 fatty acids (150 mg sardine oil & 12 MaxEPA® fish oil capsules) & eucaloric diet (including 32% fat) | • 6 wk exposure | • NS between-exposure difference in oral corticosteroid use over the study (p>.05)*
| • Race: likely Caucasian/European | | | • Method: bronchial reaction to aspirin challenge | • 6 wk exposure | • n=10/10 | • S increase in bronchodilator use only during the last 2 wk of fish oil exposure (p<.05)* & S between-exposure difference in bronchodilator use in last 2 wk, with greater use in fish oil exposure (p<.05)*
| • Number of sites: 1 | | | • Pre-study: steroid dependent (oral prednisone & inhaled beclomethasone dipropionate) (n=7) | • n=10/10 | | • S decrease in concentration of TxB_2_ only with fish oil exposure (p<.001)*
| | | | • Study: oral prednisone (n=7), fixed dose inhaled beclomethasone dipropionate and fixed dose salbutamol (2 puffs every 6 h); prednisone 30 mg/d if acute attack
Villani, 1998, Italy^72^ | • Enrolled/evaluated: 7/7 | • Non-comparative case series • | • Inclusion: asthmatic participants in clinical remission & FEV_1_>80% predicted, & positive skin prick test to ≥2 aero-allergens | • Atopic pts with mild seasonal asthma due to airborne allergens, in clinical remission; no respiratory infections <8 wk prior to enrollment; assessed outside pollen season | • EPA+DHA | NA | • S reduction in maximum fall in FEV_1_ in response to bronchial challenge (p<.05) | NR | n = 0 | • Total quality score: 4 (Grade: A) | NR
| • Age (mean & range): 31 (20–49) y | • 30 d (Run-in: NR) | • Exclusion: receiving asthma medication | • Duration: NR | • 1 g/gel capsule = 3 g/d with EPA & DHA in 1:1 ratio | | • S reduction in airways responsiveness to bronchial challenge (p<.05) | | | • Applicability: III
| • % Male: 57 | | | • Severity: mild | • 30 d exposure | | • S decrease in residual volume after 30 d (p<.05)
| • Race: NR, likely Caucasian/European | | | • Method: positive skin prick test to ≥2 aero-allergens, FEV_1_ >80% | • Free diet | | • NS ? in TLC (p>.05)
| • Number of sites: 1 | | | • Pre-study: none | • n=7/7 | | • NS ? in FEF_25–75_ (p>.05)
| | | | • Study: none | | | • NS ? in PEF (p>.05)
| | | | | | | • NS ? in slow vital capacity (p>.05)

NR = not reported; NA = not applicable; ? = change; S = significant; NS = nonsignificant; pts = participants; n = number of participants; enrolled = n qualified; evaluated = n analyzed; completed = n completing the study; Note: superscripts refer to reference list in main report

* No reported statistical test of the between-arm difference in (%) ? in the outcome

Evidence Table 3. Randomized controlled trial evidence of omega-3 fatty acids to prevent asthma

Author, Year, Location | Study Characteristics | Study Design & Duration | Eligibility Criteria | Asthma Description/Severity/Duration/Diagnostic Method/Pre-Study Medication/Study Medication | Intervention/Exposure Definitions (number Randomized) (Omega-3 Fatty Acid Type(s)/Source/Delivery/ Serving Size or Dose Intervention Length) | Comparator Definitions (number Randomized) (Control or Background Diet/Source/Delivery/Serving Size or Dose/Intervention Length) | Results | Concurrent Conditions & Medications | Number (%) of & Reasons for Dropouts/Withdrawals (Per Study Arm) | Quality (Internal Validity) & Applicability (External Validity) | Funding Source
Mihrshahi, 2003,^50,^ ^51^ Australia | • Enrolled/evaluated: 616/554 | • Factorial RCT | • Inclusion: pregnant women (36 wk gestation) with unborn children at high risk for asthma (≥ 1 parent or sibling with asthma or asthma symptoms), reasonable fluency in English, telephone at home, reside within 30 km of recruitment center | • Possible asthma & symptoms in 18 mo-old children: MD diagnosis & use of asthma medication <6 mo | • Arm C (n=159): active diet (see below) & no house dust mite reduction (advice on cleaning & ventilation; no placebo mattress covers) | • Arm A (n=149): placebo diet & no house dust mite reduction | • NS difference in diagnosed prevalence of asthma (14.7% vs 12.5% in active vs control diet groups): -2.2% [95% CI -7.9% to 3.5%]) or for any medication use, including inhaled corticosteroids (1.3 [-3.2 to 5.8]) | • Smoking in pregnancy (24%) | • Withdrew immediately after birth (n=6) & prior to 12 mo visit: birth weight <2.5 kg; major surgery or hospitalization for >1 wk; congenital malformations or other significant disease | • Randomization: 1 | • National Health and Medical Research Council of Australia, New South Wales Health Department; The Children's Hospital at Westmead; & Cooperative Research Centre for Asthma
| • Age (mean & range): 18 mo | • 18 mo interim analysis in 60 mo study (Run-in: NR) | • Exclusion: pet cat at home, families on strict vegetarian diet, multiple births, born <36 wk gestation | • Severity: American Thoracic Society definition (mild, moderate, severe) | • Arm D (n=153): active diet & active house dust mite reduction | • Arm B (n=155): placebo diet & active house dust mite reduction (impermeable mattress covers; washable play mat; bedding & mat washed in acaricidal detergent prior to birth & every 3 mo) | • Significantly lower number of episodes of wheeze ‘ever’ (9.8% [1.5%–18.1%]; p=.02) & of wheeze >1 wk (7.8% [0.5–15.1; p=.04) in active (vs control) diet arm• NS differences in number of: episodes of wheeze >1 wk unassociated with a cold (p=.34), episodes of wheeze with difficulty breathing (p=.82), visits to doctor for wheeze (p=.09), visits to emergency for wheeze (p=.30), hospital admissions for wheeze (p=.54), &, episodes of cough for >1 wk unassociated with a cold (p=.76) | • Mothers with eczema (26.9% control, 22.6% diet) | • Withdrew before 12 mo visit (n=56; reasons: NR) | • Blinding: 0 | • Goods & services from Allergopharma Joachim Ganzer KG Germany, John Sands Australia, Hasbro, Refrigerated Roadways, & AstraZeneca
| • % Male: 50 | | | • Duration: NR | • Active diet: one 500 mg capsule/d tuna fish oil (0.8 mg EPA + 3.6 mg DHA per kg body weight; 37% omega-3 fatty acids & 6% omega-6 fatty acids: Clover Corporation, Sydney, Australia) given to child in favorite foods/drinks from age 6 mo; if breast fed pre-6 mo, no supplement used (omega-3 fatty acids in breast milk equals supplement); if bottle fed, fish oil added to formula; dose standardized for fluid intake & child's age; pre-birth onwards, family given canola oil & margarine (6% omega-3 fatty acids & 16% omega-6 fatty acids) (ALA: NR) | • Placebo diet: one 500 mg/d Sunola oil capsule (0.3% omega-3 fatty acids, 7% omega-6 fatty acids, 82% monounsaturated fatty acids: Clover Corporation, Sydney, Australia) delivered as per active diet; pre-birth onwards, family given polyunsaturated oils & margarines (1.2% omega-3 fatty acids, 40% omega-6 fatty acids) | • NS effect for house dust mite intervention for any of above-noted outcomes (p>.05)p>.05) | • Family history asthma: mother (55%), father (40%) | • Withdrew before 18-mo assessment | • Withdrawals/ dropouts: 1 | • Reduced cost goods from Auspharm, Allersearch, Meadow Lea Foods, & Clover Corporation
| • Race: NR, likely European/ Caucasian; some of Aboriginal/ Torres Strait Islander descent (3%) | | | • Method: positive skin prick test, symptoms assessed by nurse & questionnaire. | • Target omega-6/omega-3 fatty acid ratio = 5:1 | • Target omega-6/omega-3 fatty acid ratio = 15–20:1 | • NS interactions between active diet and house dust mite avoidance interventions in effect on any outcomes (p<.05) | • Medications (NR) | • (n=6; reasons: NR) | • Jadad total score: 2 (Grade: C)
| • Number of Sites: 6 | | | • Pre-study: NA | • 18 mo intervention | • 18 mo intervention | • Significantly higher proportion of omega-3 fatty acids in active diet than control arms (p<.0001) &, of omega-6 fatty acids in control arm than in active diet arm (p<.0001) | | • Characteristics associated with withdrawals: parents younger, mothers less likely to be tertiary- educated, & fathers less likely to be employed full-time | • Allocation concealment: adequate
| | | | • Study: inhaled bronchodilators (albuterol, terbutaline &/or ipratropium bromide), cromoglycate or nedocromil, inhaled corticosteroids (beclomethasone, budesonide, or fluticasone), oral antihistamines, nasal steroids, oral prednisone | | | • Significantly different ratio of omega-6/omega-3 fatty acids in active (5:1) & control arm plasma (7.14: 1: p<.0001) | | • No data per study arm. | • Applicability: III
| | | | | | | • NB: Confounders equally distributed across arms (environmental smoke exposure; being male; maternal asthma history; breast-fed; low birth weight; young mothers)

NR = not reported; NA = not applicable; ? = change; S = significant; NS = nonsignificant; n = number of participants; enrolled = n qualified; evaluated = n analyzed; completed = n completing the study; Note: superscripts refer to reference list in main report

Evidence Table 4. Observational study evidence of omega-3 fatty acids for prevent of asthma

Author, Year,Location | Study Characteristics | Study Design/ Selection Criteria/ Selection Method/ Study Duration | Asthma (sub-) Population Description/ Severity/Duration/Diagnostic Method/ Medications | Other (Sub-) Population(s): Description | Factors Distinguishing (Sub-) Populations | Exposure(s) | Dietary Intake Data Collection Method/Timeframe/Informant-Administrator | Results | Number (%) of & Reasons for Exclusion | Quality Internal Validity & Applicability (External Validity) | Funding Source
Hodge, 1996,^77^ Australia | • Enrolled/evaluated: 584/468 | • Stratified case-control design | • Current asthma: wheeze & AHR (n=71): Age (mean & range): 9.6 (9.4–9.8) y; % male: 56.3; weight (mean & range): 34.0 (32.3–35.7) kg | • Normal airways (neither wheeze nor AHR: n=263): Age (mean & range): 9.5 (9.4–9.6) y; % male: 56.3; weight (mean & range): 32.8 (32–33.6) kg | • Current asthmatics vs AHR only vs wheeze only vs normal airways: atopy (93% vs 65.5% vs 48.1% 27.8%); early respiratory infection (22.5% vs 10.9% vs 22.8% vs 11.4%); parental asthma (40.9% vs 20.0% vs 41.8% vs 21.3%); Australian born (81.7% vs 81.8% vs 89.9% vs 82.5%) | • Consumption of fish over the last year (fresh fish, non-oily fish, oily fish) | • Dietary questionnaire (consumption patterns for >200 foods [& sodium intake] common in Australia, including fish): daily, weekly, monthly, rarely, never (Common-wealth Scientific & Industrial Research Organization; Division of Human Nutrition, South Australia) | • When results unadjusted, risk of current asthma significantly lower in consumers of any fresh fish [OR 0.50 (0.27–0.92); p<.05)] or oily fresh fish [OR 0.29 (0.13–0.67); p<.01); current asthma found in only 8.8% of children who ate oily fish but in 15.6% of those who ate non-oily fish only, & 23% of those who never ate fresh fish (p-values: NR) | • Did not receive questionnaire (n=10; reasons: NR) | • Total quality score: 2 (Grade: C) | • Fisheries Research and Development Corporation, Australia
| • Age (mean & range): 9.5 (9.4–9.6) y | • Inclusion: Cross-section of 808 children aged 8–11 y from schools randomly selected within 10 km radius of Sydney landmark. With airways hyper-responsiveness (AHR) to exercise, wheeze in last 12 mo, & 3-in-5 sample of normal airways (no AHR, no wheeze) by excluding 2 after every 3 from numerically ordered list | • Severity: NR | • Airways hyper-responsiveness only (n=55): Age (mean & range): 9.3 (NR) yrs; % male: 63.6; weight (mean & range): 33 (NR) kg | | • Oily fish: >2% fat (e.g., blue-eyed cod; blue mackerel) | • Time: last 12 mo | • When results adjusted for risk factors (atopy, parental asthma, parental smoking, ethnicity, country of birth, early respiratory illness, & gender), only children who ate oily fresh fish had a S reduced risk of current asthma [OR 0.26 (0.09–0.72); p<.01)]; in these children, the risk was 1/4 that of those who did not eat oily fish | • Non-responders: 106 (18.5%); NS difference between responders & non-responders in prevalence of AHR (26.0% vs 27.1%) or fish consumption (46.2% vs 52.1%) | • Applicability: III
| • % Male: 50.2 | • Exclusion: non-responders | • Duration: NR | • Wheeze only (n=79): Age (mean & range): 9.3 (NR) yrs; % male: 57; weight (mean & range): 32.9 (NR) kg | | • Non-oily fish: ≤2% fat | • Parental questionnaire (collected by blinded study coordinator) | • Significantly fewer children with current asthma included oily fish in their diet than did children with normal airways (p<.05); NS difference in proportion of children with current asthma & normal airways who ate exclusively non-oily fish (p>.05); NS difference between the 4 groups in total fish intake (servings) per wk (p>.05)
| • Race: NR, likely Caucasian/ European | • Duration: June 1993: respiratory questionnaire. Oct 1993: dietary questionnire | • Method: AHR = ≥15% fall in FEV_1_ after 6-min run on flat surface; & wheeze in the past 12 mo with or without exercise. | | | | | • Consumption of fresh fish of any kind did not significantly reduce the risk of AHR only or wheeze only either before or after adjusting for risk factors (p>.05)
| • Number of Sites: NR (all schools) | | • Medication: NR | | | | | • NS associations of both fresh fish consumption & respiratory disease with: socioeconomic status (father's occupation) or consumption of vitamins, minerals or other dietary supplements (p>.05)
Huang, 2001,^48,^ ^49^ Taiwan | • Enrolled/evaluated: 1166/1055 | • Cross-sectional study | • Asthmatic adolescents (35/36 evaluated) | • Adolescents with MD-diagnosed allergic rhinitis (n=115): nose stuffiness, running nose, or sneezing either during morning or upon exposure to dust, pollen or chemicals; | NR | • Polyunsaturated fatty acids in 24-hr food intake (seafish 1.8% of total diet): oily fish rich in omega-3 fatty acids, seafish, shellfish | • NAHSIT directed at ≥4 y olds | • In univariate analysis of food frequency data, with intake categorized by quartiles of intake frequency, higher frequencies of oily fish intake were S associated with asthma prevalence (p<.01); NS association for ‘all fish’ & shellfish with asthma (p>.05) | • NR, but likely due to lack of response | • Total quality score: 3 (Grade: B) | • Department of Health, Executive Yuan, Republic of China
| • Age (mean & range): 14.7 (13–17) y | • Inclusion: all aged 13–17 y in study areas | • Severity: NR | • Adolescents with wheeze (n=11) | | | • 2 methods: food-frequency questionnaire, &, 24-hr recall (e.g., ingredients, sizes, cooking method, etc.) | • Multivariate logistic regression of food frequency data before and after adjusting for levels of urbanization revealed that oily fish consumption was not associated with asthma prevalence (p=.65) | | • Applicability: III
| • % Male: 50 | • Exclusion: living on offshore islands & in mountain areas (unusual diets), & those reporting asthmatic symptoms but without MD asthma diagnosis | • Duration: NR | • Control participants without diagnosis of asthma or allergic rhinitis (n=1,030) | | | • Time: in the past month for food frequency questionnaire | • 24-h dietary recall data did not distinguish omega-3 & omega-6 polyunsaturated fatty acids, and so, data cannot be used here
| • Race: NR, likely Asian | • Method: stratified, multiple-staged, probability sampling (proportional to size): 3 (of 365 total) townships/districts in each of 7 strata (by dietary habit, degree of urbanization [high, intermediate, low], & geographical region) | • Method: Health status questionnaire included in NAHSIT (Nutrition and Health Survey in Taiwan), addressing 19 major diseases in youth (4–17 y), including MD diagnosis of asthma | | | | • In 3 strata: door-to-door visits to interview adolescents (response rate: 86%) | • NB: prevalence of MD-diagnosed asthma S higher in males than females (p-value: NR); S trend in association of asthma prevalence and urbanization in males (p=.001) but not females (p=.10)
| • Number of sites: 5 strata, including 3 districts within each | • Duration: 3 y (1993-1996) | • Medications: NR
Satomi, 1994, Japan^78^ | • Enrolled/ evaluated: 7,742/7,588 | • Cross sectional study | • Asthmatic children (n=706; % male: 62.5%) | • Children without asthma (n=6,882) | • NR | • Fish classified as reddish (sardine, mackerel, pike: high EPA or DHA), pale (flatfish, sea bream, turbot: low EPA & DHA) & other marine products (shellfish, seaweed, dried fish, & fish paste) | • Frequency of consumption via Cochrane-Armitage test: >4–5 meals/wk; 2–3/wk; 1/wk; 1–2/mo & <1/mo | • Overall: S negative correlation between asthma prevalence & frequency of fish consumption (p<.05) [NS difference between asthma prevalence at coastal (9.5%) & inland (9.1%) areas (NR)] | • Overall: 154 (2%) non- responders | • Total quality score: 4 (Grade: A) | NR
| • Age (mean & range): NR (6–11) y | • Inclusion: children in grades 1, 3 & 5 (gender not identified: n=153) in: coastal (high fish consumption from the Annual Statistics of Fishery Products Marketing) & inland areas | • Severity: NR | | • Coastal area children only: food allergy (n=158); eczema, hives (n=385); eczema or pimple-like growths during weaning (n=1,037); pneumonia (n=230) | | • Time: current diet | • Overall: asthma prevalence lower in those eating fish ≥4 times/wk (7.3%) as compared with <1/mo (11.1%) (p-value: NR) | | • Applicability: III
| • % Male: 49.3 | • Exclusion: NR | • Duration: NR | | | | • Parental questionnaire | • Only in coastal areas, significantly lower frequency of asthma history in those eating reddish fish >4–5/wk vs eating it <1/mo (p<.01)
| • Race: NR, likely Asian | • Method: NR (25 coastal & 18 inland schools) | • Method: NR, likely by MD (as asked via questionnaire) | | | | | • Inland areas: significantly higher asthma prevalence in those eating pale fish or seaweed >4–5/wk vs eating it <1/mo (p<.01)
| • Number of sites: 43 schools (coastal areas: 25; inland areas: 18) | • Duration: 1 mo (Oct 1985) | • Medication: NR | | | | | • Asthma prevalence significantly higher in those with pneumonia, eczema during weaning, general eczema, urticaria, or food allergy than in those without these (p<.05), with S negative correlation between asthma prevalence & reddish fish intake maintained in latter group (p<.05)
| | | | | | | | • After excluding the effects of multiple confounders positively correlated with asthma prevalence (air conditioning in home; dusty home; temperature difference between day & night; ≥1 parental smoker; maternal intake of fermented beans & mushrooms while pregnant; live near pasture), asthma prevalence decreased as reddish fish intake increased (p<.05)
| | | | | | | | • Asthmatic children only in coastal areas showed S negative relationship between reddish fish intake & asthma prevalence (p<.05) but those with asthma complicated by allergic manifestations (rhinitis; atopic dermatitis) did not (p>.05)
Takemura, 2002, Japan^76^ | • Enrolled/ evaluated 25,767/23,782 | • Cross-sectional study | • MD-identified & -treated asthma (n=1,673) in past 2 y (episodes of cough or sputum, wheezy or whistling sound while breathing, shortness of breath precluding lying down): | • Participants without current asthma (n=22,109) | • Compared to control group, asthmatics more likely to be younger (p<.0001), male (p<.001) & have parental history of asthma (p<.001) | • Fish intake on a regular diet | • Validated, quantitative food frequency questionnaire: frequency of fish intake (almost none, 1–2 meals/mo, 1–2/wk, ≥3–4/wk) | • With 1–2 meals/mo as reference standard (mode), & after adjusting for age, gender, & parental history of asthma, a significantly higher asthma prevalence observed for those eating fish 1–2 meals/wk than those eating fish 1–2/mo [OR: 1.133 (95% CI 1.021–1.258)]; & the risk increased gradually with increasing frequency of fish intake, with a S positive trend (p=.0078) | • Overall = 1,290 non-responders | • Total quality score: 3 (Grade: B) | • Tokorozawa Medical Association, Saitama, Japan
| • Age (mean & range): NR (6–15) y | • Inclusion: all 33 public elementary schools & 15 junior high schools in Tokorozawa | • Age (mean & range) = 10.41+/-2.41 y; % Male= 61.8% | • Age (mean & range): 10.78±2.54 y; | • Asthma vs control groups: maternal smoker (15.2% vs 14.6%) | | • Time: current | • With 1–2 meals/mo as reference standard (mode), & after adjusting for age, gender, parental history of asthma, vegetable & fruit intake, a significantly higher prevalence observed for those eating fish 1–2 meals/wk than those eating fish 1–2/mo [OR: 1.117 (95% CI 1.005–1.241)]; & the risk increased gradually with increasing frequency of fish intake, with a significantly positive trend (p=.0349) | • n=695 had previously experienced an asthma attack but not currently asthmatic | • Applicability: III
| • % Male: 50.4 | • Exclusion: insufficient answers on questionnaire; participants having experienced an asthma attack but not currently asthmatic | • Severity: NR | • % Male: 49.6 | | | • Parental questionnaire | • S trend relating to increasing fish intake & asthma prevalence in males (p=.049) but not females (p=.36)
| • Race: NR | • Method: NR | • Duration: NR
| • Number of Sites: 48 schools | • Duration: 15 days (2/2/98-17/2/98) | • Method: Japanese version of American Thoracic Society & Division of Lung Diseases-National Heart, Lung & Blood Institute questionnaire, & items about job history, dust exposure, ocular symptoms, family member smoking status, exposure to other indoor pollution, & parental history of asthma
| | | • Medications: NR
Troisi, 1995, USA^75^ | • Enrolled/ | • Prospective cohort study | • Adult onset asthma (n=1,206 with confirmed diagnosis, from 1,446 with positive response in 1988-1990 & 1,400 via supplementary asthma questionnaire) | NR | NR | • Dark meat fish, along with tuna fish, & shrimp | • Semi-quantitative food frequency questionnaire about food intake over the past year in 1980 & every 2 years up to 1990 (1984 & 1986 versions: differentiated dark meat fish, higher in EPA, from other types of fish) | • 6-y risk of asthma was unrelated to frequency of intake of dark meat fish (χ^2^ = -0.13; p=.90), tuna fish (χ^2^= 0.19; p=.85), & shrimp (χ^2^= -.21; p=.83) measured in 1984 | • n=446 (63%) exclusions after censoring for cancer, cardiovascular, diabetes, etc. after 1980 & before date of asthma diagnosis | • Total quality score: 4 (Grade: A) | • NIH grant CA 40356
| • evaluated: 121,700/77,866 (93,184 before exclusion criteria applied) | • Inclusion: a Nurses' Health Study (NHS) supplemental questionnaire report of MD-diagnosed asthma & asthma medication use since diagnosis (1988-1990) | • Severity: NR | | | | • Self-administered | • Adjusting for age & smoking status, a NS risk reduction of asthma for each quintile of energy-adjusted omega-3 fatty acid intake (assessed in 1984 & 1986) [e.g., fifth quintile: RR= 0.88 (95% CI 0.65–1.12)]; & NS test for trend (p=.87) | | • Applicability: II
| • Age (mean & range): NR (34–68) y | • Exclusion: asthma, cardiovascular disease, diabetes, emphysema, chronic bronchitis or cancer on or before 1980 (n=760); non-responders & those denying asthma diagnosis on questionnaire | • Duration: NR | | | | | • Adjusting for age, smoking status, body mass index, area of residence, number of physician visits, & quintiles of energy intake, a NS risk reduction of asthma for each quintile of energy-adjusted omega-3 fatty acid intake (assessed in 1984 & 1986) [e.g., fifth quintile: RR=0.85 (95% CI 0.65–1.12)]; & NS test for trend (p=.37)
| • % Male: 0 | • Method: see above | • Method: NR
| • Race: NR | • Duration: 10 y period | • Medications: beta-2 agonists, oral theophylline, steroids (inhaled, oral or intravenous), cromolyn sodium
| • Number of sites: 11

NR = not reported; NA = not applicable; ? = change; S = significant; NS = nonsignificant; n = number of participants; enrolled = n qualified; evaluated = n analyzed; completed = n completing the study; Note: superscripts refer to reference list in main report

## Listing of Included Studies*

*All reports contributing to the same study are superscripted in an Evidence Table, with superscripts referring to the reference list in the main report.

Arm J P, Horton C E, Mencia-Huerta J M, et al. Effect of dietary supplementation with fish oil lipids on mild asthma. Thorax. 1988;43(2):84-92. [pmid: 3353893].
Arm J P, Horton C E, Spur B W, et al. The effects of dietary supplementation with fish oil lipids on the airways response to inhaled allergen in bronchial asthma. Am Rev Respir Dis. 1989;139(6):1395-1400. [pmid: 2543246].
Ashida K, Mitsunobu F, Mifune T, et al. A pilot study: effects of dietary supplementation with a-linolenic acid-enriched perilla seed oil on bronchial asthma. Allergol Intern. 1997;46:181-5.
Broughton K S, Johnson C S, Pace B K, et al. Reduced asthma symptoms with n-3 fatty acid ingestion are related to 5-series leukotriene production. Am J Clin Nutr. 1997;65(4):1011-7. [pmid: 9094887].
Dry J, Vincent D. Effect of a fish oil diet on asthma: results of a 1-year double-blind study. Int Arch Allergy Appl Immunol. 1991;95(23):156-7. [pmid: 1834587].
Emelyanov A F. Treatment of asthma with lipid extract of New Zealand green-lipped mussel: a randomised clinical trial. Eur Respir J. 2002;20(3):596-600. [pmid: 12358334].
Gorelova J Y, Semikina E M. The changes of lymphocyte membrane receptors in bronchial asthma and atopic dermatitis in pediatric patients receiving treatment with polyenic fatty acids. Z Ernahrungswiss. 1998;37(1):142-3. [pmid: 9558750].
Hashimoto N, Majima T, Ichimura K, et al. [Effects of eicosapentaenoic acid in patients with bronchial asthma]. [Japanese]. Nihon Kyobu Shikkan Gakkai Zasshi Japanese J Thorac Dis. 1997;35(6):634-40.
Hodge L, Salome C M, Hughes J M, et al. Effect of dietary intake of omega-3 and omega-6 fatty acids on severity of asthma in children. Eur Respir J. 1998;11(2):361-5. [pmid: 9551739].
Hodge L, Salome C M, Peat J K, et al. Consumption of oily fish and childhood asthma risk. [see comments.]. Med J Aust. 1996;164(3):137-40. [pmid: 8628130].
Hodge L. Effect of fish oil supplements on severity of asthma in children [abstract]. Annual Scientific Meeting of the Thoracic Society of Australia and New Zealand; 1997.
Huang S, Pan W, Huang S L, et al. Dietary fats and asthma in teenagers: analyses of the first Nutrition and Health Survey in Taiwan (NAHSIT). Clin Exp Allergy. 2001;31(12):1875-80. [pmid: 11737039].
Huang S L, Lin K C, Pan W H. Dietary factors associated with physician-diagnosed asthma and allergic rhinitis in teenagers: analyses of the first Nutrition and Health Survey in Taiwan. Clin Exp Allergy. 2001;31(2):259-64. [pmid: 11251627].
Kirsch C M, Payan D G, Wong M Y, et al. Effect of eicosapentaenoic acid in asthma. Clin Allergy. 1988;18(2):177-87. [pmid: 2835194].
Machura E, Brus R, Kalacinnski W, et al. [The effect of dietary fish oil supplementation on the clinical course of asthma in children]. [Polish]. Pediatr Pol. 1996;71(2):97-102. [pmid: 8966087].
Masuev K A. [The effect of polyunsaturated fatty acids of the omega-3 class on the late phase of the allergic reaction in bronchial asthma patients]. [Russian]. Ter Arkh. 1997b;69(3):31-3. [pmid: 9229824].
Masuev K A. [The effect of polyunsaturated fatty acids on the biochemical indices of bronchial asthma patients]. [Russian]. Ter Arkh. 1997a;69(3):33-5. [pmid: 9229825].
McDonald C V. Effect of fish-oil derived omega-3 fatty acid supplements on asthma control.[abstract]. Aust N Z J Med. 1990;20:526.
Mihrshahi S, Peat J K, Marks G B, et al. Eighteen-month outcomes of house dust mite avoidance and dietary fatty acid modification in the Childhood Asthma Prevention Study (CAPS). J Allergy Clin Immunol. 2003;111(1):162-8. [pmid: 12532113].
Mihrshahi S, Peat J K, Webb K, et al. The childhood asthma prevention study (CAPS): design and research protocol of a randomized trial for the primary prevention of asthma. Control Clin Trials. 2001;22(3):333-54. [pmid: 11384793].
Nagakura T, Matsuda S, Shichijyo K, et al. Dietary supplementation with fish oil rich in omega-3 polyunsaturated fatty acids in children with bronchial asthma. Eur Respir J. 2000;16(5):861-5. [pmid: 11153584].
Okamoto M, Mitsunobu F, Ashida K. Effects of dietary supplementation with n-3 fatty acids compared with n-6 fatty acids on bronchial asthma. Inter Med. 2000a;39(2):107-11.
Okamoto M, Mitsunobu F, Ashida K, et al. Effects of perilla seed oil supplementation on leukotriene generation by leucocytes in patients with asthma associated with lipometabolism. Int Arch Allergy Immunol. 2000b;122(2):137-42. [pmid: 10878492].
Payan D G, Wong M Y, Chernov-Rogan T, et al. Alterations in human leukocyte function induced by ingestion of eicosapentaenoic acid. J Clin Immunol. 1986;6(5):402-10. [pmid: 3021806].
Picado C, Castillo J A, Schinca N, et al. Effects of a fish oil enriched diet on aspirin intolerant asthmatic patients: a pilot study. Thorax. 1988;43(2):93-7. [pmid: 3353894].
Satomi H, Minowa M, Hatano S, et al. An epidemiological study of the preventive effect of dietary fish on bronchial asthma. Bulletin of the Institute of Public Health. 1994;43(3):305-14.
Stenius-Aarniala B, Aro A, Hakulinen A, et al. Evening primose oil and fish oil are ineffective as supplementary treatment of bronchial asthma. Ann Allergy. 1989;62(6):534-7. [pmid: 2735560].
Takemura Y, Sakurai Y, Honjo S, et al. The relationship between fish intake and the prevalence of asthma: the Tokorozawa childhood asthma and pollinosis study. Prev Med. 2002;34(2):221-5. [pmid: 11817918].
Thien F C, Mencia-Huerta J M, Lee T H. Dietary fish oil effects on seasonal hay fever and asthma in pollen-sensitive subjects. Am Rev Respir Dis. 1993;147(5):1138-43. [pmid: 8484622].
Troisi R J, Willett W C, Weiss S T, et al. A prospective study of diet and adult-onset asthma. [see comments.]. Am J Respir Crit Care Med. 1995;151(5):1401-8. [pmid: 7735592].
Villani F, Comazzi R, De Maria P, et al. Effect of dietary supplementation with polyunsaturated fatty acids on bronchial hyperreactivity in subjects with seasonal asthma. Respiration. 1998;65(4):265-9. [pmid: 9730791].