# Appendix C. Data Assessment and Data Abstraction Forms

## Relevance Assessment Form

Please respond to each of the first 7 questions. Comments typed into the box can identify duplicate reports, a key review whose references should be checked, anomalies, etc.

a. Inclusion criteria:
  1 Does this study involve human participants?
    YES Can't Tell NO
  2 Does this study employ (foods known to contain) omega-3 fatty acids (n-3) as an intervention/exposure?
    YES Can't Tell NO
  3 Is the purpose of the intervention/exposure: a. when used by individuals with asthma, to improve respiratory outcomes, or, influence mediators of inflammation; or, b. to prevent asthma?
    YES Can't Tell NO
b. Exclusion criterion:
  4 Is this a narrative or systematic review, opinion piece or editorial, letter, guideline or policy paper, etc. that, if it does so at all, only describes studies (and their results) reported elsewhere (i.e., it does not present evidence published for the first time)?
    YES Can't Tell NO
c. Context:
  5 The study appears to investigate (select at least one option; click on all that apply):
    -n-3's potential impact on respiratory outcomes in individuals with asthma
    -n-3's potential impact on mediators of inflammation (e.g., leukotrienes) in individuals with asthma
    -n-3's potential to prevent asthma
    -children or adolescents as the target population
    -at least one control or comparator group
    -US population dietary intake data regarding n-3 or n-6 fatty acids
    -none of the above
  6 The study appears to also or instead concern omega-3 fatty acids as an intervention/exposure for the following human health/disease domains (select at least one option; click on all that apply):
    -cardiovascular (human or non-human/in vitro focus)
    -gastrointestinal/renal
    -autoimmune
    -cancer
    -neurology
    -child/maternal health
    -immune-mediated
    -transplantation
    -mental health
    -none of the above
    -eye health
  7 Is this study written up in a language other than English?
    YES NO
  8 Comments box

## Data Abstraction Form

Instructions: Please answer each question. Selecting response options means clicking on them. A text box requires you to provide specific information. When it is not reported (= NR), the question does not apply (= N/A), you cannot tell what/where it is (= CT), or you have no comment to make (= NC), type the relevant code in the text box. If the research report describes more than one study, answer in this eForm all the questions for the first reported study while at the same time letting the review manager know that another data abstraction form is required.

1. Initials of reviewer: COMMENTS BOX = BOX
2. Reference identification # (Refid#): BOX
3. Author, Year: BOX
4. Unique identifier # (type NR for now): BOX
5. Number of unique, review-relevant studies that this report describes: BOX
6. Publication status (select one):
  - Peer-reviewed journal publication
  - Journal publication
  - Conference abstract/poster
  - Book
  - Book chapter
  - HTA/technical report
  - Thesis
  - Unpublished document
  - Study sponsor's internal report
  - Internet document
  - Other
7. If you answered ‘Other’ to the preceding question, specify what you mean: BOX
8. If other review-relevant reports refer to this same study, provide their Refid #s: BOX
9. Country in which the study was conducted (select all that apply):
  - Australia
  - Canada
  - United States
  - Japan
  - United Kingdom (not Ireland)
  - France
  - Germany
  - Italy
  - Finland
  - Russia
  - Other
  - Not reported
10. If you answered ‘Other’ to the preceding question, specify what you mean: BOX
11. Number of sites: BOX
12. Funding source type (select all that apply):
  - Government
  - Industry
  - Private (non-industry)
  - Hospital
  - Other
  - Not reported
  - Can't tell
13. Specify the funding source(s): BOX
14. Study complexity (select one):
  - Multiple study arms, cohorts, or phases (i.e., crossover)
  - Single study arm/cohort
15. Study design (select one):
  - RCT: parallel design
  - RCT: cross-over design
  - RCT: factorial design
  - Controlled clinical trial (non-RCT)
  - Multiple cohorts
  - Single cohort
  - Case-control
  - Cross-sectional
  - Case series
  - Case study
  - Other
16. If you answered ‘Other’ to the preceding question, specify what you mean: BOX
17. Identify any notable details concerning (e.g., restricted randomization; blocking size), or problems with, the research design or its implementation (e.g., inappropriateness of: placebo/control(s), run-in and washout protocols/durations, etc.): BOX
18. Total # of individuals screened: BOX
19. # enrolled/randomized participants (hereafter, ‘study participants’): BOX
20. # study participants completing the study: BOX
21. Study participants' percentage of males: BOX
22. Comments, including notable differences between study arms/cohorts re ‘% male participants’: BOX
23. Mean age (SD/SE; range) of study participants: BOX
24. Comments, including notable differences between study arms/cohorts re age: BOX
25. Body weight of study participants (mean; range): BOX
26. Comments, including notable differences between study arms/cohorts re body weight: BOX
27. From which racial groups were study participants drawn (select all that apply)?
  - Black/African ancestry
  - Native American/Canadian
  - Inuit/Eskimo
  - Hispanic
  - Asian
  - Caucasian/European
  - Other
  - Not reported
  - Can't tell
28. Specify each racial group's percentage/proportion of full sample: BOX
29. Comments, including notable differences between study arms/cohorts re racial composition: BOX
30. Concurrent conditions (select all that apply)?
  - Diabetes
  - Lipid-related problems (e.g., hypercholesterolemia)
  - Allergic rhinitis
  - Atopy (e.g., atopic dermatitis)
  - Other allergies or sensitivities (e.g., aspirin/ASA)
  - Other
  - None reported
31. If you answered ‘Other’ to the preceding question, specify what you mean: BOX
32. Specify the type and severity (mean; SD/SE; range: with units) of each concurrent condition, as well as how it was defined and diagnosed: BOX
33. Specify the percentage/proportion of the whole sample re each type of concurrent condition: BOX
34. Comments, including notable differences between study arms/cohorts re concurrent conditions: BOX
35. Specify pre-study medications or treatments for each concurrent condition, with dose/frequency: BOX
36. Comments, including notable differences between study arms/cohorts re pre-study medications/treatments: BOX
37. Describe any pre-study use of omega-3 fatty acid supplements (may constitute a retrospective evaluation of dietary intake): BOX
38. Comments, including notable differences between study arms/cohorts re the pre-study use of omega-3 fatty acid supplements: BOX
39. How was the dietary intake of omega-3 fatty acid usage evaluated (select all that apply)?
  - Nutritionist-administered quantitative food-frequency survey(s)
  - Nutritionist-administered semi-quantitative food-frequency survey(s)
  - Self-administered quantitative food-frequency survey(s)
  - Self-administered semi-quantitative food-frequency survey(s)
  - Parent-administered quantitative food-frequency survey(s)
  - Parent-administered semi-quantitative food-frequency survey(s)
  - Direct measurement(s) of food intake
  - Survey(s), yet no details provided
  - Other
  - Can't tell
  - Not reported
40. If you answered ‘Other’ to the preceding question, specify what you mean: BOX
41. Describe any pre-study use of other dietary supplements, including dose/frequency: BOX
42. Comments, including notable differences between study arms/cohorts re the pre-study use of other dietary supplements: BOX
43. Types of pre-study diet attributed to study participants (select all that apply):
  - High fish diet
  - Fish-vegetarian diet
  - Low fish diet
  - Low fat diet
  - High fat diet
  - Mediterranean diet
  - Other
  - Can't tell
  - Not reported
44. If you answered ‘Other’ to the preceding question, specify what you mean: BOX
45. Specify percentage/proportion of participants on each diet: BOX
46. Comments, including notable differences between study arms/cohorts re the type of baseline diet: BOX
47. Describe the full sample's absolute fatty acid content of the baseline diet: BOX
48. Comments, including notable differences between study arms/cohorts re the absolute fatty acid content of the baseline diet: BOX
49. Describe the full sample's relative fatty acid content of the baseline diet: BOX
50. Comments, including notable differences between study arms/cohorts re the relative fatty acid content of the baseline diet: BOX
51. Describe the full sample's baseline blood lipid biomarker levels, with units: BOX
52. Comments, including notable differences between study arms/cohorts re these blood lipid biomarker levels: BOX
53. Describe the full sample's baseline (serum, tissue, or cell membrane) levels of fatty acids: BOX
54. Describe the full sample's baseline omega-6/omega-3 tissue ratios of fatty acid: BOX
55. Describe any notable differences between the study arms/cohorts re their baseline fatty acids (serum, tissue, or cell membrane) or omega-6/omega-3 tissue ratios of fatty acid: BOX
56. What percentage/proportion of participants were diagnosed at study entry with asthma? BOX
57. Why were <100% of participants diagnosed with asthma at study entry (e.g., primary prevention study): BOX
58. Was asthma clearly defined? YES CT NO NR
59. How was asthma defined? BOX
60. How was asthma diagnosed? BOX
61. Identify the percentage/proportion of participants per asthma sub-type: BOX
62. According to the report, what was the likely cause(s) of the asthma (e.g., exercise- or aspirin-induced): BOX
63. Comments, including notable differences between study arms/cohorts re the definition, subtypes, or causes of asthma: BOX
64. What is the certainty of the asthma diagnosis? (select one)
  - Not applicable
  - No information reported
  - Can't tell
  - Possible: compatible symptoms
  - Probable: MD clinical diagnosis
  - Definite: MD clinical diagnosis or compatible symptoms PLUS objective measure of airway reactivity (FEV_1_ improves ≥ 15% post-bronchodilator; methacholine challenge test reveals PC20 <8mg/ml; diurnal variation in PEF or FEV_1_ > 15%)
65. Comments, including notable differences between study arms/cohorts re the certainty of the asthma diagnosis: BOX
66. Was asthma severity clearly defined? YES CT NO NR
67. How was asthma severity defined (e.g., daily symptoms of cough, wheeze, breathlessness; frequency of rescue inhaler use; nocturnal awakenings; exercise limitation; emergency visits and hospitalizations; recent use of systemic [oral; IV] corticosteroids; FEV_1_, peak flow; peak flow variability; measured nonspecific airway reactivity [e.g., histamine or methacholine challenge testing])? BOX
68. Describe the full sample's baseline (mean; SD/SE; range) level of asthma severity: BOX
69. Comments, including notable differences between study arms/cohorts re participants' baseline severity of asthma: BOX
70. According to the authors, how well-controlled by medication(s) were participants' asthma? (select one)
  - Well-controlled
  - Symptomatic
  - Not indicated
  - Can't tell
  - Not applicable
71. How did the authors define well-controlled vs. symptomatic? BOX
72. Comments, including notable differences between study arms/cohorts re baseline asthma control: BOX
73. Describe any notable differences at baseline between study arms/cohorts in terms of any indices of participants' asthma clinical status or pulmonary function: BOX
74. Participants' asthma duration (mean; SD/SE; range): BOX
75. Comments, including notable differences between study arms/cohorts re asthma duration: BOX
76. Describe atopy status of participants, including their family history: BOX
77. Comments, including notable differences between study arms/cohorts re history of atopy: BOX
78. Participants' family history of asthma: BOX
79. Comments, including notable differences between study arms/cohorts re family history of asthma: BOX
80. Specify presence of furry/feathered pets at home or work (e.g., % participants): BOX
81. Comments, including notable differences between study arms/cohorts re presence of furry/feathered pets at home or work: BOX
82. Specify socioeconomic status of participants: BOX
83. Comments, including notable differences between study arms/cohorts re socioeconomic status: BOX
84. Describe participants' family size and living conditions (e.g., crowdedness; cleanliness): BOX
85. Comments, including notable differences between study arms/cohorts re family size or living conditions: BOX
86. Identify location of participants' present residence (select one):
  - 100% Urban
  - 100% Rural
  - Some from each
87. Comments, including notable differences between study arms/cohorts re residence location: BOX
88. # study participants (working) in daycare (for infections which exacerbate asthma): BOX
89. Comments, including notable differences between study arms/cohorts re study participants (working) in daycare: BOX
90. Describe participants' history of respiratory infections (e.g., bronchiolitis): BOX
91. Comments, including notable differences between study arms/cohorts re participants' history of respiratory infections: BOX
92. Describe participants' history of exposure to environmental tobacco smoke: BOX
93. Comments, including notable differences between study arms/cohorts re participants' history of exposure to environmental tobacco smoke: BOX
94. Describe participants' smoking history and present smoker status: BOX
95. Comments, including notable differences between study arms/cohorts re participants' smoking history and present smoker status: BOX
96. Other asthma risk factors, and percentage/proportion of participants re each (specify): BOX
97. Comments, including notable differences between study arms/cohorts re these risk factors: BOX
98. Other factors adversely affecting asthma control, and percentage/proportion of participants re each (specify): BOX
99. Comments, including notable differences between study arms/cohorts re these factors influencing asthma control: BOX
100. Describe pre-study asthma medication(s) or treatments, including dose/frequency: BOX
101. Comments, including notable differences between study arms/cohorts re pre-study asthma medication(s) or treatments, including dose/frequency: BOX
102. Comments re the appropriateness of pre-study asthma medications or treatments, including dose/frequency: BOX
103. Comments, including notable differences between study arms/cohorts re the appropriateness of the pre-study asthma medication(s) or treatments, including dose/frequency: BOX
104. Describe participants' pre-study exacerbation, emergency visit, or hospitalization rates: BOX
105. Comments, including notable differences between study arms/cohorts re the pre-study exacerbation, emergency visit, or hospitalization rates: BOX
106. Describe participants' pre-study rescue inhaler use: BOX
107. Comments, including notable differences between study arms/cohorts re the pre-study rescue inhaler use: BOX
108. Comments about any other asthma-related covariates (e.g., baseline serum IgE levels), including any notable differences between the study arms/cohorts in terms of these: BOX
109. Season the study was initiated: BOX
110. Season the study was completed: BOX
111. List the study's inclusion criteria: BOX
112. List the study's exclusion criteria: BOX
113. Intention of study (select all that apply)
  - Treatment
  - Primary prevention
  - Secondary prevention
  - Impact on mediators of inflammation
  - Safety
  - Other
  - Unclear
114. If you answered ‘Other’ to the preceding question, specify what you mean: BOX
115. Type of study (select one):
  - Interventional
  - Observational
116. Data were analyzed according to which criterion (select one)?
  - Intention-to-treat (all randomized/enrolled)
  - Those receiving at least one dose/serving
  - Those completing the study (i.e., with follow-up data)
  - Can't tell
  - Other
117. If you answered ‘Other’ to the preceding question, specify what you mean: BOX
118. Study duration, including units (includes run-in period duration, washout duration, etc.): BOX
119. Omega-3 fatty acid product name(s) (select all that apply):
  - Almarin
  - Coromega
  - Eiconol
  - Efamed
  - Epagis
  - MaxEPA
  - Menhaden oil
  - ResQ
  - Omacor
  - Ropufa
  - Other
  - Not reported
  - Not applicable
120. If you answered ‘Other’ to the preceding question, specify what you mean: BOX
121. Name of manufacturer of the omega-3 fatty acid product(s): BOX
122. Reported information re the purity of the omega-3 fatty acid product: BOX
123. Reported information re the presence of other, potentially active agents in the omega-3 fatty acid product: BOX
124. Asthma medications allowed or mandated during the study, including dose and frequency: BOX
125. Comments, including notable differences between study arms/cohorts/phases re participants' asthma medications, including dose/frequency: BOX
126. Permitted or mandated medications or treatments for concurrent conditions during the study (specify type, dose/frequency, and for which concurrent condition): BOX
127. Comments, including notable differences between study arms/cohorts/phases re participants' permitted or required medications or treatments for concurrent conditions: BOX
128. Review-relevant outcomes assessed (e.g., efficacy; incidence; prevalence; mediators of inflammation): BOX
129. Timing of follow-up assessment(s) per outcome, relative to start of intervention (e.g., after 8 hours; at week 4): BOX
130. Total # of study arms or cohorts (note: in a crossover trial, each phase type is considered an exposure/intervention ‘arm:’ e.g., placebo vs. omega-3): BOX
131. # crossovers: BOX
132. Define only the study arms, cohorts, or phases of interest to the present review (exclude others, for which data will not be extracted): BOX
133. With a specific omega-3 fatty acid ‘active’ arm in mind, type ARM1 in the text box: BOX
134. Re this study arm, what is the sample size at study entry? BOX
135. Sample size of those completing the study: BOX
136. Intervention length (e.g., weeks, months): BOX
137. Arm type (active; placebo; control) BOX
138. Intervention/exposure type (e.g., marine diet; plant diet; marine-based supplement; plant-based supplement; nuts; nut oil): BOX
139. Define the intervention/exposure components (e.g., ‘omega-3 rich diet;’ anchovy serving; fish oil supplement; flaxseed/linseed; rapeseed/canola; walnut oil; softgel capsule): BOX
140. Specific source(s) of omega-3 fatty acids (i.e., type[s] of fish or plant): BOX
141. Per-dose/serving amount of omega-3 fatty acids (e.g., grams): BOX
142. Dose/serving frequency (e.g., once daily): BOX
143. Timing (e.g., with breakfast; any time): BOX
144. Route of administration: BOX
145. Total daily (mean; SD/SE; range) omega-3 fatty acid intake (e.g., grams): BOX
146. Type(s) of omega-3 fatty acid identified (i.e., DHA, EPA, DPA, ALA): BOX
147. Total daily amount/dose (mean; SD/SE; range) of each type of omega-3 fatty acid, or combination (e.g., EPA+DHA) (e.g., grams): BOX
148. Omega-3 fatty acid composition (%) of the exposure/intervention: BOX
149. Permitted or mandated amount/dose (mean; SD/SE; range), frequency, method of delivery, and timing (relative to the omega-3 fatty acid exposure) of omega-6 fatty acid intake (e.g., grams): BOX
150. Permitted or mandated omega-6/omega-3 ratio of the exposure/intervention: BOX
151. Other permitted or mandated type(s) of co-intervention (e.g., anti-oxidants such as Vitamin E; other dietary supplements; other foodstuff), including respective dose/servings (mean; SD/SE; range), frequency, method of delivery, and timing (relative to the omega-3 fatty acid exposure), with units: BOX
152. Total daily fat intake (mean; SD/SE; range) of the exposure/intervention, with units: BOX
153. Total daily caloric intake (mean; SD/SE; range) of the exposure/intervention, with units: BOX
154. Describe whether, and why, it was necessary or possible to change the standard asthma medications/treatments during the course of the study: BOX
155. If standard asthma medications/treatments were changed, then how? BOX
156. If there is a second omega-3 fatty acid ‘active’ arm or, if none, then a control arm (e.g., placebo), type ARM2 in the text box (however, click here if there are no more arms/cohorts; this links directly to question #252) BOX
157. Re this study arm, what is the sample size at study entry? BOX
158. Sample size of those completing the study: BOX
159. Intervention length (e.g., weeks, months): BOX
160. Arm type (active; placebo; control) BOX
161. Intervention/exposure type (e.g., marine diet; plant diet; marine-based supplement; plant-based supplement; nuts; nut oil): BOX
162. Define the intervention/exposure components (e.g., ‘omega-3 rich diet;’ anchovy serving; fish oil supplement; flaxseed/linseed; rapeseed/canola; walnut oil; softgel capsule): BOX
163. If control/placebo, describe it (e.g., ‘omega-3 poor diet’) or what was used (e.g., olive oil, safflower oil): BOX
164. Specific source(s) of omega-3 fatty acids (i.e., type[s] of fish or plant): BOX
165. Per-dose/serving amount of omega-3 fatty acids (e.g., grams): BOX
166. Dose/serving frequency (e.g., once daily): BOX
167. Timing (e.g., with breakfast; any time): BOX
168. Route of administration: BOX
169. Total daily (mean; SD/SE; range) omega-3 fatty acid intake (e.g., grams): BOX
170. Type(s) of omega-3 fatty acid identified (i.e., DHA, EPA, DPA, ALA): BOX
171. Total daily amount/dose (mean; SD/SE; range) of each type of omega-3 fatty acid, or combination (e.g., EPA+DHA) (e.g., grams): BOX
172. Omega-3 fatty acid composition (%) of the exposure/intervention: BOX
173. Permitted or mandated amount/dose (mean; SD/SE; range), frequency, method of delivery, and timing (relative to the omega-3 fatty acid exposure) of omega-6 fatty acid intake (e.g., grams): BOX
174. Permitted or mandated omega-6/omega-3 ratio of the exposure/intervention: BOX
175. Other permitted or mandated type(s) of co-intervention (e.g., anti-oxidants such as Vitamin E; other dietary supplements; other foodstuff), including respective dose/servings (mean; SD/SE; range), frequency, method of delivery, and timing (relative to the omega-3 fatty acid exposure), with units: BOX
176. Total daily fat intake (mean; SD/SE; range) of the exposure/intervention, with units: BOX
177. Total daily caloric intake (mean; SD/SE; range) of the exposure/intervention, with units: BOX
178. Describe whether, and why, it was necessary or possible to change the standard asthma medications/treatments during the course of the study: BOX
179. If standard asthma medications/treatments were changed, then how? BOX
180. If there is an additional omega-3 fatty acid ‘active’ arm or, if none, then a control arm (e.g., placebo), type ARM3 in the text box (however, click here if there are no more arms/cohorts; this links directly to question #252) BOX
181. Re this study arm, what is the sample size at study entry? BOX
182. Sample size of those completing the study: BOX
183. Intervention length (e.g., weeks, months): BOX
184. Arm type (active; placebo; control) BOX
185. Intervention/exposure type (e.g., marine diet; plant diet; marine-based supplement; plant-based supplement; nuts; nut oil): BOX
186. Define the intervention/exposure components (e.g., ‘omega-3 rich diet;’ anchovy serving; fish oil supplement; flaxseed/linseed; rapeseed/canola; walnut oil; softgel capsule): BOX
187. If control/placebo, describe it (e.g., ‘omega-3 poor diet’) or what was used (e.g., olive oil, safflower oil): BOX
188. Specific source(s) of omega-3 fatty acids (i.e., type[s] of fish or plant): BOX
189. Per-dose/serving amount of omega-3 fatty acids (e.g., grams): BOX
190. Dose/serving frequency (e.g., once daily): BOX
191. Timing (e.g., with breakfast; any time): BOX
192. Route of administration: BOX
193. Total daily (mean; SD/SE; range) omega-3 fatty acid intake (e.g., grams): BOX
194. Type(s) of omega-3 fatty acid identified (i.e., DHA, EPA, DPA, ALA): BOX
195. Total daily amount/dose (mean; SD/SE; range) of each type of omega-3 fatty acid, or combination (e.g., EPA+DHA) (e.g., grams): BOX
196. Omega-3 fatty acid composition (%) of the exposure/intervention: BOX
197. Permitted or mandated amount/dose (mean; SD/SE; range), frequency, method of delivery, and timing (relative to the omega-3 fatty acid exposure) of omega-6 fatty acid intake (e.g., grams): BOX
198. Permitted or mandated omega-6/omega-3 ratio of the exposure/intervention: BOX
199. Other permitted or mandated type(s) of co-intervention (e.g., anti-oxidants such as Vitamin E; other dietary supplements; other foodstuff), including respective dose/servings (mean; SD/SE; range), frequency, method of delivery, and timing (relative to the omega-3 fatty acid exposure), with units: BOX
200. Total daily fat intake (mean; SD/SE; range) of the exposure/intervention, with units: BOX
201. Total daily caloric intake (mean; SD/SE; range) of the exposure/intervention, with units: BOX
202. Describe whether, and why, it was necessary or possible to change the standard asthma medications/treatments during the course of the study: BOX
203. If standard asthma medications/treatments were changed, than how? BOX
204. If there is an additional omega-3 fatty acid ‘active’ arm or, if none, then a control arm (e.g., placebo), type ARM4 in the text box (however, click here if there are no more arms/cohorts; this links directly to question #252) BOX
205. Re this study arm, what is the sample size at study entry? BOX
206. Sample size of those completing the study: BOX
207. Intervention length (e.g., weeks, months): BOX
208. Arm type (active; placebo; control) BOX
209. Intervention/exposure type (e.g., marine diet; plant diet; marine-based supplement; plant-based supplement; nuts; nut oil): BOX
210. Define the intervention/exposure components (e.g., ‘omega-3 rich diet;’ anchovy serving; fish oil supplement; flaxseed/linseed; rapeseed/canola; walnut oil; softgel capsule): BOX
211. If control/placebo, describe it (e.g., ‘omega-3 poor diet’) or what was used (e.g., olive oil, safflower oil): BOX
212. Specific source(s) of omega-3 fatty acids (i.e., type[s] of fish or plant): BOX
213. Per-dose/serving amount of omega-3 fatty acids (e.g., grams): BOX
214. Dose/serving frequency (e.g., once daily): BOX
215. Timing (e.g., with breakfast; any time): BOX
216. Route of administration: BOX
217. Total daily (mean; SD/SE; range) omega-3 fatty acid intake (e.g., grams): BOX
218. Type(s) of omega-3 fatty acid identified (i.e., DHA, EPA, DPA, ALA): BOX
219. Total daily amount/dose (mean; SD/SE; range) of each type of omega-3 fatty acid, or combination (e.g., EPA+DHA) (e.g., grams): BOX
220. Omega-3 fatty acid composition (%) of the exposure/intervention: BOX
221. Permitted or mandated amount/dose (mean; SD/SE; range), frequency, method of delivery, and timing (relative to the omega-3 fatty acid exposure) of omega-6 fatty acid intake (e.g., grams): BOX
222. Permitted or mandated omega-6/omega-3 ratio of the exposure/intervention: BOX
223. Other permitted or mandated type(s) of co-intervention (e.g., anti-oxidants such as Vitamin E; other dietary supplements; other foodstuff), including respective dose/servings (mean; SD/SE; range), frequency, method of delivery, and timing (relative to the omega-3 fatty acid exposure), with units: BOX
224. Total daily fat intake (mean; SD/SE; range) of the exposure/intervention, with units: BOX
225. Total daily caloric intake (mean; SD/SE; range) of the exposure/intervention, with units: BOX
226. Describe whether, and why, it was necessary or possible to change the standard asthma medications/treatments during the course of the study: BOX
227. If standard asthma medications/treatments were changed, then how? BOX
228. If there is an additional omega-3 fatty acid ‘active’ arm or, if none, then a control arm (e.g., placebo), type ARM5 in the text box (however, click here if there are no more arms/cohorts; this links directly to question #252) BOX
229. Re this study arm, what is the sample size at study entry? BOX
230. Sample size of those completing the study: BOX
231. Intervention length (e.g., weeks, months): BOX
232. Arm type (active; placebo; control) BOX
233. Intervention/exposure type (e.g., marine diet; plant diet; marine-based supplement; plant-based supplement; nuts; nut oil): BOX
234. Define the intervention/exposure components (e.g., ‘omega-3 rich diet;’ anchovy serving; fish oil supplement; flaxseed/linseed; rapeseed/canola; walnut oil; softgel capsule): BOX
235. If control/placebo, describe it (e.g., ‘omega-3 poor diet’) or what was used (e.g., olive oil, safflower oil): BOX
236. Specific source(s) of omega-3 fatty acids (i.e., type[s] of fish or plant): BOX
237. Per-dose/serving amount of omega-3 fatty acids (e.g., grams): BOX
238. Dose/serving frequency (e.g., once daily): BOX
239. Timing (e.g., with breakfast; any time): BOX
240. Route of administration: BOX
241. Total daily (mean; SD/SE; range) omega-3 fatty acid intake (e.g., grams): BOX
242. Type(s) of omega-3 fatty acid identified (i.e., DHA, EPA, DPA, ALA): BOX
243. Total daily amount/dose (mean; SD/SE; range) of each type of omega-3 fatty acid, or combination (e.g., EPA+DHA) (e.g., grams): BOX
244. Omega-3 fatty acid composition (%) of the exposure/intervention: BOX
245. Permitted or mandated amount/dose (mean; SD/SE; range), frequency, method of delivery, and timing (relative to the omega-3 fatty acid exposure) of omega-6 fatty acid intake (e.g., grams): BOX
246. Permitted or mandated omega-6/omega-3 ratio of the exposure/intervention: BOX
247. Other permitted or mandated type(s) of co-intervention (e.g., anti-oxidants such as Vitamin E; other dietary supplements; other foodstuff), including respective dose/servings (mean; SD/SE; range), frequency, method of delivery, and timing (relative to the omega-3 fatty acid exposure), with units: BOX
248. Total daily fat intake (mean; SD/SE; range) of the exposure/intervention, with units: BOX
249. Total daily caloric intake (mean; SD/SE; range) of the exposure/intervention, with units: BOX
250. Describe whether, and why, it was necessary or possible to change the standard asthma medications/treatments during the course of the study: BOX
251. If standard asthma medications/treatments were changed, then how? BOX
252. Was there a clear difference in daily total-gram omega-3 fatty acid intake across the study arms/cohorts/phases? YES CT NO N/A
253. Was there a clear difference in the respective daily intake amounts for each of the different omega-3 fatty acids across the study arms/cohorts/phases? YES CT NO N/A
254. Was there a clear difference in the total daily omega-6 fatty acid intake across the study arms/cohorts/phases? YES CT NO N/A
255. Was there a clear difference in the omega-6/omega-3 ratio of the daily fatty acid intake across the study arms/cohorts/phases? YES CT NO N/A
256. Was the daily overall fat intake equivalent across study arms/cohorts/phases? YES CT NO N/A
257. Was the daily caloric intake equivalent across study arms/cohorts/phases? YES CT NO N/A
258. Did control participants appear to receive more than trace amounts of omega-3 fatty acid? YES CT NO N/A
259. Were the standard medications/treatments for asthma equivalent or comparable across the study arms/cohorts/phases? YES CT NO N/A
260. Were the standard medications/treatments for concurrent conditions equivalent or comparable across the study arms/cohorts/phases? YES CT NO N/A
261. Identify any factors intentionally kept constant across the study (e.g., background diet for those in a study of the impact of supplements): BOX
262. Additional comments re the possible non-comparability of populations or interventions/exposures, and, other possible sources of bias: BOX
263. Any further comments about the study: BOX
264. Identify the question(s) this study addresses (select all that apply):
  - What is the evidence for the efficacy of omega-3 fatty acids to improve respiratory outcomes among individuals with asthma?
  - What is the evidence that the possible value (efficacy/association) of omega-3 fatty acids in improving respiratory outcomes is dependent on the: specific type of fatty acid (DHA, EPA, DPA, ALA, fish, fish oil); specific source (fish, plant, food, dietary supplement [fish oil, plant oil]); its serving size or dose (fish or dietary supplement); amount/dose of omega-6 fatty acids given as a co-intervention; ratio of omega-6/omega-3 fatty acids used; fatty acid content of blood lipid biomarkers; absolute fatty acid content of the baseline diet; relative fatty acid content of the baseline diet; tissue ratios of fatty acid (omega-6/omega-3) during the investigative period; intervention length; anti-oxidant use; and, the manufacturer and its product(s) (different purity; presence of other potentially active agents)?
  - What is the evidence that, in individuals with asthma, omega-3 fatty acids influence mediators of inflammation which are thought to be related to the pathogenesis of asthma?
  - Are omega-3 fatty acids effective in the primary prevention of asthma?
  - Among individuals with asthma, do omega-3 fatty acids alter the progression of asthma (i.e., secondary prevention)?
  - What is the evidence for adverse events, side effects, or counter-indications associated with omega-3 fatty acid use to treat or prevent asthma (DHA, EPA, DPA, ALA, fish oil, fish)?
  - What is the evidence that omega-3 fatty acids are associated with adverse events in specific subpopulations of asthmatic individual such as diabetics?

## Quality Assessment Form—Randomized Controlled Trials

## Quality Assessment Form—All Other Study Designs

## Applicability Indices

For studies of the treatment and secondary prevention (i.e., to alter the progression) of asthma:

Assign ‘I’ to a study population of otherwise ‘healthy’ asthmatic North American individuals, namely those representing a somewhat broad demographic picture (i.e., gender, race), possibly exhibiting ‘typical’ conditions concomitant to asthma (e.g., atopy), living a ‘typical’ North American lifestyle (e.g., background diet), receiving ‘typical’ types and doses of asthma treatment (e.g., medications), yet without significant comorbid health problems.

Assign ‘II’ to a study population of asthmatic individuals representing a more restricted North American demographic picture (e.g., a North American sub-population), exhibiting more severe forms of ‘typical’ condition concomitant to asthma, living a less ‘typical’ North American lifestyle, receiving less ‘typical’ types and doses of asthma treatment, or having significant comorbid health problems (e.g., diabetes).

Assign ‘III’ to a study population of asthmatic individuals representing a narrow demographic picture that is not a ‘typical’ North American one (e.g., a population living outside North America), living a lifestyle that is not a ‘typical’ North American one (e.g., different background diet), exhibiting more severe forms of ‘typical’ condition concomitant to asthma, receiving less ‘typical’ types and doses of asthma treatment, or having significant comorbid health problems.

Assign ‘X’ when applicability cannot be ascertained due to incomplete reporting, particularly of the details defining the study population of asthmatic individual, including demographics, the diagnostic criteria and method to identify asthma, comorbid health problems, and, asthma care.

For primary prevention studies:

Assign ‘I’ to a study population of typical ‘healthy’ North Americans across a broad demographic spectrum, or, those otherwise ‘typical’ North Americans (i.e., no other significant health problems) across a broad demographic spectrum yet at risk to develop asthma (e.g., family history; environmental exposure to smoke; early history of respiratory infections).

Assign ‘II’ to a study population of North Americans, with or without the risk of developing asthma, yet representing a restricted demographic picture (e.g., a sub-population), lifestyle (e.g., different background diet), or other significant health problems (e.g., diabetes).

Assign ‘III’ to a study population living outside North America, with or without the risk of developing asthma, and thus representing --relative to North Americans-- a different demographic picture or lifestyle, or, other significant health problems (e.g., diabetes).

Assign ‘X’ when applicability cannot be ascertained due to incomplete reporting, particularly of the details defining the study population.