# Appendix B. Letter to Industry Representatives

## Letter to Industry Representatives from the Three EPCs Investigating the Health Benefits of Omega-3 Fatty Acids

May 2, 2003

Dear _________,

I am writing on behalf of the Evidence Based Practice Centers at RAND, New England Medical Center and the University of Ottawa. We are conducting a systematic review of the efficacy and toxicity of omega-3 fatty acids in the prevention and treatment of a number of different diseases/conditions. This review is being conducted under a contract from the Agency for Healthcare Research and Quality (AHRQ).

We are contacting you to see if there is any evidence, including unpublished evidence, that you want considered. Our focus is on clinical trials of omega-3 fatty acids in humans, so animal and chemical studies are not necessary.

The specific questions that all the EPCs will address are detailed in the attachment to this letter.

Please contact me with any information that you might have. I will be out of town next week and will respond to any questions when I get back. If you have any questions that you would like addressed before I return, please contact Donna Mead at the address above.

Best regards,

Catherine MacLean, M.D., Ph.D.

RAND1700 Main Street, M 23-C

Santa Monica, CA 90407-2138

Voice: 310 393-0411, x6364

Fax: 310-451-6930

maclean@rand.org