# Summary Tables

Table 1. Scheme for Grading the Evidence to Support the Use or Positive Impact of Interventions

Table 1. Scheme for Grading the Evidence to Support the Use or Positive Impact of Interventions

Overall Assessment | | Quality | | Quantity | Consistency of Findings
| | Study Designs | Objective Assessment ^a^
A | Excellent | at least one RCT^b^ | ≥ 75% studies | ≥ 4 studies | consistent
B | Good | at least one controlled trial | ≥ 50% studies | ≥ 3 studies | reasonably consistent
C | Fair | no controlled trials | < 50% studies | ≥ 2 studies | inconsistent
D | Poor | no controlled trials | < 50% studies | < 2 studies | too few studies to determine

a Objective assessment as rated on the Quality Assessment Form, Question 15

b RCT= Randomized controlled trial

Table 2. Summary of selected aspects of study quality for the 27 articles addressing Question 1

Table 2. Summary of selected aspects of study quality for the 27 articles addressing Question 1

Selected Quality Assessment Domains and Items | Number of Articles
| Yes | No
Representativeness
- Healthcare providers clearly described? | 20 | 7
Bias/confounding
- Adequate comparison group? | 26 | 1
- Randomized? | 11 | 16
Intervention description
- Complete description (able to replicate)? | 24 | 3
Outcome assessment
- Blinding? | 9 | 18
- Pre- and post-test? | 13 | 14
- Objective evaluation? | 27 | 0
Analysis
- Numbers and reasons of non-inclusion? | 18 | 9
- Complete statistical analysis? | 24 | 3

Table 3. Results of studies presented by clinical area and type of outcome for articles addressing Question 1^a^

Table 3. Results of studies presented by clinical area and type of outcome for articles addressing Question 1^a^

| Main Intervention Method ^b^ | Health Process Outcomes | | | | | Patient Outcomes
| | Utilization | Quality of Providers | Appropriateness of Care | Efficacy of Treatment | Patient Adherence | Health Status | Patient Satisfaction
PREVENTION, ADULT
Adult General Prevention
Gemson, 1995 | Education | | NA/++/++/++/NA/NA/NA/++/++
McDonald, 1984 | T/R | ++/0 | | ++/++ | | | 0
Turner, 1989 | T/R | | | NA/NA/NA/NA/ NA/NA
Adult Cancer Screening
Burack, 1994 | T/R | | | ++/++/NA
Burack, 1996 | T/R | 0 | | +
Burack, 1997 | T/R | | | ++
Burack, 1998 | T/R | 0 | | ++
Burack, 2003 | T/R | ++/0 | | ++/0
Chambers, 1989 | T/R | | | ++
Dietrich, 1998 | multi | | ++ | 0/0/0/0/0/0/0
Mandelblatt, 1993 | bypass MD | | | ++/++
Manfredi, 1998 | multi | | | ++/++/0/++
McCarthy, 1997 | bypass MD | | | NA
Adult Tobacco Cessation
Ahluwalia, 1999 | T/R | | ++/++/+/++
Allen, 1998 | multi | | + | | | 0/0/0/0
Adult Cholesterol
Keyserling, 1997 | multi | | 0 | 0/0 | | ++ | ++/+/+
PREVENTION, CHILDREN
Health Behavior Screening
Schubiner, 1994 | STQ | | +/+/++/+/+ | | | | | 0
Injury Prevention
Gielen, 2001 | Education | | + | | 0 | 0 | | ++
Well Baby Care
Hornberger, 1996 | Translation | 0 | +/+/+/+/+/+ | | | | | +
MENTAL HEALTH
Alcohol
Burge, 1997 | multi | | | | | | 0/++/0/0/0/ 0/0/0
Depression
Miranda, 2003 | multi | | | ++ | | | ++/0
Callahan, 1994 | multi | | | ++/++/0/0 | | | 0
OTHER CLINICAL AREAS
Acute Respiratory Infections
Harris, 2003 | multi | | | 0/0
Asthma
Evans, 1997 | multi | NA/NA | | ++/++/NA
Chronic Renal Disease
Harris, 1998 | NC | ++/0/0/+ | | 0 | | | 0/0/0
Emergency Systems
Kellerman, 1993 | defib | | | | | | 0/0/0
End of Life
Dexter, 1998 | T/R | | ++/+ | | | +/+/+

a The outcome assessments in this table are based on between-group comparisons. “++” indicates significant improvement, “+” indicates improvement, “0” indicates no improvement, and “NA” indicates between-group comparison not available. If a cell is left blank, then the outcome type was not measured for that study. Outcomes separated by “/” indicate more than one outcome type.

b “T/R” indicates tracking and reminder, “multi” indicates multifaceted, “bypass MD” indicates bypass doctor with nurse, “STQ” indicates safe times questionnaire, “NC” indicates nephrologist consultation, and “defib” indicates defibrillators on emergency medical vehicles.

Table 4. Summary of interventions, clinical areas, and outcomes of studies addressing Question 1

Table 4. Summary of interventions, clinical areas, and outcomes of studies addressing Question 1

Intervention Type^a^ | Clinical Area (# studies) | Total # Studies | Overall Outcome Assessment across Studies | Rating of Evidence
Tracking/ Reminders | Adult, Prevention (9) | 10 | All studies reported favorable outcomes. | A
| End of Life (1)
Multifaceted | Adult, Prevention (4) | 9 | Although almost all studies reported some positive impact on one or more outcome type, results within outcome type were inconsistent across studies. | C
| Depression (2)
| Alchohol Abuse (1)
| Asthma (1)
| Upper Respiratory Tract Infections (1)
Bypass MD | Adult, Prevention (2) | 2 | Both studies reported favorable outcomes in the provision of preventive services to patients. | C
Provider Education | Adult, Prevention (1) | 2 | Both studies reported favorable impact on provider counseling behaviors. | C
| Child, Prevention (1)
Use of STQ^b^ | Child, Prevention (1) | 1 | One study reported favorable impact on provider counseling behavior. | D
Use of RST^c^ | Child, Prevention (1) | 1 | One study reported favorable outcomes on accuracy of translation and provider/patient satisfaction. | D
Use of Specialty Consult | Chronic Renal Disease (1) | 1 | One study did not demonstrate improvement. | D
Use of Defibrillators | Emergency Medicine (1) | 1 | One study did not demonstrate improvement. | D

a Note that characterization of interventions for purposes of synthesis reflects a simplification of employed methods. Consult Evidence Table 2 for details on methods for individual studies.

b STQ = safe times questionnaire

c RST = remote simultaneous translation

Table 5. Summary of selected aspects of study quality for the 64 articles addressing Question 2

Table 5. Summary of selected aspects of study quality for the 64 articles addressing Question 2

Selected Quality Assessment Domains and Items | Number of Articles
| Yes | No
Representativeness
- Healthcare providers clearly described? | 21 | 43
Bias/confounding
- Adequate comparison group? | 8 | 56
- Randomized? | 1 | 63
Intervention description
- Based on theoretical model? | 17 | 47
- Complete description (able to replicate)? | 21 | 43
Outcome assessment
- Blinding? | 3 | 61
- Pre- and post-test? | 33 | 31
- Objective evaluation? | 27 | 37
Analysis
- Numbers and reasons of non-inclusion? | 14 | 50
- Complete statistical analysis? | 15 | 49

Table 6. Results of studies presented by type of outcome for the 34 articles addressing Question 2^a^

Table 6. Results of studies presented by type of outcome for the 34 articles addressing Question 2^a^

| Provider Outcomes | | | Patient Outcomes
| Knowledge | Attitudes | Skills | Satisfaction | Patient Adherence | Health Status
Physicians
Beagan, 2003 | | 0 / 0 / 0
Copeman, 1989 | ? | + / ?
Crandall, 2003 | ++ | ++ | ++
Culhane-Pera, 1997 | ++ | + / + | ++ / ++
Dogra, 2001 | | 0 / ?
Farnill, 1997 | | | ++ / ++
Godkin, 2001 | ++ | ++
Godkin, 2003 | | ++ / ? / ++
Haq, 2000 | | ++ / + | ++
Mao, 1988 | | + | ++
Mazor, 2002 | | + | ++ / ? | ++ / ++ / ++ / ++
Nora, 1994 | ++ | + | +
Rubenstein, 1992 | ++ / ++
Tang, 2002 | | ++ / ++ / ++
Nurses
Alpers, 1996 | | + / -
Flavin, 1997 | 0
Frank-Stromborg, 1987 | | ++ / + | +
Frisch, 1990 | ++ / 0 / +
Inglis, 2000 | | ++
Jeffreys, 1999 | ++ | ++ | ++
Lasch, 2000 | ++ | ++
Napholz, 1999 | | +
Scisney-Matlock, 2000 | | | ++ / ++
Smith, 2001 | ++ | ++
St. Clair, 1999 | | ++ / ++ / +
Underwood, 1999 | + | + / + | +
Williamson, 1996 | ++ | ++ | ++
Mixed healthcare provider groups
Erkel, 1995 | + | + / + / +
Gallagher Thompson, 2000 | ++ / ++ | | ++
Gany, 1996 | ++ | ++
Way, 2002 | + | + / ++ | | ++
Other healthcare providers
Hansen, 2002 | ++
Strumphauzer, 1983 | ++ | | ++
Wade, 1991 | | | | ++ | ++

a “++” indicates significant positive effect, “+” indicates positive effect,“-“ indicates negative effect, “?” indicates partial/mixed effect, “?” indicates unclear, and “0” indicates no effect. If cell is left blank, then outcome type is not measured for that study. Outcomes separated by “/” indicate more than one outcome type