# Included Studies, Appendix C

Ahluwalia L S, Gibson C A, Kenney R E, et al. Smoking status as a vital sign. J Gen Intern Med. 1999;14:402-408. [pmid: 10417597]. [pmcid: 1496600].
Allen B Jr, Pederson L L, Leonard E H. Effectiveness of physicians-in-training counseling for smoking cessation in African Americans. J Natl Med Assoc. 1998;90(10):597-604. [pmid: 9803724].
Alpers R R, Zoucha R. Comparison of cultural competence and cultural confidence of senior nursing students in a private southern university. J Cult Divers. 1996;3(1):9-15. [pmid: 8788835].
Barton J A, Brown N J. Evaluation study of a transcultural discovery learning model. Public Health Nurs. 1992;9(4):234-41. [pmid: 1484813].
Beagan B L. Teaching Social and Cultural Awareness to Medical Students: “It's All Very Nice to Talk about It in Theory, But Ultimately It Makes No Difference”. Acad Med. 2003;78(6):605-14. [pmid: 12805041].
Bengiamin M I, Downey V W, Heuer L J. Continuing education. Transcultural healthcare: a phenomenological study of an educational experience. J Cult Divers. 1999;6(2):60-8. [pmid: 10646479].
Berman A, Manning M P, Peters E, et al. A template for cultural diversity workshops. Oncol Nurs Forum. 1998;25(10):1711-8. [pmid: 9826838].
Blackford J, Street A. Cultural conflict: the impact of western feminism(s) on nurses caring for women of non-English speaking background. J Clin Nurs. 2002;11(5):664-71. [pmid: 12201894].
Bond M L, Jones M E. Short-term cultural immersion in Mexico. Nurs Health Care. 1994;15(5):248-53. [pmid: 7970259].
Briscoe V J, Pichert J W. Evaluation of a program to promote diabetes care via existing agencies in African American communities. ABNF J. 1999;10(5):111-5. [pmid: 10795176].
Browne C V, Braun K L, Mokuau N, et al. Developing a multisite project in geriatric and/or gerontological education with emphases in interdisciplinary practice and cultural competence. Gerontologist. 2002;42(5):698-704. [pmid: 12351805].
Burack R C, Gimotty P A. Promoting screening mammography in inner-city settings. The sustained effectiveness of computerized reminders in a randomized controlled trial. Med Care. 1997;35(9):921-31. [pmid: 9298081].
Burack R C, Gimotty P A, George J, et al. How reminders given to patients and physicians affected pap smear use in a health maintenance organization: results of a randomized controlled trial. Cancer. 1998;82(12):2391-400. [pmid: 9635532].
Burack R C, Gimotty P A, George J, et al. The effect of patient and physician reminders on use of screening mammography in a health maintenance organization. Results of a randomized controlled trial. Cancer. 1996;78(8):1708-21. [pmid: 8859184].
Burack R C, Gimotty P A, George J, et al. Promoting screening mammography in inner-city settings: a randomized controlled trial of computerized reminders as a component of a program to facilitate mammography. Med Care. 1994;32(6):609-24. [pmid: 8189778].
Burack R C, Gimotty P A, Simon M, et al. The effect of adding Pap smear information to a mammography reminder system in an HMO: results of randomized controlled trial. Prev Med. 2003;36(5):547-54. [pmid: 12689799].
Burge S K, Amodei N, Elkin B, et al. An evaluation of two primary care interventions for alcohol abuse among Mexican-American patients. Addiction. 1997;92(12):1705-16. [pmid: 9581003].
Callahan C M, Hendrie H C, Dittus R S, et al. Improving treatment of late life depression in primary care: a randomized clinical trial. J Am Geriatr Soc. 1994;42(8):839-46. [pmid: 8046193].
Campinha-Bacote J, Yahle T, Langenkamp M. The challenge of cultural diversity for nurse educators. J Contin Educ Nurs. 1996;27(2):59-64. [pmid: 8698928].
Chambers C V, Balaban D J, Carlson B L, et al. Microcomputer-generated reminders. Improving the compliance of primary care physicians with mammography screening guidelines. J Fam Pract. 1989;29(3):273-80. [pmid: 2769192].
Chevannes M. Issues in educating health professionals to meet the diverse needs of patients and other service users from ethnic minority groups. J Adv Nurs. 2002;39(3):290-8. [pmid: 12121530].
Copeman R C. Medical students, Aborigines and migrants: evaluation of a teaching programme. Med J Aust. 1989;150(2):84-7. [pmid: 2725401].
Crandall S J, George G, Marion G S, et al. Applying theory to the design of cultural competency training for medical students: a case study. Acad Med. 2003;78(6):588-94. [pmid: 12805037].
Culhane-Pera K A, Reif C, Egli E, et al. A curriculum for multicultural education in family medicine. Fam Med. 1997;29(10):719-23. [pmid: 9397362].
Dexter P R, Wolinsky F D, Gramelspacher G P, et al. Effectiveness of computer-generated reminders for increasing discussions about advance directives and completion of advance directive forms. A randomized, controlled trial. Ann Intern Med. 1998;128(2):102-10. [pmid: 9441569].
Dietrich AJ, Tobin JN, Sox CH, et al. Cancer early-detection services in community health centers for the underserved. A randomized controlled trial. Arch Fam Med 1998; 7(4): 320–7; discussion 328.
Dogra N. The development and evaluation of a programme to teach cultural diversity to medical undergraduate students. Med Educ. 2001;35(3):232-41. [pmid: 11260446].
Douglas K C, Lenahan P. Ethnogeriatric assessment clinic in family medicine. Fam Med. 1994;26(6):372-5. [pmid: 8050660].
Dowell A, Crampton P, Parkin C. The first sunrise: an experience of cultural immersion and community health needs assessment by undergraduate medical students in New Zealand. Med Educ. 2001;35(3):242-9. [pmid: 11260447].
Drouin J, Rivet C. Training medical students to communicate with a linguistic minority group. Acad Med. 2003;78(6):599-604. [pmid: 12805039].
Erkel E A, Nivens A S, Kennedy D E. Intensive immersion of nursing students in rural interdisciplinary care. J Nurs Educ. 1995;34(8):359-65. [pmid: 8558281].
Evans D, Mellins R, Lobach K, et al. Improving care for minority children with asthma: professional education in public health clinics. Pediatrics. 1997;99(2):157-64. [pmid: 9024439].
Farnill D, Todisco J, Hayes S C, et al. Videotaped interviewing of non-English speakers: training for medical students with volunteer clients. Med Educ. 1997;31(2):87-93. [pmid: 9231107].
Felder E. Baccalaureate and associate degree student nurses' cultural knowledge of and attitudes toward black American clients. J Nurs Educ. 1990;29(6):276-82. [pmid: 2165148].
Flavin C. Cross-cultural training for nurses: a research-based education project. Am J Hosp Palliat Care. May-Jun. 1997;14(3):121-6. [pmid: 9295417].
Frank-Stromborg M, Johnson J, McCorkle R. A program model for nurses involved with cancer education of black Americans. J Cancer Educ. 1987;2(3):145-51. [pmid: 3274973].
Frisch N C. An international nursing student exchange program: an educational experience that enhanced student cognitive development. J Nurs Educ. 1990;29(1):10-2. [pmid: 2153775].
Gallagher Thompson D, Haynie D, Takagi K A, et al. Impact of an Alzheimer's disease education program: focus on Hispanic families. Gerontol Geriatr Educ. 2000;20(3):25-40.
Gany F, de Bocanegra H T. Maternal-child immigrant health training: changing knowledge and attitudes to improve health care delivery. Patient Educ Couns. 1996;27(1):23-31. [pmid: 8788746].
Gemson D H, Ashford A R, Dickey L L, et al. Putting prevention into practice. Impact of a multifaceted physician education program on preventive services in the inner city. Arch Intern Med. 1995;155(20):2210-6. [pmid: 7487243].
Gielen A C, Wilson M E, McDonald E M, et al. Randomized trial of enhanced anticipatory guidance for injury prevention. Arch Pediatr Adolesc Med. 2001;155(1):42-9. [pmid: 11177061].
Godkin M, Savageau J. The effect of medical students' international experiences on attitudes toward serving underserved multicultural populations. Fam Med. 2003;35(4):273-8. [pmid: 12729313].
Godkin M A, Savageau J A. The effect of a global multiculturalism track on cultural competence of preclinical medical students. Fam Med. 2001;33(3):178-86. [pmid: 11302510].
Hadwiger S C. Cultural competence case scenarios for critical care nursing education. Nurse Educ. 1999;24(5):47-51. [pmid: 10795257].
Haloburdo E P, Thompson M A. A comparison of international learning experiences for baccalaureate nursing students: developed and developing countries. J Nurs Educ. 1998;37(1):13-21. [pmid: 9476730].
Hansen N D. Teaching cultural sensitivity in psychological assessment: a modular approach used in a distance education program. J Pers Assess. 2002;79(2):200-6. [pmid: 12425384].
Haq C, Rothenberg D, Gjerde C, et al. New world views: preparing physicians in training for global health work. Fam Med. 2000;32(8):566-72. [pmid: 11002868].
Harris L E, Luft F C, Rudy D W, et al. Effects of multidisciplinary case management in patients with chronic renal insufficiency. Am J Med. 1998;105(6):464-71. [pmid: 9870830].
Harris R, Mackenzie T, Leeman-Castillo B, et al. Optimizing antibiotic prescribing for acute respiratiory tract infections in an urban urgent care clinic. J Gen Intern Med. 2003;18:326-334. [pmid: 12795730]. [pmcid: 1494862].
Hornberger J C, Gibson C D Jr, Wood W, et al. Eliminating language barriers for non-English-speaking patients. Med Care. 1996;34(8):845-56. [pmid: 8709665].
Inglis A, Rolls C, Kristy S. The impact on attitudes towards cultural difference of participation in a health focused study abroad program. Contemp Nurse. 2000;9(34):246-55. [pmid: 11855033].
Jeffreys M R. A transcultural core course in the clinical nurse specialist curriculum. Clin Nurse Spec. 2002;16(4):195-202. [pmid: 12172489].
Jeffreys M R, Smodlaka I. Changes in students' transcultural self-efficacy perceptions following an integrated approach to culture care. J Multicul Nurs Health. 1999;5(2):6-12.
Kellermann A L, Hackman B B, Somes G, et al. Impact of first-responder defibrillation in an urban emergency medical services system. JAMA. 1993;270(14):1708-13. [pmid: 8411501].
Keyserling T C, Ammerman A S, Davis C E, et al. A randomized controlled trial of a physician-directed treatment program for low-income patients with high blood cholesterol: the Southeast Cholesterol Project. Arch Fam Med. 1997;6(2):135-45. [pmid: 9075448].
Lasch K E, Wilkes G, Lee J, et al. Is hands-on experience more effective than didactic workshops in postgraduate cancer pain education?. J Cancer Educ. 2000;15(4):218-22. [pmid: 11199239].
Lindquist G J. A cross-cultural experience: comparative study in nursing and health care. J Nurs Educ. 1984;23(5):212-4. [pmid: 6325640].
Lockhart J S, Resick L K. Teaching cultural competence. The value of experiential learning and community resources. Nurse Educ. 1997;22(3):27-31. [pmid: 9197654].
Mandelblatt J, Traxler M, Lakin P, et al. A nurse practitioner intervention to increase breast and cervical cancer screening for poor, elderly black women. The Harlem Study Team. J Gen Intern Med. 1993;8(4):173-8. [pmid: 8515326].
Manfredi C, Czaja R, Freels S, et al. Prescribe for health. Improving cancer screening in physician practices serving low-income and minority populations. Arch Fam Med. 1998;7(4):329-37. [pmid: 9682686].
Mao C, Bullock C S, Harway E C, et al. A workshop on ethnic and cultural awareness for second-year students. J Med Educ. 1988;63(8):624-8. [pmid: 3398017].
Marvel M K, Grow M, Morphew P. Integrating family and culture into medicine: a family systems block rotation. Fam. 1993;25(7):441-442.
Mazor S S, Hampers L C, Chande V T, et al. Teaching Spanish to pediatric emergency physicians: Effects on patient satisfaction. Arch Pediatr Adolesc Med. 2002;156(7):693-695. [pmid: 12090837].
McCarthy B D, Yood M U, Bolton M B, et al. Redesigning primary care processes to improve the offering of mammography. The use of clinic protocols by nonphysicians. J Gen Intern Med. 1997;12(6):357-63. [pmid: 9192253]. [pmcid: 1497119].
McDonald C J, Hui S L, Smith D M, et al. Reminders to physicians from an introspective computer medical record. A two-year randomized trial. Ann Intern Med. 1984;100(1):130-8. [pmid: 6691639].
Miranda J, Duan N, Sherbourne C, et al. Improving care for Minorities: Can Quality Improvement Interventions Improve Care and Outcomes for Depressed Minorites? Results of a Randomized, Controlled Trial. Health Serv Res. 2003;38(2):613-630. [pmid: 12785564]. [pmcid: 1360906].
Napholz L. A comparison of self-reported cultural competency skills among two groups of nursing students: implications for nursing education. J Nurs Educ. 1999;38(2):81-3. [pmid: 10698608].
Nora L M, Daugherty S R, Mattis-Peterson A, et al. Improving cross-cultural skills of medical students through medical school-community partnerships. West J Med. 1994;161(2):144-7. [pmid: 7941532]. [pmcid: 1022526].
Oneha M F, Sloat A, Shoultz J, et al. Community partnerships: redirecting the education of undergraduate nursing students. J Nurs Educ. 1998;37(3):129-35. [pmid: 9535229].
Rolls C, Inglis A, Kristy S. Study abroad programs: creating awareness of and changing attitudes to nursing, health and ways of living in other cultures. Contemp Nurse. 1997;6(34):152-6. [pmid: 9511657].
Rooda L, Gay G. Staff development for culturally sensitive nursing care. J Nurs Staff Dev. 1993;9(6):262-5. [pmid: 8263587].
Rubenstein H L, O'Connor B B, Nieman L Z, et al. Introducing students to the role of folk and popular health belief- systems in patient care. Acad Med. 1992;67(9):566-8. [pmid: 1520410].
Ryan M, Ali N, Carlton K H. Community of Communities: an electronic link to integrating cultural diversity in nursing curriculum. J Prof Nurs. 2002;18(2):85-92. [pmid: 11977006].
Ryan M, Twibell R, Brigham C, et al. Learning to care for clients in their world, not mine. J Nurs Educ. 2000;39(9):401-8. [pmid: 11138745].
Schubiner H, Tzelepis A, Wright K, et al. The clinical utility of the Safe Times Questionnaire. J Adolesc Health. 1994;15(5):374-82. [pmid: 7947851].
Scisney-Matlock M. Systematic methods to enhance diversity knowledge gained: a proposed path to professional richness. J Cult Divers. 2000;7(2):41-7. [pmid: 11249260].
Sinnott M J, Wittmann B. An introduction to indigenous health and culture: the first tier of the Three Tiered Plan. Aust J Rural Health. 2001;9(3):116-20. [pmid: 11421962].
Smith L S. Evaluation of an educational intervention to increase cultural competence among registered nurses. J Cult Divers. 2001;8(2):50-63. [pmid: 11855050].
St Clair A, McKenry L. Preparing culturally competent practitioners. J Nurs Educ. 1999;38(5):228-34. [pmid: 10438097].
Stumphauzer J S, Davis L C. Training community-based, Asian-American mental health personnel in behavior modification. J Community Psychol. 1983;11(3):253-8. [pmid: 10262377].
Tang T S, Fantone J C, Bozynski M E, et al. Implementation and evaluation of an undergraduate Sociocultural Medicine Program. Acad Med. 2002;77(6):578-85. [pmid: 12063207].
Tomlinson-Clarke S. Assessing outcomes in a multicultural training course: A qualitative study. Couns Psychol. 2000;13(2):221-231.
Turner B J, Day S C, Borenstein B. A controlled trial to improve delivery of preventive care: physician or patient reminders?. J Gen Intern Med. 1989;4(5):403-9. [pmid: 2677271].
Underwood S M. Development of a cancer prevention and early detection program for nurses working with African Americans. J Contin Educ Nurs. 1999;30(1):30-6. [pmid: 10036415].
Underwood S M, Dobson A. Cancer prevention and early detection program for educators: reducing the cancer burden of among African Americans within the academic arena. J Natl Black Nurses Assoc. 2002;13(1):45-55. [pmid: 12242750].
Velde B P, Wittman P P. Helping occupational therapy students and faculty develop cultural competence. Occ Ther Health Car. 2001;13(34):23-32.
Wade P, Berstein B. Culture sensitivity training and counselor's race: effects on black female client's perceptions and attrition. J Couns Psychol. 1991;38:9-15.
Warner J R. Cultural competence immersion experiences: public health among the Navajo. Nurse Educ. 2002;27(4):187-90. [pmid: 12131817].
Way B B, Stone B, Schwager M, et al. Effectiveness of the New York State Office of Mental Health Core Curriculum: Direct care staff training. Psychiatr Rehabil J. 2002;25(4):398-402. [pmid: 12013268].
Wendler M C, Struthers R. Bridging culture on-line: Strategies for teaching cultural sensitivity. J Prof Nurs. 2002;18(6):320-7. [pmid: 12486638].
Williamson E, Stecchi J M, Allen B B, et al. Multiethnic experiences enhance nursing students' learning. J Community Health Nurs. 1996;13(2):73-81. [pmid: 8764382].