# Listing of Excluded Articles

Affonso D D, Mayberry L, Inaba A, et al. Hawaiian-style “talkstory”: psychosocial assessment and intervention during and after pregnancy. J Obstet Gynecol Neonatal Nurs. 1996;25(9):737-42. [pmid: 8951110].
no evaluation of an intervention
Affonso D D, Mayberry L J, Inaba A, et al. Neighborhood women's health watch: partners in community care. Adv Pract Nurs Q. 1995;1(3):34-40. [pmid: 9447028].
not targeted to healthcare providers or organizations
Ailinger R L, Zamora L, Molloy S, et al. Nurse practitioner students in Nicaragua. Clin Excell Nurse Pract. 2000;4(4):240-4. [pmid: 11261086].
no evaluation of an intervention
Albritton T A, Wagner P J. Linking cultural competency and community service: a partnership between students, faculty, and the community. Acad Med. 2002;77(7):738-9. [pmid: 12114156].
no evaluation of an intervention
Alexander M. Cinemeducation: An In ovatine approach to teaching multi-cultural dicersity in medicine. Annals of behavioral science and medical education. 1995;2(1):23-28.
no evaluation of an intervention
Andersen M D. Personalized nursing: an effective intervention model for use with drug-dependent women in an emergency room. Int J Addict. 1986;21(1):105-22. [pmid: 3486836].
not targeted to healthcare providers or organizations
Badger T A, Cardea J M, Biocca L J, et al. Assessment and management of depression: an imperative for community-based practice. Arch Psychiatr Nurs. 1990;4(4):235-41. [pmid: 2241243].
other: duplicate
Badger T A, Mishel M H, Biocca L J, et al. Depression assessment and management: evaluating a community-based mental health training program for nurses. Public Health Nurs. 1991;8(3):170-5. [pmid: 1946152].
not relevant to minority health
Bahry V J, Fullerton J T, Lops V R. Provision of comprehensive perinatal services through rural outreach: A model program. J Rural Health. 1989;5(4):387-396. [pmid: 10296594].
only quality (Q1) and not RCT or concurrent CCT
Baker S S, Burkhalter N C. Teaching transcultural nursing in a transcultural setting. J Transcult Nurs. 1996;7(2):10-3. [pmid: 8974411].
no evaluation of an intervention
Baldwin D, Nelms T. Difficult dialogues: impact on nursing education curricula. J Prof Nurs. 1993;9(6):343-6. [pmid: 8300971].
no evaluation of an intervention
Bardack M A, Thompson S H. Model prenatal program of Rush Medical College at St. Basil's Free Peoples Clinic Chicago. Public Health Rep. 1993;108(2):161-5. [pmid: 8464973]. [pmcid: 1403356].
no evaluation of an intervention
Bartz R. Beyond the biopsychosocial model: new approaches to doctor-patient interactions. J Fam Pract. 1999;48(8):601-7. [pmid: 10496638].
no original data
Beisecker A E, Hayes J, Ashworth J K, et al. Providing information about breast cancer via public forums. Cancer Detect Prev. 1997;21(4):370-9. [pmid: 9232329].
not relevant to minority health
Bengiamin MI, Downey VW, and Heuer LJ. Transcultural healthcare: a phenomenological study of an educational experience. J Cult Divers 1999; 6(2): 60–6; quiz 67–8.
not targeted to healthcare providers or organizations
Benoliel J Q. Death influence in clinical practice: a course for graduate students. Death Education. 1982;5(4):327-346.
not relevant to minority health
Berlin E A, Fowkes W C Jr. A teaching framework for cross-cultural health care. Application in family practice. West J Med. 1983;139(6):934-938. [pmid: 6666112]. [pmcid: 1011028].
no original data
Bidigare S A, Ellis A R. Family physicians' role in recruitment of organ donors. Arch Fam Med. 2000;9(7):601-5. [pmid: 10910306].
not relevant to minority health
Bittle M, Duggleby W, Ellison P. Implementation of the essential elements of service learning in three nursing courses. J Nurs Educ. 2002;41(3):129-32. [pmid: 11939232].
no original data
Blackford J, Street A. Problem-based learning: an educational strategy to support nurses working in a multicultural community. Nurse Educ Today. 1999;19(5):364-72. [pmid: 10693484].
no evaluation of an intervention
Blue AV, Kern DH, Chessman AW, et al. A collaborative clerkship with a focus on rural community health. J S C Med Assoc 2001; 97(9): 383–4, 387–9.
no evaluation of an intervention
Boekeloo B O, Schamus L A, Simmens S J, et al. A STD/HIV prevention trial among adolescents in managed care. Pediatrics. 1999;103(1):107-15. [pmid: 9917447].
only quality (Q1) and not RCT or concurrent CCT
Bogden P E, Abbott R D, Williamson P, et al. Comparing standard care with a physician and pharmacist team approach for uncontrolled hypertension. J Gen Intern Med. 1998;13(11):740-5. [pmid: 9824519]. [pmcid: 1497023].
not relevant to minority health
Bonner S, Zimmerman B J, Evans D, et al. An individualized intervention to improve asthma management among urban Latino and African-American families. J Asthma. 2002;39(2):167-79. [pmid: 11990232].
not targeted to healthcare providers or organizations
Bowen J, Yaste C. Effect of a stroke protocol on hospital costs of stroke patients. Neurolog. 1994;44(10):1961-4.
only quality (Q1) and not RCT or concurrent CCT
Bravo M, Canino G J, Rubio-Stipec M, et al. A cross-cultural adaptation of a psychiatric epidemiologic instrument: the diagnostic interview schedule's adaptation in Puerto Rico. Cult Med Psychiatry. 1991;15(1):1-18. [pmid: 2060311].
not targeted to healthcare providers or organizations
Brill J R, Ohly S, Stearns M A. Training community-responsive physicians. Acad Med. 2002;77(7):747. [pmid: 12114168].
meeting abstract
Burack R, Gimmotty P, Moncrease A, et al. The intial and sustained efffectiveness of an intervention to improve breast cancer control in an inner-city health department. Clin Res. 1992;40:607A.
meeting abstract
Burack R C, Gimotty P A, Stengle W, et al. Detroit's avoidable mortality project: breast cancer control for inner-city women. Public Health Rep. 1989;104(6):527-35. [pmid: 2511584]. [pmcid: 1580164].
no evaluation of an intervention
Burns I T, Zimmerman R K, Santibanez T A. Effectiveness of chart prompt about immunizations in an urban health center. J Fam Pract. 2002;51(12):1018. [pmid: 12540325].
not relevant to minority health
Burrows A. Patient-centred nursing care in a multi-racial society: the relevance of ethnographic perspectives in nursing curricula. J Adv Nurs. 1983;8(6):477-85. [pmid: 6558083].
no original data
Buttriss G, Kuiper R, Newbold B. The use of a homeless shelter as a clinical rotation for nursing students. J Nurs Educ. 1995;34(8):375-7. [pmid: 8558284].
not relevant to minority health
Caggiula A W, Watson J E, Kuller L H, et al. Cholesterol-lowering intervention program. Effect of the step I diet in community office practices. Arch Intern Med. 1996;156(11):1205-13. [pmid: 8639015].
not relevant to minority health
Carpio B A, Majumdar B. Experiential learning: an approach to transcultural education for nursing. J Transcult Nurs. 1993;4(2):4-11. [pmid: 8507435].
no evaluation of an intervention
Chrisman N J. Backyard cultural change: diversity workshops at the institution level. J Multicul Nurs Health. 1998;4(1):6-10.
no evaluation of an intervention
Chrisman NJ, Schultz PR. Transforming health care through cultural competence training IN: Cultural diversity in nursing: issues, strategies, and outcomes (Dienemann JA). 1997.
no original data
Chugh U, Dillmann E, Kurtz S M, et al. Multicultural issues in medical curriculum: implications for Canadian physicians. Med Teach. 1993;15(1):83-91. [pmid: 8326850].
no evaluation of an intervention
Chussil J T. Cultural competency in nursing. Dermatol Nurs. 1998;10(6):393. [pmid: 10670315].
does not include human data
Cultural diversity in the nursing curriculum: a guide for implementation. 1986.
no original data
Improving minority health outcomes through culturally specific care. Nursing Trends and Issues 1997; 2(3): 1–8.
no intervention
Practice notes: strategies in health education. Program: Institute for Cross Cultural Competence in the Healthcare System. Health Educ Behav 2001; 28(5): 530–1.
no evaluation of an intervention
Report and recommendations for the first national conference on teaching of transcultural nursing. J Transcult Nurs 1992; 4(1): 41–2.
does not include human data
Waerea te ara Ri te ora… a bicultural approach to nursing… Maori representation. N Z Nurs J 1987; 80(3): 17.
no original data
Clinton J F. Cultural diversity and health care in America: knowledge fundamental to cultural competence in baccalaureate nursing students. J Cult Divers. 1996;3(1):4-8. [pmid: 8788834].
no evaluation of an intervention
Cook P R, Cullen J A. Diversity as a value in undergraduate nursing education. . Nurs Health Care Perspect. 2000;21(4):178-83.
no evaluation of an intervention
Costanza M E, Stoddard A M, Luckmann R, et al. Promoting mammography: results of a randomized trial of telephone counseling and a medical practice intervention. Am J Prev Med. 2000;19(1):39-46. [pmid: 10865162].
not relevant to minority health
Crampton P, Dowell A, Parkin C, et al. Combating effects of racism through a cultural immersion medical education program. Acad Med. 2003;78(6):595-8. [pmid: 12805038].
other: duplicate
Cunningham Warburton PA. A study of the relationship between cross-cultural training, the Scale to Assess World Views, and the quality of care given by nurses in a psychiatric setting. 1988.
other: non-pubilshed
Daddy J, Clegg A. Cultural sensitivity: a practical approach to improving services. Nurs Stand. 2001;15(33):39-40. [pmid: 12216266].
no evaluation of an intervention
Dana R H, Aguilar-Kitibutr A, Diaz-Vivar N, et al. A teaching method for multicultural assessment: psychological report contents and cultural competence. J Pers Assess. 2002;79(2):207-15. [pmid: 12425385].
not targeted to healthcare providers or organizations
Das M K, Bhattacharyya N. Paediatric immunisation: Special emphasis on measles and MMR vaccinations. J Indian Med Assoc. 2002;100(5):320-321. [pmid: 12418635].
no intervention
Davidson M B, Karlan V J, Hair T L. Effect of a pharmacist-managed diabetes care program in a free medical clinic. Am J Med Qual. 2000;15(4):137-42. [pmid: 10948785].
only quality (Q1) and not RCT or concurrent CCT
Dedier J, Penson R, Williams W, et al. Race, ethnicity, and the patient-caregiver relationship. Oncologist. 1999;4(4):325-331. [pmid: 10476544].
no evaluation of an intervention
Delgado M. Alcohol use/abuse among Latinos: Issues and examples of culturally competent services: Introduction. Alcoholism Treatment Quarterly. 1998;16(12):1-3.
no original data
Delgado M. Natural support systems and AOD services to communities of color: A California case example. Alcoholism Treatment Quarterly. 1995;13(4):13-23.
not targeted to healthcare providers or organizations
DeSantis L. The relevance of transcultural nursing to international nursing. Int Nurs Rev 1988; 35(4): 110–2, 116.
no original data
DiCicco Bloom B. Practical approaches to developing cultural competency. Home Health Care Management and Practice. 2000;12(2):30-7.
no intervention
Dietrich A J, O'Connor G T, Keller A, et al. Cancer: improving early detection and prevention. A community practice randomised trial. BMJ. 1992;304(6828):687-91. [pmid: 1571644]. [pmcid: 1881551].
not relevant to minority health
Dohlie M B, Mielke E, Bwire T, et al. COPE (client-oriented, provider-efficient), a model for building community partnerships that improve care in East Africa. J Healthc Qual. 2000;22(5):34-39. [pmid: 11184028].
does not apply to any research question
Dowd S B, Poole V L, Davidhizar R, et al. Death, dying and grief in a transcultural context: application of the Giger and Davidhizar Assessment Model. Hosp J. 1998;13(4):33-56. [pmid: 9883126].
no evaluation of an intervention
Drouin J, Jean P. Educating future physicians for a minority population: a French-language stream at the University of Ottawa. Acad Med. 2002;77(3):217-21. [pmid: 11891158].
no evaluation of an intervention
Dyck I, Forwell S. Occupational therapy students' first year fieldwork experiences: Discovering the complexity of culture. Can J Occup Ther. 1997;64(4):185-196.
no intervention
Elliott B A, Johnson K M, Elliott T E, et al. Enhancing Cancer Pain Control among American Indians (ECPCAI): a study of the Ojibwe of Minnesota. J Cancer Educ. 1999;14(1):28-33. [pmid: 10328321].
no evaluation of an intervention
Ferrell B R, Grant M, Ritchey K J, et al. The Pain Resource Nurse Training Program: A unique approach to pain management. Journal of Pain & Symptom Management. 1993;8(8):549-556. [pmid: 7525784].
not relevant to minority health
Fisher S, Groce S B. Doctor-patient negotiation of cultural assumptions. Sociol Health Illn. 1985;7(3):342-374.
not relevant to minority health
Flores G. Culture and the patient-physician relationship: achieving cultural competency in health care. J Pediatr. 2000;136(1):14-23. [pmid: 10636968].
no original data
Fraser H C, Kutner J S, Pfeifer M P. Senior medical students' perceptions of the adequacy of education on end-of-life issues. J Palliat Med. 2001;4(3):337-43. [pmid: 11596545].
no intervention
Freeman P. A culturally orientated curriculum for Aboriginal health workers. World Health Forum. 1993;14(3):262-6. [pmid: 8397732].
no evaluation of an intervention
Friedman R H, Kazis L E, Jette A, et al. A telecommunications system for monitoring and counseling patients with hypertension. Impact on medication adherence and blood pressure control. Am J Hypertens. 1996;9(4 Pt 1):285-92. [pmid: 8722429].
not relevant to minority health
Gara-Trevino E S. A psychiatric curriculum directed to the care of the hospanic patient. Acad Psychiatry. 1997;21(1):1-10.
no evaluation of an intervention
Gentry A F, Fudge K A, Wellman G, et al. A novel comprehensive DUE program--five years of experience. Top Hosp Pharm Manage. 1991;11(2):18-30. [pmid: 10128632].
not relevant to minority health
Gifford D R, Holloway R G, Frankel M R, et al. Improving adherence to dementia guidelines through education and opinion leaders. A randomized, controlled trial. Ann Intern Med. 1999;131(4):237-46. [pmid: 10454944].
not relevant to minority health
Goiceochea-Balbona A. Culturally-specific health care model for ensuring helath care use by rural ethnically diverse families affected by HIV/AIDS. Health Soc Work. 1997;22(3):172-180. [pmid: 9260081].
no evaluation of an intervention
Guyer B, Hughart N, Strobino D, et al. Assessing the impact of pediatric-based development services on infants, families, and clinicians: challenges to evaluating the Health Steps Program. Pediatrics. 2000;105(3):E33. [pmid: 10699135].
no evaluation of an intervention
Hanna K. Multicultural considerations for the advanced practice nurse anesthetist in the preoperative teaching area. Nurs Adm Q. 1997;21(4):55-60. [pmid: 9295650].
no intervention
Headrick L A, Speroff T, Pelecanos H I, et al. Efforts to improve compliance with the National Cholesterol Education Program guidelines. Results of a randomized controlled trial. Arch Intern Med. 1992;152(12):2490-6. [pmid: 1456861].
not relevant to minority health
Healton C, Taylor S, Burr C, et al. The impact of patient education about the effect of zidovudine on HIV perinatal transmission: knowledge gain, attitudes, and behavioral intent among women with and at risk of HIV. Am J Prev Med. 1996;12(4 Suppl):47-52. [pmid: 8874704].
not targeted to healthcare providers or organizations
Heins H C Jr, Nance N W, McCarthy B J, et al. A randomized trial of nurse-midwifery prenatal care to reduce low birth weight. Obstet Gynecol. 1990;75(3 Pt 1):341-5. [pmid: 2406656].
not targeted to healthcare providers or organizations
Hendricson W D, Wood P R, Hidalgo H A, et al. Implementation of a physician education intervention. The Childhood Asthma Project. Arch Pediatr Adolesc Med. 1994;148(6):595-601. [pmid: 8193683].
only quality (Q1) and not RCT or concurrent CCT
Herman C J, Speroff T, Cebul R D. Improving compliance with breast cancer screening in older women. Results of a randomized controlled trial. Arch Intern Med. 1995;155(7):717-22. [pmid: 7695460].
not relevant to minority health
Herman C J, Speroff T, Cebul R D. Improving compliance with immunization in the older adult: results of a randomized cohort study. J Am Geriatr Soc. 1994;42(11):1154-9. [pmid: 7963201].
not relevant to minority health
Hernandez C A, Antone I, Cornelius I. A grounded theory study of the experience of type 2 diabetes mellitus in First Nations adults in Canada. J Transcult Nurs. 1999;10(3):220-8. [pmid: 10693409].
not targeted to healthcare providers or organizations
Hershey C O, Grant B J. Controlled trial of a patient-completed history questionnaire: effects on quality of documentation and patient and physician satisfaction. Am J Med Qual. 2002;17(4):126-35. [pmid: 12153065].
not targeted to healthcare providers or organizations
Hill M N, Bone L R, Hilton S C, et al. A clinical trial to improve high blood pressure care in young urban black men: recruitment, follow-up, and outcomes. Am J Hypertens. 1999;12(6):548-54. [pmid: 10371363].
not targeted to healthcare providers or organizations
Hislop T G, Deschamps M, Teh C, et al. Facilitators and barriers to cervical cancer screening among Chinese Canadian women. Can J Public Health. 2003;94(1):68-73. [pmid: 12583683].
no intervention
Hjelm K, Isacsson A, Apelqvist J. Healthcare professionals' perceptions of beliefs about health and illness in migrants with diabetes mellitus. Practical-Diabetes-International. 1998;15(8):233-7.
no intervention
Houldin A D, Reville B, Boland B A, et al. Graduate education in oncology nursing for minorities. J Cancer Educ. 2002;17(4):201-204. [pmid: 12556056].
does not apply to any research question
Humphreys T, Shofer F S, Jacobson S, et al. Preformatted charts improve documentation in the emergency department. Ann Emerg Med. 1992;21(5):534-40. [pmid: 1570909].
not relevant to minority health
Huttlinger K, Keating S B. Understanding cultural diversity through a student exchange program. Nurse Educ. 1991;16(5):29-33. [pmid: 1922994].
no evaluation of an intervention
Imperato P J. A Third World international health elective for U.S. medical students. The 16-year experience of the State University of New York Health Science Center at Brooklyn. J Community Health. 1996;21(4):241-68. [pmid: 8842888].
no intervention
Jaber L A, Halapy H, Fernet M, et al. Evaluation of a pharmaceutical care model on diabetes management. Ann Pharmacother. 1996;30(3):238-43. [pmid: 8833557].
not targeted to healthcare providers or organizations
Jackson D, Sullivan J R. Integrating the creative arts into a midwifery curriculum: a teaching innovation report. Nurse Educ Today. 1999;19(7):527-32. [pmid: 10808894].
not relevant to minority health
Jacobson T A, Thomas D M, Morton F J, et al. Use of a low-literacy patient education tool to enhance pneumococcal vaccination rates. A randomized controlled trial. JAMA. 1999;282(7):646-50. [pmid: 10517717].
not targeted to healthcare providers or organizations
Jeffreys M R, O'Donnell M. Cultural discovery: an innovative philosophy for creative learning activities. J Transcult Nurs. 1997;8(2):17-22. [pmid: 9369661].
no original data
Jeffs L. Research in progress: the impact of cultural safety nursing education on nursing and midwifery practice. Nurs Prax N Z. 2001;17(1):44.
no original data
Jones M E, Bond M L, Mancini M E. Developing a culturally competent work force: an opportunity for collaboration. J Prof Nurs. 1998;14(5):280-7. [pmid: 9775635].
no evaluation of an intervention
Kaiser M M, Barry T L, Kaiser K L. Using focus groups to evaluate and strengthen public health nursing population-focused interventions. J Transcult Nurs. 2002;13(4):303-10. [pmid: 12325245].
only quality (Q1) and not RCT or concurrent CCT
Kamien M. Education in community medicine with an emphasis on the health of an Aboriginal community: a pilot project. Med J Aust. 1975;2(13):509-13. [pmid: 1196198].
published prior to 1980
Kataoka-Yahiro M, Yoder M, Cohen J. Ten steps to create an innovative community-based pediatric experience as part of a clinical practicum: a model. J Pediatr Nurs. 1996;11(5):309-14. [pmid: 8908899].
no original data
Kater V. A tale of teaching in two cities. Int Nurs Rev. 2000;47(2):121-5. [pmid: 10884181].
no evaluation of an intervention
Kavanagh K, Absalom K, Beil W Jr, et al. Connecting and becoming culturally competent: a Lakota example. ANS Adv Nurs Sci. 1999;21(3):9-31. [pmid: 10416854].
no original data
Kavanagh K, Pope D, Weiss K, et al. Students experience the Pine Ridge South Dakota Reservation. Imprint. 1995;42(5):48-51. [pmid: 7498952].
no original data
Kavanagh K H. Summers of no return: transforming care through a nursing field school. J Nurs Educ. 1998;37(2):71-9. [pmid: 9489681].
no evaluation of an intervention
Kearnes DR. Impact of a nurse practitioner and physician collaborative practice on older adults admitted to a large urban hospital: differences in treatment and outcome. Nurse Pract 1994; 19(8): 32, 34–6.
not relevant to minority health
Keitz S A, Box T L, Homan R K, et al. Primary care for patients infected with human immunodeficiency virus: a randomized controlled trial. J Gen Intern Med. 2001;16(9):573-82. [pmid: 11556937]. [pmcid: 1495270].
not relevant to minority health
Kirkpatrick M K, Brown S. Efficacy of an international exchange via the Internet. J Nurs Educ. 1999;38(6):278-81. [pmid: 10512469].
not relevant to minority health
Knight R A, Remington P L. Training internal medicine residents to screen for domestic violence. J Womens Health Gend Based Med. 2000;9(2):167-74. [pmid: 10746520].
not relevant to minority health
Kollar S J, Ailinger R L. International clinical experiences: long-term impact on students. Nurse Educ. 2002;27(1):28-31. [pmid: 11840069].
no evaluation of an intervention
Kristal L, Pennock P W, Foote S M, et al. Cross-cultural family medicine residency training. J Fam Pract. 1983;17(4):683-7. [pmid: 6619751].
no evaluation of an intervention
Larkin G L, Rolniak S, Hyman K B, et al. Effect of an administrative intervention on rates of screening for domestic violence in an urban emergency department. Am J Public Health. 2000;90(9):1444-8. [pmid: 10983204]. [pmcid: 1447616].
not relevant to minority health
Lavizzo-Mourey R, Mackenzie E R. Cultural competence: Essential measurements of quality for managed care organizations. Ann Intern Med. 1996;124(10):919-921. [pmid: 8610923].
no original data
Lefley H P, Bestman E W. Public-academic linkages for culturally sensitive community mental health. Community Ment Health J. 1991;27(6):473-88. [pmid: 1663441].
no original data
Leininger M. Culture care theory: a major contribution to advance transcultural nursing knowledge and practices. J Transcult Nurs 2002; 13(3): 189–92; discussion 200–1.
no original data
Leininger M. The significance of cultural concepts in nursing… originally published in Minnesota League for Nursing, vol. 10, no. 3, 3–12, in 1966, and in the Journal of Nursing Education (1967). J Transcult Nurs. 1990;2(1):52-9. [pmid: 2264943].
no intervention
Leininger M. Transcultural nurse specialists and generalists: new practitioners in nursing. J Transcult Nurs 1989; 1(1): 4–16 (18 ref).
no original data
Leonard P J. Consciousness-raising groups as a multicultural awareness approach: an experience with counselor trainees. Cult Divers Ment Health. 1996;2(2):89-98. [pmid: 9225564].
no evaluation of an intervention
Lie D, Rucker L, Cohn F. Using literature as the framework for a new course. Acad Med. 2002;77(11):1170. [pmid: 12431951].
no evaluation of an intervention
Lindquist G J. Integration of international and transcultural content in nursing curricula: a process for change. J Prof Nurs. 1990;6(5):272-9. [pmid: 2229723].
no intervention
Little M, Saul G D, Testa K, et al. Improving pregnancy outcome and reducing avoidable clinical resource utilization through telephonic perinatal care coordination. Lippincotts Case Manag. 2002;7(3):103-12. [pmid: 12048340].
not targeted to healthcare providers or organizations
Loue S, Lloyd L, Loh L. HIV prevention in U.S. Asian Pacific Islander communities: an innovative approach. J Health Care Poor Underserved. 1996;7(4):364-76. [pmid: 8908892].
no evaluation of an intervention
MacPhee D, Kreutzer J C, Fritz J J. Infusing a diversity perspective into human development courses. Child Dev. 1994;65(2 Spec No):699-715. [pmid: 8013249].
not targeted to healthcare providers or organizations
Martey J O, Elkins T E, Wilson J B, et al. Innovative community-based postgraduate training for obstetrics and gynecology in west Africa. Obstet Gynecol. 1995;85(6):1042-6. [pmid: 7770252].
does not apply to any research question
Mawn B, Pakkala K. Immunization update: a community-based nursing education program. J Contin Educ Nurs. 2000;31(3):101-10. [pmid: 11111508].
not relevant to minority health
McCaskill Stevens W, Pinto H, Marcus A C, et al. Recruiting minority cancer patients into cancer clinical trials: a pilot project involving the Eastern Cooperative Oncology Group and the National Medical Association. J Clin Oncol. 1999;17(3):1029-39. [pmid: 10071298].
does not apply to any research question
McGeeP.Teaching transcultural care: a guide for teachers of nursing and health care. 1992
no intervention
Moore M L. From randomized trial to community-focused practice. Image J Nurs Sch. 1999;31(4):349-54. [pmid: 10628101].
no evaluation of an intervention
Morell V W, Sharp P C, Crandall S J. Creating student awareness to improve cultural competence: Creating the critical incident. Med Teach. 2002;24(5):532-534. [pmid: 12450475].
no evaluation of an intervention
Muender M M, Moore M L, Chen G J, et al. Cost-benefit of a nursing telephone intervention to reduce preterm and low-birthweight births in an African American clinic population. Prev Med. 2000;30(4):271-6. [pmid: 10731454].
not targeted to healthcare providers or organizations
Mundinger M O, Kane R L, Lenz E R, et al. Primary care outcomes in patients treated by nurse practitioners or physicians: a randomized trial. JAMA. 2000;283(1):59-68. [pmid: 10632281].
does not apply to any research question
Narayanasamy A. Transcultural nursing. The ACCESS model: a transcultural nursing practice framework. Br J Nurs. 2002;11(9):643-50. [pmid: 12048479].
no intervention
Nelson W A, Wood S O, Nalepka C D. Development of a culturally sensitive rural practicum. Nurse Educ. 1993;18(3):10-3. [pmid: 8336847].
not relevant to minority health
Nestel D. Evaluation of a communication skills course: Cultural relevance of the patient-centred interview in a Hong Kong Chinese setting. Med Teach. 2001;23(2):212-214. [pmid: 11371301].
does not apply to any research question
Nguyen T, Vo P H, McPhee S J, et al. Promoting early detection of breast cancer among Vietnamese-American women. Results of a controlled trial. Cancer. 2001;91(1 Suppl):267-73. [pmid: 11148592].
only quality (Q1) and not RCT or concurrent CCT
Nyamathi A, Flaskerud J H, Leake B, et al. Evaluating the impact of peer, nurse case-managed, and standard HIV risk-reduction programs on psychosocial and health-promoting behavioral outcomes among homeless women. Res Nurs Health. 2001;24(5):410-22. [pmid: 11746070].
not targeted to healthcare providers or organizations
Nyamathi A M, Flaskerud J, Bennett C, et al. Evaluation of two AIDS education programs for impoverished Latina women. AIDS Educ Prev. 1994;6(4):296-309. [pmid: 7986651].
not targeted to healthcare providers or organizations
O'Brien L A, Grisso J A, Maislin G, et al. Nursing home residents' preferences for life-sustaining treatments. JAMA. 1995;274(22):1775-9. [pmid: 7500508].
not targeted to healthcare providers or organizations
O'Connell D L, Henry D, Tomlins R. Randomised controlled trial of effect of feedback on general practitioners' prescribing in Australia. BMJ. 1999;318(7182):507-11. [pmcid: 27749]. [pmid: 10024260].
not relevant to minority health
O'Hara EM, Zhan L. Cultural and pharmacologic considerations when caring for Chinese elders. J Gerontol Nurs 1994; 20(10): 11–6 (9 ref).
no intervention
Ofori-Adjei D, Arhinful D K. Effect of training on the clinical management of malaria by medical assistants in Ghana. Soc Sci Med. 1996;42(8):1169-76. [pmid: 8737435].
does not apply to any research question
Olds D L, Henderson C R Jr, Tatelbaum R, et al. Improving the life-course development of socially disadvantaged mothers: a randomized trial of nurse home visitation. Am J Public Health. 1988;78(11):1436-45. [pmid: 3052116]. [pmcid: 1350235].
not targeted to healthcare providers or organizations
Olson L L. Commentary on Resolving conflict in a multicultural nursing department [original article by Martin K et al appears in NURS MANAGE 1994; 25(1):49–51]. AONE's-Leadership-Prospectives. 1994;2(3):14.
no evaluation of an intervention
Oneha MFM. Ka mauli O ka `aina a he mauli kanaka (the life of the land is the life of the people): an ethnographic study from a Hawaiian sense of place. 2000.
not targeted to healthcare providers or organizations
Perez-Cuevas R, Guiscafre H, Munoz O, et al. Improving physician prescribing patterns to treat rhinopharyngitis. Intervention strategies in two health systems of Mexico. Soc Sci Med. 1996;42(8):1185-94. [pmid: 8737437].
only quality (Q2) and not conducted in the US
Persaud D I, Barnett S E, Weller S C, et al. An asthma self-management program for children, including instruction in peak flow monitoring by school nurses. J Asthma. 1996;33(1):37-43. [pmid: 8621369].
not targeted to healthcare providers or organizations
Peters A L, Davidson M B, Ossorio R C. Management of patients with diabetes by nurses with support of subspecialists. HMO Pract. 1995;9(1):8-13. [pmid: 10141351].
not relevant to minority health
Peterson R, Smith J. A patient care team approach to multicultural patient care issues. J Nurs Care Qual. 1996;10(3):75-9. [pmid: 8634474].
no evaluation of an intervention
Philips B U, Mahan J M, Perry R R. Minority recruitment to the health professions: a matched comparison six-year follow-up. J Med Educ. 1981;56(9 I):742-747. [pmid: 7277436].
not targeted to healthcare providers or organizations
Philis-Tsimikas A, Walker C. Improved care for diabetes in underserved populations. J Ambul Care Manage. 2001;24(1):39-43. [pmid: 11189795].
not targeted to healthcare providers or organizations
Poteet G W. Ethnic diversity. J Nurs Adm. 1986;16(3):6. [pmid: 3633317].
no original data
Pozen M W, D'Agostino R B, Selker H P, et al. A predictive instrument to improve coronary-care-unit admission practices in acute ischemic heart disease. A prospective multicenter clinical trial. N Engl J Med. 1984;310(20):1273-8. [pmid: 6371525].
not relevant to minority health
Princeton J C. Promoting culturally competent nursing education. J Nurs Educ. 1993;32(5):195-7. [pmid: 8388936].
no intervention
Ramsden I. Cultural safety in nursing education in Aotearoa (New Zealand). Nurs Prax NZ. 1993;8(3):4-10.
no intervention
Rankin S B, Kappy M S. Developing therapeutic relationships in multicultural settings. Acad Med. 1993;68(11):826-7. [pmid: 8216647].
no evaluation of an intervention
Reuben D B, Smith S R. Community health projects as part of a core clinical clerkship: teaching research skills in a community setting. J Community Health. 1987;12(4):257-64. [pmid: 3429711].
not relevant to minority health
Riegel B, Carlson B, Glaser D, et al. Standardized telephonic case management in a Hispanic heart failure population: an effective intervention. Dis Manage Health Outcomes. 2002;10(4):241-9.
not targeted to healthcare providers or organizations
Rivero Kempf R. AT&T language line: educating transcultural nurses on federal mandates and interpreter use. J Transcult Nurs. 1999;10(2):159-60. [pmid: 10476169].
not relevant to minority health
Roberts R R, Zalenski R J, Mensah E K, et al. Costs of an emergency department-based accelerated diagnostic protocol vs hospitalization in patients with chest pain: a randomized controlled trial. JAMA. 1997;278(20):1670-6. [pmid: 9388086].
not targeted to healthcare providers or organizations
Rogers M A, Small D, Buchan D A, et al. Home monitoring service improves mean arterial pressure in patients with essential hypertension. A randomized, controlled trial. Ann Intern Med. 2001;134(11):1024-32. [pmid: 11388815].
not relevant to minority health
Rollman B L, Hanusa B H, Gilbert T, et al. The electronic medical record. A randomized trial of its impact on primary care physicians' initial management of major depression. Arch Intern Med. 2001;161(2):189-97. [pmid: 11176732].
not relevant to minority health
Ryan M, Twibell R S. Outcomes of a transcultural nursing immersion experience: confirmation of a dimensional matrix. J Transcult Nurs. 2002;13(1):30-9. [pmid: 11776013].
does not apply to any research question
Sadler G R, Nguyen F, Doan Q, et al. Strategies for reaching Asian Americans with health information. Am J Prev Med. 1998;14(3):224-8. [pmid: 9569224].
not targeted to healthcare providers or organizations
Scholes J, Moore D. Clinical exchange: one model to achieve culturally sensitive care. Nurs Inq. 2000;7(1):61-71. [pmid: 11022536].
not relevant to minority health
Schoonover S C, Bassuk E L, Smith R, et al. The use of videotape programs to teach interpersonal skills. J Med Educ. 1983;58(10):804-10. [pmid: 6620341].
not relevant to minority health
Schraeder C, Shelton P, Sager M. The effects of a collaborative model of primary care on the mortality and hospital use of community-dwelling older adults. J Gerontol A Biol Sci Med Sci. 2001;56(2):M106-12. [pmid: 11213273].
not relevant to minority health
Schwartzberg J G, Guttman R. Effect of training on physician attitudes and practices in home and community care of the elderly. Arch Fam Med. 1997;6(5):439-44. [pmid: 9305686].
not relevant to minority health
Sebern M D. Cost and efficacy of pressure ulcer management in a metropolitan visiting nurse association. Decubitus. 1989;2(3):58-9. [pmid: 2775474].
not targeted to healthcare providers or organizations
Selker H P, Beshansky J R, Griffith J L. Use of the electrocardiograph-based thrombolytic predictive instrument to assist thrombolytic and reperfusion therapy for acute myocardial infarction. A multicenter, randomized, controlled, clinical effectiveness trial. Ann Intern Med. 2002;137(2):87-95. [pmid: 12118963].
not relevant to minority health
Shadick K M. Development of a transcultural health education program for the Hmong. Clin. 1993;7:48-53.
no original data
Shapiro J, Lie D. Using literature to help physician-learners understand and manage “difficult” patients. Acad Med. 2000;75(7):765-8. [pmid: 10926032].
not relevant to minority health
Share L, Chaikin S, Pomeranets S, et al. Implementation of guidelines for preventing early onset group B streptococcal infection. Semin. 2001;25(2):107-113.
only quality (Q1) and not RCT or concurrent CCT
Sharieff GQ, Hoecker C, and Silva PD. Effects of a pediatric emergency department febrile infant protocol on time to antibiotic therapy. J Emerg Med 2001.
not relevant to minority health
Sharma SB. Bridging the gap: anthropological brokerage in nursing care. 1988
other: non-pubilshed
Shea S, Basch C E, Wechsler H, et al. The Washington Heights-Inwood Healthy Heart Program: a 6-year report from a disadvantaged urban setting. Am J Public Health. 1996;86(2):166-71. [pmid: 8633731]. [pmcid: 1380323].
no original data
Sheales A. The Victorian Management Residency Programme: a student's perspective. Aust Health Rev. 1992;15(3):345-53. [pmid: 10121784].
not relevant to minority health
Sheinfeld Gorin S, Gemson D, Ashford A, et al. Cancer education among primary care physicians in an underserved community. Am J Prev Med. 2000;19(1):53-8. [pmid: 10865164].
only quality (Q1) and not RCT or concurrent CCT
Sherwood G D. Creating change through partnership: Developing continuing educational resources in rural areas. J Contin Educ Health Prof. 1995;15(2):101-105.
no evaluation of an intervention
Shortell SM, Bennett CL, and Byck GR. Assessing the impact of continuous quality improvement on clinical practice: what it will take to accelerate progress. Milbank 1998; 76(4): 593–624, 510.
no evaluation of an intervention
Simon M S, Gimotty P A, Coombs J, et al. Factors affecting participation in a mammography screening program among members of an urban Detroit health maintenance organization. Cancer Detect Prev. 1998;22(1):30-8. [pmid: 9466046].
not targeted to healthcare providers or organizations
Simon M S, Gimotty P A, Moncrease A, et al. The effect of patient reminders on the use of screening mammography in an urban health department primary care setting. Breast Cancer Res Treat. 2001;65(1):63-70. [pmid: 11245341].
not targeted to healthcare providers or organizations
Slack M K, Cummings D M, Borrego M E, et al. Strategies used by interdisciplinary rural health training programs to assure community responsiveness and recruit practitioners. J Interprof Care. 2002;16(2):129-38. [pmid: 12073953].
no evaluation of an intervention
Smith C A. The lived experience of care within the context of cultural diversity. J Holist Nurs. 1994;12(3):282-90. [pmid: 7829855].
no intervention
Smith S. The Tex-Mex leap. Nurs Times. 1998;94(44):38-9. [pmid: 9919253].
no original data
Smith S E. Increasing transcultural awareness: the McMaster-Aga Khan-CIDA Project workshop model. J Transcult Nurs. 1997;8(2):23-31. [pmid: 9369662].
no evaluation of an intervention
Sommer S. Faculty forum. Multicultural nursing education. J Nurs Educ. 2001;40(6):276-8. [pmid: 11554462].
no original data
Sookhoo D, Adams J, Anionwu E. In the melting pot… educating students to become culturally competent. Nurs Times. 2000;96(29):40-1. [pmid: 11963016].
no intervention
Soto-Greene M, Wright L, Gona O D, et al. Minority enrichment programs at the New Jersey Medical School: 26 years in review. Acad Med. 1999;74(4):386-9. [pmid: 10219218].
not relevant to minority health
Spitzer A, Kesselring A, Ravid C, et al. Learning about another culture: project and curricular reflections… the care of Ethiopian Jews who immigrated to Israel. J Nurs Educ. 1996;35(7):322-8. [pmid: 8892120].
no original data
Sterling R C, Gottheil E, Weinstein S P, et al. The effect of therapist/patient race- and sex-matching in individual treatment. Addiction. 2001;96(7):1015-22. [pmid: 11440612].
no intervention
Stumpf S H, Bass K. Cross cultural communication to help physician assistants provide unbiased health care. Public Health Rep. 1992;107(1):113-5. [pmid: 1346725]. [pmcid: 1403612].
no evaluation of an intervention
Taylor V M, Taplin S H, Urban N, et al. Community organization to promote breast cancer screening ordering by primary care physicians. J Community Health. 1996;21(4):277-91. [pmid: 8842890].
not relevant to minority health
Thobaben M, Mattingly H J. Cultural sensitivity: educating home healthcare nurses to be transcultural nurses. Home Healthc Nurse. 1993;11(4):61-3. [pmid: 8365912].
no original data
Thompson J W. A curriculum for learning about American Indians and alaska natives in psychiatric residency program. Acad Psychiatry. 1996;20:5-14.
no evaluation of an intervention
Ulrey K L, Amason P. Intercultural communication between patients and health care providers: an exploration of intercultural communication effectiveness, cultural sensitivity, stress, and anxiety. Health Commun. 2001;13(4):449-63. [pmid: 11771806].
no intervention
Vest G W, Ronnau J, Lopez B R, et al. Alternative health practices in ethnically diverse rural areas: a collaborative research project. Health Soc Work. 1997;22(2):95-100. [pmid: 9131355].
only quality (Q1) and not RCT or concurrent CCT
White J E, Begg L, Fishman N W, et al. Increasing cervical cancer screening among minority elderly. Education and on-site services increase screening. J Gerontol Nurs. 1993;19(5):28-34. [pmid: 8491958].
not targeted to healthcare providers or organizations
Wilborn KP. A critical Heideggerian hermeneutic analysis of the meaning of nursing students' clinical experience in Haiti. 2000.
other: non-pubilshed
Yates M, Craddock E. Culturally sensitive care in a forensic setting. Nurs Times. 1998;94(26):68-9. [pmid: 9739714].
no evaluation of an intervention