# Acknowledgments

We thank Christine Napolitano for data entry and management, as well as for assistance with preparation of the report.