# Appendix D: Peer Reviewers

First Name | Last Name | Affiliation
Partner
Helen | Wu | National Quality Forum
Internal Peer Reviewer - Johns Hopkins University
Martha | Hill | Johns Hopkins University School of Nursing
Technical Experts
Laura | Petersen | Houston VA Medical Center, Baylor College of Medicine
Kevin | Fiscella | Departments of Family and Community & Preventive Medicine, University of Rochester School of Medicine
Robert | Beltran | Latino Medical Policy Institute
Anne | Beal | Commonwealth Fund
Marsha | Lillie-Blanton | Kaiser Family Foundation
Peer Reviewers
Robert | Like | Center for Healthy Families and Cultural Diversity, Department of Family Medicine, UMDNJ - Robert Wood Johnson Medical School
Spero | Manson | American Indian and Alaska Native Programs, University of Colorado Health Sciences Center
Jeanette | South-Paul | University of Pittsburgh School of Medicine, Department of Family Medicine
Dawn | Clancy | Department of Medicine, Medical University of South Carolina, Center for Healthcare Research
Debra | Danoff | American Association of Medical Colleges
Denice | Cora-Bramble | Children's National Medical Center
Pamela | Dickson | The Robert Wood Johnson Foundation
Internal Experts
Debra | Roter | Department of Health Policy and Management, Johns Hopkins Bloomberg School of Public Health
Haya | Rubin | Quality of Care Research, Johns Hopkins University
Jon | Samet | Department of Epidemiology, Johns Hopkins Bloomberg School of Public Health