# Appendix C: Evidence Tables

Evidence Table 1. Description of study characteristics for articles addressing Question 1

Study | Targeted Healthcare Providers/Levels of Training/ Number of Providers | Study Design^a^ | Study Setting | Clinical Areas | Objectives | Summary of Quality Assessment ^b^
| | | | | | Rep | Bias | Inter | Out | Analy
PREVENTION, ADULT
Adult, General Prevention
Gemson, 1995 | Physician | CCT | Hospital Outpatient | Tobacco, Cancer, Immunization, Obesity, Exercise counselling | To test the effectiveness of a multifaceted physician prevention education program using prototype materials from “Put Prevention into Practice Program” and didactic nursing.
| Resident/fellow, Professional
| n=254
McDonald, 1984 | Physician, nurse clinicians | RCT | Hospital Outpatient | Cancer, Immunization, Obesity | To determine the effect of the reminder system on physician's use of individual actions and to find improvements in patient outcomes that may result from the computer reminders.
| Resident/fellow, Professional
| n=126
Turner, 1989 | Physician | CCT | Hospital Outpatient | Cancer, Immunization | To determine if two different interventions (computer record/reminder for physician and preventive status questionnaire for patients) would influence the rate of preventive services.
| Resident/fellow
| n=34
Adult, Cancer Screening
Burack, 1994 | Nurse, Physician | RCT | Community Health Clinic, Hospital Outpatient, HMO | Cancer | To determine effectiveness of a patient and physician reminder system to increase use of screening mammography.
| Professional
| n=25
Burack, 1996 | Physician | RCT | Group Practice, HMO | Cancer | To evaluate the overall effectiveness of the four combinations of patient/physician reminders on mammography screening.
| Professional
| n=20
Burack, 1997 | Physician | RCT | Community Health Clinic, HMO | Cancer | To evaluate the sustained effectiveness of a computerized reminder system in promoting mammography during a second year of continuing education.
| Professional
| n=not applicable
Burack, 1998 | Physician | RCT | Group Practice | Cancer | To evaluate the overall effectiveness of the combinations of patient and physician reminder interventions regarding pap smear use.
| Professional
| n=20
Burack, 2003 | Physician | RCT | Home/Community, HMO | Cancer | To better understand the potential interaction among procedure reminders.
| Professional
| n=20
Chambers, 1989 | Physician | RCT | Hospital Outpatient | Cancer | To investigate the influence on mammogram ordering of a reminder bulletin or “ticker system” integrated with a microcomputerized system that links clinical encounters data and billing data.
| Resident/fellow, Professional
| n=30
Dietrich, 1998 | Nurse, Physician, Office staff, Clinical directors | RCT | Community Health Clinic | Cancer | To test an intervention for increasing rates of cancer early-detection services in community/migrant health centers.
| Professional
| n=not specified
Mandelblatt, 1993 | Nurse, Physician | CCT | Hospital Outpatient | Cancer | To increase breast and cervical cancer screening among elderly black women of low socioeconomic status using public hospital primary care clinics.
| Resident/fellow, Professional
| n=not specified
Manfredi, 1998 | Physician | RCT | Group Practice, Solo Practice, HMO, Community of free standing clinics | Cancer | To evaluate a health maintenance organization-sponsored intervention to improve cancer screening in private physician practices serving low-income minority populations.
| Professional
| n=not specified
McCarthy, 1997 | Nurse, Medical assistant | CCT | Hospital Outpatient | Cancer | (1) To develop new processes for offering mammography. (2) To determine whether protocols executed completely by non-physicians would increase mammography utilization.
| Professional
| n=not specified
Adult, Tobacco Cessation
Ahluwalia, 1999 | Physician | CCT | Hospital Outpatient | Tobacco | To assess whether or not a smoking status stamp would change physician counseling patterns.
| Resident/fellow
| n=45
Allen, 1998 | Physician | RCT | Hospital Outpatient | Tobacco | To assess the effectiveness of physicians in training counseling for smoking cessation in African Americans.
| Resident/fellow
| n=158
Adult, Cholesterol
Keyserling, 1997 | Physician, Nurse practitioners, Physician assistants | RCT | Community Health Clinic | Hypercholesterolemia | To assess the effectiveness of a cholesterol-lowering intervention designed to facilitate the management of hypercholesterolemia by primary care clinicians.
| Professional
| n=42
PREVENTION, CHILDREN
Health Behavior Screening
Schubiner, 1994 | Physician | RCT | Community Health Clinic | Health behavior screening | To determine the effect of use of the Safe Times Questionnaire (STQ) on the length and nature of the psychosocial risk assessment, the degree of patient satisfaction, and the ability of physicians to identify adolescents at risk in the topic area covered by the STQ.
| Pre-professional training, Resident/fellow
| n=not specified
Injury Prevention in Children
Gielen, 2001 | Physician | RCT | Hospital Outpatient | Injury prevention in children | To improve patients' safety practices for the prevention of burns, falls and poisoning among children aged 0 to 2 years living in low income inner-city neighborhoods.
| Resident/fellow
| n=31
Well Baby Care
Hornberger, 1996 | Physician | RCT | Hospital Outpatient | Well baby care | To determine the impact of remote simultaneous versus proximate consecutive interpretation on translation errors, provider and patient satisfaction, provider ratings of patient understanding, and accuracy of translation.
| Professional
| n=4
MENTAL HEALTH
Alcohol
Burge, 1997 | Physician | RCT | Hospital Outpatient | Alcohol abuse | To examine the effect of two primary care interventions for alcohol abuse on outpatients (1) drinking patterns, (2) psychosocial problems, and (3) blood test results over a period of 18 months.
| Resident/fellow
| n=not specified
Depression
Callahan, 1994 | Physician | RCT | Group Practice | Care coordination, Major depression | To assess the effect of a multi-faceted physician targeted intervention to improve the recognition and treatment of depression in primary care among an elderly population with co-morbidities.
| Professional
| n=103
Miranda, 2003 | Nurse, Physician, Nurse practitioner | RCT | Group Practice, HMO Primary Care Practice | Major depression | To determine if quality improvement, practice initiated interventions for depressed primary care clinics can improve care across groups and improve health and employment outcomes among ethnic minorities over those of whites.
| Professional
| n=181
OTHER CLINICAL AREAS
Acute Respiratory Infections
Harris, 2003 | Physician, Nurse practitioner | CCT | Hospital Outpatient | Prescribing for acute respiratory tract infections | To decrease unnecessary antibiotic use for acute respiratory tract infections in adults in a point of service health care setting.
| Professional
| n=42
Asthma
Evans, 1997 | Nurse, Physician, Clerical staff, Laboratory technicians, Public health assistants | RCT | Community Health Clinic | Asthma | To determine if training of professional and support staff (in intervention clinics) would (1) increase the number of children diagnosed with asthma and receiving continuing care and (2) improve quality of care by increasing staff use of new pharmacologic and educational treatment methods.
| Professional
| n=134
Chronic renal disease
Harris, 1998 | Physician | RCT | Hospital Outpatient | Care coordination, Renal disease | To assess whether a comprehensive multidisciplinary program for chronic renal insufficiency patients slow the decline of renal function.
| Resident/fellow, Professional
| n=not applicable
Emergency Systems
Kellermann, 1993 | Firefighters | CCT | Home/Community | Emergency first response | (1) To determine if first responder defibrillation can improve rates of cardiac resuscitation and survival in urban EMS system served by paramedics. (2) To determine if rapid pre-hospital defibrillation can compensate for delayed notification of EMS or lack of bystander CPR. (3) To determine if station characteristics can be used to identify optimal locations of automated external defibrillators.
| Professional
| n=40
End of Life
Dexter, 1998 | Physician | RCT | Hospital Outpatient | End of Life | Determine effect of computer-generated reminders to physicians on frequency of advance directive discussions between patients and their primary care givers.
| Resident/fellow, Professional
| n=147

a CCT= controlled clinical trial; RCT= randomized controlled trial

b assessments of methodological strengths and weaknesses in 5 domains, as categorized by following symbols:

= quality score of 80% or above

= quality score of 50 to 79%

= quality score of less than 50%

Domains:

Rep = representativeness of targeted healthcare providers and/or patients

Bias = potential for bias and confounding

Inter = description of interventions

Out = assessment of outcomes

Analy = analytic approach

Evidence Table 2. Description of intervention characteristics for articles addressing Question 1

Study | Targeted Healthcare Providers/Levels of Training | Study Design | Group | Patient Race/Ethnicity | Interventions | Educational Methods | Patient Interventions
PREVENTION, ADULT
Adult, General Prevention
Gemson, 1995 | Physician Resident/fellow, Professional | CCT | Control n=471 | 93% African American, 5% Hispanic | No Interventions
| | | Intervention n=529 | 92% African American, 5% Hispanic | Education, pads of prevention prescription forms | Written Material, AV material, Lecture
McDonald, 1984 | Physician, nurse clinicians Resident/fellow, Professional | RCT | Control n=not specified | | No Interventions
| | | Intervention n=not specified | | Tracking/reminder system
Turner, 1989 | Physician Resident/fellow | CCT | Patient intervention n=86 | | | | Questionnaire of status of preventive services before primary care visit
| | | Physician and patient interventions n=64 | | Tracking/reminder system | | Questionnaire of status of preventive services before primary care visit
| | | Physician intervention n=103 | | Tracking/reminder system
Adult, Cancer Screening
Burack, 1994 | Nurse, Physician Professional | RCT | Full intervention n=1382 | | Education, Tracking/reminder system | Lecture | Elimination of out-of-Pocket expenses for patients, post-card and telephone follow-up
| | | Limited intervention n=1343 | | Education | Lecture | Elimination of out-of-pocket expenses for patients
Burack, 1996 | Physician Professional | RCT | Control n=596 | | No Interventions
| | | Patient reminders n=592 | | | | Patient reminder letters
| | | Physician and patient reminders n=590 | | Tracking/reminder system | | Patient reminder letters
| | | Physician reminders n=590 | | Tracking/reminder system
Burack, 1997 | Physician Professional | RCT | Full intervention n=1413 | | Education, Tracking/reminder system | Physician and staff orientation
| | | Limited intervention n=1413 | | Education | Physician and staff orientation
Burack, 1998 | Physician Professional | RCT | Control n=964 | | No Interventions
| | | Patient reminders n=964 | | | | Patient reminder letters
| | | Physician and patient reminder n=960 | | Tracking/reminder system | | Patient reminder letters
| | | Physician reminders n=960 | | Tracking/reminder system
Burack, 2003 | Physician Professional | RCT | Mammogram only reminder group n=1228 | | Tracking/reminder system | | Patient reminder letter
| | | Pap smear and mammogram reminder group n=1243 | | Tracking/reminder system | | Patient reminder letter
Chambers, 1989 | Physician Resident/fellow, Professional | RCT | Control n=623 | 31% White | No Interventions
| | | Intervention n=639 | 28% White | Tracking/reminder system
Dietrich, 1998 | Nurse, Physician, Office staff, Clinical directors Professional | RCT | Control n=1267 | 23% African American, 22% White, 26% Hispanic | No Interventions
| | | Intervention n=1381 | 31% African American, 22% White, 22% Hispanic | Education, Tracking/reminder system, preventive care flow sheets, advice to center leaders, external chart identifiers | Written Material, provider workshops | Patient-held health diaries, patient education materials
Mandelblatt, 1993 | Nurse, Physician Resident/fellow, Professional | CCT | Control n=not specified | 82% African American, 15% White, 2% Hispanic | Tracking/reminder system
| | | Intervention n=not specified | 93% African American, 1% White, 1% Hispanic | Screening offered directly to patient by nurse practitioner | | Patient counseling and screening offered directly to patient by nurse practitioner
Manfredi, 1998 | Physician Professional | RCT | Control n=42230 | | Flow sheets supplied but not actively encouraged
| | | Intervention n=52392 | | Education, Tracking/reminder system, Audit & Feedback, incorporation of cancer screening in guidelines and into HMO quality assurance procedures | Written Material, on-site training of staff and 2 follow-up assistant visits CME seminar for physicians, NCI screening guidelines | Health maintenance cards with letter of explanation from HMO
McCarthy, 1997 | Nurse, Medical assistant Professional | CCT | Control (Clinic A) n=2560 | 79% African American, 18% White | No Interventions
| | | Control (Clinic B) n=2124 | 73% African American, 24% White | No Interventions
| | | Intervention n=1250 | 82% African American, 15% White | Education, Nurses and medical assistants screened all patients to ensure mammography was up to date and then initiated referrals for patients not up to date | Flow diagram for mammogram screening
Adult, Tobacco Cessation
Ahluwalia, 1999 | Physician Resident/fellow | CCT | Control n=not specified | 100% African American | No Interventions
| | | Intervention n=not specified | 100% African American | Tracking/reminder system, smoking stamp which physicians needed to mark as never, former, or current
Allen, 1998 | Physician Resident/fellow | RCT | Control n=571 | 100% African American | No Interventions
| | | Intervention n=515 | 100% African American | Education, Reward Incentive, summary sheet of patient's smoking history on outside of medical record | Written Material, AV material, Lecture, review of videotapes of counseling sessions, didactic sessions, role play | Written material given to patients about smoking cessation
Adult, Cholesterol
Keyserling, 1997 | Physician, Nurse practitioners, Physician assistants Professional | RCT | Control n=188 | 40% African American, 47% White, 12% American Indian/Native Alaskan | No Interventions
| | | Intervention n=184 | 39% African American, 50% White, 11% American Indian/Native Alaskan | Education, Tracking/reminder system, nutritionist completed summary on each referred patient which was mailed to clinician, letter to clinician urging drug treatment in all patients who have not responded to diet therapy after 7 months | Written Material, Lecture | Patient education materials
PREVENTION, CHILDREN
Health Behavior Screening
Schubiner, 1994 | Physician Pre-professional training, Resident/fellow | RCT | Control (Interview) n=not specified | | Education | Written Material, Lecture
| | | Intervention (STQ) n=not specified | | Education, provision of Safe Times Questionnaire completed by patient | Written Material, Lecture
Injury Prevention in Children
Gielen, 2001 | Physician Resident/fellow | RCT | Control n=76 | | Education | Written Material, Lecture
| | | Intervention n=120 | | Education | Written Material, Lecture, 5 additional hours of experiential learning
Well Baby Care
Hornberger, 1996 | Physician Professional | RCT | Proximate consecutive translation n=not specified | 100% Hispanic | Proximate consecutive translation of patient and physician statements by an interpreter in the examination room
| | | Remote simultaneous translation n=not specified | 100% Hispanic | Remote simultaneous translation of patient and physician statements by interpreter in another location
MENTAL HEALTH
Alcohol
Burge, 1997 | Physician Resident/fellow | RCT | Control n=not specified | 100% Hispanic | No Interventions
| | | Patient intervention n=not specified | 100% Hispanic | | | Psychoeducation (9 hours)
| | | Physician and patient intervention n=not specified | 100% Hispanic | Education, Tracking/reminder system, Standing Orders/protocols/guidelines/algorithms | Written Material, Lecture (8 hours) | Psychoeducation (9 hours)
| | | Physician intervention n=not specified | 100% Hispanic | Education, Tracking/reminder system, Standing Orders/protocols/guidelines/algorithms | Written Material, lecture (8 hours)
Depression
Callahan, 1994 | Physician Professional | RCT | Control n=100 | 53% African American | Education | Lecture
| | | Intervention n=75 | 50% African American | Education, Standing Orders/protocols/guidelines/algorithms, 3 additional primary care visits scheduled with depressed patients | Written Material, Lecture, instruction in use of materials
Miranda, 2003 | Nurse, Physician, nurse practitioner Professional | RCT | Behavioral therapists n=not specified | | Education, in kind resources to support costs | Written Material, Lecture, Small Group, Academic Detailing | Nurse used culturally tailored written materials and videotapes to activate depressed patients to engage in treatment and psychotherapist provided individual and group Cognitive Behavioral Therapy for 8–12 sessions
| | | Control n=not specified | | | Written Material, (national practice guidelines)
| | | Nurse follow-up n=not specified | | Education, in kind resources to support costs | Written Material, Lecture, Small Group, Academic Detailing | Nurse used culturally tailored written materials and videotapes to activate depressed patients to engage in treatment and then nurses provided follow-up assessments for 6 to 12 months
OTHER CLINICAL AREAS
Acute Respiratory Infections
Harris, 2003 | Physician, nurse practitioners Professional | CCT | Baseline control group n=671 | 16% African American, 39% White, 42% Hispanic | No Interventions
| | | Full intervention n=393 | 9% African American, 35% White, 41% Hispanic | Education, Standing Orders/protocols/guidelines/algorithms, posters for acute respiratory infection treatment guidelines in exam rooms | Written Material, Computer-based material, Lecture | Posters in exam rooms, computerized education in waiting room for patients
| | | Limited intervention n=805 | 12% African American, 37% White, 48% Hispanic | Education, Standing Orders/protocols/guidelines/algorithms, posters for acute respiratory infection treatment guidelines in exam rooms | Written Material, Lecture | Posters in exam rooms
Asthma
Evans, 1997 | Nurse, Physician, Clerical staff, Laboratory technicians, Public health assistants Professional | RCT | Control n=not specified | 46% African American, 34% Hispanic | Standing Orders/protocols/guidelines/algorithms, access to new medicines through increased distribution to clinics
| | | Intervention n=not specified | 44% African American, 33% Hispanic | Education, Standing Orders/protocols/guidelines/algorithms, access to new medicines through increased distribution to clinics 1) monthly visits by nurse-educator to clinic to help solve problems, 2) consultation (telephone) available with “expert” physician | Written Material, AV material, Lecture, Small Group, interactive exercise, performance of skit, clinical observation of “expert” physicians
Chronic renal disease
Harris, 1998 | Physician Resident/fellow, Professional | RCT | Control n=231 | 80% African American | No Interventions
| | | Intervention n=206 | 81% African American | Letter to primary care physician including summary of actions taken by consultant nephrologist, suggestions for future care, and summary of clinic visit | | Consultation with nephrologist
Emergency systems
Kellermann, 1993 | Firefighters Professional | CCT | Cardiopulmonary resuscitation control n=432 | 59% African American | No Interventions
| | | Automated external defibrillators n=447 | 60% African American | Education | Simulated cardiac arrest scenario (“mega code” exercise)
End of life
Dexter, 1998 | Physician Resident/fellow, Professional | RCT | Control n=253 | 60% African American, 39% White | Education | Written Material, Lecture, Face-to-face meetings
| | | Instruction and Proxy Intervention n=277 | 56% African American, 44% White | Education, Tracking/reminder system | Written Material, Lecture, Face-to-face meetings
| | | Instruction Directive n=219 | 56% African American, 44% White | Education, Tracking/reminder system | Written Material, Lecture, Face-to-face meetings
| | | Proxy Directive n=260 | 49% African American, 51% White | Education, Tracking/reminder system | Written Material, Lecture, Face-to-face meetings

Evidence Table 3. Results from articles addressing Question 1

Study | Targeted Healthcare Providers/Levels of Training | Study Design | Outcome Type | Outcome | How Measured | Intervention Effect | Summary
| | | | | | | Between-Group Summary | Within-Group Summary
PREVENTION, ADULT
Adult, General Prevention
Gemson, 1995 | Physician Resident/fellow, Professional | CCT | Quality of Providers | Breast self examination counseling | Patient report | Changes in breast self-exam counseling rates received by patients pre and post intervention time period: intervention + 0.12 (p<0.01); control -0.06 (p=0.25). | not available | significant improvement
| | | Quality of Providers | Nutrition and weight control counseling | Patient report | Changes in nutrition and weight control counseling rates received by patients pre and post intervention time period: intervention +0.11 (p=0.02); control -0.05 (p=0.27). | not available | significant improvement
| | | Quality of Providers | Prevention knowledge | Provider written test | The overall change in physician knowledge of prevention was significantly greater for the intervention [+2.67 (SD 3.96)] compared to control [+1.58 (SD 3.43)] (p=0.03). | significant improvement | not available
| | | Quality of Providers | Exercise counseling | Provider self report | Positive change in physician exercise counseling practices comparing intervention to control (p<0.01). | significant improvement | not available
| | | Quality of Providers | Nutrition and weight control counseling | Provider self report | Positive change in physician nutrition and weight control counseling practices comparing intervention to control (p<0.01). | significant improvement | not available
| | | Quality of Providers | Smoking cessation counseling | Patient report | Change in receipt of smoking cessation counseling rates pre and post intervention time period: intervention +0.03 (p=0.08), control +0.01 (p=0.4). | not available | improvement
| | | Quality of Providers | Breast cancer screening | Provider self report | Positive change in physician breast cancer screening practices comparing intervention to control (p=0.01). | significant improvement | not available
| | | Quality of Providers | Smoking cessation counseling | Provider self report | Positive change in physician smoking cessation counseling practices comparing intervention to control (p<0.01). | significant improvement | not available
| | | Quality of Providers | Exercise counseling | Patient report | Changes in exercise counseling rates received by patients pre and post intervention time period: intervention + 0.07 (p<0.01); control + 0.03 (p=0.14). | not available | significant improvement
McDonald, 1984 | Physician, nurse clinicians Resident/fellow, Professional | RCT | Health Status | Blood pressure, weight, serum glucose, serum hemoglobin, serum potassium, and blood urea nitrogen | Medical record review | No significant differences between patients assigned to intervention group physicians and control physicians. | no improvement | not available
| | | Utilization | Hospitalizations and emergency room visits for patients eligible for pneumococal or influenza vaccines | Review of admission logs | Patients cared for by intervention group physicians had fewer hospitalizations and emergency room visits in the years influenza occurred (p<0.02). | significant improvement | not available
| | | Utilization | Overall number of hospitalizations, emergency room visits, or clinic visits | Review of admission logs | No significant overall differences between patients assigned to intervention group physicians and control physicians. | no improvement | not available
| | | Appropriateness of Care | Physician response to computerized reminders | Computer record review | 49% of physicians responded to computerized reminders in intervention group compared to 29% in control group (p<0.001). | significant improvement | not available
| | | Appropriateness of Care | Physician response to computerized reminders regarding preventive care | Computer record review | Physicians in intervention group were 2 to 4 times more likely to apply preventive care to their eligible patients than were control group physicians (p<0.005). | significant improvement | not available
Turner, 1989 | Physician Resident/fellow | CCT | Appropriateness of Care | Guaiac test rates | Medical record review | Guaiac test rates increased from 34.1% to 50% in the physician-reminder group (p<0.05), increased from 32.6% to 42.5% (p=ns) in the patient-reminder group, and increased from 29.7% to 46.1% (p<0.05) in the combined intervention group. | not available | significant improvement
| | | Appropriateness of Care | Rectal exam rates | Medical record review | Rectal exam rates increased from 10.4% to 52.6% in the physician-reminder group (p<0.05), increased from 32.3% to 46.9% (p<0.05) in the patient-reminder group, and increased from 34.1% to 57.1% (p<0.05) in the combined intervention group. | not available | significant improvement
| | | Appropriateness of Care | Pap smear rates | Medical record review | Pap smear rates increased from 20.3% to 33.1% in the physician-reminder group (p=ns), decreased from 29.4% to 27.5% (p=ns) in the patient-reminder group, and increased from 20.5% to 40% (p=ns) in the combined intervention group. | not available | no improvement
| | | Appropriateness of Care | Breast exam rates | Medical record review | Breast exam rates increased from 37.5% to 53.5% in the physician-reminder group (p<0.05), increased from 41.2% to 53.6% (p<0.05) in the patient-reminder group, and increased from 38.3% to 47.8% (p=ns) in the combined intervention group. | not available | significant improvement
| | | Appropriateness of Care | Mammogram rates | Medical record review | Mammogram rates increased from 14.3% to 15% in the physician-reminder group (p=ns), increased from 15% to 46.6% (p<0.05) in the patient-reminder group, and increased from 0% to 4.8% (p=ns) in the combined intervention group. | not available | significant improvement
| | | Appropriateness of Care | Tetanus immunization rates | Medical record review | No change reported in any group. | not available | no improvement
Adult, Cancer Screening
Burack, 1994 | Nurse, Physician Professional | RCT | Appropriateness of Care | Mammogram appointment | Mammogram appointment rates | At each site, full intervention status was associated with significant increase in mammogram appointment rates with absolute increase from 13% to 29% compared to limited intervention. | significant improvement | not available
| | | Appropriateness of Care | Overall use of mammography | Mammogram appointment completion rates | Compared to limited intervention, full intervention was associated with a significant increase in the mammography rate at each of the sites. | significant improvement | not available
| | | Appropriateness of Care | Completion of first mammogram appointment | Completed mammogram appointments | No differences in completion of first mammography appointment between full intervention groups. | not available | not available
Burack, 1996 | Physician Professional | RCT | Utilization | Primary care visit rates in 1 year | Administrative data | No significant relation between interventions and primary care visitation. | no improvement | not available
| | | Appropriateness of Care | Mammography screening rates (completion in study year) | Administrative data | Mammography rates were higher for the two groups of women assigned to the physician reminder intervention, but only at one of two HMO sites. No significant difference for patient intervention. | improvement | improvement
Burack, 1997 | Physician Professional | RCT | Appropriateness of Care | Annual mammography rates | Medical record review; computerized administrative records | At the end of year 2, mammography rates were 44% for full intervention versus 28% for limited intervention at the health department (OR: 1.84, 95% CI:1.40, 2.40) and 45% for full versus 46% for limited at the health maintenance organization (OR: 1.06, 95% CI: 0.08, 1.42). | significant improvement | not available
Burack, 1998 | Physician Professional | RCT | Appropriateness of Care | Completion of pap smear | Reports of pap-smear results | Women who received the patient and physician reminders together had 1.23 times the odds of completing pap smear screening (95% CI, 1.01, 1.50) than women who received neither intervention. The pap smear rates for women in the patient only or physician only intervention were not significantly different than the pap smear rates for women who received neither intervention. | significant improvement | not available
| | | Utilization | Primary care visits | Administrative data | No significant association of intervention. | no improvement | not available
Burack, 2003 | Physician Professional | RCT | Appropriateness of Care | Completing pap smear | Medical record review | Combined reminder treatment associated with increased likelihood of pap smear (30% versus 23%, p=0.007) OR 1.39. | significant improvement | not available
| | | Appropriateness of Care | Completing mammogram | Medical record review | No difference between combined reminder treatment and mammogram only reminder (39% versus 40%). | no improvement | not available
| | | Utilization | Visits to gynecology | Medical record review | Combined reminder treatment associated with increased rate of visits (34% versus 29%, p=0.001). | significant improvement | not available
| | | Utilization | Visits to primary care physician | Medical record review | No difference between groups. | no improvement | not available
Chambers, 1989 | Physician Resident/fellow, Professional | RCT | Appropriateness of Care | Mammography rates | Medical record review | At the end of the study period, 27% of the experimental group were up-to-date as compared with 21% of the control group (p=0.011). | significant improvement | not available
Dietrich, 1998 | Nurse, Physician, Office staff, Clinical directors Professional | RCT | Appropriateness of Care | Mammography rates in females over 50 | Medical record review | Both interventions and control groups showed increased rates, 58% to 65% in the intervention group (p=0.008) versus 59% to 64% in the control group (p=0.02). | no improvement | improvement
| | | Appropriateness of Care | Oral cavity exam | Medical record review | Both intervention and control groups showed significantly increased rates, 67% to 78% in the intervention group versus 73% to 83% in the control group (p<0.001). | no improvement | significant improvement
| | | Appropriateness of Care | Rates of clinical breast exams in all females | Medical record review | Both intervention and control groups showed increased rates, 50% to 63% in the intervention group versus 55% to 59% in the control group (significant in both groups). | no improvement | significant improvement
| | | Appropriateness of Care | Rates of pap test in all females | Medical record review | Intervention showed no change in rates, changing from 52% to 55%, while the control group increased rates from 43% to 62% (p<0.01) | no improvement | improvement
| | | Appropriateness of Care | Fecal occult blood test | Medical record review | Both intervention and control groups increased rates, 9% to 19% in the intervention group versus 7% to 19% in the control group (not significant in either group). | no improvement | improvement
| | | Appropriateness of Care | Digital rectal exam | Medical record review | Both intervention and control groups showed increased rates, 35% to 41% in the intervention group (not significant) versus 34% to 49% in the control group (p=0.03). | no improvement | improvement
| | | Quality of Providers | Rates of breast self-exam advice in all females | Medical record review | Both interventions and control groups showed increased rates, 4% to 13% in the intervention group (p<0.001) versus 3% to 8% in the control group (not significant). Intervention showed a greater increase than control (p=0.009). | significant improvement | significant improvement
| | | Appropriateness of Care | Sigmoidoscopy | Medical record review | Neither intervention or control arm increased rates, 3% to 3% in the intervention group versus 2% to 2% in the control group. | no improvement | no improvement
Mandelblatt, 1993 | Nurse, Physician Resident/fellow, Professional | CCT | Appropriateness of Care | Mammography screening rates | Medical record review | Significant increase in the mammography screening rate in intervention 18% to 40% versus control 18% to 18% (p<0.01). | significant improvement | not available
| | | Appropriateness of Care | Pap test screening rates | Medical record review | Significant increase in the pap test screening rate in the intervention 17% to 57% versus the control 12% to 18% (p<0.01). | significant improvement | not available
Manfredi, 1998 | Physician Professional | RCT | Appropriateness of Care | Rates of pap smears among eligible patients of HMO/not of HMO | Medical record review | Rates increase in HMO patients only from 55.7% at baseline to 59.7% post-intervention but decrease in control group from 56.1% to 48.2% (not statistically significant). | significant improvement | not available
| | | Appropriateness of Care | Rates of clinical breast exams (CBE) among eligible patients of HMO/not of HMO | Medical record review | No effect of intervention in HMO patients/positive effect of intervention among non-HMO patients with rates increasing from 26.6 to 36.5% in intervention clinics and decreasing in control clinics (p<0.05). | significant improvement | not available
| | | Appropriateness of Care | Rates of fecal occult blood testing (FOBT) among eligible patients of HMO/not of HMO | Medical record review | Rates increased in both groups of patients. For HMO patients, rates increased from 3.2% to 12.5% in the intervention clinics with decrease in control clinics (p<0.05). In non-HMO patients, rates increased from 4.5% to 5.2% in intervention clinics while de | significant improvement | not available
| | | Appropriateness of Care | Rates of mammograms among eligible patients of HMO/not of HMO | Medical record review | No effect of intervention in either group of patients. | no improvement | not available
McCarthy, 1997 | Nurse, Medical assistant Professional | CCT | Appropriateness of Care | Mammography screening rates | Computerized audit of billing records | Prior to the intervention, the proportion of visits in which women were up-to-date was 68% in the intervention clinic and 66% in each control clinic. At the end of evaluation, there was an absolute increase of 9% in the intervention group (95% CI 2–16%) while one control clinic had an absolute increase of 1% (95%. CI:-5, 7%) and the other has an absolute decrease of 2% (95%. CI: - 3, 5%). | not available | significant improvement
Adult, Tobacco Cessation
Ahluwalia, 1999 | Physician Resident/fellow | CCT | Quality of Providers | Smoking cessation counseling by provider; ASK if patient smokes cigarettes or any other form of tobacco | Patient report | Odds ratio of “ASK” between intervention and control: if smokes cigarettes 3.97 (2.87, 5.49); if uses other tobacco products 1.40 (0.91, 2.18). | significant improvement | not available
| | | Quality of Providers | Smoking cessation counseling by provider; ASSIST how or when to quit smoking | Patient report | Odds ratio of “ASSIST” between intervention and control groups: how to quit 1.60 (0.78, 3.31); set a date 0.74 (0.16, 3.34). | improvement | not available
| | | Quality of Providers | Smoking cessation counseling by provider; ADVISE to quit smoking | Patient report | Odds ratio of “ADVISE” between intervention and control groups 1.75 (1.29, 2.35). | significant improvement | not available
| | | Quality of Providers | Smoking cessation counseling by provider; ARRANGE follow-up or refer to specialist | Patient report | Odds ratio of “ARRANGE” between intervention and control 1.97 (1.20, 3.24). | significant improvement | not available
Allen, 1998 | Physician Resident/fellow | RCT | Quality of Providers | Protocol adherence | Patient report | Only 16% of the control group patients compared to nearly 70% of the intervention patients reported that their physician urged them to quit smoking. | improvement | not available
| | | Patient Adherence | 3 month quit rate | Patient report | 6.1% for intervention group versus 5.2% for control group (p=not specified). | no improvement | not available
| | | Patient Adherence | 12 month quit rate | Saliva cotinine tests | 3.2% for intervention group versus 2.8% for control group, (p=not specified). | no improvement | not available
| | | Patient Adherence | 12 month quit rate | Patient report | 8.4% for intervention group versus 10.6% for control group (not significant). | no improvement | not available
| | | Patient Adherence | 3 month quit rate | Saliva cotinine tests | 2% for intervention group versus 1.8% for control group (not significant). | no improvement | not available
Adult, Cholesterol
Keyserling, 1997 | Physician, Nurse practitioners, Physician assistants Professional | RCT | Health Status | Difference in total cholesterol among participants not on lipid lowering therapy at one year | Blood tests | Average reduction of 0.14 mmol/L (5.3 mg/dL) greater in intervention group (p=0.01). | significant improvement | not available
| | | Quality of Providers | Clinician dietary counseling behavior | Medical record review | Cholesterol mentioned in progress note for 10% of intervention patients and 30% of control patients on first routine follow-up (statistical significance not assessed). | no improvement | not available
| | | Appropriateness of Care | Referral for dietary counseling | Medical record review | 9% of control group patients compared to 2% of intervention patients referred for dietary counseling (statistical significance not assessed). | no improvement not available
| | | Appropriateness of Care | Number patients taking lipid lowering medication | Medical record review | 8% of intervention patients compared to 15% of control group patients were taking lipid-lowering medication on follow-up (p=0.05). | no improvement | not available
| | | Health Status | Difference in total cholesterol among all study participants at one year | Blood tests | Averaged over 1 year follow-up, the total cholesterol reduction in the intervention group was 0.08 mmol/L (3.0 mg/dL) greater than in control group (p=0.09). | improvement | not available
| | | Patient Adherence | Dietary habits | Patient report, dietary risk assessment | Sustained decrease in both groups with average reduction in the intervention group significantly more than for the control group (p>0.001). | significant improvement | not available
| | | Health Status | Difference in LDL among all study participants at one year | Blood tests | Average reduction 0.10 mmol/L (3.7 mg/dL) greater in intervention group (p=0.08). | improvement | not available
PREVENTION, CHILDREN
Health Behavior Screening
Schubiner, 1994 | Physician Pre-professional training, Resident/fellow | RCT | Quality of Providers | Total time of interview | Videotaped encounters | Physicians in intervention group had shorter visits than physicians in the control group. | improvement | not available
| | | Quality of Providers | Accuracy of physician assessment of patient need for interventions in each “Safe Times” topic area | Compared to “gold standard” of psychologist interview | Physicians in the intervention group had higher agreement with psychologist ratings in identification of subjects at risk for depression and family conflicts than the physicians in the control group. | improvement | not available
| | | Patient Satisfaction | Patient satisfaction | Medical Interview Satisfaction Scale | No difference in satisfaction between groups. | no improvement | not available
| | | Quality of Providers | Time spent making assessment versus counseling in each area | Videotaped encounters | Physicians in intervention group spent less time in assessment rather than counseling in each of the “Safe Times” areas (p<0.05). | significant improvement | not available
| | | Quality of Providers | Total time spent in each of the “Safe Times” topics | Videotaped encounters | Physicians in intervention group spent less time discussing each of the specific “Safe Times” topics. | improvement | not available
| | | Quality of Providers | Time spent discussing “Safe Times” topics | Videotaped encounters | Physicians in intervention group spent less time discussing all “Safe Times” topics. | improvement | not available
Injury Prevention in Children
Gielen, 2001 | Physician Resident/fellow | RCT | Patient Adherence | Safety practices | Self report and home-observation | Groups did not differ. no improvement | not available
| | | Efficacy of Treatment | Parental knowledge and beliefs regarding injury prevention | Follow-up interview | Groups did not differ. | no improvement | not available
| | | Patient Satisfaction | Satisfaction | Patient report | Patients in the intervention group rated the help they received with safety topics significantly higher than patients in the control group (p=0.01). | significant improvement | not available
| | | Quality of Providers | Injury prevention counseling | Audiotape analysis | Mention of safety strategies was higher in intervention group (9.4 +/- 6.8) than control group (3.7 +/- 3.2). | improvement | not available
Well Baby Care
Hornberger, 1996 | Physician Professional | RCT | Quality of Providers | Adequacy of interpretation | Audiotape analysis | The remote simultaneous translation group had a 13% lower rate of inaccurately interpreted mother utterance per visit than the proximate consecutive service (most were omissions). | improvement | not available
| | | Quality of Providers | Number of questions asked by mother | Audiotape analysis | Significantly more questions were asked by mothers in the remote simultaneous translation than with the proximate consecutive translation service (no p-values given). | improvement | not available
| | | Quality of Providers | Provider preference for type of intervention | Provider self report | Providers preferred remote simultaneous translation to proximate consecutive translation. | improvement | not available
| | | Utilization | Duration of encounter | Audiotape analysis | No significant difference between intervention and control. | no improvement | not available
| | | Quality of Providers | Number of explanations by mother | Audiotape analysis | The number of mother explanations per visit was 22% more in the remote simultaneous translation group than in the proximate consecutive translation group visits. | improvement | not available
| | | Quality of Providers | Number of explanations by physicians | Audiotape analysis | The number of physician explanations per visit was 18% more in the remote simultaneous translation group than in the proximate consecutive translation group visits. | improvement | not available
| | | Patient Satisfaction | Patient preference for type of intervention | Patient self report | All 17 mothers who experienced both types of translation and who responded to the survey preferred remote simultaneous translation. | improvement | not available
| | | Quality of Providers | Patient-physician eye-to-eye contact | Provider self-report | Physician reported that eye-to-eye contact was improved in remote simultaneous translation group. | improvement | not available
MENTAL HEALTH
Alcohol
Burge, 1997 | Physician Resident/fellow | RCT | Health Status | Addiction Severity Index (ASI) Family Score | Interview; medical record review | Decreased over time in all groups (p=0.000), but decrease more significant for physician intervention group at 12 months (p=0.003). | significant improvement | significant improvement
| | | Health Status | Addiction Severity Index (ASI) Employment Score | Interview; medical record review | No change over time in any group (not significant) at 12 months. | no improvement | no improvement
| | | Health Status | Addiction Severity Index (ASI) Alcohol score | Interview; medical record review | Decreased over time in all groups (p=0.000). No difference between groups at 12 months. | no improvement | significant improvement
| | | Health Status | Drinks per week | Interview; medical record review | Decreased over time for all groups (p=0.000). No difference between groups at 12 months. | no improvement | significant improvement
| | | Health Status | Addiction Severity Index (ASI) Medical Score | Interview; medical record review | Decreased over time in all groups (p=0.000) at 12 months. | no improvement | significant improvement
| | | Health Status | Mean Corpuscular Volume (MCV) | Blood test | Decreased over time in all groups (p=0.000). No difference between groups at 12 months. | no improvement | significant improvement
| | | Health Status | Liver enzymes (SGot, SGPt, GGT) | Blood test | No difference between groups at 12 months. SGoT decreased over time (p=0.000) in all groups. | no improvement | significant improvement
Depression
Callahan, 1994 | Physician Professional | RCT | Appropriateness of Care | Percentage of patients with depression diagnosis recorded at 6 months | Medical record review | 32.3% (intervention) versus 12.1% (control) (p=0.002). | significant improvement | not available
| | | Appropriateness of Care | Percentage of patients with newly-prescribed antidepressant at 6 months | Medical record review | 26.0% (intervention) versus 8.0% (control) (p=0.01). | significant improvement | not available
| | | Appropriateness of Care | Percentage of patients referred to psychiatry at 6 months | Medical record review | 13.7% (intervention) versus 12.1% (control) (no significant differences). | no improvement | not available
| | | Health Status | Depression | Hamilton Depression Scale | Both groups showed statistically significant improvement in depression at 6 months (no significant difference between groups). | no improvement | not available
| | | Appropriateness of Care | Percentage of patients in whom drug associated with depression was discontinued | Medical record review | 22.0% (intervention) versus 23.0% (control) (no significant difference). | no improvement | not available
Miranda, 2003 | Nurse, Physician, nurse practitioner Professional | RCT | Health Status | Depression | Composite International Diagnostic Interview (CIDI) | At 6 and 12 months, patients in both intervention groups were less likely than patients in control group to meet criteria for probable depressive disorder (39.9% versus 49.9%, p=0.001). In subgroup analysis only African American and Latino patients were significantly less likely to screen positive for depression, whereas the difference was not significant for white patients. | significant improvement | not available
| | | Appropriateness of Care | Appropriate depression care | Not specified | At 6 and 12 months, all patients (African American, Latino, and white) in both intervention groups were more likely than controls to receive counseling or to receive anti-depressant medications (50.9% versus 39.7%, p<0.001). | significant improvement | not available
| | | Health Status | Employment | Telephone and mailed survey | At 6 and 12 months, there were no improvements for African American or Latino patients in employment rates, however, there were improvements for white patients. | no improvement | not available
OTHER CLINICAL AREAS
Acute Respiratory Infections
Harris, 2003 | Physician, nurse practitioners Professional | CCT | Appropriateness of Care | Antibiotic prescription rates for acute bronchitis | Medical record review | The proportion of patients with acute bronchitis decreased from 58% in the baseline period to 30% and 24% among patients exposed to the limited and full interventions (p<0.001 for intervention groups versus baseline). No differences between groups. | no improvement | significant improvement
| | | Appropriateness of Care | Antibiotic prescription rates for non-specific upper respiratory tract infections | Medical record review | Antibiotic prescriptions for nonspecific upper respiratory tract infections decreased from 14% to 3% and 1% in the limited and full intervention groups (p<0.001 for intervention groups versus baseline). No difference between limited and full intervention groups. | no improvement | significant improvement
Asthma
Evans, 1997 | Nurse, Physician, Clerical staff, Laboratory technicians, Public health assistants Professional | RCT | Appropriateness of Care | Patient education by physician and nurse | Patient report | Patient reported education by physicians was 71% for intervention versus 58% for control patients (p<0.01), and by nurses was 61% for intervention versus 41% for control patients (p<0.05). | significant improvement | not available
| | | Utilization | Continuity of care | Average number of visits made by children with asthma per year | Average number of visits made by children with asthma increased in intervention clinics from baseline through both follow-up periods (2.15 in 1992 versus 2.42 in 1993 versus 1.41 in 1991, p<0.001) and remained the same in control clinics. | not available | significant improvement
| | | Appropriateness of Care | Use of appropriate medicines | Proportion of patients with asthma who had each type of medication dispensed | In the intervention clinics, a higher proportion of patients with asthma compared to controls were given inhaled anti-inflammatory medication (17 versus 3, p<0.001), spacers devices (28 versus 3, p<0.001), and anti-inflammatory meds (68 versus 50, p<0.05). | significant improvement | not available
| | | Utilization | Continuity of care | Proportion of patients treated for asthma in 1 year who returned for treatment the next year | Percent of patients with asthma in year 1 who returned in year 2 increased in intervention clinics 16% to 32% (p<.0002) and decreased slightly in control clinics 14% to 12% (not significant). | not available | significant improvement
| | | Appropriateness of Care | Identification/ treatment of asthma patients | Number of asthmatic patients per 1000 clinic patients | Intervention clinics doubled (p<.001) rate at which they identified asthma patients with no change in control clinics during both 1st and 2nd follow-up years. | not available | significant improvement
Chronic Renal Disease
Harris, 1998 | Physician Resident/fellow, Professional | RCT | Utilization | All outpatient clinic visits (years 3–5 after enrollment) | Medical record review | Intervention group patients had significantly more outpatient clinic visits overall than did control group patients, 26 versus 18 (p<0.001). | significant improvement | not available
| | | Health Status | Blood pressure (years 3–5 after enrollment) | Medical record review | No significant differences in systolic and diastolic blood pressures between groups. | no improvement | not available
| | | Utilization | Emergency department visits (years 3–5 after enrollment) | Medical record review | No significant difference in emergency department visits between groups. | no improvement | not available
| | | Utilization | Hospitalizations (years 3–5 after enrollment) | Medical record review | No significant difference in number of hospitalizations between groups. | no improvement | not available
| | | Appropriateness of Care | Calcium channel blocker use (years 3–5 after enrollment) | Medical record review | Patients in the intervention group were more likely to be on a calcium channel blocker than were patients in control group, 49% versus 35% (p=0.003). | no improvement | not available
| | | Utilization | Ophthalmology clinic visits (years 3–5 after enrollment) | Medical record review | Patients in the intervention group had a greater number of ophthalmology appointments than did patients in the control group, 1.8 versus 1.2 (p=0.07). | improvement | not available
| | | Health Status | Cumulative 5 year mortality | Death certificate from Indiana State Department of Health, hospital death summaries, discharge status reports, autopsy reports | No significant difference in intervention (29%) versus control (33%) group in cumulative 5 year mortality. | no improvement | not available
| | | Health Status | Change in renal function (years 3–5 after enrollment) | Medical record review | Intervention group patients had lower creatinine clearance than did control group patients, 30 versus 34 (p=0.10). | no improvement | not available
Emergency Systems
Kellermann, 1993 | Firefighters Professional | CCT | Health Status | Neurological deficits | Physician/nurse report | Neurological outcomes for survivors of both groups were similar. | no improvement | not available
| | | Health Status | Survival to hospital discharge | Hospital report | Patients treated by automated external defibrillator equipped responders were no more likely to survive to hospital discharge. | no improvement | not available
| | | Health Status | Survival to hospital admission | Written report | Patients treated by automated external defibrillator equipped responders were no more likely to survive to hospital admission. | no improvement | not available
End of Life
Dexter, 1998 | Physician Resident/fellow, Professional | RCT | Patient Adherence | Completion of either Instruction or Proxy Directive | Patients complete either Directive | The percentage of patients who completed either directive was 15% in the instruction and proxy group, 7% in the instruction group, 3% in the proxy group, and 4% in the control group. | improvement | not available
| | | Quality of Providers | Discussion of advance directives | Patient report | Compared with control, dissemination of advanced directives had OR of 7.7 (3.4 to 18) in instruction and proxy group; 4.4 (2.1 to 9.4) in instruction group; and 2.5 (1.1 to 5.5) in proxy group. | significant improvement | not available
| | | Quality of Providers | Initiation of discussion | Patient report | Discussions initiated by physician in 86% of instances in instruction and proxy group, 77% in instruction group, 43% in proxy group, and 38% in control group. | improvement | not available
| | | Patient Adherence | Completion of Proxy Directive | Completion of form by patient | The percentage of patients who complete a Proxy Directive was 8% in the instruction and proxy group, 4% in the instruction group, 1% in the proxy group, and 2% in the control group. | improvement | not available
| | | Patient Adherence | Completed Instruction Directive | Completion of form by patient | The percentage of patients who completed an instruction directive in the instruction and proxy group was 15%, 7% in instruction group, 2% in proxy group, and 2% in control group. | improvement | not available

Evidence Table 4. Description of study characteristics for articles addressing Question 2, sorted by targeted healthcare provider(s)

Study | Categorization of Curriculum Content | | Training Methods | Contact Time | Training Objectives
| Cultural Concepts | Specific Cultures
PHYSICIAN
Beagan, 2003, Canada | Language, Specific cultural content | Not Specified | Clinical experiences, Lectures, Standardized patient, Small group | 1 afternoon each week held over 2 years | To develop physicians who are sensitive to the ethnic, cultural, and gender diversity of the community.
| | | | | To develop students skills to address critical issues in the doctor-patient relationship including cross-cultural healthcare.
Copeman, 1989, Australia | Racism, Doctor-patient interactions, Language, Specific cultural content | Other specific culture: Aboriginal | Case scenarios, Clinical experiences, Discussion (group), Interviewing members, Presentations | Not Specified | To be aware and reassess any prejudices, stereotypes, and judgmental attitudes towards Aboriginal or ethnic minorities.
| | | | | To practice overcoming difficulties in communicating with persons of different cultures and languages.
| | | | | To be aware of difficulties in communicating with different cultures.
| | | | | To understand how sociocultural backgrounds affect health.
| | | | | To learn basic facts about Aboriginal and migrant health, their social, and cultural backgrounds.
Crandall, 2003, U. S. | General concepts of culture, Racism, Specific cultural content, Socioeconomic status (SES) | Not Specified | Audio/Visual, Case scenarios, Demonstration/role, Interviewing members, Lectures, Problem based, Readings, Role play | 20 2–3 hour sessions held over 1 year | To help students become more culturally competent by moving towards conscious incompetence, and in some instances to conscious competence.
Culhane-Pera, 1997, U. S. | General concepts of culture, Doctor-patient interactions, Language, Specific cultural content | Hispanic | Audio/Visual, Clinical experiences, Discussion (group), Drill/practice exercise, Lectures, Literature, Presentations, Role play | 3 1-day sessions | To define culture and factors influencing culture of different population groups.
| | | | | To describe beliefs, values, behaviors, and health practices of ethnic groups.
| | | | | To be aware of own cultural beliefs, values, and practices and respect patients' and families' behaviors and values as pertinent to their medical problems.
| | | | | To appreciate the heterogeneity of patients, providers, and the clinical encounter.
| | | | | To inquire about beliefs, practices, and values of patients and family.
| | | | | To obtain medical history considering cultural information.
| | | | | To perform physical exam that is adjusted to the patient's cultural desires. To work with interpreters.
| | | | | To consider cultural information in making diagnostic and therapeutic plans.
| | | | | To be aware of sociocultural factors.
Dogra, 2001, U. K. | General concepts of culture | Not Specified | Brainstorming, Case scenarios, Drill/practice exercise, Lectures, Self study, Small group | 2 hours sessions in one week | To evaluate students' own attitudes and perceptions of different groups within society.
| | | | | To demonstrate respect for patients and colleagues that encompasses without prejudice, diversity of background and opportunity, language, culture, and way of life.
| | | | | To assess both the positive and negative impact of students' attitudes on their future practices as doctors.
| | | | | To apply the principles the students have learned from the exercises to other similar situations.
| | | | | To recognize the limitations of students' knowledge and seek appropriate advice with respect to students' understanding of another person's perspective.
| | | | | To describe at least two cultures different from your own.
| | | | | To outline the current legislation that exists to prevent discrimination.
| | | | | To respect the differences that exist between different groups of people.
Douglas, 1994, U. S. | General concepts of culture, Doctor-patient interactions, Language, Specific cultural content, Access issues | Asian/Pacific Islander, Hispanic | Audio/Visual, Clinical experiences, Discussion (group),, Readings, Self study | Not Specified | To learn about the errors that can occur with use of translators.
| | | | | To teach physicians about themselves (self awareness of culture/language).
| | | | | To deliver culturally sensitive healthcare.
| | | | | To address need of minority community.
Dowell, 2001, New Zealand | General concepts of culture, Specific cultural content | Other specific culture: Maori | Culture immersion | one week full-time | To increase awareness of importance of cultural issues.
| | | | | To encourage students to adopt broad public health approaches in assessing the health needs of defined communities.
Drouin, 2003, Canada | Language | Other specific culture: Francophone Canadian | Observation and feedback, Standardized patient | 15 < 2 hour sessions held over 2 years | To expose students to clinical scenarios that reflect the primary care practice of francophone physicians and to introduce them to cultural aspects of healthcare.
| | | | | To give students the opportunity to learn clinical skills efficiently outside the tertiary care centers where instruction in French was rarely possible.
Farnill, 1997, Australia | Language | Other specific culture: non-English speaking | Discussion (group), Interviewing members, Small group | 16 < 2-hour sessions held over 7 months | To interview people of non-English speaking backgrounds.
| | | | | To develop students' basic skills in interviewing.
| | | | | To increase student sensitivity to multicultural issues.
Godkin, 2001, U. S. | General concepts of culture, Language, Specific cultural content, Socioeconomic status (SES) | Asian/Pacific Islander, Hispanic | Culture immersion, Interviewing members, Language lessons, Lectures, Community service | 30 half-day sessions over 1 year plus 6 weeks full time | To develop sensitivity through first-hand experiences when living in a new country.
| | | | | To develop abilities to speak the language of an immigrant, refugee, or undocumented population new to Massachusetts.
| | | | | To develop an understanding of the culture and health beliefs of the newcomer group and the problems that they face.
| | | | | To promote a career preference to serve underserved populations.
Godkin, 2003, U. S. | General concepts of culture, Specific cultural content | Asian/Pacific Islander, African American, Hispanic | Culture immersion | Not Specified | To improve language skills for pre-clinical students in a formal language program.
Haq, 2000, U. S. | General concepts of culture, Specific cultural content | Asian/Pacific Islander, African American, Hispanic | Brainstorming, Case scenarios, Clinical experiences, Culture immersion, Discussion (group), Drill/practice exercise, Lectures, Conduction of community health activities, Role play | 8–10 weeks full time | To learn about 23 vital areas of international health, including planning, sanitation, nutrition, etc.
Mao, 1988, U. S. | General concepts of culture, Doctor-patient interactions, Specific cultural content | Not Specified | Audio/Visual, Discussion (group), Role play, Small group | 1 4-hour session held once only | To improve ability to provide medical care appropriate to patients ethnic and sociocultural backgrounds.
| | | | | To use LEARN (Listen, Explain, Acknowledge, Recommend, Negotiate) model as a framework for resolving physician-patient conflicts.
| | | | | To acknowledge that ethnic and sociocultural differences between a physician and a patient can influence the type of medical care given.
| | | | | To understand ethnic differences between patients and students.
Marvel, 1993, U. S. | General concepts of culture, Doctor-patient interactions | Not Specified | Audio/Visual, Case scenarios, Interviewing members, Readings, Role play, Small group | 16 sessions held over 4 weeks | To understand basic family systems concepts.
| | | | | To understand how one's own cultural and family background influences the doctor-patient relationship.
| | | | | To conduct a family conference.
| | | | | To identify developmental tasks in the family life cycle.
| | | | | To identify cultural factors that affect health care.
| | | | | To recognize the family role in chemical dependency.
Mazor, 2002, U. S. | Language, Specific cultural content | Hispanic | Case scenarios, Language lessons | 2-hour sessions held weekly for 10 weeks | To improve understanding of Hispanic cultural beliefs.
| | | | | To improve ability in taking medical history in Spanish.
| | | | | To determine whether a course in medical Spanish for Pediatric Emergency department physicians is associated with an increase in patient satisfaction for Spanish-speaking-only families.
Nora, 1994, U. S. | Language, Specific cultural content, Access issues | Hispanic | Clinical experiences, Culture immersion, Demonstration/role, Discussion (group), Language lessons, Lectures, Presentations, Readings, Small group | 30 2-hour sessions plus 8 days full time | To learn about demographic, geographic, and cultural differences between Hispanics and Anglo-Americans and implications for health care.
| | | | | To teach medical terminology and physician-patient conversation.
| | | | | To explore issues of health care in a developing Hispanic country.
| | | | | To improve ability to understand health issues and communicate them to Spanish-speaking patients.
Rubenstein, 1992, U. S. | General concepts of culture, Specific cultural content | Asian/Pacific Islander | Case scenarios, Discussion (group), Interviewing members, Lectures, Presentations, Small group | 1 4-hour session held once only | To describe the effect of non-conventional health beliefs in doctor-patient relationship.
| | | | | To identify resources for learning more about these beliefs.
| | | | | To recognize how pervasive such beliefs are in our society.
| | | | | To interview a person about his/her health beliefs and practices.
Sinnott, 2001, Australia | General concepts of culture, Specific cultural content | Other specific culture: Aboriginal | Lectures, Readings | 1 < 2-hour session held once only | To be aware of the role of indigenous hospital liaison officers.
Tang, 2002, U. S. | Not Specified | Not Specified | Case scenarios, Lectures, Role play, Self reflection, Small group | sessions held over four years | To prepare students to negotiate sociocultural issues that will emerge in their clinical experiences.
| | | | | To increase the knowledge about sociocultural factors in medical students future patient care.
| | | | | To increase understanding of the relationships among sociocultural background, health, and medicine.
NURSE
Alpers, 1996, U. S. | General concepts of culture, Specific cultural content | Asian/Pacific Islander, African American, Hispanic | Home visits, Not Specified | Not Specified | To improve skill specific transcultural tasks.
| | | | | To increase knowledge of specific cultural patterns.
| | | | | To increase knowledge of general transcultural concepts.
| | | | | To improve confidence and competence in providing care to minorities (African Americans, Latino-Hispanics, Southeast Asians).
Barton, 1992,U. S. | General concepts of culture, Specific cultural content | Hispanic | Clinical experiences, Culture immersion | Not Specified | To explore the extent to which student discovery learning occurs when the teaching model includes clinical experience involving transcultural health care.
Berman, 1998, U. S. | General concepts of culture, Specific cultural content | Asian/Pacific Islander, African American, Hispanic | Audio/Visual, Case scenarios, Lectures, Readings, Small group | 3 one-day sessions plus 1 two-day session | To identify beliefs, sources of information, and access of minority/underserved populations.
| | | | | To increase cultural sensitivity.
| | | | | To identify appropriate nursing interventions for minorities.
| | | | | To identify cancer-related needs in different minorities.
| | | | | To identify barriers to adequate cancer nursing care for minority/underserved populations.
Blackford, 2002, Australia | General concepts of culture, Specific cultural content, Gender roles and sexuality | Other specific culture: non-English speaking | Discussion (group), Interviewing members | < 2-hour sessions held every two weeks for 7 months | To examine health professionals own Anglo-Australian culture and its impact on other ethnic communities.
Bond, 1994, U. S. | General concepts of culture, Language, Specific cultural content | Hispanic | Culture immersion, Language lessons, Literature, Presentations, Readings, Self reflection, Small group | Not Specified | To allow the student to compare observations to what is reported in the literature.
| | | | | To gain exposure to the Spanish language.
| | | | | To explore Mexican culture.
| | | | | To increase knowledge of Mexican health care beliefs.
| | | | | To acknowledge the challenges presented in planning and delivering culturally sensitive and competent care within health care work settings.
| | | | | To experience the Mexican culture by beginning to learn the language, living with people, sharing food and customs, and ultimately gaining insight into behavior.
Campinha-Bacote, 1996, U. S. | General concepts of culture | Not Specified | Audio/Visual, Drill/practice exercise, Lectures, Experimental exercises | 4 < 2-hour sessions | To increase cultural awareness and knowledge of nurses.
| | | | | To improve the cultural skills of nurses.
Felder, 1990, U. S. | General concepts of culture, Doctor-patient interactions, Specific cultural content | African American | Not Specified | Not Specified | To test for any significant difference between baccalaureate and associate degree nursing students' cultural knowledge and attitudes towards black American clients.
| | | | | To test for any significant difference of cultural knowledge of black Americans among baccalaureate and associate degree seniors and freshmen.
| | | | | To test for any significant difference in the attitudes of baccalaureate and associate degree seniors and freshmen where programs have provided similar training experiences.
Flavin, 1997, U. S. | Doctor-patient interactions, Specific cultural content | Asian/Pacific Islander | Audio/Visual, Case scenarios, Discussion (group), Presentations, Role play | < 2-hour sessions held weekly for 3 weeks | To provide culturally relevant quality care to clients from cultures different from nurses' own.
Frank-Stromborg, 1987, U. S. | Specific cultural content | African American | Demonstration/role, Discussion (group), Lectures,, Role play | 1 day session held once only | To identify cancer risks at the individual and community level.
| | | | | To describe nursing role in prevention/detection of cancers in black Americans.
| | | | | To integrate what was learned into clinical practice.
| | | | | To explore nurses' own feelings toward cancer.
| | | | | To palpate simulated prostate and gynecological malignancies.
| | | | | To increase cancer prevention/detection activities among Black Americans.
Frisch, 1990, U. S. | General concepts of culture, Specific cultural content | Hispanic | Culture immersion | 6 weeks full-time | To assess the change in students' thinking maturity over time.
| | | | | To assess the level of cognition of undergraduate students.
| | | | | To examine whether exposure to diversity challenged established views and brought measurable cognitive change.
Hadwiger, 1999, U. S. | Doctor-patient interactions, Language, Specific cultural content | African American, American Indian/Alaska Native, Hispanic, Other specific culture | Case scenarios | 4 sessions | To learn about the cultural background of another group, particularly healthcare practices, communication styles, and specific health-problems.
| | | | | To have the nursing student reflect on how his/her beliefs and assumptions differs from the patient.
| | | | | To negotiate a plan of care without resorting to ethnocentric attitudes or stereotypes.
Haloburdo, 1998, U. S. | General concepts of culture, Specific cultural content | Hispanic | Clinical experiences, Culture immersion, Lectures | Not Specified | Not specified.
Inglis, 2000,Asia; Australia | Doctor-patient interactions, Specific cultural content | Asian/Pacific Islander | Lectures, Visits to local hospitals and health centers, Field trip | 3 weeks full time | To improve knowledge about the Nepalese people and their health system.
| | | | | To improve behaviors directed towards the Nepalese people.
| | | | | To improve students' attitudes and beliefs about the Nepalese people.
Jeffreys, 1999, U. S. | General concepts of culture, Specific cultural content | Not Specified | Clinical experiences, Discussion (group), Lectures, Written assignments, Readings | Not Specified | To systematically conduct basic cultural assessment.
| | | | | To discover importance of culturally competent care.
| | | | | To identify similarities and differences among individuals from cultural groups.
| | | | | To distinguished between varying levels of acculturation.
Jeffreys, 2002,U. S. | General concepts of culture, Doctor-patient interactions, Access issues | Not Specified | Audio/Visual, Discussion (group), Lectures, Readings, Role play, Small group | Not Specified | To identify strategies to integrate cultural health assessment.
| | | | | To discuss impact of healthcare policy on diverse populations.
| | | | | To identify ethical, legal, and moral dimensions of interventions from transcultural perspective.
| | | | | To identify role of provider in culturally competent care.
| | | | | To discuss application of transcultural care.
| | | | | To discuss theories of culture.
| | | | | To discuss future directions and challenge of transcultural care.
| | | | | To discuss issues in diversity and healthcare in relation to culturally competent clinical practice.
| | | | | To critically appraise selected theories/research.
Lasch, 2000, U. S. | Specific cultural content | Not Specified | Clinical experiences, Discussion (group), Lectures, Presentations | 1 1-day sessions held once only | To improve cancer pain knowledge hands-on experience.
| | | | | To improve attitudes relating to cancer pain among nurses of patients from 11 different ethnic groups.
| | | | | To improve knowledge about cancer pain among nurses of patients from 11 different ethnic groups.
| | | | | To increase durability of attitudes related to cancer pain via hands-on-experience.
Lindquist, 1984, U. K. | Specific cultural content | Not Specified | Culture immersion, Discussion (group), Lectures | sessions held daily for 4 weeks | To learn about another culture and health care delivery system.
Lockhart, 1997, U. S. | General concepts of culture, Access issues | African American, American Indian/Alaska Native, Hispanic, Other specific culture | Drill/practice exercise, Lectures, Simulations; Field experience; Self assessment | Not Specified | To explore ways to promote knowledge development of and the profession's involvement in transcultural nursing.
| | | | | To investigate cultural diversity as it relates to the nursing program.
| | | | | To examine select healthcare delivery and acceptance issues related to an individual's background.
| | | | | To examine specific concepts and principles in transcultural health care system.
| | | | | To explore the evaluation of transcultural nursing as a specialty area.
Napholz, 1999, U. S. | General concepts of culture, Language, Specific cultural content | African American | Clinical experiences, Presentations, Small group | 3 2-hour sessions | To increase cultural sensitivity.
| | | | | To apply change strategies.
| | | | | To formulate culturally relevant care plans.
| | | | | To discuss openly racial and ethnic differences.
| | | | | To adapt to clients' interactive style and language.
Oneha, 1998, U. S. | General concepts of culture | Asian/Pacific Islander | Case scenarios, Clinical experiences, Discussion (group), Problem based, Small group | sessions held weekly | To identify the role of nurses in multi professional team.
| | | | | To solve culturally sensitive group problems.
| | | | | To adjust activities to benefit the community.
| | | | | To identify the impact of culture on nursing care.
| | | | | To accept the controls, constraints, and ambiguity in community based practice.
Rolls, 1997, Australia | General concepts of culture | Asian/Pacific Islander | Culture immersion, Discussion (group), Readings | 4 2-hour sessions plus 4 weeks full time | To develop an understanding of the forces influencing international health care services.
| | | | | To create awareness and change attitudes towards different cultures.
Rooda, 1993, U. S. | General concepts of culture, Specific cultural content | Asian/Pacific Islander, African American, Hispanic | Discussion (group), Drill/practice exercise, Lectures, Reflection, Small group | 1 1-day session held once only | To learn how the culture of various ethnic groups affects their healthcare practices.
| | | | | To develop a sequence of learning to be used for increasing cultural awareness.
Ryan, 2000, U. S. | General concepts of culture | Not Specified | Culture immersion | Not Specified | No stated objectives.
Ryan, 2002, U. S. | General concepts of culture, Language, Specific cultural content | Asian/Pacific Islander, African American, Other specific culture | Case scenarios, Discussion (group), Web page | Not Specified | To learn new ways of communicating and facilitating dialogue about culture.
| | | | | To gain insight into both one's own and others' cultural beliefs.
| | | | | To gain insight into social orientation.
| | | | | To identify health behaviors unique to a culture.
| | | | | To increase knowledge about health practices in another country.
| | | | | To discuss nursing interventions for case study.
| | | | | To increase awareness of culture in healthcare and the environmental influences in cultural heritage.
Scisney-Matlock, 2000, U. S. | General concepts of culture | Not Specified | Lectures, Web pages; Written and verbal presentations, Small group | Not Specified | To increase exposure to information and activities devoted to understanding other racial/ethnic groups.
| | | | | To increase knowledge of diversity.
Smith, 2001, U. S. | General concepts of culture, Specific cultural content | Not Specified | Case scenarios, Demonstration/role, Lectures, Simulations | 1 session held once only | To improve confidence in performing specific transcultural skills.
| | | | | To improve confidence in knowledge of cultural patterns within different groups.
| | | | | To improve knowledge of cultural concepts (culturally specific health and illness concerns, values, and family orientation issues).
St Clair, 1999, U. S. | General concepts of culture, Doctor-patient interactions | African American | Culture immersion | 2–3 weeks full time | To change nursing students' self-efficacy and cultural perceptions.
| | | | | To determine if there are changes in the nurse-patient relationship as a result of these cultural immersions.
| | | | | To improve cultural sensitivity.
| | | | | To change nursing students' ethnocentrism.
Underwood, 1999, U. S. | Specific cultural content | African American | Case scenarios, Demonstration/role, Lectures, Outreach with national prevention organization | Not Specified | To identify common attitudes of African Americans towards cancer.
| | | | | To describe nurses' role in cancer prevention and early detection.
| | | | | To describe procedures for performing screening examinations for 5 common cancers.
| | | | | To conduct NCI breast self exam or smoking cessation program.
| | | | | To identify factors which facilitate and impede cancer prevention in the African American community.
| | | | | To identify individuals at increased risk for 5 common cancers.
| | | | | To design a community-based cancer prevention program including: development, implementation, and evaluation.
Underwood, 2002, U. S. | Specific cultural content | African American | Lectures, Presentations, Role play, Small group | Not Specified | To discuss the nurse education role in prevention and early detection and strategies to enhance understanding of burden of cancer experienced by African Americans.
| | | | | To identify etiological factors associated with 5 common cancers among African Americans.
| | | | | To describe signs and symptoms associated with 5 common cancers in the African American population.
| | | | | To describe incidence mortality and survival of breast, cervical, prostrate, colorectal, and lung cancer in African Americans.
| | | | | To teach programs related to breast health, smoking cessation, and smoking prevention.
| | | | | To discuss recommended cancer screening procedures and diagnostic examination for 5 common cancers in African Americans.
| | | | | To provide nurse educators with information and resources on the prevention and control of cancer in African Americans.
| | | | | To propose a strategy for educating students to promote health screening and early detection for African Americans in the community or practice setting.
| | | | | To describe procedures for accessing state-of-the-art cancer information on the Internet and World-Wide Web.
| | | | | To identify common attitudes of African Americans towards cancer, cancer prevention, early detection, and cancer cure.
| | | | | To identify established organizations with cancer control as a major objective.
| | | | | To identify factors which facilitate or impede cancer prevention and early detection.
Warner, 2002, U. S. | General concepts of culture, Specific cultural content | American Indian/Alaska Native | Culture immersion | Not Specified | To “broaden horizons”.
Wendler, 2002, U. S. | General concepts of culture, Specific cultural content | African American, American Indian/Alaska Native, Hispanic, Other specific culture | Interviewing members, internet learning, cultural enrichment activities, Small group | Not Specified | To evaluate the impact of culture on health, illness, and wellness.
| | | | | To analyze the theoretical and conceptual approaches underlying cultural congruency/competency.
| | | | | To evaluate health patterns of different ethnic groups: African-American, Hispanic, Asian, and Native American.
| | | | | To synthesize the scholarly literature to facilitate healthcare planning, implementation, and/or evaluations that are culturally competent.
| | | | | To examine the interrelationships among a pluralistic society, the culturally diverse group within the society, and the health/illness status and beliefs of the group members, with a specific focus on the peoples of the African-American, Hispanic, Asian, and Native American cultures.
Williamson, 1996, U. S. | General concepts of culture | Not Specified | Audio/Visual, Clinical experiences, Culture immersion, Discussion (group), Interviewing members, Presentations, Readings | sessions held weekly | To increase the students' knowledge of ethnic groups.
| | | | | To increase students' ability to care for ethnic groups.
OTHER PROVIDERS/ MIXED GROUPS
Nurse, Physician, Receptionists, Volunteers, Business office staff
Gallagher Thompson, 2000, U. S. | Doctor-patient interactions, Specific cultural content, Access issues | Hispanic | Audio/Visual, Discussion (group), Lectures, | 1 session held once only | To increase knowledge about Hispanic Alzheimer's patients and their families.
| | | | | To increase general knowledge about Alzheimer's disease.
| | | | | To increase knowledge of Hispanic beliefs about dementia.
| | | | | To increase referrals of Hispanic Alzheimer's patients and their families to the appropriate specialized services about Alzheimer's disease.
Nurse, Physician, Social workers, Nurse's aides, Receptionists, Clerks
Gany, 1996, U. S. | Language, Specific cultural content | Asian/Pacific Islander, African American, Hispanic | Discussion (group), Personal experiences, Role play | 4 sessions | To learn about expectations and behaviors of immigrant groups concerning pregnancy, birth, well-baby care, contraceptive use, and folk remedies.
| | | | | To learn about immigrant epidemiology, management of disease and other health issues, the impact of immigration, and use of folk medicine.
| | | | | To discern between health beliefs that are beneficial or neutral to the child and well-being of the mother and those that are harmful.
| | | | | To bridge differences between the Western biomedical system and alternative healthcare systems.
| | | | | To learn about the impact of migration in family dynamics and interaction, and the increased possibility of family violence.
| | | | | To become aware of own interview style and learn effective communication strategies in the bilingual medical interview.
Nurse, Pharmacist
Chevannes, 2002, U. K. | General concepts of culture | Not Specified | Audio/Visual, Case scenarios, Clinical experiences, Discussion (group), Lectures, Presentations | Not Specified | To develop skills (i.e. history taking) to meet the health needs of ethnic minorities.
| | | | | To change practice as a result of training.
| | | | | To improve culture knowledge of ethnic minority patients and their health care needs.
Nurse, Pharmacist, Physician, Occupational Therapy, Physical Therapy, Health administration
Erkel, 1995, U. S. | Specific cultural content | African American | Audio/Visual, Case scenarios, Clinical experiences, Culture immersion, Literature, Presentations, Readings, Role play | 5 weeks full time | To develop culturally sensitive health professionals able to function within interdisciplinary team in rural setting.
Nurse, Pharmacist, Physician, Any staff with direct patient contact
Way, 2002, U. S. | General concepts of culture | Not Specified | Not Specified | 1 sessions held once only | To enhance recognition and understanding of other cultures.
Community health worker, Undergraduate student
Bengiamin, 1999, U. S. | General concepts of culture, Specific cultural content, Access issues | Asian/Pacific Islander, American Indian/Alaska Native, Hispanic, Other specific culture | Audio/Visual, Discussion (group), Literature, Presentations | Not Specified | To explore one's own cultural background.
| | | | | To increase knowledge of student perception of transcultural nursing.
| | | | | To facilitate cultural awareness from a holistic care perspective.
| | | | | To develop a sense of cultural awareness.
| | | | | To cultivate skills that allow students to understand and analyze cultural differences.
Community health worker, Church nurse guild members and other interested community organizations
Briscoe, 1999, U. S. | Access issues | African American | Case scenarios, Discussion (group), Lectures, Readings, Role play | 1 2-hour session held once only | To instruct organization members on strategies for maximizing medical encounters.
| | | | | To identify strategies to overcome practical obstacles to quality of care, utilization (e.g., manage child care, transportation).
| | | | | To develop a plan for overcoming attitudinal obstacles to health care utilization, especially diabetes screening.
| | | | | To describe and implement a plan for promoting sources of high quality diabetes care within the organization.
| | | | | To implement a plan for identifying sources of high quality diabetes care in their communities.
Social workers
Browne, 2002, U. S. | General concepts of culture | Not Specified | Case scenarios, Clinical experiences, Drill/practice exercise, Lectures | Not Specified | To incorporate knowledge of diverse cultural, norms, issues, and values in the assessments of and interventions with culturally diverse age groups.
| | | | | To provide a greater emphasis on interdisciplinary team work and cultural competence.
| | | | | To increase knowledge of diverse cultural norms, issues, and values.
| | | | | To increase awareness of diverse cultural norms, issues, and values.
Psychologists
Hansen, 2002, U. S. | General concepts of culture, Doctor-patient interactions, Language, Specific cultural content | Not Specified | Discussion (group), Writing cultural autobiography, Readings, Self study | 2 1-day sessions | To develop cultural awareness.
| | | | | To self assess one's multicultural competence.
| | | | | To establish rapport and convey empathy in culturally sensitive manner.
| | | | | To explain results in a culturally sensitive contextual manner.
| | | | | To modify assessment tools and conclusions appropriately for use with identified group.
| | | | | To know how to assess variables of special relevance to identified groups.
| | | | | To understand culture-specific assessment procedures and tools.
| | | | | To ascertain effects of therapist-client language differences.
Tomlinson-Clarke, 2000, U. S. | General concepts of culture, Racism, Specific cultural content | Other specific culture: Aboriginal | Discussion (group), Use of “critical incidents” to develop skills, Readings | 15 sessions held weekly | To understand people within a socio-cultural context; addressing race, oppression, and ethnicity. Familiarity with current research in multicultural field.
| | | | | To discuss culture, identity, appreciation of one's own culture and biases.
| | | | | To use critical incidents to develop multicultural communication skills.
Mental health professionals
Stumphauzer, 1983, U. S. | General concepts of culture, Access issues | Asian/Pacific Islander | Case scenarios, Discussion (group), Readings | 2-hour sessions held weekly for 10 weeks | No stated objectives.
Occupational therapy
Velde, 2001, U. S. | Specific cultural content | African American | Clinical experiences, Culture immersion, Interviewing members, Literature, Presentations, Self reflection, Small group | 20–28 hours total | To know about cultural differences between Tillery community members and students/faculty.
| | | | | To note personal awareness of cultural differences between Tillery community members and students.
| | | | | To study effects of cultural differences on behavior of Tillery community members and students/faculty.
Counselors
Wade, 1991, U. S. | Specific cultural content | African American | Discussion (group), Role play | 4 hours total | To increase knowledge necessary to understand and to respond to attitudes that low-income black women bring to counseling.
| | | | | To increase cultural sensitivity.
| | | | | To increase self-awareness necessary to understand and to respond to attitudes that low-income black women bring to counseling.
| | | | | To increase skills necessary to understand and to respond to attitudes that low-income black women bring to counseling.

Evidence Table 5. Description of study quality for articles addressing Question 2, sorted by targeted healthcare provider(s)

Study | Study Design | Summary of Quality Assessment^a^ | | | | | Selected Aspects of Quality
| | Rep | Bias | Inter | Out | Analy | Comparison Group? | Complete Description? | Blinding? | Objective Strategy? | Numbers/ Reasons for Non-inclusion? | Complete Statistical Analysis?
PHYSICIAN
Beagan, 2003 | Post-test only with external control | | | | | | Y | N | N | N | N | N
Copeman, 1982 | Pre-/post-test | | | | | | N | N | N/A | Y | N | N
Crandall, 2003 | Pre-/post-test | | | | | | N | N | N/A | Y | Y | Y
Culhane-Pera, 1997 | Pre-/post-test | | | | | | N | Y | N/A | N | N | N
Dogra, 2001 | Pre-/post-test | | | | | | N | Y | N/A | Y | Y | N
Douglas, 1994 | Post-test only | | | | | | N | N | N/A | N | N | N
Dowell, 2001 | Post-test only | | | | | | N | Y | N/A | N | N | N
Drouin, 2003 | Post-test only | | | | | | N | Y | N | N | N | N
Farnill, 1997 | Pre-/post-test | | | | | | N | Y | N/A | Y | N | Y
Godkin, 2001 | Concurrent controlled trial (CCT) | | | | | | Y | Y | N | Y | Y | N
Godkin, 2003 | Concurrent controlled trial (CCT) | | | | | | Y | N | N | N | N | Y
Haq, 2002 | Pre-/post-test | | | | | | N | Y | N/A | N | N | N
Mao, 1988 | Pre-/post-test | | | | | | N | Y | N | N | N | N
Marvel, 1993 | Post-test only | | | | | | N | N | N/A | N | N | N
Mazor, 2002 | Pre-/post-test | | | | | | N | Y | N/A | Y | N | Y
Nora, 1994 | Pre-/post-test with external control | | | | | | N | Y | N | Y | Y | N
Rubenstein, 1992 | Pre-/post-test | | | | | | N | N | N/A | Y | N | N
Sinnott, 2001 | Post-test only | | | | | | N | N | N | N | N | N
Tang, 2002 | Pre-/post-test | | | | | | N | Y | N/A | N | N | Y
NURSE
Alpers, 1996 | Concurrent controlled trial (CCT) | | | | | | Y | N | N | Y | N | N
Barton, 1992 | Post-test only | | | | | | N | N | N/A | N | Y | N/A
Berman, 1998 | Post-test only | | | | | | N | Y | N/A | N | N | N
Blackford, 2002 | Qualitative | | | | | | N | N | N/A | N | N | N
Bond, 1994 | Post-test only | | | | | | N | N | N/A | N | N | N
Campinha-Bacote, 1996 | Post-test only | | | | | | N | N | N/A | N | N | N
Felder, 1990 | Post-test only | | | | | | N | N | N | Y | N | Y
Flavin, 1997 | Pre-/post-test | | | | | | N | N | N/A | Y | Y | N
Frank-Stromborg, 1987 | Pre-/post-test | | | | | | N | Y | N/A | Y | Y | Y
Frisch, 1990 | Concurrent controlled trial (CCT) | | | | | | Y | N | Y | Y | N | N
Hadwiger, 1999 | Post-test only | | | | | | N | Y | N/A | N | N | N
Haloburdo, 1998 | Qualitative | | | | | | N | N | N/A | N | Y | N/A
Inglis, 2000 | pre-/post-test with external control | | | | | | N | Y | Y | Y | N | N
Jeffreys, 1999 | Pre-/post-test | | | | | | N | N | N/A | Y | N | N
Jeffreys, 2002 | Post-test only | | | | | | N | N | N/A | N | N | N/A
Lasch, 2000 | Randomized controlled trial (RCT) | | | | | | Y | Y | N | Y | N | N
Lindquist, 1984 | Post-test only | | | | | | N | N | N | N | N | N
Lockhart, 1997 | Post-test only | | | | | | N | N | N/A | N | N | N
Napholz, 1999 | Concurrent controlled trial (CCT) | | | | | | Y | N | N | Y | N | Y
Oneha, 1998 | Post-test only | | | | | | N | N | N/A | N | N | N
Rolls, 1997 | Post-test only | | | | | | N | N | N/A | N | Y | N
Rooda, 1993 | Post-test only | | | | | | N | N | N/A | N | N | N/A
Ryan, 2002 | Post-test only | | | | | | N | Y | N/A | N | N | N
Ryan, 2000 | Qualitative | | | | | | N | N | N/A | N | N | N/A
Scisney-Matlock, 2000 | Concurrent controlled trial (CCT) | | | | | | Y | Y | N | Y | N | Y
Smith, 2001 | Concurrent controlled trial (CCT) | | | | | | Y | N | N | Y | Y | Y
St Clair, 1999 | Concurrent controlled trial (CCT) | | | | | | Y | N | N | Y | N | N
Underwood, 1999 | Pre-/post-test | | | | | | N | Y | N/A | N | N | N
Underwood, 2002 | Post-test only | | | | | | N | N | N/A | N | Y | N
Warner, 2002 | Post-test only | | | | | | N | N | N/A | N | N | N
Wendler, 2002 | Post-test only | | | | | | N | N | N/A | N | N | N
Williamson, 1996 | Pre-/post-test | | | | | | N | N | N/A | Y | N | Y
OTHER PROVIDERS/ MIXED GROUPS
Nurse, Physician, Receptionists, Volunteers, Business office staff
Gallagher Thompson, 2000 | Pre-/post-test | | | | | | N | N | N/A | Y | N | N
Nurse, Physician, Social workers, Nurse's aides, Receptionists, Clerks
Gany, 1996 | Pre-/post-test | | | | | | N | N | N/A | Y | N | Y
Nurse, Pharmacist
Chevannes, 2002 | Post-test only | | | | | | N | N | N/A | N | Y | N/A
Nurse, Pharmacist, Occupational therapy, Physical therapy, Health administration
Erkel, 1995 | Pre-/post-test | | | | | | N | N | N/A | N | N | N
Nurse, Pharmacist, Physician, Any staff with direct patient contact
Way, 2002 | Pre-/post-test | | | | | | N | N | N/A | Y | N | Y
Community health worker, Undergraduate students
Bengiamin, 1999 | Qualitative | | | | | | N | N | N/A | N | Y | N/A
Community health worker, Church nurse guild members and other interested community organizations
Briscoe, 1999 | Post-test only | | | | | | N | N | N/A | N | N | N
Social workers
Browne, 2002 | Post-test only | | | | | | N | N | N/A | N | N | N
Psychologists
Hansen, 2002 | Post-test only with external control | | | | | | N | Y | N | Y | N | Y
Tomlinson-Clarke, 2000 | Post-test only | | | | | | N | N | N/A | N | N | N
Mental health professionals
Stumphauzer, 1983 | Pre-/post-test | | | | | | N | Y | N/A | Y | N | N
Occupational therapy
Velde, 2001 | Qualitative | | | | | | N | N | N/A | N | N | N
Counselors
Wade, 1991 | Randomized controlled trial (RCT) | | | | | | Y | N | Y | Y | Y | Y

a assessments of methodological strengths and weaknesses in 5 domains, as categorized by the following symbols:

= quality score of 80% or above

= quality score of 50 to 79%

= quality score of less than 50%

Domains:

Rep = representativeness of targeted healthcare providers and/or patients

Bias = potential for bias and confounding

Inter = description of interventions

Out = assessment of outcomes

Analy = analytic approach

Evidence Table 6. Results from articles addressing Question 2, sorted by targeted healthcare providers(s)

Study | Evaluation Methods | Outcomes
PHYSICIAN
Beagan, 2003 | Individuals interviews, questionnaires | There were no differences in the percent of students who thought various characteristics of patients (for example appearance, English ability, social class, race, gender, culture) affected their treatments.
| | There were no differences in the percent of students who thought physicians' social and cultural characteristics affected their medical practice.
| | There were no differences in the percent of students who thought their own social and cultural factors affected their medical school experience.
Copeman, 1989 | Self-assessment forms, Written exam | A 2-item test of knowledge showed significant improvement on one item measuring knowledge of cardiovascular disease but no improvement on the item measuring mental illness among Aboriginals.
| | After the intervention, only 20% felt “quite competent” to interview a non English speaking patient through an interpreter and 76% thought they could “probably manage”.
| | After the curriculum, medical students were less likely to agree, 1) that migrants take away jobs from other Australians (p<0.01) and 2) that restrictions should be placed on the Aboriginal to protect him from his own lack of responsibility (p<0.05) and medical students were significantly more likely to agree 1) that the cause of Aboriginal poor health is disposition from their land (p<0.01) and 2) that in general Aborigines are pretty much all alike (p<0.05).
Crandall, 2003 | Written exam, The multicultural assessment questionnaire | Statistically significant improvement of the 4 items of the skills sub-scale occurred after the course (p=0.000).
| | Statistically significant improvement on the 6 items of the knowledge sub-scale occurred after the course (p=0.000).
| | Statistically significant improvement of the 6 items of the attitudes sub-scale occurred after the course (p=0.000).
Culhane-Pera, 1997 | Group interviews, Observer questionnaire, Participant ratings, Self-assessment forms | Average scores on a 4-item attitudinal self-assessment improved from 3.93 to 4.1, though this change was not statistically significant.
| | Average scores on a 6-item self-assessment of skills (related to incorporating cultural issues into clinical care) improved from 3.33 to 3.96 (p=0.000).
| | Residents self-assessments of their level of cultural competence significantly increased between initial and final evaluations.
| | Although faculty's initial assessment of resident's level of cultural competence did not correlate well with residents' own assessment r=0.092), final competence level assessment did r=0.507, p<0.05).
| | Average scores on a 6-item knowledge self-assessment of general cultural issues improved from 2.87 to 3.47 (p=0.000).
| | Participants ranked the entire curriculum of 4.33/5 for importance and 4.26/5 for quality.
Dogra, 2001 | Self-assessment forms, Written exam | There was no statistical difference in responses to case scenarios before and following training.
| | After the intervention, students had significantly different responses on 8 out of 25 attitudinal items about cultural issues, (p<0.05).
Douglas, 1994 | Patient rating, Self-assessment forms | Participants in the curriculum developed a keener appreciation of their own culture and that of their patients.
| | In a follow-up survey of patients, the majority felt that evaluation in the ethnogeriatric clinic was helpful and that they had benefitted from the assessment approach.
Dowell, 2001 | Participant ratings, Written exam | Students were able to successfully identify the health needs of a population.
| | Forming an attachment with Maori people resulted in students finding they actually cared about them.
| | Students rated the course highly.
Drouin, 2003 | Participant ratings | Students rated the communication encounters positively in terms of quality and relevance of the scenarios, realism of role-playing, usefulness of feedback by patient and supervising clinician, and perception concerning acquisition of new communication skills.
Farnill, 1997 | Patient rating, Self-assessment forms, Video/Audiotape | Students reported significantly more competence on all self-assessment dimensions (p<0.001) related to interviewing patients of non-English speaking patients.
| | Community volunteers reported positive experiences being interviewed by the students.
| | Blinded psychologist rating of video showed students to be significantly more competent in interviewing a non-English-speaking patient in the post-intervention video over pre-intervention video (p<0.01).
Godkin, 2001 | Self-assessment forms, Written exam | Students in the intervention group showed significant improvements in self-assessed knowledge of cultural beliefs, practices, and health needs on 8 out of 9 items.
| | Students in the intervention group showed significant improvements on 7 out of 20 cultural competence items, and had significantly better cultural competence attitudes than students who did not participate in the intervention.
Godkin, 2003 | Self-assessment forms | Compared to students who did not elect to travel internationally, students who traveled were significantly more interested in an international component in career, interested in working with underserved, recognizing need to know another language and recognizing need to know a patient's financial constraints.
| | After traveling to another country, preclinical medical students were more likely (than before they had traveled) to report (on a scale from 1 to 5) that they had an interest in an international component to their career (4.37 compared to 4.06, p<0.001), that they had an interest in an international component to their career (3.97 compared to 3.67, p<0.01), that there is a need to understand cultural differences (4.43 compared to 4.16, p<0.01), that there is a need to know another language (4.51 compared to 4.15, p<0.001), and that there was a need to be an advocate for the whole community (4.14 compared to 3.91, P=0.03).
| | After traveling to another country, medical students in their clinical years were more likely (than before they had traveled) to report (on a scale from 1 to 5) that there was a need to understand cultural differences (4.51 compared to 4.23, p<0.001), that they were enthusiastic about being a physician (4.17 compared to 3.86, p+0.03), ant that they had a sense of idealism in the role of physician (3.65 compared to 3.16, p<0.001), but were less likely to report a need to work collaboratively with other professionals (3.93 compared to 4.19, p=0.02) and that they had awareness of their future role as physicians (4.14 compared to 4.35, p=0.04).
Haq, 2000 | Essays, Participant ratings, Self-assessment forms, Open-ended questions | 96% would recommend international health experiences to other students.
| | Participants experienced significant positive changes in attitude towards communication and community health issues (p ≤ 0.03) between the pre and post-test.
| | 83% of participants said the experiences changed how they would practice medicine.
| | Participants gained significant positive improvements on each of 10 self-assessed clinical skills between the pre and post-test (p=0.001).
Mao, 1988 | Participant ratings | In 1986, 94% approved the use of student discussion leaders, 85% enjoyed the videotapes, and 49% found the role playing exercises helpful.
| | In 1986 and 1987, 70% of students found that the workshop achieved its objectives and 10% wanted more specific cultural information.
| | In 1986 and 1987 a few students commented that the workshop should explore racial and gender issues in more depth.
| | 1985 showed some “significant” improvement in making treatment choices in three case studies (paired t-tests).
| | There was significant improvement on 3 of 9 attitudes measured.
Marvel, 1993 | Participant ratings | The curriculum received an average score of 7.1 out of 10 (range: 5.4 – 8.0) on usefulness of rotation objectives to current practice.
| | All respondents recommended to continue the rotation in the curriculum.
Mazor, 2002 | Performance audits, Patient rating, Self-assessment forms | Families in the post-intervention period were more likely to strongly agree that “the physician was concerned about my child” (OR 2.1, [1.0–4.2]) than families in the pre-intervention period.
| | Families in the post-intervention period were more likely to strongly agree that “the physician listened to what I said” (OR 2.9, [1.4–5.9]) than families in the pre-intervention period.
| | Families in the post-intervention were more likely to strongly agree that “the physician made me feel comfortable” (OR 2.6, [1.1–4.4]) than families in the pre-intervention period.
| | Physicians used a professional interpreter less often in the post-intervention period (55% versus 29%, odds ratio 0.34, [0.16–0.71]).
| | Physicians scored higher on measures of data gathering without the use of an interpreter (17.2 pre-test versus 22.4 post-test, p=0.01).
| | All but one of the physicians in the post-intervention period expressed increased confidence in addressing various emergency department chief complaints in Spanish.
| | Families in the post-intervention period were more likely to strongly agree that “the physician was respectful” (OR 3.0, [1.4–6.5]) than families in the pre-intervention period.
Nora, 1994 | Group interviews, Participant ratings, Written exam | Spanish language proficiency went from 60% pre-test to 75% post-test.
| | Using the misanthropy scale (which indicates openness to those not like oneself), there were no significant differences between intervention and control post course but there was a trend towards increased acceptance of others in the intervention group.
| | Students reported liking the opportunity to meet Mexicans and traditional healers.
| | Students were positive about their experience in Mexico; one reported that it exceeded their expectations. In comments six months later, four of the eight students who went to Mexico described the experience as life-changing.
| | Cultural knowledge of Hispanic health in the intervention group went from 40% precourse to 58% post course versus the control group 46% pre and 42% post (p=0.007).
Rubenstein, 1992 | Participant ratings, Written exam | Participants developed increased knowledge of ways physicians ignorance of patient's health beliefs can adversely affect clinical encounter (on Likert scale out of 5 points: pre-test 3.3, post-test 4.6 (p<0.0001)).
| | The curriculum scored a mean rating of 3.5 (0=lowest; 4=highest) in usefulness.
| | Participants developed increased knowledge about available resources to learn about non-conventional health beliefs (pre-test 3.8, post test 4.9 (p<0.0001)).
Sinnott, 2001 | Individuals interviews, Self-assessment forms | Interviews with 14 indigenous hospital liaison officers indicated that the program was perceived as beneficial by 100% of those interviewed.
Tang, 2002 | Self-assessment forms | After the intervention, the students reported increased understanding of the importance of incorporating sociocultural factors into patient care (p<0.01).
| | After the intervention, the students reported significantly increased understanding of the impact of sociocultural issues on the patient-physician relationship and on patients' health (p<0.001).
| | After the intervention, the students reported significantly greater understanding of the relationship among sociocultural issues, health, and medicine (p<0.001).
NURSE
Alpers, 1996 | Self-assessment forms, Bernol and Froman Cultural Self-Efficacy Scale | Intervention group has a greater confidence/competence in providing care to African-American and Hispanic clients.
| | Control group felt more confidence/competence in entering ethnically distinct community, and understanding Asian folk health practices than did the group who had received class content on culturalism.
Barton, 1992 | Weekly journal entries | Students gained an understanding of both differences and similarities between their own culture and that of the migrant farm workers.
| | Reflections on gaining awareness of the particular lifestyles of another culture were related to being able to observe and absorb ordinary events.
| | Students experienced growth by developing respect for the migrant community.
| | Students were incensed at inadequacies of the health care delivery system, and the insensitive and sometimes prejudicial treatment they saw their clients experience.
Berman, 1998 | Self-assessment forms | Between 44–91% of participants (depending on type of workshop attended) believed that, as a result of their participation in the program, they had 1) increased patient compliance, 2) shared knowledge with other providers, and 3) optimized use of existing resources.
Blackford, 2002 | Qualitative evaluation of group process | The process deepened nurses understanding of and insight into cultural biases regarding: 1 feminist expectations of gender roles, 2 gender equality, 3 patriarchy, 4 distinction between equity and equality, and 5 cultural sensitivity in nursing practice.
Bond, 1994 | Self-assessment forms | Students reported increased Spanish language skills.
| | Students learned a variety of field methods for data collection for qualitative research.
| | Students expressed surprise that health care, access, physical settings, and care modalities could be so different in a country bordering the U.S.
| | Students reported a better understanding of the circumstances from which Mexican clients enter the U.S. health care system.
| | Students learned a great deal about themselves, their beliefs, and their own values, coping styles, and resources.
| | Students reported increased knowledge about Mexican American cultural practices.
| | Many students were surprised at the common bond they shared with women of their Mexican families.
Campinha-Bacote, 1996 | Participant ratings | Approximately 90% of the participants rated the program as good to excellent.
Felder, 1990 | Written exam | No significant difference between freshmen and seniors nursing students in either program in attitudes towards black American clients.
| | Baccalaureate seniors scored significantly higher than freshmen on the cultural knowledge test of black American clients (p<0.001), however there were no differences in knowledge between freshmen and seniors in the associate degree program.
Flavin, 1997 | Essays, Participant ratings, Written exam | The curriculum received good scores for design, relevancy of information, and meeting participant expectations.
| | There were no significant changes in “learning scores” regarding knowledge of practices and values of four targeted cultures prior to and after the curriculum.
Frank-Stromborg, 1987 | Self-assessment forms, Cancer Attitude Inventory (CAI); Pittsburgh Attitude Survey (PAS); Activities survey | Activities survey reported increased community activities in cancer prevention and early detection.
| | Scores on the Pittsburgh Attitude Survey (PAS) self report measuring cancer attitudes improved from the pre-test (mean=81) to the post-test (mean=82, p<0.08).
| | 94% rated simulated practice with models as excellent to above average, 98% rated the speakers as excellent to above average, and 78% rated the program as excellent.
| | Scores on the Cancer Attitude Inventory (CAI) improved from pre-test (mean=132) to the post-test (mean=139, p<0.001).
Frisch, 1990 | Written exam, Measure of Epistemological Reflection (MER) | 5 out of 9 students that increased their scores on the Measure of Epistemological Reflection (MER) went on exchange to Mexico.
| | Seventy-one percent of the measured cognitive improvement seen in the senior class can be attributed to the Mexico program (p=0.018).
| | The Mexico exchange students were 3.5 times as likely to improve show cognitive improvement as measured by the Measure of Epistemological Reflection (MER) than were students that did not participate.
Hadwiger,1999 | Essays describing relationship with patient | The nursing students became more aware of how their own culture affects the nursing care they provide.
| | Emphasis was placed on the establishment of trust in the cross-cultural relationship in post-intervention essays.
| | Respect for the patient and the patient's culture was constantly shown in post-intervention essays.
| | Students were more likely to include the patient in exploring goals and interventions in post-intervention essays.
Haloburdo, 1998 | Individuals interviews | Students reported increased cultural sensitivity (in both those traveling to developed and developing countries), a recognition of universal human characteristics, and increased self-confidence.
| | Students identified an increased knowledge of sociopolitical resources influencing health care population based health programs, and international attitudes towards the U.S.
Inglis, 2000 | Written exam | Students who participated in the intervention showed significant shifts on 8 out of 23 attitudinal items towards more understanding of cross-cultural issues, whereas students in the control group showed no change on any items.
Jeffreys, 1999 | Self-assessment forms, Transcultural Self-Efficacy Tool | Practical (interviewing) subscale score on the Transcultural Self-Efficacy Tool increased between pre and post-test from 16 to 55% (p<0.001).
| | Affective subscale scores on the Transcultural Self-Efficacy Tool increased between pre and post-test from 16 to 43% (p<0.001).
| | Cognitive subscale scores on the Transcultural Self-Efficacy Tool increased between pre and post-test from 2 to 28% (p<0.001).
Jeffreys, 2002 | Participant ratings | Several students suggested inclusion of more complementary and alternative medicine.
| | Students reported learning the most from topics such as conceptual models, ethnopharmacology, multiple heritage individuals, and lesbian clients.
Lasch, 2000 | Written exam | Nurses participating in both intervention programs (workshop only and enriched model) significantly changed pain management attitudes (p=0.01), and maintained this change at 1 year follow-up, whereas the control group had no change.
| | Both intervention groups (workshop only and enriched model) significantly improved knowledge of cancer pain management over control group at post test and follow-up (p<0.0001).
Lindquist, 1984 | Participant ratings | A great deal of personal and professional growth experienced by nursing students who participated.
Lockhart, 1997 | Self-assessment forms | Participants reported positive long term influences on their ability to provide culturally sensitive nursing care.
Napholz, 1999 | Self-assessment forms, Written exam, Ethnic Competency Skills Assessment (ECSA) | Both groups significantly increased scores Ethnic Competency Skills Assessment (ECSA), however the experimental group increased much higher than the control group.
Oneha, 1998 | Participant ratings, Self-assessment forms | Students rated the curriculum as helpful in identifying and investigating issues and thinking critically and analytically.
| | Students reported greater awareness of societal problems.
| | Students reported a greater ability to solve real problems in this field.
| | Students reported re-examination of their former attitudes.
Rolls, 1997 | Individuals interviews, Qualitative analysis | Attitudes towards another culture, language, and religion changed to a level of acceptance and understanding.
| | Students reported increased self confidence.
Rooda, 1993 | Essays, Feedback | Department directors who participated thought the issue of culture, ethnic identity, and healthcare was timely and that they could use what they learned to educate their staff.
Ryan, 2000 | Group interviews | Students reported several strategies to use to “learn to care for clients in their world not mine”: preparation activities, dependencies or group support, use of coping skills, learning to communicate differently, live and think differently.
| | Students experienced personal and professional growth.
| | Students reported increased awareness of need to communicate in culturally sensitive ways.
| | Students report greater appreciation of the value of others.
Ryan, 2002 | Self-assessment forms | Participants reported that they gained insight into own (69%) and others' (86%) cultural beliefs.
| | Participants reported learning new ways of communicating (69%).
| | Participants reported increased awareness of culture in healthcare (91%).
| | Participants reported increased knowledge about health practices (89%).
Scisney-Matlock, 2000 | Self-assessment forms, 5 selected items measured with Michigan Longitudinal Study Scales (MLSS) | Knowledge of diversity gained through course work was not statistically significant different between experimental group and control group.
| | Intervention group showed statistically significant increase in activities devoted to understanding other racial/ethnic groups.
| | Intervention group showed statistically significant increase in self-reported social interactions with peers of different race/ethnicities.
| | Intervention group showed statistically significant increase in satisfaction with relevance of course work to their own ethnicity.
Smith, 2001 | Self-assessment forms, Written exam, Cultural Self-Efficacy Scale (CSES) | Questionnaire measuring knowledge of cultural diversity taken in 3 phases showed significant increases over time (p<0.001) in the intervention group and no improvement in the control group.
| | Cultural self-efficacy scale (CSES) taken in the 3 phases, showed significant improvements in self-efficacy (p<0.001) in the intervention group and no improvement in the control group.
St Clair, 1999 | Essays, Self-assessment forms, Journal; Field notes; Cultural Self-Efficacy Scale (CSES) | Continual growth in cultural self-efficacy scores for students in international clinical exercises (mean score 3.7) over those who remained in the US (mean score 3.3) in the follow-up testing period (p=0.007).
| | There was a statistically significant increase in cultural self-efficacy scores on the post-test in all students.
| | Students developed sensitivity to being a minority through international experience.
Underwood, 1999 | Participant ratings, Self-assessment forms | Since completing the program, many participants have designed and implemented a number of innovative cancer prevention programs.
| | Participants indicated more confidence in their ability to positively influence cancer prevention behaviors in practice and community.
| | Participants indicated that the curriculum changed their attitudes towards nurses role in cancer prevention and early detection.
| | Participants indicated increased knowledge of cancer prevention and early detection among African Americans.
Underwood, 2002 | Self-assessment forms | Between 33% to 50% of participants reported that their knowledge had substantially increased on a wide range of items (N=50) concerning five common cancers among African Americans.
Warner, 2002 | Group interviews | Students were able to identify common ground of human experiences.
| | Students expressed frustration over intractable health problems.
| | Students were able to contrast Navajo healing with Western ways.
Wendler, 2002 | Essays, Participant ratings | Almost all students said they would recommend the course to others.
| | Students rated the course process, activities, and outcomes highly.
Williamson, 1996 | Group interviews, Self-assessment forms, Written exam, Cultural Self-Efficacy Scale | Attitudes about cultural patterns. Showed sustained improvements in African American [begin 2.77 (0.66), middle 3.31 (0.72), end 3.61 (0.65)], Hispanics [begin 2.58 (0.70), middle 3.31 (0.70), end 3.69 (0.71)], and SE Asians [begin 2.28 (0.69), middle 3.64 (0.69), end 3.35 (0.77)] (p<0.001).
| | Students improved in transcultural skills (begin 3.29 (SD +/-0.69), middle 3.64 (SD +/-0.69), end 3.96 (SD +/-0.66) (p<0.001)).
| | Participants improved their knowledge of cultural concepts (beginning 2.92 (+/- 0.74), middle 3.49 (+/- 0.70), end 3.68 (+/- 0.66) (p<0.001)).
OTHER PROVIDERS/ MIXED GROUPS
Nurse, Physician, Receptionists, Volunteers, Business Office Staff
Gallagher Thompson, 2000 | Self-assessment forms, Written exam | Statistically significant increased referrals of Hispanic Alzheimer's patients and/or families to the appropriate specialized services about Alzheimer's disease (p<0.005).
| | Statistically significant increase in participants knowledge of Hispanic beliefs about Alzheimer's disease (p<0.05).
| | Statistically significant increase in participants general knowledge about Alzheimer's disease (p<0.005).
Nurse, Physician, Social Workers, Nurse's Aides, Receptionists, Clerks
Gany, 1996 | Written exam | There was a significant attitude shift on 12 item exam in which the mean score was 33.76 on the pre-test compared to 35.68 on the post-test (p<0.003).
| | There was a significant knowledge shift on 21 item scale exam about immigrant health in which students scored 15.8% correct in the pre-intervention period compared to 18.6% correct in the post-intervention period (p<0.0001).
Nurse, Pharmacist
Chevannes, 2002 | Self-assessment forms, Focus groups | After the intervention, 8/17 said that they were not able to bring about change in practice and 4/17 participants were able to identify areas of practice that had changed.
| | Qualitative: “I have become more conscious of stereotyping.”
| | Participants reported a better understanding of the concepts of ethnicity and race, and community resources available.
| | 82% believed that training added to their knowledge.
| | Participants reported the acquisition of confidence to engage with colleagues about different cultural values and practices.
Nurse, Pharmacist, Physician, Occupational Therapy, Physical Therapy, Health Administration
Erkel, 1995 | Participant ratings, Self-assessment forms | Interdisciplinary team interaction, exposure to new practice opportunities, and the community-oriented primary care project were the elements of the course that were most enjoyed by students.
| | Participants gained an increased awareness to barriers to care for rural clients.
| | Participants gained increased knowledge of rural, transcultural, and interdisciplinary issues; principles of case-management, patient focused care, and community oriented primary care.
| | Course evaluations revealed that classroom and field trips met student expectations.
| | 72% of students reported that the practicum influenced them to consider practicing in a rural setting.
| | Participants gained an appreciation for rural lifestyle.
Nurse, Pharmacist, Physician, Any Staff with Direct Patient Contact
Way, 2002 | Participant ratings, Patient rating, Self-assessment forms | After the intervention there was an increased perception among patients of seeing staff members of their ethnicity (p=0.04) and of finding magazines/reading materials on ward that contained information of interest (p=0.04). There was also a significant increase in patients' reporting that staff would see them as individuals (p=0.06).
| | There was a statistically significant increase in participants' perception that there were pictures on walls that may remind patients of family/friends (p=0.01), and that there were magazine/reading materials that contain information in which the patient may be interested (p=0.0001).
| | 58% of participants increased interest in learning patient and family background, and 59% of participants increased sensitivity to cultural competence.
| | 59% of participants increased awareness of special needs of recipients who do not speak English.
Community Health Workers, Undergraduate Students
Bengiamin, 1999 | Self-assessment forms, Open-ended questions | Students evidenced a greater awareness of the ever-changing and complex life stages across life's continuum through a transformational process of personal growth and emerging definition of culture.
| | After the intervention students understood the significance of recognizing socioeconomic status as a culture of its own.
| | Students gained the ability to view health care in a holistic manner.
Community Health Worker, Church Nurse Guild Members and Other Interested Community Organizations
Briscoe, 1999 | Self-assessment forms, Intent to take action form | At six months follow-up, 30% of nurse participants had fulfilled their intention compared to <10% of nurses in other groups.
| | After the curriculum, participants reported that they intended to arrange for a community group to take a diabetes risk test (71%), distribute diabetes material at community health fairs or church services (67%), present African-American Program modules (59%), promote health foods at pot luck suppers (56%), and arrange cooking or exercise classes (38%).
Social Workers
Browne, 2002 | Individuals interviews, Self-assessment forms | After the intervention, 100% felt competent about their role in an interdisciplinary team.
| | After the intervention, 100% believed that their style of practice was culturally competent.
| | After the intervention, 7 of 12 felt knowledgeable regarding elder abuse and the full range of social work interventions.
| | After the intervention, 100% agreed that they understood normal aging.
| | After the intervention, 11 of 12 agreed that they were knowledgeable about common ethical dilemmas, policy analysis, program evaluations, and resources development.
Psychologists
Hansen, 2002 | Written exam | Those who completed the program scored 88.3% on knowledge test, those who did not take the program (control) scored 75.3% (p<0.001).
Tomlinson-Clarke, 2000 | Individuals interviews, Participant ratings | Overall students perceived textbooks and reading as helpful in gathering understanding of multicultural issues.
| | Acquisition of multi-cultural knowledge was considered by participants to be useful and transferable in developing effective counseling interventions at 4 months follow-up.
| | Critical incidents that involved students' interactions with one another were most frequently cited as enhancing learning.
Mental Health Professionals
Stumphauzer, 1983 | Observer questionnaire, Participant ratings, Written exam | Trainees ability to do behavioral analysis and treatment plan increased significantly (p<0.01) from the pre-intervention period to the post-intervention period.
| | The course was seen by all trainees as having added “a greater deal” or “a considerable amount” to their knowledge base.
| | There were significant increases on a 23-item test measuring knowledge of behavioral modification principles, from 38% correct on pre-test to 68% correct on post-test (p<0.01).
Occupational Therapy
Velde, 2001 | Interviews | Qualitative/quotes from students/faculty: student quote - “I feel that Tillery people would prefer to see our differences and respect them for those differences rather than act as if we are the same.”
| | Qualitative/quotes from students/faculty: faculty quote - “I respect and value the differences I see between Tillery residents and myself.”
Counselors
Wade, 1991 | Patient rating, Barrett-Lennard Relationship Intervention; Counselor Effectiveness Scale; Counselor Rating Form | Brief culture sensitivity training produced significant differences in client perceptions of counselors and the counseling process and was more important than racial pairing.
| | Clients assigned to counselors in culture sensitivity training returned for more follow-ups (mean 2.88 versus 1.90).