# Appendix A: Search Strings and Priority Journals

Search Strategy for MEDLINE ^®^

((minority groups[mh] OR ethnic groups[mh] OR urban health[mh] OR urban population[mh] OR minority[tiab] OR urban[tiab] OR inner-city[tiab] OR black*[tiab] OR african american*[tiab] OR mexican*[tiab] OR native*[tiab] OR indian*[tiab] OR latina[tiab] OR latino[tiab]) AND (nurs*[tiab] OR physician*[tiab] OR health professional*[tiab] OR health care provider*[tiab] OR health personnel[mh]) AND (randomized controlled trial [pt] OR controlled clinical trial [pt] OR randomized controlled trials [mh] OR random allocation [mh] OR double-blind method [mh] OR single-blind method [mh]) NOT (animal [mh] NOT human [mh])) OR ((cultura*[tiab] OR multicultural[tiab] OR transcultural[tiab] OR divers*[tiab] OR cultural diversity[mh] OR transcultural nursing[mh] OR ethnic[tw] OR minority[tw]) AND (competen*[tiab] OR sensitiv*[tiab] OR attitude*[tiab] OR experience[tiab] OR knowledge[tiab]) AND (education[mh] OR ed[sh] OR educat*[tiab] OR train*[tiab] OR curriculum[tiab]) AND (nurs*[tiab] OR physician*[tiab] OR health professional*[tiab] OR health care provider*[tiab] OR student*[tiab])) AND eng[la] AND 1980:2003[dp] NOT review[pt]

Search Strategy for the Cochrane CENTRAL Register of Controlled Trials

1. (minority or ethnic or (inner next city) or cultural) (1980 to current date)
2. ((health next professional) or physician or nurse) (1980 to current date)
3. 1 and 2

Search Strategy for EMBASE

1. cultural.mp
2. “ETHNIC, RACIAL AND RELIGIOUS GROUPS”/ or ETHNIC DIFFERENCE/ or “ETHNIC OR RACIAL ASPECTS”/ or “ETHNIC AND RACIAL GROUPS”/ or ETHNIC GROUP/ or ethnic.mp.
3. MINORITY GROUP/ or minority.mp.
4. 1 or 2 or 3
5. exp EDUCATION/ or education.mp.
6. 4 and 5
7. health professional.mp. or Health Practitioner/
8. (physician or nurse).mp.
9. STUDENT/
10. 7 or 8 or 9
11. 6 and 10
12. cultural competence.mp
13. 11 or 12
14. limit 13 to (human and english language)

Search Strategy for the Cumulative Index of Nursing and Alliance Health Literature (CINAHL)

((minority in TI,AB or ethnic in TI,AB or urban in TI,AB or inner-city in TI,AB or “Cultural-Diversity” / all TOPICAL SUBHEADINGS / all AGE SUBHEADINGS in DE or “Minority-Groups” /all TOPICAL SUBHEADINGS /all AGE SUBHEADINGS in DE or “Ethnic-Groups” /all TOPICAL SUBHEADINGS /all AGE SUBHEADINGS in DE or “Urban-Health” /all TOPICAL SUBHEADINGS /all AGE SUBHEADINGS in DE) and (“Health-Personnel” / all TOPICAL SUBHEADINGS / all AGE SUBHEADINGS in DE or health care provider* in TI,AB or nurs* in TI,AB or physician* in TI,AB or health professional* in TI,AB) and (LA:NU = ENGLISH) and (PY:NU >= 1980) AND (“clinical trials” /all TOPICAL SUBHEADINGS /all AGE SUBHEADINGS in DE)) or ((“Education-” / all TOPICAL SUBHEADINGS / all AGE SUBHEADINGS in DE or educat* in TI,AB or train* in TI,AB or curriculum in TI,AB ) and ( “Transcultural-Nursing” / all TOPICAL SUBHEADINGS / all AGE SUBHEADINGS in DE or “Cultural-Diversity” / all TOPICAL SUBHEADINGS / all AGE SUBHEADINGS in DE or “Cultural-Sensitivity” / all TOPICAL SUBHEADINGS / all AGE SUBHEADINGS in DE or “Cultural-Competence” / all TOPICAL SUBHEADINGS / all AGE SUBHEADINGS in DE or ((cultura* in TI,AB or divers* in TI,AB) and (sensitiv* in TI,AB or attitude in TI,AB or knowledge in TI,AB or competen* in TI,AB))) and (“Health-Personnel” / all TOPICAL SUBHEADINGS / all AGE SUBHEADINGS in DE or “health care provider*” in TI,AB or nurs* in TI,AB or physician* in TI,AB or “health professional*” in TI,AB ) and (LA:NU = ENGLISH) and (PY:NU >= 1980))

Search Strategy for the Specialized Register of Effective Practice and Organization of Care Cochrane Review Group (EPOC)

(minority OR ethnic OR cultural OR urban)

Search Strategy for the Research and Development Resource Base in Continuing Medical Education (RDRB/CME)

- selected indexed and non-indexed fields
- OR'd terms together

minority

cultural

racial

Journals Hand Searched

Academic Medicine

Archives of Pediatric and Adolescent Medicine

Ethnicity and Disease

Health Services Research

Journal of the American Medical Association

Journal of General Internal Medicine

Journal of Health Care for the Poor and Underserved

Journal of Transcultural Nursing

Medical Care

Milbank Quarterly

New England Journal of Medicine

Pediatrics