# Evidence Tables

Evidence Table 1. Number of comparisons of diagnostic methods for acute bacterial rhinosinusitis included in the meta-analysis

| Puncture | Radiography | Ultrasound | Clinical Examination | Number of Comparisons for Each Diagnostic Method
Puncture | 0 | 6 | 4 | 1 | 12
Radiography | | 0 | 3 | 3 | 12
Ultrasound | | | 0 | 1 | 8
Clinical examination | | | | 0

Evidence Table 2. Studies comparing diagnostic methods for acute bacterial rhinosinusitis included in the meta-analysis

Diagnostic Comparisons | Number of Studies | Study(s)
Puncture vs ...
Radiography | 6 | Kuusela, Kurri, Sirola, 1982 van Buchem, Peeters, Beaumont et al., 1995 McNeill, 1962 Revonta, 1980 Savolainen, Pietola, Kiukaanniemi et al., 1997 Laine, Maatta, Varonen et al., 1998
Ultrasound | 4 | Kuusela, Kurri, Sirola, 1982 van Buchem, Peeters, Beaumont et al., 1995 Revonta, 1980 Savolainen, Pietola, Kiukaanniemi et al.,1997
Clinical examination | 1 | Berg and Carenfelt, 1988
Radiography vs ...
Ultrasound | 3 | Berg and Carenfelt, 1985 Rohr, Spector, Siegel et al., 1986 Jensen and von Sydow, 1987
Clinical examination | 3 | Axelsson and Runze, 1976 Jannert, Andreasson, Helin et al., 1982 Williams, Simel, Roberts et al., 1992
Ultrasound vs ...
Clinical examination | 1 | van Duijn, Brouwer, and Lamberts, 1992

Evidence Table 3. Summary of included studies comparing radiography with puncture for diagnosing acute bacterial rhinosinusitis

Study, Year Identifier ^1^ | Setting | Population | Diagnostic Methods | Diagnostic Criteria: Sensitivity / Specificity | Blinding of Test Interpretation
McNeill 1962 Sinusdx01 | Country: United Kingdom Location: hospital clinic Specialty: no data | 150 patients Age: 10-50+ Symptoms: no data Sx duration: no data | Puncture: of inferior meatus and sinus irrigated X-ray: occipitomental, occipitofrontal, & lateral | Based on number of sinuses Opacity of sinus: 41% / 85% Fluid or opacity: 76% / 76% Mucous membrane thickening or fluid or opacity: 97% / 21% | Puncture: not blinded X-ray: not blinded
Revonta 1980 82064726 | Country: Finland Location: hospital clinic Specialty: ENT | 230 sinuses Age: 7-71 Symptoms: no data Sx duration: no data | Puncture: of inferior meatus and sinus irrigated X-ray: occipitomental, occipitofrontal, & lateral | Based on number of sinuses Fluid or opacity Series 1: 71% / 92% Series 3: 80% / 80% | Puncture: no data X-ray: blinded
Kuusela 1982 Sinusdx02 | Country: Finland Location: military hospital Specialty: ENT, nurse | 105 military recruits Age: no data Symptoms: no data Sx duration: "acute" | Puncture: sinus irrigated X-ray: occipitomental, occipitofrontal, & lateral | Based on number of sinuses Fluid or opacity: 83% / 72% | Puncture: no data X-ray: no data
van Buchem 1995 34263670 | Country: Netherlands Location: office, hospital Specialty: primary, ENT | 113 patients Age: 18-60+ Symptoms: headache and/or nasal Sx duration: "acute" | Puncture: of inferior meatus and sinus irrigated X-ray: occipitomental, occipitofrontal, & lateral | Based on number of sinuses Mucous membrane thickening or fluid or opacity: 63% / 91% | Puncture: blinded X-ray: blinded
Laine 1998 98230889 | Country: Finland Location: office Specialty: primary | 39 patients Age: 16-68 Symptoms: no data Sx duration: < 30 days | Puncture: "antral puncture" and sinus irrigated X-ray: occipitomental, occipitofrontal, & lateral | Based on number of sinuses Radiologist's overall impression: 61% / 98% | Puncture: not blinded X-ray: blinded
Savolainen 1997 97434410 | Country: Finland Location: hospital clinic Specialty: ENT | 161 patients Age: 17-68 Symptoms: no data Sx duration: < 30 days | Puncture: aspirated and sinus irrigated X-ray: standard 3- or 4-view projections including Waters view | Based on number of sinuses Fluid or opacity: 53% / 77% Mucous membrane thickening or fluid or opacity: 93% / 62% | Puncture: no data X-ray: blinded

Abbreviations: ENT - ear, nose, and throat specialist; sx - symptoms

1 Medline or unique identifying number assigned by EPC. Only first author cited

Evidence Table 4. Summary of included studies comparing ultrasonography with puncture for diagnosing acute bacterial rhinosinusistis

Study, Year Identifier ^1^ | Setting | Population | Diagnostic Methods | Diagnostic Criteria: Sensitivity / Specificity | Blinding of Test Interpretation
Revonta 1980 82064726 | Country: Finland Location: hospital clinic Specialty: ENT | 430 sinuses Age: 7-71 Symptoms: no data Sx duration: no data | Puncture: of inferior meatus and sinus irrigated U/S: Series 1 - Echoview, A-mode, 6 Mhz frequency, 10 mm transducer diameter; Series 3 - Echoview and Sinuscan Proto Series 4 -Sinuscan Proto, 3 Mhz frequency, 10 mm transducer diameter | Based on number of sinuses Criteria not described Series 1: 87% / 91% Series 3: 94% / 72% Series 4: 92% / 81% | Puncture: not blinded U/S: no data
Kuusela 1982 Sinusdx02 | Country: Finland Location: military hospital Specialty: ENT,nurse | 105 military recruits Age: no data Symptoms: no data Sx duration: no data | Puncture: sinus irrigated U/S: Sinuscan A-mode, 3 Mhz frequency | Based on number of sinuses Back wall echo present Physician's impression: 71% / 64% Nurse's impression: 73% / 64% | Puncture: no data U/S: no data
van Buchem 1995 34263670 | Country: Netherlands Location: office, hospital Specialty: primary, ENT | 113 patients Age: 18-60+ Symptoms: headache and/or nasal Sx duration: no data | Puncture: of inferior meatus and sinus irrigated U/S: Aloka sector scanner, 5 Mhz frequency | Based on number of sinuses "Abnormal:" 54% / 94% | Puncture: blinded U/S: blinded
Laine 1998 98230889 | Country: Finland Location: office Specialty: primary | 39 patients Age: 16-68 Symptoms: no data Sx duration: < 30 days | Puncture: antral puncture and sinus irrigated U/S: Sinuscan 101, 3 Mhz frequency, 8 mm transducer diameter. Operator was an untrained physician | Based on number of sinuses "Maxillary sinusitis:" 61% / 53% | Puncture: blinded U/S: blinded
Savolainen 1997 97434410 | Country: Finland Location: hospital clinic Specialty: ENT | 161 patients Age: 17-68 Symptoms: no data Sx duration: < 30 days | Puncture: aspirated and sinus irrigated U/S: Sinuscan 102 A-mode, 3 Mhz frequency | Based on number of sinuses Fluid: 71% / 64% Mucous membrane thickening or fluid: 96% / 30% | Puncture: no data U/S: blinded

1 Medline or unique identifying number assigned by EPC. Only first author cited

Abbreviations: ENT - ear, nose, and throat specialist; sx - symptoms

Evidence Table 5. Summary of included studies comparing ultrasonography with radiography for diagnosing acute bacterial rhinosinusitis

Study, Year Identifier ^1^ | Setting | Population | Diagnostic Methods | Diagnostic Criteria: Sensitivity / Specificity | Blinding of Test Interpretation
Berg 1985 85239592 | Country: Sweden Location: hospital Specialty: ENT | 105 patients Age: 10-75 Symptoms: paranasal region and purulent ostial discharge Sx duration: < 90 days | X-ray: occipitomental, occipitofrontal, lateral, & axial U/S: Sinuson 810 A-mode | Based on number of patients Back wall echo present: 63% / 70% | X-ray: no data U/S: no data
Rohr 1986 86251847 | Country: USA Location: hospital Specialty: no data | 99 patients Age: 18-74 Symptoms: no data Sx duration: no data | X-ray: occipitomental, posteroanterior and lateral projections for most cases U/S: Echosine A-mode, 3.5 Mhz frequency, 13 mm transducer diameter Sinusvu 2500 A-mode, 3.5 Mhz frequency, 8 mm transducer diameter | Based on number of sinuses Back wall echo present Echosine: 60% / 92% Sinusvu: 29% / 95% | X-ray: blinded U/S: blinded
Jensen 1987 87185030 | Country: Sweden Location: hospital Specialty: ENT | 138 patients Age: adults, mean 33 Symptoms: fever and nasal discharge or other Sx duration: "acute" | X-ray: occipitomental, occipitofrontal, lateral, & axial in sinuses with no air, occipitomental in the decubitus position for pathologic findings with air in maxillary sinuses U/S: 3 types of A-mode U/S, 3 Mhz frequency, 13 mm transducer diameter for Sinuson 810 and Echosine 1000, and 10 mm transducer diameter for the Sinuscan 101 | Based on number of sinuses Fluid: 66% / 92% Mucous membrane thickening or fluid: 67% / 83% | X-ray: blinded U/S: blinded

1 MEDLINE or unique identifying number assigned by EPC. Only first author cited

Abbreviations: ENT - ear, nose, and throat specialist; sx - symptoms

Evidence Table 6. Summary of included studies comparing clinical examination with radiography for diagnosing acute bacterial rhinosinusitis

Study, Year Identifier ^1^ | Setting | Population | Diagnostic Methods | Diagnostic Criteria: Sensitivity / Specificity | Blinding of Test Interpretation
Axelsson 1976 77077896 | Country: Sweden Location: no data Specialty: ENT | 164 patients Age: average 35 Symptoms: no data Sx duration: "acute" | X-ray: occipitomental, occipitofrontal, lateral, & axial Clinical exam: Questionnaire, exam of nasal cavity & upper respiratory airways | Based on number of sinuses Overall impression: 39% / 70% | X-ray: no data Exam: no data
Jannert 1982 83030026 | Country: Sweden Location: no data Specialty: no data | 175 patients Age: 0-15 Symptoms: no data Sx duration: "acute" | X-ray: occipitomental, occipitofrontal, lateral, & occipitomental in lateral position Clinical exam: Risk score items - purulent nasal secretion, hx of upper respiratory infection prior 2 weeks, sinus pain or tenderness | Based on number of patients Risk score >1: 98% / 21% >2: 77% / 65% =3: 22% / 92% | X-ray: no data Exam: no data
Williams 1992b 93036949 | Country: USA Location: office Specialty: primary | 247 patients Age: median 50 Symptoms: rhinorrhea, facial pain, or self-suspected sinusitis Sx duration: <90 days, median 11.5 | X-ray: Waters, Caldwell, lateral, and submentovertex Clinical exam: Risk score items - maxillary toothache, abnormal transillumination, poor response to decongestants, purulent secretions, colored nasal discharge by history. Overall clinical impression | Based on number of patients Risk score >1: 96% / 22% >2: 80% / 58% >3: 51% / 86% >4: 17% / 97% = 5: 2% / 100% Overall impression Intermediate probability: 76% / 64% High probability: 40% / 90% | X-ray: blinded Exam: blinded

1 Medline or unique identifying number assigned by EPC. Only first author cited

Abbreviations: ENT - ear, nose, and throat specialist; sx - symptoms; hx - history

Evidence Table 7. Summary of included studies comparing clinical examination with puncture for diagnosing acute bacterial rhinosinusitis

Study, Year Identifier ^1^ | Setting | Population | Diagnostic Methods | Diagnostic Criteria: Sensitivity / Specificity | Blinding of Test Interpretation
Berg 1988a 88266684 | Country: Sweden Location: emergency room Specialty: ENT | 155 patients Age: mean 37.6 Symptoms: pus in middle meatus Sx duration: < 90 days | Puncture: "antral puncture" and aspiration Clinical exam: Risk score items - Purulent rhinorrhea with unilateral predominance, local pain with unilateral predominance, bilateral purulent rhinorrhea, presence of pus in nasal cavity | Based on number of patients Overall impression: 76% / 69% Risk score >1: 99% / 49% >2: 96% / 77% >3: 81% / 89% = 4: 24% / 97% | Puncture: no data Exam: blinded

1M Medline or unique identifying number assigned by EPC. Only first author cited

Abbreviations: ENT - ear, nose, and throat specialist; sx - symptoms

Evidence Table 8. Summary of included studies comparing clinical examination with ultrasonography for diagnosing acute bacterial rhinosinusitis

Study, Year Identifier ^1^ | Setting | Population | Diagnostic Methods | Diagnostic Criteria: Sensitivity / Specificity | Blinding of Test Interpretation
van Duijn 1992 93006464 | Country: Netherlands Location: office Specialty: primary | 400 patients Age: 15-65+ Symptoms: no data Sx duration: no data | U/S Echosine 1000 A-mode, 3.5Mhz frequency Clinical exam: 21 symptoms and 15 signs evaluated | Based on number of patients Criteria not described: 36% / 90% | U/S: Not blinded Exam: no data

1 Medline or unique identifying number assigned by EPC. Only first author cited

Abbreviations: ENT - ear, nose, and throat specialist; sx - symptoms

Evidence Table 9. Number of randomized controlled trials comparing antibiotic treatment for acute bacterial rhinosinusitis

[image] ^1^ Studies in outlined boxes were used in the meta-analysis

Evidence Table 10. Randomized controlled trials comparing antibiotic treatment for acute bacterial rhinosinusitis

Treatment Comparisons | | Number of Studies | Study(s)
Amoxicillin vs. ...
| Amoxicillin-clavulanate | 1 | Wald, Chiponis, and Ledesma-Medina, 1986
| Amoxicillin | 1 | Kment, Georgopoulos, Ridl et al., 1995
| Azidocillin | 1 | Axelsson, Jensen, Melin et al., 1981
| Azithromycin | 2 | Casiano, 1991 Felstead and Daniel, 1991
| Bacampicillin | 1 | Nord, 1988
| Brodimoprim | 1 | Nyffenegger, Riebenfeld, and Macciocchi, 1991
| Cefaclor | 2 | Wald, Reilly, Casselbrant et al., 1984 Huck, Reed, Nielsen et al., 1993
| Cefixime | 4 | Fiscella and Chow, 1991 Edelstein, Avner, Chow et al., 1993 Matthews and Suprax/Amoxicillin Clinical Study Team, 1997 Rimmer and Suprax/Amoxicillin Clinical Study Team, 1997
| Cefpodoxime | 1 | von Sydow, Savolainen, and Soderqvist, 1995
| Cefuroxime | 1 | Brodie, Knight, and Cunningham, 1989
| Clarithromycin | 2 | Karma, Pukander, Penttila et al., 1991 Calhoun and Hokanson, 1993
| Cyclacillin | 1 | Scheld, Sydnor, Farr et al., 1986
| Minocycline | 1 | Mattucci, Levin, and Habib, 1986
| Penicillin | 1 | Lindbaek, Hjortdahl, and Johnsen, 1996a
| Pivampicillin | 4 | Axelsson, Jensen, Melin et al., 1981 Moran, 1983 ^1^ Shenderey, Marsh, and Talbot, 1985 ^1^ Moorhouse, Hickey, and O'Hanrahan, 1985
| Placebo | 3 | Wald, Chiponis, and Ledesma-Medina, 1986 Lindbaek, Hjortdahl, and Johnsen, 1996a van Buchem, Knottnerus, Schrijnemaekers et al., 1997
Amoxicillin-clavulanate vs. ...
| Cefpodoxime | 1 | Camacho, Cobo, Otte et al., 1992
| Ceftibuten | 1 | De Abate, Perrotta, and Dennington, 1992
| Clarithromycin | 1 | Dubois, Saint-Pierre, and Tremblay, 1993
| Loracarbef | 1 | Sydnor, Scheld, Gwaltney et al., 1992
| Placebo | 1 | Wald, Chiponis, and Ledesma-Medina, 1986
Ampicillin vs. ...
| Doxycycline | 1 | Agbim, 1974
Azithromycin vs. ...
| Azithromycin | 1 | Ficnar, Huzjak, Oreskovic et al., 1997
| Cefaclor | 1 | O'Doherty, 1996
| Clarithromycin | 1 | Muller, 1993
| Erythromycin | 1 | Felstead and Daniel, 1991
| Penicillin | 1 | Haye, Lingaas, Hoivik et al., 1996
| Roxithromycin | 1 | Muller, 1996
Bacampicillin vs. ...
| Bacampicillin | 2 | Sorri, Peltomaki, and Jokinen, 1981 von Sydow, Einarsson, Grafford et al., 1981
Brodimoprim vs. ...
| Cephalexin | 1 | Bockmeyer, Riebenfeld, and Clasen, 1994
| Doxycycline | 4 | Salmi, Lehtomaki, and Kylmamaa, 1986 Arndt, Riebenfeld, Maier et al., 1994 Rahlfs, Macciocchi, and Monti, 1996 ^2^
| Roxithromycin | 1 | Manzini and Caroggio, 1993
Cefaclor vs. ...
| Cefuroxime | 1 | Sydnor, Gwaltney, Cocchetto et al., 1989
| Cefixime | 1 | Carenfelt, Melen, Odkvist et al., 1990
| Cefpodoxime | 1 | Gehanno, Depondt, Barry et al., 1990
| Cefetamet | 1 | Gauger, Inoka, Germano et al., 1990
Cefprozil vs. ...
| Amoxicillin-clavulanate | 1 | Russell, Nolen, Allen et al. 1997 (3 arms/2 dosages)
| Cefprozil | 1 | Russell, Nolen, Allen et al., 1997
Cefuroxime vs. ...
| Sparfloxacin | 1 | Gehanno and Berche, 1996
Clarithromycin vs. ...
| Roxithromycin | 1 | de Campora, Camaioni, Leonardi et al., 1992
Cyclacillin vs. ...
| Placebo | 1 | Ganança and Trabulsi, 1973
Doxycycline vs. ...
| Loracarbef | 1 | Scandinavian Study Group, 1993
| Placebo | 1 | Stalman, van Essen, van der Graaf et al., 1997
| Spiramycin | 1 | Boezeman, Kayser, and Siemelink, 1988
Erythromycin vs. ...
| Erythromycin | 1 | Wuolijoki, Flygare, Hilden et al., 1988 (3 arms/3 dosages)
Lincomycin vs. ...
| Irrigation | 1 | Axelsson, Chidekel, Grebelius et al., 1970
Loracarbef vs. ...
| Loracarbef | 1 | Zeckel, Johns, Masica et al., 1995
Methacycline vs. ...
| Placebo | 1 | Axelsson, Chidekel, Grebelius et al., 1971
Penicillin vs. ...
| Erythromycin | 2 | von Sydow, Axelsson, and Jensen, 1984 Soderstrom, Blomberg, Christensen et al., 1991
| Irrigation | 1 | Axelsson, Chidekel, Grebelius et al., 1970
| Lincomycin | 1 | Axelsson, Chidekel, Grebelius et al., 1970
| Methacycline | 1 | Axelsson, Chidekel, Grebelius et al., 1971
| Placebo | 2 | Axelsson, Chidekel, Grebelius et al., 1971 Wald, Chiponis, and Ledesma-Medina, 1986
| TMP/SMZ | 1 | Quick, 1975
Pivampicillin vs. ...
| Azidocillin | 1 | Axelsson, Jensen, Melin et al., 1981
| Placebo | 1 | Jeppesen and Illum, 1972
| Pivampicillin | 1 | Christensen and Hartmann, 1980
Tetracycline vs. ...
| Clindamycin | 1 | Westerman, Panzer, and Atkinson, 1975
| TMP/SMZ | 1 | Otte, Viada, Buchi et al., 1983
| Pivampicillin ^1^ | 1 | Beatson, Marsh, and Talbot, 1985
| vs. ^3^
Trimethoprim/ Sulfamethoxazole (TMP/SMZ) vs. ...
| Erythromycin | 1 | Federspil and Koch, 1983
| Pivampicillin ^1^ | 2 | Osman and Menday, 1983 Wallace, Marsh, and Talbot, 1985
| Sulphadiazine/TMP | 1 | Federspil and Bamberg, 1981
| TMP/SMZ | 1 | Williams, Holleman, Samsa et al., 1995

Evidence Table 11. Description of randomized controlled trials included in meta-analysis comparing placebo with antibiotics^1^

Author, Year Identifier ^2^ | Population & Setting | Design (Jadad score) | Treatment | Outcome
Axelsson 1970 70286389 | 156 Swedish patients (age 13-80) presenting signs & symptoms of acute sinusitis confirmed by X-ray. | Not blinded. (1) | 4 arms consisting of: (1) (nasal decongestant-oxymetazoline - 3 gtt 3 TID (2) (irrigation QOD & decongestant (3) (penicillin V -400 mg TID & decongestant for 10 days (4) (lincomycin - 500 mg TID & decongestant for 8 days | Assessments at day 5 and day 10 consisting of X-ray evaluation using a point system and subjective evaluation. The outcomes include: restored, improved, unimproved, and deteriorated for both visits.
Ganança 1973 74081204 | 50 adult Brazilian patients presenting inflammation of the sinus membrane and purulent nasal discharge that was culture positive. | Double blinded. (4) | 2 arms consisting of cyclacillin 500 mg TID vs placebo (similar preparation) TID for 7 days. | Global clinical rating consists of: very much improved, improved, and unchanged. The categories combined the ratings of symptoms, signs, and changes in nasal cytology.
Wald 1986 86232357 | 136 pediatric patients (age 2-16) were recruited from a U.S. children's hospital presenting symptoms < 30 days and diagnosis confirmed by X-rays. | Double-blinded. Patients were stratified by age and a clinical severity score was assigned based on symptoms & signs. (4) | 3 arms consisting of amoxicillin or amoxicillin-clavulanate potassium, 40 mg/kg/d 3 divided doses, or look-alike placebo for 10 days. Patients were prescribed antihistamine- decongestants. | Clinical assessment at day 3 and day 10. Using a 10-point questionnaire: cure - complete absence of symptoms (score <2 pt.); improved - half the original score, same; failure - worsening or persistence of symptoms.
Lindbaek 1996a 96343743 | 130 Norwegian GP patients (age 16-74) presenting symptoms < 30 days with a clinical diagnosis of acute sinusitis confirmed by CT. | Double-blinded. Patients were stratified by clinical severity score and by location of sinusitis. (5) | 3 arms consisting of penicillin V 1320 mg TID vs amoxicillin 500 mg TID vs placebo (similar in appearance) for 10 days. Patients were allowed decongestants and mild analgesics. | Patient self-assessment at day 3 and day 10 plus a daily diary. Categories include restored, much better, somewhat better, unimproved, and worse. Clinical follow up and severity assessment compared day 0 to day 10.
van Buchem 1997 97232963 | 214 adult Dutch GP patients presenting symptoms <90 days with a clinical diagnosis of acute sinusitis confirmed by X-rays were referred to the ENT clinic. | Double-blinded. Recorded were Hx, symptoms & signs, erythrocyte sedimentation rate, and leucocyte count with differential. (5) | 2 arms consisting of amoxicillin 750 mg TID vs placebo (similar to amoxicillin) TID for 7 days. Ancillary treatment consisted of xylometazoline steam inhalation, and paracetamol if necessary. | At week 1 and week 2, clinic visit with ENT for symptom scores and week 2, cure rate, along with X-rays. Cure was defined as having no symptoms. Additional follow up after 1 year if patients experienced recurrent symptoms.
Stalman 1997 98125140 | 192 patients (age 15-65) presenting signs & symptoms from 5 to 180 days were recruited for a multisite (12) GP study. | Double-blinded. (5) | 2 arms consisting of doxycycline, 100 mg BID day 1 and 100 mg/day for days 2-10 or placebo for 10 days. Ancillary tx as needed consisting of xylometazoline nose drops and 15-minute steam inhalation TID for both groups. If necessary, Paracetamol was allowed. | Using the McGill-Melzack Pain Questionnaire, the patient recorded onto a daily diary. An outcome of cure was defined: resolution of pain, resumption of daily activities, school/work and cessation of ancillary therapy. Assessments made of each arena.

1 Except folate Inhibitors

2 Medline or unique identifying number assigned by EPC. Only first author cited

Abbreviations: hx - history;. tx - treatment;. GP - general practice;. gtt - drops;. QOD - every other day;. BID - 2 times per day; TID - 3 times per day; QID - 4 times per day

Evidence Table 12. Description of randomized controlled trials included in meta-analysis comparing amoxicillin with other antibiotics 1

Author, Year Identifier ^2^ | Population & Setting | Design (Jadad score) | Treatment | Outcome
Wald 1984 84114106 | 50 pediatric patients (age 1-16) were recruited from a U.S. children's hospital, ER or ENT dept presenting symptoms <30 days and diagnosis confirmed by X-rays. | Double-blinded. (5) | 2 arms consisting of amoxicillin or cefaclor, 40 mg/kg/d three divided doses for 10 days. Patients were prescribed antihistamine & decongestants, Novafed and Afrin, TID. | Clinical assessment at 10-14 day. The outcomes include: cure - complete absence of fever, headache, cough, and nasal discharge or congestion, improvement - nearly complete resolution of clinical illness, symptom relapse - clinical cure followed by return of respiratory symptoms (while on tx), failure - worsening or persistence of symptoms on protocol.
Matucci 1986 86076561 | 58 patients (age 12-76) presenting symptoms & signs consistent with acute bacterial sinusitis, confirmed by X-rays and puncture. | Not blinded. (2) | 2 arms consisting of minocycline 100 mg BID vs amoxicillin 250 mg TID for 10 days with a 20- day option if clinically or bacteriologically indicated. Nasal decongestants and analgesics were allowed. | Overall clinical responses consisting of cured, improved, and failed. Bacteriologic results were categorized into, organism eliminated, or present. X-rays findings were categorized into, cleared, improved, and unchanged.
Wald 1986 86232357 | 136 pediatric patients (age 2-16) were recruited from a U.S. children's hospital presenting symptoms < 30 days and diagnosis confirmed by X-rays. | Double-blinded. Patients were stratified by age and a clinical severity score was assigned based on symptoms & signs. (4) | 3 arms consisting of amoxicillin or amoxicillin-clavulanate potassium, 40 mg/kg/d 3 divided doses, or look-alike placebo for 10 days. Patients were prescribed antihistamine-decongestants. | Clinical assessment at day 3 and day 10. Using a 10-point questionnaire: cure - complete absence of symptoms (score <2 pt.); improved - half the original score, same; failure - worsening or persistence of symptoms.
Brodie 1989 90184878 | 160 adult British patients (age 16 or greater) presenting signs & symptoms of acute sinusitis or acute on chronic sinusitis were recruited for a multicenter GP study. | Investigator-blinded. (2) | 2 arms consisting of cefuroxime axetil 250 mg BID vs amoxicillin 250 mg TID for 10 days. | Assessment conducted at day 10-14 and 10-20 days after treatment. Outcome response were categorized as: cured, improved, failure, or inaccessible.
Casiano 1991 92026154 | 78 patients (age 16-73) recruited for a multicenter (13) study with the diagnosis of acute maxillary sinusitis confirmed by transantral aspiration. | Investigator-blinded. (3) | 2 arms consisting of azithromycin 500 mg day 1, 250 mg/day on days 2-5 vs amoxicillin 500 mg TID for 10 days. | Clinical assessment at days 10-13, outcomes include: satisfactory - signs & symptoms resolved with no infection; improvement - signs & symptoms with infection; unsatisfactory - no apparent clinical response.
Felstead 1991 92084035 | 258 patients (age 17-76) recruited for an 8-center, 5- country, European study with clinical evidence of acute bacterial infection of the frontal and/or maxillary sinusitis. | Not blinded. Randomization list used. (3) | 2 arms consisting of azithromycin 500 mg for day 1, 250 mg/day on days 2-5 vs amoxicillin 500 mg TID for 10 days. | Clinical outcomes include: cured improved, and not cured. The following was assessed: total and differential leucocyte counts, signs & symptoms, and X-ray findings.
Karma 1991 91216883 | 100 Finnish and Swedish GP patients (age 17-69) presenting signs & symptoms & suggestive X-ray of acute sinusitis confirmed by antral puncture. | Patient-blinded. (2) | 2 arms consisting of clarithromycin 500 mg BID vs amoxicillin 500 mg TID for 10 days. 0.05% oxymetazoline nasal spray was allowed twice daily for the first 3 days. | Clinical assessment on days 10-12, outcomes include: cure - pre-tx signs & symptoms resolved; improved - improvement incomplete resolution of infection; failure - persistence of pre-tx signs & symptoms; or undetermined - outcome is unevaluable. X-ray categories: resolved - no evidence of sinusitis; improved - no change, worse.
Fiscella 1991 Sinustx05 | 33 patients (age ^3^ 18) were diagnosed with acute bacterial sinusitis or acute exacerbation on chronic sinusitis were enrolled at a university ENT clinic. | Single-blinded. The pharmacy was not blinded to the patient allocation to treatment arms,although the patient and physician were blinded. (1) | 2 arms consisting of cefixime 400 mg QD or amoxicillin 500 mg TID for 10 days. Use of nasal decongestant was allowed if appropriate. | Clinical outcomes include: cure - symptoms resolved & no evidence of infection; improvement - symptoms substantially alleviated with evidence of infection; failure - no response to tx;, relapse - clinical improvement followed by deterioration during tx; or nonevaluable - failure to return.
Edelstein 1993 93133048 | 114 patients (age 18-73) were recruited for a multisite study presenting signs & symptoms <182 days and diagnosis of acute or acute on chronic sinusitis confirmed by X-ray. | Not blinded. (1) | 2 arms consisting of cefixime 400 mg/day vs amoxicillin 500 mg TID for 10 days. Physician discretion for patients with resistant organisms to receive amoxicillin-clavulanate potassium 500 mg TID. No ancillary treatments allowed. | Clinical outcomes include: cured - symptoms resolved & no evidence of infection; improved - symptoms substantially alleviated with evidence of infection; failure - no response to tx; and relapse - clinical improvement during or after tx followed by deterioration.
Huck 1993 94163345 | 108 patients (age 17-69) presenting signs & symptoms of acute (<14 days), recurrent, or chronic sinusitis confirmed by X-ray. Antral puncture conducted for microbiologic tests. | Double-blinded. Patient data was stratified by chronicity of sinusitis. (3) | 2 arms consisting of cefaclor 500 mg BID vs amoxicillin 500 mg TID for 10 days. | Clinical outcomes were categorized as: improvement - signs & symptoms improved or resolved; failure - obvious therapeutic failure, and relapse - presence of signs & symptoms that recurred.
Calhoun 1993 94154893 | 142 U.S. and Canadian patients (age 14-77) recruited from 4 primary care centers were diagnosed with acute maxillary sinusitis confirmed by sinus X-ray. | Investigator-blinded. (2) | 2 arms consisting of clarithromycin 500 mg BID vs amoxicillin 500 mg TID for 7-14 days. All patients used 0.05% oxymetazoline nasal spray twice daily for the first 3 days. | Clinical outcomes were categorized as: cure - signs & symptoms resolved; improved - signs & symptoms lessened, but unresolved; failure - signs & symptoms unchanged or worsened; relapse - worsening or recurrence of signs & symptoms within 6 week follow up; and indeterminate - not evaluable. X-ray results classified as: resolved, Improvement, no change, and worsening.
von Sydow 1995 96143362 | 286 patients (age 18-78) from Sweden, Finland and Norway recruited for a multisite study, presenting signs & symptoms <30 days consistent with acute sinusitis confirmed by X-ray and puncture for those X-ray findings of opaque sinuses. | Double-blinded. Pre- and posttreatment X-rays were scaled and compared. (4) | 2 arms consisting of cefpodoxime 200 mg BID vs amoxicillin 750 mg BID for 10 days. Patients received xylometazoline for 7 days or less. | Clinical assessment at 11-20 days compared with pre-tx exam. Categories include: satisfactory - absence of clinical signs & absence or improvement of X-ray signs/points; improved - clinical signs improved, & improved or unchanged X-ray signs/points; unsatisfactory - clinical & X-ray signs/points unchanged or worsened.
Matthews 1997 Sinustx01 | 182 patients (age 18-78) presenting signs & symptoms consistent with acute sinusitis were recruited from 9 U.S. medical centers. Dx was confirmed by X-ray and puncture. | Not blinded. Cases with chronic or acute exacerbation of chronic sinusitis were enrolled but not clinically evaluable. (2) | 2 arms consisting of cefixime 400 mg QD vs amoxicillin 500 mg TID for 10 days. Nasal decongestants and/or an additional 4 days of tx drugs given at the investigator's discretion. | Clinical response categorized as success; consisting of cure or improvement (absence or substantially diminished signs/symptoms), or failure, consisting of relapse or failure (significant improvement followed by deterioration or no or minimal response to tx).
Rimmer 1997 Sinustx02 | 323 patients (age ^3^18) from 19 community centers in the UK were recruited, provided that they had uncomplicated acute sinusitis for a duration 3 weeks. | Double-blinded, parallel group. (3) | 2 arms consisting of cefixime 200 mg/day plus a matched placebo BID vs amoxicillin 250 mg TID for 10 days. | Clinical response categorized as success, consisting of cure or improvement, or failure, consisting of relapse or failure. Patients had at least 3 days of tx if judged a clinical failure.

1 Except folate inhibitors

2 > MEDLINE or unique identifying number assigned by EPC. Only first author cited

Abbreviations: ER - emergency room; ENT - ear, nose and throat specialist; hx - history; tx - treatment; GP - general practice; Gtt - drops; QD - every day; QOD - every other day. BID - 2 times per day; TID - 3 times per day. QID - 4 times per day

Evidence Table 13. Description of randomized controlled treatment trials included in meta-analysis comparing folate inhibitors with other antibiotics

Author, Year Identifier ^1^ | Population & Setting | Design (Jadad score) | Treatment | Outcome
Otte 1983 84273842 | 43 Chilean patients (age 17-56) presenting signs & symptoms of acute bacterial diagnosed by their ENTs, confirmed by X-ray and nasal swab. | Double-blinded. (3) | 2 arms consisting of tetracycline 500 mg QID vs sulfamethopyrazin 200 mg - trimethoprim 250 mg daily (2 tablet loading on day 1) for 10 days. | Global assessment includes categories: cured - clinically better, normal X-rays and sterile culture; improved - clear or much better symptoms by day 5, improved X-rays, and sterile culture; no change - persistence of some symptoms, abnormal X-rays, and positive culture; and failure - no improvement after therapy.
Osman 1983 Sinustx03 | 186 UK patients (age 11-76) were recruited from ENT dept of 3 general hospitals, 106 with sinusitis and/or rhinitis. | Investigator-blinded. Signs & symptoms were recorded and scaled. (2) | 2 arms consisting of Miraxid 450 mg BID vs co-trimoxazole 960 mg BID for 10 days. | Clinical assessment consisting of: success, improved, or failed.
Wallace 1985 86080813 | 318 British patients (age 10-76) presenting with signs & symptoms of acute upper respiratory tract infections to their general practitioner were recruited for a multicenter study. | Investigator-blinded. The patients were stratified into four diagnostic groups, including sinusitis, otitis media, throat infections, and bronchitis. (2) | 2 arms consisting of 250 mg pivampicillin plus 200 mg pivmecillinam hydrochloride BID vs 800 mg sulphamethoxazole plus 160 mg trimethoprim BID for 7 days. | Follow up at 1 week with overall assessment to treatment scaled: cured - presenting symptoms or signs no longer present; improved - presenting symptoms or signs less but not completely resolved; and failed - presenting symptoms or signs no better or worse.
Salmi 1986 86247086 | 60 Finnish conscripts (age 18-28) hospitalized for acute respiratory tract infections of known or suspected bacterial etiology. | Double-blinded. All patients had X-rays and possible pathologic findings were monitored until normalization confirmed. Data were stratified by disease. (5) | 2 arms consisting of brodimoprim 400 mg for 1 day followed by 200 mg/day for 10 days vs doxycycline 200 mg followed by 100 mg/day for 10 days. | Clinical assessment consisting of: cure, improved, or failure.
Manzini 1993 94253884 | 74 Italian ENT patients (age 18-65) diagnosed with acute frontal sinusitis and antritis of bacterial origin. | Not blinded. (1) | 2 arms consisting of 200 mg/day brodimoprim (400 mg loading dose on day 1) vs roxithromycin 150 mg BID for a maximum of 12 days. | Clinical data collected and scored for facial pain, headache, nasal stiffness, hyposmia, and nasal secretion. Clinical efficacy was categorized as success, improvement, and failure.
Arndt 1994 95165185 | 70 patients (age 20-60) presenting signs & symptoms were recruited to the ENT dept of a German university hospital for acute sinusitis confirmed by and X-ray and positive culture by swab. | Not blinded. (2) | 2 arms consisting of brodimoprim 200 mg/day vs doxycycline 100 mg/day for 8-12 days. 53 patients received concomitant medications, mainly nasal decongestants. | Overall clinical findings resolution at end of study defined as: cure - complete regression of clinical signs/symptoms; improvement - clear regression of clinical signs within 4-5 days with incomplete; and failure - an apparent response or deterioration.
Bockmeyer 1994 95073260 | 49 European patients (age 19-74) presenting signs & symptoms of acute sinusitis confirmed by transillumination and positive culture of nasal discharge by swab. | Not blinded. (2) | 2 arms consisting of 200 mg brodimoprim/day (400 mg loading dose on day 1) vs 500 mg cephalexin TID for 8-12 days. Mucolytic nose drops and steam inhalations were permitted. | Overall clinical response was defined as: cure - complete absence of pretreatment signs/symptoms; improvement - clear improvement of clinical symptoms but not completely resolved; failure - no apparent response to treatment or deterioration.
Rahlfs ^2^ 1996 Sinustx04 | 27 evaluable patients enrolled in a single center German study. Age 16-75 and diagnoses including acute, recurrent, and acute exacerbation of sinusitis, per protocol | Not blinded, parallel group. (2) | 2-arm study consisting of brodimoprim 400 mg loading, then 200 mg BID vs doxycycline 200 mg loading, then 100 mg QID. Mean days (range); 8.4, (6-11) and 9.1 (9-12), respectively. | Global clinical assessment consisting of: cure - complete resolution of clinical signs/symptoms; improvement - clear regression of clinical signs/symptoms; and failure - no apparent response or deterioration.
Rahlfs ^2^ 1996 Sinustx04 | 22 evaluable patients enrolled in a single center Swedish study. Age 16-75 and diagnoses including acute, recurrent, and acute exacerbation of sinusitis, per protocol. | Not blinded, parallel group. (2) | 2-arm study consisting of brodimoprim 400 mg loading, then 200 mg BID vs doxycycline 200 mg loading, then 100 mg QID. Mean days (range); 12.2, (9-16) and 12.3 (8-20), respectively. | Global clinical assessment consisting of: cure - complete resolution of clinical signs/symptoms; improvement - clear regression of clinical signs/symptoms; and failure - no apparent response or deterioration.

1 Medline or unique identifying number assigned by EPC. Only first author cited

2 Individual study data extracted from meta-analysis by Rahlfs

Abbreviations: hx - history; tx - treatment; GP - general practice; Gtt - drops; QOD - every other day; BID - 2 times per day; TID - 3 times per day; QID - 4 times per day

Evidence Table 14. Description of randomized controlled treatment trials included in meta-analysis comparing penicillin with other antibiotics^1^

Author, Year Identifier ^2^ | Population & Setting | Design (Jadad score) | Treatment | Outcome
Axelsson 1970 70286389 | 156 Swedish patients (age 13-80) presenting signs & symptoms of acute sinusitis confirmed by X-ray. | Not blinded. (1) | 4 arms consisting of: nasal decongestant-oxymetazoline - 3 gtt 3 TID irrigation QOD & decongestant (penicillin V -400 mg TID & decongestant for 10 days (lincomycin - 500 mg TID & decongestant for 8 days | Assessments at day 5 and day 10 consisting of X-rays evaluation using a point system and subjective evaluation. The outcomes include: restored, improved, unimproved, and deteriorated for both visits.
von Sydow 1984 85114999 | 100 Swedish patients (mean age 33, 36) presenting signs & symptoms 28 days of acute maxillary sinusitis, confirmed by X-ray. | Double-blinded. (4) | 2 arms consisting of erythromycin 500 mg BID vs penicillin V 1.6 g BID for Nasal decongestants (Nezeril, Draco) allowed. | Clinical outcomes include: recovered - no symptoms, normal nasal mucous membranes; improved - negligible symptoms and/or catarrhal mucous membranes without purulent discharge; failure - symptoms and/or purulent discharge.
Lindbaek 1996a 96343743 | 130 Norwegian GP patients (age 16-74) presenting symptoms <30 days with a clinical diagnosis of acute sinusitis confirmed by CT. | Double-blinded. Patients were stratified by clinical severity score and by location of sinusitis. (5) | 3 arms consisting of penicillin V 1320 mg TID vs amoxicillin 500 mg TID vs placebo (similar in appearance) for 10 days. Patients were allowed decongestants and mild analgesics. | Patient self-assessment at day 3 and day 10 plus a daily diary. Categories include: restored, much better, somewhat better, unimproved, and worse. Clinical follow up and severity assessment conducted at day 10 compared with day 0.
Haye 1996 97151573 | 438 Norwegian GP patients (age 19-71) presenting signs & symptoms 11 <30 days with a diagnosis of acute maxillary sinusitis confirmed by X-ray, were recruited for a multisite study. | Double-blinded, double-dummy, parallel group. Computerized randomization in blocks of six to one of two arms. (5) | 2 arms consisting of azithromycin 500 mg for 3 days and 2 placebo tablets TID for 10 days vs penicillin V two 660 mg tablets TID for 10 days and one placebo tablet for 3 days. | Assessments at 3-5, 10-12, & 23-27 days. Clinical outcomes include: cure - absence of all pre-tx signs & symptoms; improvement - partial resolution of pre-tx signs & symptoms; failure - no change or worsening of pre-tx symptoms.

1 Except folate inhibitors

2 Medline or unique identifying number assigned by EPC. Only first author cited

Abbreviations: hx - history;. tx - treatment; GP - general practice; Gtt - drops; QOD - every other day; BID - 2 times per day; TID - 3 times per day; QID - 4 times per day

Evidence Table 15. Diagnostic criteria^1^ for acute bacterial rhinosinusitis in studies used in meta-analysis comparing placebo with antibiotics^1^

Author, Year Identifier ^3^ | Maximum No. of Days Symptoms Allowed | X-ray - Dx Criteria | Puncture - Dx Criteria | Nasal Swab & Culture | Comments
Axelsson 1970 70286389 | Acute ^4^ | Positive: demonstrated secretion | - | - | Puncture performed on 55 (35%) opaque maxillary sinuses to demonstrate secretion
Ganança 1973 4081204 | Acute ^4^ | - | - | Positive bacteria culture | 100% sinus membrane inflammation w/purulent nasal discharge
Wald 1986 86232357 | 10 - 30 | Abnormal: air-fluid level, partial or complete opacification, or at least 4 mm thickening | - | - | Transillumination
Lindbaek 1996a 96343743 | 30 | - | - | - | CT positive: presence of fluid level or total opacification
van Buchem 1997 97232963 | <90 mean duration 2.2 weeks | Positive: opacity, air-fluid level, and/or mucosal thickening >5 mm | - | - | -
Stalman 1997 98125140 | 5 - 180 | - | - | - | -

1 All presenting signs and symptoms

2 Except folate inhibitors

3 MEDLINE or unique identifying number assigned by EPC. Only first author cited

4 Defined by author

Evidence Table 16. Diagnostic criteria^1^ for acute bacterial rhinosinusitis in studies used in meta-analysis comparing amoxicillin with other antibiotics^1^

Author, Year Identifier ^3^ | Maximum No. of Days Symptoms Allowed | X-ray - Dx Criteria | Puncture - Dx Criteria | Nasal Swab & Culture | Comments
Wald 1984 84114106 | 30 | Abnormal: air-fluid level, partial or complete opacification, or at least 4 mm thickening | - | - | Hx "severe" or "persistent" respiratory symptoms, 100% pts had puncture but not used in diagnosis criteria
Matucci 1986 86076561 | Acute ^4^ | 0-clear, 1-slight, 2-moderate, 3-severe | Positive culture by aspiration of maxillary antrum or rinse of sinus cavity | - | -
Wald 1986 86232357 | 10 - 30 | Abnormal: air-fluid level, partial or complete opacification, or at least 4 mm thickening | - | - | Transillumination
Brodie 1989 90184878 | Acute | - | - | - | -
Casiano 1991 92026154 | Acute | - | Positive culture by transantral aspiration of maxillary sinus | - | Pt included in study only if organisms are susceptible to both study medications
Felstead 1991 92084035 | Acute | | - | Unspecified # of pts | "Acute bacterial infection of the frontal and/or maxillary sinus," concurrent diseases allowed-18%
Karma 1991 91216883 | Acute ^4^ | "Suggestive" of sinusitis | To confirm presence of fluid and susceptibility of bacterial culture | - | Pt included in study only if organisms are susceptible to both study medications
Fiscella 1991 Sinustx05 | Acute ^4^ | Positive: opacification or airfluid level | To obtain specimens for bacterial culture & sensitivity | - | Investigator given discretion to change the therapy based on culture results. Symptom duration<28 days except 2 patients in each arm.
Edelstein 1993 93133048 | Patient' symptoms ranged from 1 to 182 days. Mean duration 23-24 days. | Positive: opacity, air-fluid level, and/or mucosal thickening>5 mm | - | - | Investigator given some discretion to change the therapy based on culture results
Huck 1993 94163345 | <14 | Positive: opacity, air-fluid level, and/or mucosal thickening at lateral angle of sinus | - | - | 100% of pts had antral puncture for culture specimen, diagnosis not based on puncture
Calhoun 1993 94154893 | Acute ^4^ | Clear, mucosal thickening, or air-fluid level, but criteria not clearly stated | - | - | -
von Sydow 1995 96143362 | <30 | Positive: "secretion" | - | - | Totally opaque sinuses from X-rays findings punctured to confirm diagnosis
Matthews 1997 Sinustx01 | Acute | Positive: opacity or air-fluid level | Antral puncture to confirm susceptibility of bacterial culture | - | Pt included in study only if organisms are susceptible to both study medications
Rimmer 1997 Sinustx02 | 21 | N/A | - | - | Culture taken, method not described

1 All presenting signs and symptoms

2 Except folate inhibitors

3 MEDLINE or unique identifying number assigned by EPC. Only first author cited

4 Defined by author

Evidence Table 17. Diagnostic criteria^1^ for acute bacterial rhinosinusitis in studies used in meta-analysis comparing folate inhibitors with other antibiotics

Author, Year Identifier ^2^ | Maximum No. of Days Symptoms Allowed | X-ray - Dx Criteria | Puncture - Dx Criteria | Nasal Swab & Culture | Comments
Otte 1983 84273842 | Acute ^3^ | N/A | - | 100% positive culture only | -
Osman 1983 Sinustx03 | Acute ^3^ | - | - | - | -
Wallace 1985 86080813 | Acute ^3^ mean duration 5.7 days | - | - | - | "An acute respiratory tract infection...suitable for Abx Tx"
Salmi 1986 86247086 | Acute ^3^ | - | - | -
Manzini 1993 94253884 | Acute ^3^ | - | - | - | "Diagnosis of acute frontal-maxillary sinusitis of bacterial origin," nasal discharge cultured
Arndt 1994 95165185 | Acute ^3^ | N/A | - | 100% positive culture only | -
Bockmeyer 1994 95073260 | Acute ^3^ | - | - | Positive bacterial culture of nasal discharge | Transillumination
Rahlfs 1996 Sinustx04 | Acute ^3^ | - | - | - | Patient excluded if bacterial isolates (when obtained) were drug resistant

1 All presenting signs and symptoms

2 MEDLINE or unique identifying number assigned by EPC. Only first author cited

3 Defined by author

Abbreviations: dx - diagnosis; tx - treatment

Evidence Table 18. Diagnostic criteria^1^ for acute bacterial rhinosinusitis in studies used in meta-analysis comparing penicillin with other antibiotics^1^

Author, Year Identifier ^3^ | Maximum No. of Days Symptoms Allowed | X-ray - Dx Criteria | Puncture - Dx Criteria | Nasal Swab & Culture | Comments
Axelsson 1970 70286389 | Acute ^4^ | Positive: demonstrated secretion | - | - | Puncture performed on 55 (35%) opaque maxillary sinuses to demonstrate secretion
von Sydow 1984 85114999 | <28 | Positive: secretion | - | - | Totally opaque sinuses from X-rays findings punctured to confirm diagnosis
Lindbaek 1996a 96343743 | <30 | - | - | - | CT positive: presence of fluid level or total opacification
Haye 1996 97151573 | 11 <30 | Positive: opacity, air-fluid level, or mucosal thickening >6 mm | - | - | -

1 All presenting signs and symptoms

2 Except folate inhibitors

3 MEDLINE or unique identifying number assigned by EPC

4 Defined by author

Abbreviation: dx - diagnosis

Evidence Table 19. Results of randomized controlled trials included in meta-analysis comparing placebo with antibiotics^1^

Author, Year Identifier ^2^ | Results ^3^ :Percentage Cure or Improved (number / total) | Discontinuation Due To Major Adverse Events (no. of events) | Minor Adverse Events (no. of events) | Additional Comments / Data
Axelsson 1970 70286389 | Placebo: 71.8% (23/32) Irrigation: 80.5% (29/36) Penicillin V: 82.8% (29/35) Lincomycin: 84.6% (33/39) | None | Placebo: nausea (2) Irrigation: epistaxis after puncture (2) Penicillin V: nausea (2), stool (1) Lincomycin: loose bowel movement (27) | At day 5 and day 10, all arms showed radiograph improvement.
Ganança 1973 74081204 | Cyclacillin: 93% (28/30) Placebo: 55% (11/20, "improved" only) | None | Cyclacillin: abdominal discomfort (1), diarrhea (1), headache (1) Placebo: of upper abdominal pain (1), perianal cutaneous rash (1) | -
Wald 1986 86232357 | Amoxicillin: 83.3% (25/30) Amoxicillin-clavulanate potassium: 75.0% (21/28) Placebo: 60.0% (21/35) | Amoxicillin: pruritic erythematous rash (1) Amoxicillin-clavulanate potassium: diarrhea (5) Placebo: pruritic erythematous rash (1), diarrhea (1) | No additional data | For tx arms combined or analyzed separately, tx patients more likely to be cured than placebo patients, p<0.01 and p<0.05, 3 and 10 days, respectively.
Lindbaek 1996a 96343743 | Penicillin V: 82.1% (32/39) Amoxicillin: 88.6% (39/44) Placebo: 56.8% (25/44) | 12 patients discontinued tx; 3 had severe GI events & withdrew, 6 placebo cases were given amoxicillin & 1 was given penicillin V. 2 amoxicillin patients were given doxycycline. | More than half in tx had adverse events, mainly diarrhea. | Mean duration of sinusitis: Amoxicillin: 9 days Penicillin: 11 days Placebo: 17 days Mean (95% CI) reduction of clinical severity scores: Amoxicillin: 5.5 (4.9, 6.0) Penicillin V: 5.4 (5.0, 5.8) Placebo: 3.4 (2.8, 4.0)
van Buchem 1997 97232963 | Amoxicillin: 83% (87/105) Placebo: 77% (78/101) | Amoxicillin: none Placebo: (1) | Mostly gastrointestinal or rash Amoxicillin: 28% Placebo:9% | The clinical scores for week 1 and 2 and the mean differences between baseline and follow up scores were the same for both arms. The mean improvement for X-rays for both arms were similar.
Stalman 1997 98125140 | All patients: 60% / 85% (cured / improved) | Doxycycline: (4) Placebo: none | Including major adverse events - Doxycycline: nausea (9), vomiting (5), abdominal pain (5), diarrhea (2), rash (2), dizziness (1) Placebo: nausea (2) | Median day (95% CI) for the cessation/resumption of these areas:: Doxycycline Placebo Pain 4 5 daily activities5 6 school/work 6 4 analgesics 5 7 nose drops 7 8

1 Except folate inhibitors

2 MEDLINE or unique identifying number assigned by EPC. Only first author cited

3 Clinical or global evaluation

Abbreviations: GI - gastrointestinal; tx - treatment; CI - confidence interval

Evidence Table 20. Results of randomized controlled trials included in meta-analysis comparing amoxicillin with other antibiotics ^1^

Author, Year Identifier ^2^ | Results ^3^ : Percentage Cure or Improved (number / total) | Discontinuation Due To Major Adverse Events (no. of events) | Minor Adverse Events (no. of events) | Additional Comments / Data
Wald 1984 84114106 | Amoxicillin: 85.2% (23/27) Cefaclor: 86.9% (20/23) | Unknown | Amoxicillin: urticarial rash (1) "significant adverse event" unknown if patient withdrew Cefaclor: none | Pretherapy maxillary sinus aspirates from 79 sinuses in 50 children yield "notable" bacterial growth in 51 (65%) sinuses. S. pneumoniae, B. catarrhalis, and H. influenzae were common agents. Radiographic outcomes were the similar in either arms.
Matucci 1986 86076561 | Minocycline: 100%(25/25) Amoxicillin: 95.4% (21/22) | Minocycline: upset stomach (1), nausea (1) Amoxicillin: 1 hives (1), sternal pressure (1) | Minocycline: GI-related (3) Amoxicillin: skin-related (4) | Minocycline: no organism present X-ray clear & improved - 90.9% (20/22) Amoxicillin: 95.2% (20/21) organisms eliminated X-ray clear & improved - 70% (14/20)
Wald 1986 86232357 | Amoxicillin: 83.3% (25/30) Amoxicillin-clavulanate potassium: 75.0% (21/28) | Amoxicillin: pruritic erythematous rash (1) Amoxicillin-clavulanate Potassium: diarrhea (5) | No additional data | For tx arms combined or analyzed separately, tx patients more likely to be cured than placebo patients, p<0.01 and p<0.05, 3 and 10 days, respectively.
Brodie 1989 90184878 | Cefuroxime axetil: 95.5% (43/45) Amoxicillin: 94.2% (49/52) | Cefuroxime axetil: GI-related (3) Amoxicillin: GI-related (3) | No additional data | -
Casiano 1991 92026154 | Azithromycin:100% (23/23) Amoxicillin: 100% (15/15) | None | Azithromycin: headache (2) & nausea (1) for 2 patients Amoxicillin: GI-related (3) | -
Felstead 1991 92084035 | Azithromycin: 97.5% (120/123) Amoxicillin:98.3%(119/121) | Azithromycin: none Amoxicillin: 3 patients for vaginitis, rash, or urticaria | Mostly GI-related Azithromycin:5% Amoxicillin:11% | -
Karma 1991 91216883 | Clarithromycin:90.6% (29/32) Amoxicillin: 91.4% (32/35) | Clarithromycin: none Amoxicillin: diarrhea (1) | Mostly GI complaints (diarrhea & abdominal pain) Clarithromycin:16% Amoxicillin: 26% | X-ray clear & improved - Clarithromycin: 90.9% (30/33) Amoxicillin: 88.5% (31/35)
Fiscella 1991 Sinustx05 | Cefixime: 87.5% (14/16) Amoxicillin: 80.0% (12/15) | Cefixime: none Amoxicillin: diarrhea (1) | Cefixime: diarrhea (2), abdominal cramps (1), dry mouth (1), rash (1) Amoxicillin: diarrhea (2), nausea (2), vomiting (1) | One patient from each arm was dropped due to noncompliance.
Edelstein 1993 93133048 | Cefixime: 94.3% (50/53) Amoxicillin: 95.9% (47/49) | Cefixime: GI-related (1), rash (1) Amoxicillin: GI-related (1), rash (1) | Cefixime: 5 events include an antrostomy complication & GI upsets in 3 patients, GI-related (27) Amoxicillin: GI-related (12), skin- related (5), dizziness (1), vaginitis (1) | -
Huck 1993 94163345 | Cefixime: 86% (24/28) Amoxicillin: 86% (24/28) | Cefixime: none Amoxicillin: diarrhea & vaginitis (1) | Cefixime: vaginitis (2) Amoxicillin: vaginitis (1), epistaxis (1), edema (1), herpes simplex (1) | Improved X-ray results for both studies - 89% (50/56)
Calhoun 1993 94154893 | Clarithromycin: 90.9% (50/55) Amoxicillin: 88.5% (54/61) | None | Mostly GI-related: Clarithromycin: 26% (18) Amoxicillin: 14% (10) | X-ray resolution or improved: Clarithromycin: 78.1% (43/55) Amoxicillin: 91.8% (56/61)
von Sydow 1995 96143362 | Cefpodoxime: 95.7% (112/117) Amoxicillin: 91.1% (103/113) | Cefpodoxime: (4) Amoxicillin: (7) | Including major adverse events -mostly GI-related (diarrhea): Cefpodoxime: 20% (26) Amoxicillin: 9% (12) | 1 patient from each arm had nose-bleeding requiring hospitalization. 1 patient from the amoxicillin arm was hospitalized because of urticaria & dyspnea.
Matthews 1997 Sinustx01 | Cefixime: 83.8% (31/37) Amoxicillin: 88.2% (30/34) | Cefixime: 5.26% (5/95) Amoxicillin: 7.31% (6/82) (including nonacute sinusitis). | Mostly GI-related, including diarrhea, abdominal pain, & dyspepsia. | There were no differences between the arms in drug-related incidences.
Rimmer 1997 Sinustx02 | Cefixime: 91.2% (135/148) Amoxicillin: 88.9% (144/162) | Mostly diarrhea -Cefixime: (6) Amoxicillin: (1) | Cefixime: GI-related (16.7%-7 severe)Amoxicillin: GI-related (6.6%-2 severe) Other events: headache & dizziness | 2 cefixime patients, each had spontaneous bone fracture and abnormal liver function resulting in hospitalization.

1 Except folate inhibitors

2 MEDLINE or unique identifying number assigned by EPC. Only first author cited

3 Clinical or global evaluation

Abbreviations: GI - gastrointestinal; tx - treatment

Evidence Table 21. Results of randomized controlled trials included in meta-analysis comparing folate inhibitors with other antibiotics

Author, Year Identifier ^1^ | Results ^2^ :Percentage Cure or Improved (number / total) | Discontinuation Due To Major Adverse Events (no. of events) | Minor Adverse Events (no. of events) | Additional Comments / Data
Otte 1983 84273842 | Tetracycline: 64.7% (11/17) Sulfamethopyrazin- trimethoprim: 71.4%(10/14) | None | Minor GI complaints & skin reactions - Tetracycline: 58.8% Sulfamethopyrazin-trimethoprim:64.2% | -
Osman 1983 Sinustx03 | Miraxid: 90.0% (45/50) Co-trimoxazole: 60.4% (29/48) | Miraxid: (4) Co-trimoxazole: (4) | Miraxid: (2) Co-trimoxazole: (3) | -
Wallace 1985 86080813 | Pivmecillinam/pivampicillin:83.3% (25/30) Co-trimoxazole: 86.8% (33/38) | None | Mostly GI-related, particularly from the co-trimoxazole arm. Pivmecillinam/pivampicillin:19 (11.9%) Co-trimoxazole:24 (15.8%) | -
Salmi 1986 86247086 | Brodimoprim: 93.8% (15/16) Doxycycline: 100% (12/12) | None | Brodimoprim: diarrhea (1) Doxycycline: none | -
Manzini 1993 94253884 | Brodimoprim:85.7% (30/35) Roxithromycin:71/0% (27/38) | Brodimorpim:1 - cause unknown | Roxithromycin: diarrhea with stomach pain (2), skin-related (1) | Bacterial eradication -Brodimorpim:21 (87.5%) Roxithromycin: 18 (69.2%)
Arndt 1994 95165185 | Brodimoprim: 96.4% (27/28) Doxycycline: 96.1% (25/26) | Brodimoprim: diarrhea (1), exanthema (1), tremor (1), 'inactivity of compound'(1) Doxycycline:'inactivity of compound' (1) | GI-related (nausea, diarrhea), CNS skin-related, circulatory disorders, & kidney pain - Brodimoprim: (7) Doxycycline: CNS (3) | -
Bockmeyer 1994 95073260 | Brodimoprim: 100% (24/24) Cephalexin: 95% (20/21) | None | Brodimoprim: skin-related (1) Cephalexin: none | -
Rahlfs ^3^ 1996 Sinustx04 (German) | Brodimoprim: 100% (14/14) Doxycycline: 92.3% (12/13) | Unknown | Brodimoprim: (1) Doxycycline: none | -
Rahlfs ^3^ 1996 Sinustx04 (Swedish) | Brodimoprim: 88.9% (8/9) Doxycycline:100% (13/13) | Unknown | Brodimoprim: (2) Doxycycline: (1) | -

1 MEDLINE or unique identifying number assigned by EPC. Only first author cited

2 Clinical or global evaluation

3 Individual study data extracted from meta-analysis by Rahlfs

Abbreviations: GI - gastrointestinal; CNS - central nervous system

Evidence Table 22. Results of randomized controlled trials included in meta-analysis comparing penicillin with other antibiotics^1^

Author, Year Identifier ^2^ | Results ^3^ : Percentage Cure or Improved (number / total) | Discontinuation Due To Major Adverse Events (no. of events) | Minor Adverse Events (no. of events) | Additional Comments / Data
Axelsson 1970 70286389 | Penicillin V:82.8% (29/35) Lincomycin: 84.6% (33/39) | None | Penicillin V: nausea (2), stool (1) Lincomycin: loose bowel movement (27) | At day 5 and day 10, all arms showed radiograph improvement.
von Sydow 1984 85114999 | Erythromycin:97.9% (46/47) Penicillin V:90.9% (40/44) | Erythromycin: epigastric pain & vomiting(1) Penicillin V: urticaria (1) | Mostly GI-related Erythromycin: (18), some epigastric pain Penicillin V: (9)
Lindbaek 1996a 96343743 | Amoxicillin: 88.6% (39/44) Penicillin V: 82.1% (32/39) | 12 patients discontinued tx; 3 had severe GI events & withdrew, 6 placebo cases were given amoxicillin & 1 was given penicillin V. 2 amoxicillin cases were given doxycycline. | More than half in tx had adverse events, mainly diarrhea. | Mean duration of sinusitis: Amoxicillin: 9 days Penicillin: 11 days Placebo: 17 days Mean(95% CI) reduction of clinical severity scores: Amoxicillin: 5.5 (4.9, 6.0) Penicillin V: 5.4 (5.0, 5.8) Placebo: 3.4 (2.8, 4.0
Haye 1996 97151573 | Outcome at 10-12 days Azithromycin: 97.3% (214/220) Penicillin V: 94.9% (205/216) | None | Mostly GI-related (diarrhea, nausea, abdominal pain), some skin-related, & loss of appetite - Azithromycin: (89) Penicillin V: (112)

1 Except folate inhibitors.

2 MEDLINE or unique identifying number assigned by EPC. Only first author cited.

3 Clinical or global evaluation.

Abbreviations: GI - gastrointestinal; tx - treatment; CI - confidence interval.

Evidence Table 23. Description of randomized controlled trials of ancillary treatment

Author, Year Identifier ^1^ | Population & Setting | Design | Treatment | Outcome
Taub 1967 67252056 | 59 patients (age 14-66) with signs & symptoms of acute or chronic sinusitis. Most were atopic and had previously unsuccessful. | Double-blinded. Some patient data stratified by diagnosis. | 2 arms consisting of bromelain 50,000 Rorer units or placebo, 2 tablets QID for 6 days, in conjunction with either: tetracycline, decongestant nasal spray, or both, or aspirin. | Levels of signs & symptoms were recorded. Overall outcome measures include: excellent, good, fair, and poor.
Ryan 1967 67260013 | 50 patients (age 9-70) presenting signs & symptoms of acute sinusitis. | Double-blinded. | 2 arms consisting of bromelain or placebo 2 tablets QID for 6 days. Standard tx consisted of capsules containing antihistaminic decongestant & analgesic agents, antibiotics. | Levels of individual signs & symptoms were recorded. Overall outcome measures include: excellent, good, fair, and poor.
Seltzer 1967 68098638 | 48 patients (age 9-74) diagnosed with acute sinusitis and 1 patients with chronic sinusitis were recruited from one ENT's private practice. 7 patients were hospitalized cases. 1 patient had sickle cell anemia, but adverse effect from previous treatments. | Double-blinded. Baseline examination of patients included severity rating. | 2 arms consisting of bromelain or placebo 2 tablets QID for 6 days. 46 patients had standard tx consisting of antibiotics, singly, or in conjunction with salicylate (17), ephedrine (4), antihistamines (3), and sulfonamides (3). | Levels of individual signs & symptoms were recorded. Overall outcome measures include: excellent, good, fair, and poor.
Lewison 1970 71034799 | 100 patients (age 12-64) with nasal congestion from various disorders were recruited: acute and subacute sinusitis, acute exacerbation of chronic sinusitis, acute rhinitis, eustachianitis, serous otitis media, & seasonal & perennial allergy. | Allocation of treatments by alternate method. | 2 arms consisting of xylometazoline hydrochloride spray, 2-3 times daily & before bedtime vs a combination of phenylephrine hydrochloride and diphenylpyraline hydrochloride tablets, BID or TID as needed, for 2 weeks. Dosage decreased with improved condition. Obvious bacterial infections were treated with antibiotics. | Patients examined twice weekly for 2 weeks. Outcome measures include: good - complete symptomatic relief & exam revealed decongestion; fair - symptoms persist but with marked improvement; and poor - slight or no improvement.
Harris 1971 72143625 | 52 patients (mean age 30.2) with acute sinusitis were recruited. | Single-blinded, between-patient study. | 2 arms consisting of bromhexine 8 mg combined with oxytetracycline 250 mg vs oxytetracycline ("placebo") 250 mg, QID for 5 days. | Evaluation at day 7. Outcome measures include: good-improvement within 24 hours of tx, complete resolution; fair - improvement within 3-6 days, adequate results; and poor - slight or no improvement within 3-6 days.
Meltzer 1993 94081230 | 180 patients (age >14, mean 36.8) presenting signs & symptoms of acute (53%) and chronic (47%) sinusitis were recruited from the practices of allergy specialists for a multicenter study. Diagnosis for 175 was confirmed by X-ray. | Double-blinded, parallel trial. Signs & symptoms separately scored for severity. | 2 arms consisting of flunisolide 0.025% solution, 2 sprays in each nostril TID (300 µg/day), or placebo spray TID for 7 weeks. Tx consisted of amoxicillin/clavulanate potassium 500 mg TID orally for 3 weeks (phase I), continued use of nasal spray for 4 weeks (phase II). | Visual analog scale (VAS) used to assess parameters singly, as well as globally. X-rays assessed using VASs.
Wiklund 1994 94346266 | Study 1 - 73 patients (age 16-69) presenting symptoms of acute maxillary sinusitis confirmed by X-ray. Study 2 - 48 patients (age 20-62) presenting symptoms of acute maxillary sinusitis confirmed by X-ray. | Study 1 - single-blinded. Patient diary were kept to record symptoms. Study 2 - double-blinded. Patient diary used to record symptoms. | Study 1 - 4 arms consisting of oxymetazoline vs placebo administered by nasal bellows container or nasal spray. 2 arms used the bellows technique for 4 days, oxymetazoline 25 ml, 0.25 mg/ml, or placebo (NaCl). 2 arms used a nasal spray, oxymetazoline 0.5 mg/ml or placebo for 10 days. All patients had standard tx of phenoxymethyl-penicillin 1 g. 2 tablets BID for 10 days. Study 2 - 2 arms consisting of oxymetazoline 0.25 mg/ml vs placebo administered by nasal bellows container for 4 days. All patients had standard tx of phenoxymethyl-penicillin 2 g. 2 tablets BID for 7 days. | Study 1 - X-rays performed at 7 and 28 days, scores calculated. Cured< 1. Study 2 - X-rays performed at 7 and 14 days, scores calculated. Cured< 1.
McCormick 1996 97031318 | 68 patients (age 1-18) with sinusitis symptoms from 7 to 30 days, were recruited from a pediatric outpatient department of a university hospital. Diagnosis was confirmed by X-ray. | Double-blinded. Symptom score established at baseline, day 3 and day 14 from questionnaire. | Oxymetazoline 0.05% & brompheniramine 2 mg & phenylpropanolamine 12.5 mg per 5 mL. Standard tx consisted of amoxicillin TID for 14 days. Antibiotic & ancillary treatment dosages determined by body weight. | Symptom score calculated at day 3 and day 14. X-rays taken at day 14.
Barlan 1997 97351444 | 151 Turkish patients (age 1-15) pediatric outpatient clinic of university hospital presenting signs & symptoms of acute sinusitis >7 days. X-rays confirmed diagnosis in 79 of 89 who completed study. | Double-blinded. Daily diary used to record symptoms. Weekly exams by the same physician. | 2 arms consisting of budesonide or placebo spray, BID in each nostril, in addition to amoxicillin clavulanate 40 mg/kg/day for 3 weeks. | Median of weekly symptoms scores for weeks 1, 2, and 3 compared, also with baseline.
Braun 1997 97369575 | 139 French patients (age 15-65) with chronic allergic rhinitis were recruited from outpatient clinics by 8 ENT specialists. The patients presented with acute exacerbation of sinusitis 2-30 days. Diagnosis was confirmed by X-rays. | Double-blinded, parallel trial. Severity of symptoms scored. Daily diary recorded by patients for 28 days, used to calculate symptom score. | 2 arms consisting of loratadine 10 mg/day or placebo for 28 days. Tx included amoxicillin and clavulanate acid 2 g/day for 14 days, prednisone 40 mg/day for 4 days, and 20 mg for 4 days. | Total symptom score calculated by adding scores of all symptoms.

1 MEDLINE unique identifying number. Only first author cited

Abbreviations: tx - treatment; BID - 2 times per day; TID - 3 times per day; QID - 4 times per day; ENT - ear, nose, and throat specialist; VAS - Visual Analog Scale

Evidence Table 24. Results of randomized controlled trials of ancillary treatment

Author, Year Identifier ^1^ | Results: Percentage With Positive Results (number / total) | Discontinuation Due To Major Adverse Events (no. of events) | Minor Adverse Events (no. of events) | Additional Comments / Data
Taub 1967 67252056 | Bromelain: 69% (20/29) (100% excellent) Placebo: 40% (12/30) (excellent or good) | None | None | 28 patients with acute sinusitis.31 patients with chronic sinusitis. Concomitant tx consisted of tetracycline - 4, decongestant - 4, aspirin - 2, and tetracycline plus decongestant - 47. No statistical difference between the patients with acute sinusitis to those with chronic sinusitis in terms of response to treatment.
Ryan 1967 67260013 | Bromelain: 87% (20/23) Placebo: 68% (17/25) (excellent or good) | None | No additional data | Two patients in the bromelain arm dropped out; one failed to return after first visit, and one withdrew due to nausea from the standard therapy.
Seltzer 1967 68098638 | Bromelain: 80% (20/25) Placebo: 50% (12/24) (excellent or good) | None | None | Mean tx time for the bromelain patients was 10 days compared with 16 days for the placebo patients.
Lewison 1970 71034799 | Xylometazoline hydrochloride: 80% (4/5) Phenylephrine hydrochloride & diphenylpyraline hydrochloride: 66.6% (4/6) | None | Unknown, data not stratified by diagnoses. Events for total population:xylometazoline hydrochloride- nausea (2) Phenylephrine hydrochloride & diphenylpyraline hydrochloride: drowsiness (2), headache (1), dizziness (1) | -
Harris 1971 72143625 | Bromhexine: 96.1% (25/26) "Placebo":53.8% (14/26) | None | None | -
Meltzer 1993 94081230 | The mean score of therapy using VAS was significantly higher for the flunisolide arm compared with placebo arm (69.4 vs 56.3, p=0.007) at phase I. | 19 withdrew mostly for GI events caused by antibiotics during phase I. 4 withdrew during phase II. | No additional data | 8 patients withdrew during phase I because of tx failure. 10 withdrew during phase II because of tx failure or recurrence.
Wiklund 1994 94346266 | Study 1- Mean X-ray score day 7 & 28 for bellows: Oxymetazoline - 29%,57% Placebo - 34%,75% Mean X-ray score day 7 & 28 for spray: Oxymetazoline - 31%,73% Placebo - 58%,73% Study 2- Mean X-ray score (day 7 & 14): Oxymetazoline - 34%,65% Placebo - 33%,41% | None | Unknown | Study 1 - no statistical difference between 4 arms comparing individual changes in X-rays score from day 0 to day 7 & day 0 to day 28. Symptoms reporting showed no difference in decline among the 4 arms. Study 2 - no statistical difference between 2 arms comparing individual changes in X-rays score from day 0 to day 7 & day 0 to day 14. Symptoms reporting showed no difference between the 2 arms at day 0 or at day 14.
McCormick 1996 97031318 | No significance difference between mean scores for ancillary tx vs placebo | 2 because of antibiotic response. | Unknown | X-rays findings showed no statistical difference between the two arms although both arms had statistical improvement from baseline to follow up at day 14.
Barlan 1997 97351444 | Statistically significant scores for the 3-week median scores compared for cough & nasal discharge. By week 2, the budesonide arm had a significant improvement in cough & nasal score compared with week 1 or compared with the placebo arm at week 2. | After 1 week of amoxicillin-clavulanate, 1 patient continued tx with cefaclor because of skin rash. | None | 2 patients from each arm experienced relapse within 1 month after end of tx. Significant scores for both arms compared with baseline for cough & nasal discharge.
Braun 1997 97369575 | Percent of total with an improved score: Loratadine: 66% Placebo: 48% | None | Nausea & diarrhea experienced by similar number of patients in both arms. | -

1 MEDLINE unique identifying number. Only first author cited

Abbreviations: tx - treatment; VAS - Visual Analog Scale