# Acronyms and Abbreviations

ABRS: acute bacterial rhinosinusitis

AHCPR: Agency for Health Care Policy and Research

CFU: colony-forming unit

CI: confidence interval

CNS: central nervous system

CT: computerized tomography

EM: Expectation maximization

ENT: ear, nose, and throat specialist

EPC: Evidence-based Practice Center

FN: false negative

GI: gastrointestinal

GP: general practice

Gtt: drops

HIV: human immunodeficiency virus

HMO: health management organization

Hx: history

ICD-9-CM: International Classification of Disease, 9th edition, clinically modified

MRI: magnetic resonance imaging

NAMCS: National Ambulatory Medical Care Survey

NEMC: New England Medical Center

NRSA: National Research Service Award

pts: patients

q-adj day: quality-adjusted day

QAO: quality-adjusted outcome

QID: 4 times per day

QOD: every other day

RR: risk ratio

Rx: antibiotic prescription

SE: antibiotic side effect

Sens: sensitivity

SMZ: sulfamethoxazole

Spec: specificity

SROC: summary receiver operating characteristic

Sx-free day: symptom-free day

TID: 3 times per day

TMP: trimethoprim

TN: true negative

TP: true positive

Tx: treatment

1/Var.: 1/Variance; provides the relative weight of the study

VAS: Visual Analog Scale