# References

Agbim OG. A comparative trail of doxycycline ("Vibramycin") and ampicillin in the treatment of acute sinusitis. Curr Med Res Opin. 1974;2(5):291-4. [pmid: 4606101].
Aitken M, Taylor JA. Prevalence of clinical sinusitis in young children followed up by primary care pediatricians. Arch Pediatr Adolesc Med. 1998 Mar;152(3):244-8.
Alvart R. An open multicentre study to compare the efficacy and safety of sultamicillin with that of cefuroxime axetil in acute ear nose and throat infections in adults. J Int Med Res. 1992;20(Suppl 1):53A-61A.
American Society for Microbiology. Program and abstracts of the Interscience Conference on Antimicrobial Agents and Chemotherapy 1993, 1994, 1995, 1996, 1997. Washington, DC.
Antila J, Suonpaa J, Lehtonen OP. Bacteriological evaluation of 194 adult patients with acute frontal sinusitis and findings of simultaneous maxillary sinusitis. Acta Otolaryngol Suppl (Stockh). 1997;529:162-4. [pmid: 9288299].
Arason VA, Kristinsson KG, Sigurdsson JA, Stefandottir G, Molstad S, Gudmundsson S. Do antimicrobials increase the carriage rate of penicillin resistant pneumococci in children? Cross sectional prevalence study. BMJ. 1996;313:387-91. [pmid: 8761224].
Arndt J, Riebenfeld D, Maier H, Weidauer H. Therapeutic efficacy and tolerability of brodimoprim in comparison with doxycycline in acute sinusitis in adults. J Chemother. 1994 Oct;6(5):322-7.
Axelsson A, Brorson JE. Bacteriological findings in acute maxillary sinusitis. ORL J Otorhinolaryngol Relat Spec. 1972;34(1):1-9. [pmid: 4405604].
Axelsson A, Chidekel N. Symptomatology and bacteriology correlated to radiological findings in acute maxillary sinusitis. Acta Otolaryngol (Stockh). 1972 Jul-Aug;74(1):118-22.
Axelsson A, Runze U. Symptoms and signs of acute maxillary sinusitis. ORL J Otorhinolaryngol Relat Spec. 1976;38(5):298-308. [pmid: 1034250].
Axelsson A, Chidekel N, Grebelius N, Jensen C. Treatment of acute maxillary sinusitis. A comparison of four different methods. Acta Otolaryngol (Stockh). 1970 Jul;70(1):71-6.
Axelsson A, Chidekel N, Grebelius N, Jensen C, Sarne S. Treatment of acute maxillary sinusitis. II. A comparison of five further methods. Acta Otolaryngol (Stockh). 1971 Jul-Aug;72(1):148-54.
Axelsson A, Jensen C, Melin O, Singer F, von Sydow C. Treatment of acute maxillary sinusitis. V. Amoxicillin azidocillin, phenylpropanolamine and pivampicillin. Acta Otolaryngol (Stockh). 1981 Mar-Apr;91(3-4):313-8.
Baquero F. Trends in antibiotic resistance of respiratory pathogens: An analysis and commentary on a collaborative surveillance study. J Antimicrob Chemother. 1996 Jul;38[Suppl A]:117-32.
Barlan IB, Erkan E, Bakir M, Berrak S, Basaran MM. Intranasal budesonide spray as an adjunct to oral antibiotic therapy for acute sinusitis in children. Ann Allergy Asthma Immunol. 1997 Jun;78(6):598-601.
Beatson JM, Marsh BT, Talbot DJ. A clinical comparison of pivmecillinam plus pivampicillin (Miraxid) and a triple tetracycline combination (Deteclo) in respiratory infections treated in general practice. J Int Med Res. 1985;13(4):197-202. [pmid: 3930309].
Beck JR, Pauker SG. The Markov process in medical prognosis. Med Decis Making. 1983;3(4):419-58. [pmid: 6668990].
Benninger MS. Rhinitis, sinusitis, and their relationships to allergies. Am J Rhinol. 1992 Mar;6(2):37-43.
Benninger MS, Anon J, Mabry RL. The medical management of rhinosinusitis. Otolaryngol Head Neck Surg. 1997;117:S41-S49. [pmid: 9334787].
Benson V, Marano MA. Current estimates from the National Health Interview Survey, 1992. Vital Health Stat [10]. 1994 Jan;189:1-269.
Berg O, Carenfelt C. Etiological diagnosis in sinusitis: Ultrasonography as clinical complement. Laryngoscope. 1985 Jul;95(7 Pt 1):851-3.
Berg O, Carenfelt C. Analysis of symptoms and clinical signs in the maxillary sinus empyema. Acta Otolaryngol (Stockh). 1988 Mar-Apr;105(3-4):343-9.
Berg O, Carenfelt C, Kronvall G. Bacteriology of maxillary sinusitis in relation to character of inflammation and prior treatment. Scand J Infect Dis. 1988;20(5):511-6. [pmid: 3222668].
Berg O, Carenfelt C, Rystedt G, Anggard A. Occurrence of asymptomatic sinusitis in common cold and other acute ENT-infections. Rhinology. 1986 Sep;24(3):223-5.
Bigby M, Jick S, Jick H, Arndt K. Drug induced cutaneous reactions: A report from the Boston Collaborative Drug Surveillance Program on 15,438 consecutive inpatients, 1975 to 1982. JAMA. 1986;256:3358-63. [pmid: 2946876].
Bjorkwall T. Bacteriological examinations in maxillary sinusitis: Bacterial flora of the maxillary antrum. Acta Otolaryngol suppl (Stockh). 1950;83:1-58.
Bockmeyer M, Riebenfeld D, Clasen B. Controlled study of brodimoprim and cephalexin in the treatment of patients with acute sinusitis in general practice. Clin Ther. 1994 Jul-Aug;16(4):653-61.
Boezeman AJ, Kayser AM, Siemelink RJ. Comparison of spiramycin and doxycycline in the empirical treatment of acute sinusitis: preliminary results. J Antimicrob Chemother. 1988 Jul;22 (Suppl B):165-70. [pmid: 3182439].
Bradley JS, Kaplan SL, Klugman KP, Leggiadro RJ. Consensus: Management of infections in children caused by Streptococcus pneumoniae with decreased susceptibility to penicillin. Pediatr Infect Dis J. 1995 Dec;14(12):1037-41.
Bradley PJ, Shaw, MD. Three decades of brain abscess in Merseyside. J R Coll Surg Edinb. 1983 Jul;28(4):223-8.
Braun JJ, Alabert JP, Michel FB, Quiniou M, Rat C, Cougnard J, Czarlewski W, Bousquet J. Adjunct effect of loratadine in the treatment of acute sinusitis in patients with allergic rhinitis. Allergy. 1997 Jun;52(6):650-5.
Brodie DP, Knight S, Cunningham K. Comparative study of cefuroxime axetil and amoxycillin in the treatment of acute sinusitis in general practice. J Int Med Res. 1989 Nov-Dec;17(6):547-51.
Brook I. Aerobic and anaerobic bacterial flora of normal maxillary sinuses. Laryngoscope. 1981 Mar;91(3):372-6. [pmid: 7464398].
Brook I. Microbiology and management of sinusitis. J Otolaryngol. 1996 Aug;25(4):249-56. [pmid: 8863213].
Burke TF, Guertler AT, Timmons JH. Comparison of sinus x-rays with computed tomography scans in acute sinusitis. Acad Emerg Med. 1994 May-Jun;1(3):235-9.
Caldwell J, Cluff L. Adverse reactions to antimicrobial agents. JAMA. 1974;230:77-80. [pmid: 4479056].
Calhoun KH, Hokanson JA. Multicenter comparison of clarithromycin and amoxicillin in the treatment of acute maxillary sinusitis [see comments]. Arch Fam Med. 1993 Aug;2(8):837-40.
Calhoun KH, Waggenspack GA, Simpson CB, Hokanson JA, Bailey BJ. CT evaluation of the paranasal sinuses in symptomatic and asymptomatic populations. Otolaryngol Head Neck Surg. 1991 Apr;104(4):480-3.
Camacho AE, Cobo R, Otte J, et al. Clinical comparison of cefuroxime axetil and amoxicillin/clavulanate in the treatment of patients with acute bacterial maxillary sinusitis. Am J Med. 1992 Sep;93(3):271-6.
Cardinale V, editor. Drug topics red book. Oradell, N.J.: Medical Economics Company; 1997.
Carenfelt C, Melen I, Odkvist L, Olsson O, Prellner K, Rudblad S, Savolainen S, Skaftason S, Sorri M, Synnerstad B. Treatment of sinus empyema in adults. A coordinated Nordic multicenter trial of cefixime vs. cefaclor. Acta Otolaryngol (Stockh). 1990 Jul-Aug;110(1-2):128-35.
Casiano RR. Azithromycin and amoxicillin in the treatment of acute maxillary sinusitis. Am J Med. 1991 Sep 12;91(3A):27S-30S. [pmid: 1656739].
Chambers HF, Neu HC. Penicillins. In: Mandell GL, Bennett JE, Dolin R, editors. Mandell, Douglas and Bennett's principles and practice of infectious diseases. 4 ^ th ^ ed. New York: Churchill Livingstone; 1995a. p. 233.
Chambers HF, Neu HC. Other β-lactam antibiotics. In: Mandell GL, Bennett JE, Dolin R, editors. Mandell, Douglas and Bennett's principles and practice of infectious diseases. 4 ^ th ^ ed. New York: Churchill Livingstone; 1995b. p. 264.
Christensen CH, Hartmann E. Treatment of sinusitis and otitis media with pivampicillin. Pharmatherapeutica. 1980;2(7):469-74. [pmid: 7208541].
Coltran RS, Kumar V, Robbins SL, editors. Robbins pathologic basis of disease. 5th ed. Philadelphia: WB Saunders; 1995. p. 53-83.
Davies A, Lewith G, Goddard J, Howarth P. The effect of acupuncture on nonallergic rhinitis: A controlled pilot study. Altern Ther Health Med. 1998 Jan;4(1):70-4.
De Abate CA, Perrotta RJ, Dennington ML, Ziering RM. The efficacy and safety of once-daily ceftibuten compared with co-amoxiclav in the treatment of acute bacterial sinusitis. J Chemother. 1992 Dec;4(6):358-63.
de Bock GH, Dekker FW, Stolk J, Springer MP, Kievit J, van Houwelinge JC. Antimicrobial treatment in acute maxillary sinusitis: A meta-analysis. J Clin Epidemiol. 1997;50:881-90. [pmid: 9291872].
de Bock GH, Houwing-Duistermaat JJ, Springer MP, Kievit J, van Houwelingen JC. Sensitivity and specificity of diagnostic tests in acute maxillary sinusitis determined by maximum likelihood in the absence of an external standard. J Clin Epidemiol. 1994 Dec;47(12):1343-52.
de Campora E, Camaioni A, Leonardi M, Fardella P, Fiaoni M. Comparative efficacy and safety of roxithromycin and clarithromycin in upper respiratory tract infections. Diagn Microbiol Infect Dis. 1992 May-Jun;15(4 Suppl):119S-122S.
de Ferranti SD, Ioannidis JP, Lau J, Anninger W, Barza M. Are amoxycillin and folate inhibitors as effective as other antibiotics for acute sinusitis? A meta-analysis. BMJ. 1998;317:632-7. [pmcid: 28657]. [pmid: 9727991].
Dempster AP, Laird NM, Rubin DB. Maximum likelihood from incomplete data via the EM algorithm. J R Stat Soc Series B. 1977;39(10):1-38.
Dingle JH, Badger GF, Jordan WS Jr. Illnesses in a group of Cleveland families. Cleveland: The Press of Western Reserve University; 1964. p. 347.
Druce HM. Diagnosis of sinusitis in adults: History, physical examination, nasal cytology, echo, and rhinoscope. J Allergy Clin Immunol. 1992 Sep;90(3 Pt 2):436-41. [pmid: 1527333].
Drummond M, Brandt A, Luce B, Rovira J. Standardizing methodologies for economic evaluation in health care. Int J Tech Assess Health Care. 1993;9(1):26-36.
Dubois J, Saint-Pierre C, Tremblay C. Efficacy of clarithromycin vs. amoxicillin/clavulanate in the treatment of acute maxillary sinusitis. Ear Nose Throat J. 1993 Dec;72(12):804-10.
Edelstein DR, Avner SE, Chow JM, Duerksen RL, Johnson J, Ronis M, Rybak LP, Bierman WC, Matthews BL, Kohlbrenner VM. Once-a-day therapy for sinusitis: A comparison study of cefixime and amoxicillin. Laryngoscope. 1993 Jan;103(1 Pt 1):33-41.
Eneroth CM, Lundberg C. The antibacterial effect of antibiotics in treatment of maxillary sinusitis. Acta Otolaryngol (Stockh). 1976 May-Jun;81(5-6):475-83.
Evans FO Jr, Sydnor JB, Moore WE, Moore GR, Manwaring JL, Brill AH, Jackson RT, Hanna S, Skaar JS, Holdeman LV, Fitz-Hugh S, Sande MA, Gwaltney JM Jr. Sinusitis of the maxillary antrum. N Engl J Med. 1975 Oct 9;293(15):735-9.
Falser N, Mittermayer H, Weuta H. Antibacterial treatment of otitis and sinusitis with ciprofloxacin and penicillin V -- a comparison. Infection. 1988;16(Suppl 1):S51-S54. [pmid: 3131251].
Federspil P, Bamberg P. Sulphadiazine/trimethoprim once daily in maxillary sinusitis: A randomized double-blind comparison with sulphamethoxazole/trimethoprim B. I.D. J Int Med Res. 1981;9(6):478-81.
Federspil P, Koch J. Double-blind comparative trial of trimethoprim/sulfamethopyrazine once daily vs erythromycin 4 X daily in patients with ENT infections. Int J Clin Pharmacol Ther Toxicol. 1983 Oct;21(10):535-9.
Felstead SJ, Daniel R. Short-course treatment of sinusitis and other upper respiratory tract infections with azithromycin: A comparison with erythromycin and amoxycillin. European Azithromycin Study Group. J Int Med Res. 1991 Sep-Oct;19(5):363-72.
Ferguson BJ, Mabry RL. Laboratory diagnosis. Otolaryngol Head Neck Surg. 1997 Sep;117(3 Pt 2):S12-S26.
Ficnar B, Huzjak N, Oreskovic K, Matrapazovski M, Klinar I. Azithromycin: 3-day versus 5-day course in the treatment of respiratory tract infections in children. Croatian Azithromycin Study Group. J Chemother. 1997 Feb;9(1):38-43.
Fiscella RG, Chow JM. Cefixime for treatment of maxillary sinusitis. Am J Rhinol. 1991;5:193-7.
Fleiss JL. The statistical basis of meta-analysis. Stat Meth Med Res. 1993;2:121-45.
Friedland IR, McCracken GH Jr. Management of infections caused by antibiotic-resistant Streptococcus pneumoniae. N Engl J Med. 1994 Aug 11;331(6):377-82.
Gable CA, Jones JK, Floor M, Stuffa J, Lian J, Rajan M. Chronic sinusitis: Relation to upper respiratory infections and allergic rhinitis. Pharmacoepidemiol Drug Safety. 1994;3:337-49.
Ganança M, Trabulsi LR. The therapeutic effects of cyclacillin in acute sinusitis: In vitro and in vivo correlations in a placebo-controlled study. Curr Med Res Opin. 1973;1(6):362-8. [pmid: 4359033].
Gauger U, Inoka P, Germano G, Kissling M. Cefetamet in the treatment of acute sinusitis in adult patients. J Int Med Res. 1990 May-Jun;18(3):228-34.
Gehanno P, Berche P. Sparfloxacin versus cefuroxime axetil in the treatment of acute purulent sinusitis. Sinusitis Study Group. J Antimicrob Chemother. 1996 May;37(Suppl A):105-14.
Gehanno P, Depondt J, Barry B, Simonet M, Dewever H. Comparison of cefpodoxime proxetil with cefaclor in the treatment of sinusitis. J Antimicrob Chemother. 1990 Dec;26(Suppl E):87-91.
Gold SM, Tami TA. Role of middle meatus aspiration culture in the diagnosis of chronic sinusitis. Larnygoscope. 1997 Dec;107:1586-9.
Gordts F, Clement PA, Destryker A, Desprechins B, Kaufman L. Prevalence of sinusitis signs on MRI in a non-ENT paediatric population. Rhinology. 1997 Dec;35(4):154-7.
Green M, Wald ER. Emerging resistance to antibiotics: Impact on respiratory infections in the outpatient setting. Ann Allergy Asthma Immunol. 1996 Sep;77(3):167-73; quiz 173-5.
Gwaltney JM Jr. Acute community-acquired sinusitis. Clin Infect Dis. 1996;23:1209-23. [pmid: 8953061].
Gwaltney JM Jr. Rhinoviruses. In: Evans AS and Kaslow RA, editors. Viral infection of human: Epidemiology and control. 4 ^ th ^ ed. New York: Plenum Press; 1997.
Gwaltney JM Jr, Jones JG, Kennedy DW. Medical management of sinusitis: Educational goals and management guidelines. The International Conference on Sinus Disease. Ann Otol Rhinol Laryngol Suppl. 1995 Oct;167:22-30. [pmid: 7574266].
Gwaltney JM Jr, Sydnor A Jr, Sande MA. Etiology and antimicrobial treatment of acute sinusitis. Ann Otol Rhinol Laryngol Suppl. 1981 May-Jun;(3 Pt 3):68-71.
Gwaltney JM Jr, Phillips CD, Miller RD, Riker DK. Computed tomographic study of the common cold. N Engl J Med. 1994;330:25-30. [pmid: 8259141].
Gwaltney JM Jr, Scheld WM, Sande MA, Sydnor A. The microbial etiology and antimicrobial therapy of adults with acute community-acquired sinusitis: A fifteen-year experience at the University of Virginia and review of other selected studies. J Allergy Clin Immunol. 1992 Sep;90(3 Pt 2):457-61.
Hadley JA, Schaefer SD. Clinical evaluation of rhinosinusitis: History and physical examination. Otolaryngol Head Neck Surg. 1997 Sep;117(3 Pt 2):S8-S11.
Hamory BH, Sande MA, Sydnor A Jr, Seale DL, Gwaltney JM Jr. Etiology and antimicrobial therapy of acute maxillary sinusitis. J Infect Dis. 1979 Feb;139(2):197-202.
Hansen JG, Schmidt H, Rosborg J, Lund E. Predicting acute maxillary sinusitis in a general practice population. BMJ. 1995;311:233-6. [pmid: 7627042].
Harris PG. A comparison of "bisolvomycin" and oxytetracycline in the treatment of acute infective sinusitis. Practitioner. 1971 Dec;207(242):814-7. [pmid: 4947232].
Haye R, Lingaas E, Hoivik HO, Odegrd T. Efficacy and safety of azithromycin versus phenoxymethylpenicillin in the treatment of acute maxillary sinusitis. Eur J Clin Microbiol Infect Dis. 1996 Nov;15(11):849-53.
Huck W, Reed BD, Nielsen RW, Ferguson RT, Gray DW, Lund GK, ZoBell DH, Moster MB. Cefaclor vs. amoxicillin in the treatment of acute, recurrent, and chronic sinusitis. Arch Fam Med. 1993 May;2(5):497-503.
International Rhinosinusitis Advisory Board. Infectious rhinosinusitis in adults: classification, etiology and management. Ear Nose Throat J. 1997 Dec;76(12 Suppl):1-22.
Ioannidis JPA. Effect of the statistical significance of results on the time to completion and publication of randomized efficacy trials. JAMA. 1998;279:281-6. [pmid: 9450711].
Ioannidis JPA, Lau J. Can quality of clinical trials and meta-analyses be quantified?. Lancet. 1998 Aug 22;352(9128):590-1.
Ioannidis JPA, Cappelleri JC, Lau J, Skolnik PR, Melville B, Chalmers TC, Sacks HS. Early or deferred zidovudine in HIV-infected adults without an AIDS-defining illness: A meta-analysis. Ann Intern Med. 1995;122:856-66. [pmid: 7741372].
Irwig L, Tosteson AN, Gatsonis C, Lau J, Colditz G, Chalmers TC, Mosteller F. Guidelines for meta-analyses evaluating diagnostic tests. Ann Intern Med. 1994 Apr 15;120(8):667-76.
Jadad AR, Moore RA, Carroll D, Jenkinson C, Reynolds DJ, Gavaghan DJ, McQuay HJ. Assessing the quality of reports of randomized clinical trials: Is blinding necessary?. Controlled Clin Trials. 1996;17:1-12. [pmid: 8721797].
Jannert M, Andreasson L, Helin I, Pettersson H. Acute sinusitis in children -- symptoms, clinical findings and bacteriology related to initial radiologic appearance. Int J Pediatr Otorhinolaryngol. 1982 Jun;4(2):139-48.
Jensen C, von Sydow C. Radiography and ultrasonography in paranasal sinusitis. Acta Radiol. 1987 Jan-Feb;28(1):31-4.
Jeppesen F, Illum P. Pivampicillin (Pondocillin) in the treatment of maxillary sinusitis. Acta Otolaryngol (Stockh). 1972 Nov;74(5):375-82.
Johnson DL, Markle BM, Wiedermann BL, Hanahan L. Treatment of intracranial abscesses associated with sinusitis in children and adolescents. J Pediatr. 1988;113:15-23. [pmid: 3385523].
Johnson SE, Foord RD. Cephalexin dosage in general practice assessed by double-blind trial. Curr Med Res Opin. 1972;1:37-48. [pmid: 4589401].
Jorgensen JH, Doern GV, Maher LA, Howell AW, Redding JS. Antimicrobial resistance among respiratory isolates of Haemophilus influenzae , Moraxella catarrhalis , and Streptococcus pneumoniae in the United States. Antimicrob Agents Chemother. 1990 Nov;34(11):2075-80. [pmcid: 172002].
Jousimies-Somer HR, Savolainen S, Ylikoski JS. Bacteriological findings of acute maxillary sinusitis in young adults. J Clin Microbiol. 1988 Oct;26(10):1919-25. [pmcid: 266699].
Kalbfleisch J, Prentice R. The statistical analysis of failure time data. New York: John Wiley and Sons; 1980. Chapter 2.
Kaliner MA, Osguthorpe JD, Fireman P, Anon J, Georgitis J, Davis ML, Naclerio R, Kennedy D. Sinusitis: Bench to bedside. Current findings, future directions. Otolaryngol Head Neck Surg. 1997 Jun;116(6 Pt 2):S1-S20.
Karma P, Pukander J, Penttila M, Ylikoski J, Savolainen S, Olen L, Melen I, Loth S. The comparative efficacy and safety of clarithromycin and amoxycillin in the treatment of outpatients with acute sinusitis. J Antimicrob Chemother. 1991 Feb;27(Suppl A):83-90. [pmid: 1827106].
Kassirer JP, Moskowitz AJ, Lau J, Pauker SG. Decision analysis: A progress report. Ann Intern Med. 1987;106:275-91. [pmid: 3541727].
Kennedy DW. First-line management of sinusitis: A national problem? Overview. Otolaryngol Head Neck Surg. 1990 Nov;103(5(Pt 2)):847-54. [pmid: 2125118].
Klossek JM, Dubreuil L, Richet H, Richet B, Sedallian A, Beutter P. Bacteriology of the adult middle meatus. J Laryngol Otol. 1996 Sep;110(9):847-9.
Klugman KP. The clinical relevance of in-vitro resistance to penicillin, ampicillin, amoxycillin and alternative agents, for the treatment of community-acquired pneumonia caused by Streptococcus pneumoniae, Haemophilus influenzae and Moraxella catarrhalis. J Antimicrob Chemother. 1996 Jul;38(Suppl A):133-40.
Kment G, Georgopoulos A, Ridl W, Muhlbacher J. Amoxicillin concentrations in nasal secretions of patients with acute uncomplicated sinusitis and in paranasal sinus mucosa of patients with chronic sinusitis. Eur Arch Otorhinolaryngol. 1995;252(4):236-8. [pmid: 7546679].
Kuusela T, Kurri J, Sirola R. Ultrasound in the diagnosis of paranasal sinusitis of conscripts: Comparison of results of ultrasonography, roentgen examination, and puncture and irrigation. Ann Med Milit Fenn. 1982;57:138-41.
Laine K, Maättä T, Varonen H, Mäkelä M. Diagnosing acute maxillary sinusitis in primary care: A comparison of ultrasound, clinical examination and radiography. Rhinology. 1998 Mar;36(1):2-6.
Laird NM, Mosteller F. Some statistical methods for combining experimental results. Int J Technol Assess Health Care. 1990;6:5-30. [pmid: 2361819].
Lanza DC, Kennedy DW. Adult rhinosinusitis defined. [Review] [29 refs]. Otolaryngol Head Neck Surg. 1997 Sep;117(3 Pt 2):S1-S7.
Lau J, Ioannidis JPA, Schmid CH. Quantitative synthesis in systematic reviews. Ann Intern Med. 1997 Nov 1;127(9):820-6.
Levy SB. Confronting multidrug resistance. A role for each of us. JAMA. 1993 Apr 14;269(14):1840-2. [pmid: 8459518].
Levy SB. The challenge of antibiotic resistance. Sci Am. 1998 Mar;278(3):46-53. [pmid: 9487702].
Levy SB, Fitzgerald GB, Macone AB. Changes in intestinal flora of farm personnel after introduction of a tetracycline-supplemented feed on a farm. N Engl J Med. 1976 Sep 9;295(11):583-8.
Lewison E. Comparison of the effectiveness of topical and oral nasal decongestants. Eye Ear Nose Throat Mon. 1970 Jan;49(1):16-8. [pmid: 4098115].
Lin R. A perspective on penicillin allergy. Arch Intern Med. 1992;152:930-7. [pmid: 1580718].
Lindbaek M, Hjortdahl P, Johnsen UL. Randomised, double blind, placebo controlled trial of penicillin V and amoxycillin in treatment of acute sinus infections in adults [see comments]. BMJ. 1996a Aug 10;313(7053):325-9. [pmcid: 28684].
Lindbaek M, Hjortdahl P, Johnsen UL. Use of symptoms, signs, and blood tests to diagnose acute sinus infections in primary care: Comparison with computer tomography. Fam Med. 1996b;28:183-8. [pmid: 8900550].
Linde K, Clausius N, Ramirez G, Melchart D, Eitel F, Hedges LV, Jonas WB. Are the clinical effects of homeopathy placebo effects? A meta-analysis of placebo-controlled trials. Lancet. 1997 Sep 20;350(9081):834-43.
Littenberg B, Moses LE. Estimating diagnostic accuracy from multiple conflicting reports: A new meta-analytic method. Med Decis Making. 1993 Oct;13(4):313-21.
Lloyd GA, Lund VJ, Scadding GK. CT of the paranasal sinuses and functional endoscopic surgery: A critical analysis of 100 symptomatic patients. J Laryngol Otol. 1991 Mar;105(3):181-5.
Lund VJ, Kennedy DW. Quantification for staging sinusitis. The Staging and Therapy Group. Ann Otol Rhinol Laryngol. 1995 Oct;167:17-21.
MacLeod B. Paranasal sinus radiography. [Review] [22 refs]. Emer Med Clin North Am. 1991 Nov;9(4):743-55.
Mahakit P, Pumhirun P. A preliminary study of nasal mucociliary clearance in smokers, sinusitis and allergic rhinitis patients. Asian Pac J Allergy Immunol. 1995 Dec;13(2):119-21.
Mantel N, Haenszel W. Statistical aspects of the analysis of data from retrospective studies of disease. J Natl Cancer Inst. 1959;22:719-48. [pmid: 13655060].
Manzini M, Caroggio A. Efficacy and tolerability of brodimoprim and roxithromycin in acute sinusitis of bacterial origin in adults. J Chemother. 1993 Dec;5(6):521-5.
Mason EO Jr, Kaplan SL, Lamberth LB, Tillman J. Increased rate of isolation of penicillin-resistant Streptococcus pneumoniae in a children's hospital and in vitro susceptibilities to antibiotics of potential therapeutic use. Antimicrob Agents Chemother. 1992 Aug;36(8):1703-7. [pmcid: 192034].
MathSoft. S-PLUS4 User's Guide, Data Analysis Products Division. Seattle, WA, 1977.
Matthews BL, Suprax/Amoxicillin Clinical Study Team. Effectiveness and safety of cefixine and amoxicillin in adults with acute bacterial sinusitis. Postgrad Med 1997 Spec Rpt:41-9.
Mattucci KF, Levin WJ, Habib MA. Acute bacterial sinusitis. Minocycline vs amoxicillin. Arch Otolaryngol Head Neck Surg. 1986 Jan;112(1):73-6.
McCaig LF, Hughes JM. Trends in antimicrobial drug prescribing among office-based physicians in the United States. JAMA. 1995 Jan;273(3):214-9.
McCormick DP, John SD, Swischuk LE, Uchida T. A double-blind, placebo-controlled trial of decongestant-antihistamine for the treatment of sinusitis in children. Clin Pediatr (Phila). 1996 Sep;35(9):457-60. [pmcid: 358331].
McNeill RA. Comparison of findings on transillumination, x-ray and lavage of the maxillary sinus. J Laryngol Otol 1962; 1009-13.
Meltzer EO. The prevalence and medical and economic impact of allergic rhinitis in the United States. J Allergy Clin Immunol. 1997 Jun;99(6 Pt 2):S805-S828. [pmid: 9215265].
Meltzer EO, Orgel HA, Backhaus JW, Busse WW, Druce HM, Metzger WJ, Mitchell DQ, Selner JC, Shapiro GG, Van Bavel JH et al. Intranasal flunisolide spray as an adjunct to oral antibiotic therapy for sinusitis. J Allergy Clin Immunol. 1993 Dec;92(6):812-23.
Moorhouse EC, Hickey MP, O'Hanrahan MT, Clarke PC. General practice studies with combined pivampicillin/pivmecillinam (Miraxid). Ir Med J. 1985 Nov;78(11):314-7.
Moran DG. A multicentre general practice study comparing pivampicillin (Pondocillin) and amoxycillin (Amoxil) in respiratory tract infections. J Int Med Res. 1983;11(6):370-4. [pmid: 6360752].
Moses LE, Shapiro D, Littenberg B. Combining independent studies of a diagnostic test into a summary ROC curve: Data-analytic approaches and some additional considerations. Stat Med. 1993 Jul 30;12(14):1293-316.
Muller O. Comparison of azithromycin versus clarithromycin in the treatment of patients with upper respiratory tract infections. J Antimicrob Chemother. 1993 Jun;31(Suppl E):137-46. [pmid: 8396085].
Muller O. An open comparative study of azithromycin and roxithromycin in the treatment of acute upper respiratory tract infections. J Antimicrob Chemother. 1996 Jun;37(Suppl C):83-92. [pmid: 8818849].
Mulrow C, Cook D, editors. Systematic reviews: Synthesis of best evidence for health care decisions. Philadelphia: American College of Physicians; 1998.
National Center for Health Statistics. National Ambulatory Medical Care Survey. CD-ROM 1990-1995; Series 13.
National Center for Health Statistics. National Hospital Discharge Survey. CD-ROM 1994; Series 13.
Nelson CT, Mason EO Jr, Kaplan SL. Activity of oral antibiotics in middle ear and sinus infections caused by penicillin-resistant Streptococcus pneumoniae: Implications for treatment. Pediatr Infect Dis J. 1994 Jul;13(7):585-9.
Neu HC. The crisis in antibiotic resistance. Science. 1992 Aug 21;257(5073):1064-73. [pmid: 1509257].
Nissinen A, Gronroos P, Huovinen P, et al. Development of beta-lactamase-mediated resistance to penicillin in middle-ear isolates of Moraxella catarrhalis in Finnish children, 1978-1993. Clin Infect Dis. 1995;21:1193-6. [pmid: 8589142].
Nord CE. Efficacy of penicillin treatment in purulent maxillary sinusitis. A European multicenter trial. Infection. 1988 Jul-Aug;16(4):209-14. [pmid: 3141290].
Nyffenegger R, Riebenfeld D, Macciocchi A. Brodimoprim versus amoxicillin in the treatment of acute sinusitis. Clin Ther. 1991 Sep-Oct;13(5):589-95.
O'Doherty B. An open comparative study of azithromycin versus cefaclor in the treatment of patients with upper respiratory tract infections. J Antimicrob Chemother. 1996 Jun;37(Suppl C):71-81. [pmid: 8818848].
Osman MF, Menday AP. Single-blind comparison of miraxid and co-trimoxazole in patients with sinusitis and otitis. In: Spitzy KH and Karrer K, editors. Proceedings of the 13 ^ th ^ International Congress of Chemotherapy. Vienna, Austria; 1983:26-9. SS 4.1/1-5.
Otte J, Viada JA, Buchi MD, Salgado O. Treatment of acute sinusal processes of adults with tetracycline and a combination of sulfamethopyrazine-trimethoprim. Rev Med Chil. 1983 Nov;111(11):1157-61.
Parsons DS, Wald ER. Otitis media and sinusitis: Similar diseases. Otolaryngol Clin North Am. 1996 Feb;29(1):11-25.
Patel K, Chavda SV, Violaris N, Pahor AL. Incidental paranasal sinus inflammatory changes in a British population. J Laryngol Otol. 1996 Jul;110(7):649-51.
Podvinec M. Co-tetroxazin (Tibirox) und Doxycyclin (Vibramycin) in der Behandlung von Infekten der oberen Luftwege: eine Doppelblindstudie. Ther Umschau. 1982;39:815-20.
Quick CA. Comparison of penicillin and trimethoprim-sulfamethoxazole in the treatment of ear, nose and throat infections. Can Med Assoc J. 1975 Jun 14;112(13 Spec No):83-6. [pmid: 805651].
Rahlfs VW, Macciocchi A, Monti T. Brodimoprim in upper respiratory tract infections. Clin Drug Invest. 1996;11(2):65-76.
Revonta M. Ultrasound in the diagnosis of maxillary and frontal sinusitis. Acta Otolaryngol Suppl (Stockh). 1980;370:1-55. [pmid: 6272532].
Rimmer D, Suprax/Amoxicillin Clinical Study Team. Efficacy of cefixime and amoxicillin in adults with actue sinusitis. Postgrad Med 1997 Spec Rpt:50-7.
Rodriguez WJ, Schwartz RH, Thorne MM. Increasing incidence of penicillin- and ampicillin-resistant middle ear pathogens. Pediatr Infect Dis J. 1995 Dec;14(12):1075-8.
Rohr AS, Spector SL, Siegel SC, Katz RM, Rachelefsky GS. Correlation between A-mode ultrasound and radiography in the diagnosis of maxillary sinusitis. J Allergy Clin Immunol. 1986 Jul;78(1 Pt 1):58-61.
Russell MD, Nolen T, Allen JM, Skuba K, DeRegis RG, Nicaise C. Cefprozil vs amoxicillin/clavunate in the treatment of acute, uncomplicated maxillary sinusitis in adults. Infections in Medicine. 1997 Mar;14(Suppl A):43-50.
Ryan RE. A double-blind clinical evaluation of bromelains in the treatment of acute sinusitis. Headache. 1967 Apr;7(1):13-7. [pmid: 4859824].
Salmi HA, Lehtomaki K, Kylmamaa T. Comparison of brodimoprim and doxycycline in acute respiratory tract infections. A double-blind clinical trial. Drugs Exp Clin Res. 1986;12(4):349-53. [pmid: 3522157].
Savolainen S, Pietola M, Kiukaanniemi H, Lappalainen E, Salminen M, Mikkonen P. An ultrasound device in the diagnosis of acute maxillary sinusitis. Acta Otolaryngol Suppl (Stockh). 1997;529:148-52. [pmid: 9288296].
Saxon A, Beall G, Rohr A, Adelman D. Immediate hypersensitivity reactions to beta-lactam antibiotics. Ann Intern Med. 1987;107:204-15. [pmid: 3300459].
Scandinavian Study Group. Loracarbef versus doxycycline in the treatment of acute bacterial maxillary sinusitis. Scandinavian Study Group. J Antimicrob Chemother. 1993 Jun;31(6):949-61.
Scheld WM, Sydnor A Jr, Farr B, Gratz JC, Gwaltney JM Jr. Comparison of cyclacillin and amoxicillin for therapy for acute maxillary sinusitis. Antimicrob Agents Chemother. 1986 Sep;30(3):350-3. [pmcid: 180459].
Schmid CH, Lau J, McIntosh M, Cappelleri JC. An empirical study of the effect of the control rate as a predictor of treatment efficacy in meta-analysis of clinical trials. Stat Med. 1998;17:1923-42. [pmid: 9777687].
Schulz KF, Chalmers I, Hayes RJ, Altman DG. Empirical evidence of bias: Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. 1995;273:408-12. [pmid: 7823387].
Seltzer AP. Adjunctive use of bromelains in sinusitis: A controlled study. Eye Ear Nose Throat Mon. 1967 Oct;46(10):1281-8. [pmid: 4864820].
Seppala H, Klaukka T, Lehtonen R, Nenonen E, Huovinen P. Outpatient use of erythromycin: Link to increased erythromycin resistance in group A streptococci. Clin Infect Dis. 1995;21:1378-85. [pmid: 8749619].
Seppala H, Klaukka T, Vuopio-Varkila J, Muotiala A, Helenius H, Lager K, Huovinen P. The effect of changes in the consumption of macrolide antibiotics on erythromycin resistance in group A streptococci in Finland. Finnish Study Group for Antimicrobial Resistance. N Engl J Med. 1997 Aug 14;337(7):441-6.
Sezik E, Yesilada E. Clinical effects of the fruit juice of Ecbalium elaterium in the treatment of sinusitis. J Toxicol Clin Toxicol. 1995;33(4):381-3. [pmid: 7629911].
Shapiro GG, Rachelefsky GS. Introduction and definition of sinusitis. J Allergy Clin Immunol. 1992 Sep;90(3 Pt 2):417-8.
Shenderey K, Marsh BT, Talbot DJ. A multi-centre general practice comparison of a fixed-dose combination of pivmecillinam plus pivampicillin with amoxycillin in respiratory tract infections. Pharmatherapeutica. 1985;4(5):300-5. [pmid: 4070323].
Skelton R, Maixner W, Isaacs D. Sinusitis-induced subdural empyema. Arch Dis Child. 1992;67:1478-80. [pmid: 1362638].
Small M, Dale BA. Intracranial suppuration 1968-1982 -- a 15 year review. Clin Otolaryngol. 1984 Dec;9(6):315-21.
Soderstrom M, Blomberg J, Christensen P, Hovelius B. Erythromycin and phenoxymethylpenicillin (penicillin V) in the treatment of respiratory tract infections as related to microbiological findings and serum C-reactive protein. Scand J Infect Dis. 1991;23(3):347-54. [pmid: 1909052].
Sonnenberg FA, Pauker SG, Kassirer JP. DecisionMaker 7.0^TM^. Pratt Medical Group. Boston, MA 1990.
Sorri M, Peltomaki E, Jokinen K. Bacampicillin in acute maxillary sinusitis: Concentration in sinus secretion and clinical effect. A randomized, double-blind study of two dosage regimens. Scand J Infect Dis. 1981;13(4):277-80. [pmid: 7031861].
Spector SL. Overview of comorbid associations of allergic rhinitis. J Allergy Clin Immunol. 1997 Feb;99(2):S773-S780. [pmid: 9042070].
Stalman W, van Essen GA, van der Graaf Y, de Melker RA. The end of antibiotic treatment in adults with acute sinusitis-like complaints in general practice? A placebo-controlled double-blind randomized doxycycline trial. Br J Gen Pract. 1997 Dec;47(425):794-9.
Stoller EP, Forster LE, Portugal S. Self-care responses to symptoms by older people. A health diary study of illness behavior. Med Care. 1993 Jan;31(1):24-42.
Suzuki K, Nishiyama Y, Sugiyama K, Miyamoto N, Baba S. Recent trends in clinical isolates from paranasal sinusitis. Acta Otolaryngol Suppl (Stockh). 1996;525:51-5. [pmid: 8908270].
Sydnor A Jr, Gwaltney JM Jr, Cocchetto DM, Scheld WM. Comparative evaluation of cefuroxime axetil and cefaclor for treatment of acute bacterial maxillary sinusitis. Arch Otolaryngol Head Neck Surg. 1989 Dec;115(12):1430-3.
Sydnor TA Jr, Scheld WM, Gwaltney J Jr, Nielsen RW, Huck W, Therasse DG. Loracarbef (LY 163892) vs amoxicillin/clavulanate in bacterial maxillary sinusitis. Ear Nose Throat J. 1992 May;71(5):225-32.
Taub SJ. The use of bromelains in sinusitis: a double-blind clinical evaluation. Eye Ear Nose Throat. Mon 1967 Mar;46(3):361-1 passim.
Turner BW, Cail WS, Hendley JO, Hayden FG, Doyle WJ, Sorrentino JV, Gwaltney JM Jr. Physiologic abnormalities in the paranasal sinuses during experimental rhinovirus colds. J Allergy Clin Immunol. 1992 Sep;90(3 Pt 2):474-8.
Ueda D, Yoto Y. The ten-day mark as a practical diagnostic approach for acute paranasal sinusitis in children. Pediatr Infect Dis. 1996;15:576-9.
Urdal K, Berdal P. The microbial flora in 81 cases of maxillary sinusitis. Acta Otolaryngol (Stockh). 1949;37:20-5.
van Buchem L, Peeters M, Beaumont J, Knottnerus JA. Acute maxillary sinusitis in general practice: The relation between clinical picture and objective findings. Eur J Gen Pract. 1995;1:155-60.
van Buchem FL, Knottnerus JA, Schrijnemaekers VJ, Peeters MF. Primary-care-based randomised placebo-controlled trial of antibiotic treatment in acute maxillary sinusitis [see comments]. Lancet. 1997 Mar 8;349(9053):683-7.
Van Cauwenberge P, Verschraegen G, Van Renterghem L. Bacteriological findings in sinusitis (1963-1975). Scand J Infect Dis Suppl. 1976;(9):72-7. [pmid: 1070150].
van Duijn NP, Brouwer HJ, Lamberts H. Use of symptoms and signs to diagnose maxillary sinusitis in general practice: Comparison with ultrasonography [see comments]. BMJ. 1992 Sep 19;305(6855):684-7. [pmcid: 27737].
Varonen H, Mäkelä M, Savolainen S, Läärä E, Jorgen H. Comparison of ultrasound, radiography and clinical examination in the diagnosis of acute maxillary sinusitis: A systematic review. Unpublished.
von Sydow C, Axelsson A, Jensen C. Treatment of acute maxillary sinusitis. Erythromycin base and phenoxymethyl-penicillin (penicillin V). Rhinology. 1984 Dec;22(4):247-54.
von Sydow C, Savolainen S, Soderqvist A. Treatment of acute maxillary sinusitis -- comparing cefpodoxime proxetil with amoxicillin. Scand J Infect Dis. 1995;27(3):229-34. [pmid: 8539546].
von Sydow C, Einarsson S, Grafford K, Hansson P, Jensen C. Bacampicillin twice daily in acute maxillary sinusitis: An alternative dosage regimen. J Antimicrob Chemother. 1981 Nov;8(Suppl C):109-14. [pmid: 7033200].
Wald ER. Anaerobes in otitis media and sinusitis. Ann Otol Rhinol Laryngol Suppl. 1991 Sep;154:14-6. [pmid: 1952678].
Wald ER. Rhinitis and acute and chronis sinusitis. In: Bluestone ED, editor. Pediatric otolaryngology. 3 ^ rd ^ ed. Philadelphia: Saunders; 1996. p. 845-6.
Wald ER, Chiponis D, Ledesma-Medina J. Comparative effectiveness of amoxicillin and amoxicillin-clavulanate potassium in acute paranasal sinus infections in children: A double-blind, placebo-controlled trial. Pediatrics. 1986 Jun;77(6):795-800. [pmcid: 116575].
Wald ER, Guerra N, Byers C. Upper respiratory infections in young children: Duration of and frequency of complications. Pediatrics. 1991 Feb;87(2):129-33.
Wald ER, Reilly JS, Casselbrant M, Ledesma-Medina J, Milmoe, GJ, Bluestone CD, Chiponis D. Treatment of acute maxillary sinusitis in childhood comparative study of amoxicillin and cefaclor. J Pediatr. 1984 Feb;104(2):297-302.
Wallace RB, Marsh BT, Talbot DJ. A multi-centre general practice clinical evaluation of pivmecillinam plus pivampicillin ("Miraxid") and co-trimoxazole ("Septrin") in respiratory tract infections. Curr Med Res Opin. 1985;9(10):659-65. [pmid: 3907987].
Werk LN, Bauchner H. Practical considerations when treating children with antimicrobials in the outpatient setting. Drugs. 1998 Jun;55(6):779-90.
Westerman T, Panzer JD, Atkinson WH. Comparative efficacy of clindamycin HCl and tetracycline HCl in acute sinusitis. Eye Ear Nose Throat Mon. 1975 Jun;54(6):236-8.
Wiesenauer M, Gaus W, Bohnacker U, Haussler S. Efficiency of homeopathic preparation combinations in sinusitis. Results of a randomized double blind study with general practitioners. Arzneimittelforschung. 1989 May;39(5):620-5.
Wiklund L, Stierna P, Berglund R, Westrin KM, Tonnesson M. The efficacy of oxymetazoline administered with a nasal bellows container and combined with oral phenoxymethyl-penicillin in the treatment of acute maxillary sinusitis. Acta Otolaryngol Suppl (Stockh). 1994;515:57-64. [pmid: 8067245].
Williams JW, Roberts L, Distell B, Simel DL. Diagnosing sinusitis by X-ray: Is a single view adequate?. J Gen Intern Med. 1992 Sep;7(5):481-5.
Williams JW Jr, Simel DL, Roberts L, Samsa GP. Clinical evaluation for sinusitis. Making the diagnosis by history and physical examination [see comments]. Ann Intern Med. 1992 Nov 1;117(9):705-10.
Williams JW Jr, Simel DL. Does this patient have sinusitis? Diagnosing acute sinusitis by history and physical examination. JAMA. 1993 Sep;270(10):1242-6.
Williams JW Jr, Holleman DR Jr, Samsa GP, Simel DL. Randomized controlled trial of 3 vs 10 days of trimethoprim/sulfamethoxazole for acute maxillary sinusitis [see comments]. JAMA. 1995 Apr 5;273(13):1015-21.
Williams JW Jr, Aguilar C, Makela M, Cornell J, Hollman D, Chiquette E, Simel D. Antibiotic therapy for acute sinusitis: A systematic literature review. In: Douglas R, Bridges-Webb C, Glasziou P, Lozano J, Steinhoff M, Wang E, editors. Acute respiratory infections module of the Cochrane database of systematic reviews [updated 03 June 1997]. The Cochrane Library [database on disk and CD-ROM]. The Cochrane Collaboration. Oxford: Update Software; 1997; Issue 4.
Winther B, Gwaltney JM Jr. Therapeutic approach to sinusitis: Anti-infectious therapy as the baseline of management. Otolaryngol Head Neck Surg. 1990 Nov;103(5(Pt 2)):876-8.
Wispelwey B, Scheld WM. Brain abscess. In: Mandell GL, Douglas RG, Bennett JE, Dolin R, editors. Principles and practice of infectious diseases. 4 ^ th ^ ed. New York: Churchill Livingstone; 1995. p. 887-98.
Wright AL, Holberg CJ, Martinez FD, Halouen M, Morgan W, Toussig LM. Epidemiology of physician-diagnosed allergic rhinitis in childhood. Pediatrics. 1994 Dec;94(6(Pt 1)):895-901. [pmcid: 524358].
Wuolijoki E, Flygare U, Hilden M, Hurme J, Jarvinen H, Leskinen J, Pynnonen S, Riikonen A, Salomaa V, Seuri M et al. Treatment of respiratory tract infections with erythromycin acistrate and two formulations of erythromycin base. J Antimicrob Chemother. 1988 Jun;21(Suppl D):107-12.
Zeckel ML, Johns D Jr, Masica DN, Farlow D. Twice-daily dosing of loracarbef 200 mg versus 400 mg in the treatment of patients with acute maxillary sinusitis. Clin Ther. 1995 Mar-Apr;17(2):214-30.