# Acknowledgments

We thank our colleagues, Helena Varonen, Marjukka Mäkelä, Seppo Savolainen, and Esa Läärä, from Finland, and Jörgen Hilden from Denmark, for generously providing us with a copy of their manuscript on a meta-analysis of the diagnostic tests for acute sinusitis. We would like to give special thanks to Dr. Varonen for her assistance in extracting the necessary data from a Finnish language article.

We thank the technical experts representing the partner organizations for their most valuable contributions. They provided critical insights on this topic, reviewed an earlier draft of this report, and provided prompt assistance when requested. We also thank our patient representatives for taking time out to provide important insights from the patient's perspective in the clinical management of this condition.

We are very grateful to the British Medical Journal for permission to use in the evidence report substantial portions of the material, including text, tables, and figures, from a meta-analysis authored by several EPC members.