# Results

## MEDLINE Search Results

The primary MEDLINE search strategy yielded 4,070 English language titles. Additional search strategies along with secondary sources and subsequent MEDLINE updates yielded an additional 38 articles, bringing the total number of records to 4,108.

Screening of the abstracts and articles identified about 330 articles potentially useful to address the five questions formulated by the advisory group, and these were retrieved for review. Detailed examination of these articles identified 49 prospective comparisons of diagnostic tests or clinical criteria and 83 randomized controlled treatment trials. Of the antibiotic treatment trials, 72 articles reported 74 comparisons that met the basic inclusion criteria as outlined for the evidence report. Detailed data abstraction was performed on studies that met inclusion criteria for meta-analyses: 14 comparisons of diagnostic studies and 30 randomized controlled trials. In addition, even though not used in a meta-analysis, data were extracted from the 10 randomized ancillary treatment trials. The results of the detailed data extraction are presented in the evidence tables.

## Foreign Language Studies

We performed a MEDLINE search to assess the potential bias of excluding non-English articles in the primary search strategy. Over 3,200 foreign language titles were retrieved using the text word, "sinusitis" and "human" and "not English" between 1966 and February 1998. The number of non-English articles represents 43 percent of the total number of MEDLINE indexed articles using the search strategy of "sinusitis" and "human."

English translations of the titles and abstracts of the non-English articles were screened using a low threshold for retrieving the full paper for further examination. Additional analyses were performed to examine the distribution of specific foreign languages and their publication rate over time (Table 5). We also provided a breakdown of potentially usable non-English studies in Table 6.

Table 5. Results of MEDLINE search for non-English articles

| MEDLINE | MED93 | MED90 | MED85 | MED80 | MED75 | MED66
| 1995-98 | 1993-94 | 1990-92 | 1985-89 | 1980-84 | 1975-79 | 1966-74 | Subtotal
All sinusitis and human | 1,194 | 687 | 975 | 1,284 | 953 | 810 | 1,525 | 7,428
English only | 942 | 514 | 654 | 771 | 551 | 339 | 435 | 4,206
non-English | 252 | 173 | 321 | 513 | 402 | 471 | 1,090 | 3,222
Percentage non-English | 21% | 25% | 33% | 40% | 42% | 58% | 71% | 43%
Russian | 48 | 21 | 68 | 120 | 69 | 148 | 276 | 750
German | 54 | 30 | 53 | 120 | 124 | 130 | 235 | 746
French | 31 | 33 | 61 | 65 | 59 | 55 | 146 | 450
Japanese | 37 | 24 | 53 | 76 | 40 | 28 | 171 | 429
Spanish | 36 | 25 | 24 | 32 | 12 | 6 | 25 | 160
Italian | 12 | 6 | 18 | 16 | 18 | 14 | 70 | 154
Polish | 6 | 10 | 8 | 12 | 23 | 21 | 41 | 121
Rumanian | 1 | 0 | 1 | 13 | 13 | 24 | 37 | 89
Dutch | 3 | 3 | 5 | 15 | 13 | 6 | 9 | 54
Czech | 1 | 0 | 1 | 6 | 12 | 11 | 15 | 46
Chinese | 13 | 4 | 8 | 9 | 2 | 0 | 2 | 38
Portuguese | 0 | 3 | 1 | 0 | 2 | 2 | 17 | 25
Danish | 2 | 2 | 5 | 6 | 1 | 2 | 6 | 24
Serbo-Croatian | 1 | 1 | 6 | 7 | 3 | 8 | 6 | 32
Hungarian | 0 | 0 | 0 | 0 | 1 | 4 | 16 | 21
Norwegian | 1 | 5 | 1 | 1 | 0 | 2 | 7 | 17
Swedish | 2 | 4 | 2 | 2 | 3 | 1 | 3 | 17
Finnish | 0 | 0 | 3 | 3 | 1 | 2 | 4 | 13
Slovak | 1 | 0 | 0 | 6 | 1 | 1 | 2 | 11
Hebrew | 1 | 2 | 1 | 0 | 4 | 1 | 0 | 9
Bulgarian | 1 | 0 | 0 | 0 | 0 | 5 | 0 | 6
Turkish | 0 | 0 | 1 | 2 | 0 | 0 | 0 | 3
Ukraine | 1 | 0 | 0 | 0 | 0 | 0 | 1 | 2
Korean | 0 | 0 | 0 | 2 | 0 | 0 | 0 | 2
Afrikaans | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 1
Multilingual | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 1
Thai | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 1

Table 6. Screening of MEDLINE-indexed non-English articles

MEDLINE file | Medline | MED93 | MED90 | MED85 | MED80 | MED75 | MED66
| 1995-98 | 1993-94 | 1990-92 | 1985-89 | 1980-84 | 1975-79 | 1966-74 | Subtotal
All sinusitis and human | 1,194 | 687 | 975 | 1,284 | 953 | 810 | 1,525 | 7,428
English only | 942 | 514 | 654 | 771 | 551 | 339 | 435 | 4,206
non-English | 252 | 173 | 321 | 513 | 402 | 471 | 1,090 | 3,222
Percentage non-English | 21% | 25% | 33% | 40% | 42% | 58% | 71% | 43%
Treatment comparisons
Screened in by title | 2 | 3 | 3 | 4 | 3 | 1 | | 16
Language | Ger, Fre | Rus, Fre, Spa | Dut, Fre, Fre | Spa, Ita, Ger(2) | Ger(2), Spa | Rus
? Suitable | 0 | 0 | 1 (Fre) | 1 (Ger) | 2 (Ger, Spa) | 0
Rejected by abstract, MH | 1 (Ger) | 1 (Rus) | 0 | 0 | 0 | 1
Meets criteria for M-A | | | | | | 0
Diagnostic studies
Screened in by title | 1 | 2 | 1 | 1 | 1 | 2 | | 8
Language | Ita | Rus, Jpn | Ita | Ger | Dut | Ger (2)
? Suitable | 0 | 1 (Jpn) | 1 (Ita) | 0 | 1 (Dut) | 2 (Ger)
Rejected by abstract, MH | 1 (Ita) | 1 (Rus) | 0 | 1 (Ger) | 0
Meets criteria for M-A | 0 | | | 0

Shown in Table 5 are the results of the non-English MEDLINE search. It is interesting to note that between the years 1966 through 1979, there were more non-English than English articles indexed in MEDLINE (58 to 71 percent) on this topic. In recent years, the percentage of non-English articles fell, down to 21 percent for the last 3 years. The actual number of non-English articles also has decreased despite an increase in the total number of articles. Non-English articles were published in 28 different languages; many of these articles were published in Russian (23.3 percent), followed by German (23.1 percent), French (14 percent), and Japanese (13.3 percent).

Screening of the non-English abstracts identified through MEDLINE found few potentially usable studies (Table 6). Several non-English studies that were used in our meta-analyses had already been identified through other methods described in Chapter 2. Therefore, despite the large number of non-English articles, we were confident that using primarily English language articles would not adversely bias our results.

## Summary of Evidence Found

Evidence Tables 1-24 provide information about the characteristics and results of the studies supporting conclusions in the evidence report and in the meta-analyses. In addition to the diagnostic criteria, several important study characteristics are described here.

### Use of Sinus Puncture as the Research Diagnostic Reference Standard

The research reference standard for verification of bacterial infection of the sinuses relies on microbiologic culture of sinus aspirates. Of the studies reviewed for inclusion in this evidence report, 7 of 14 studies of diagnostic test comparisons, 5 of 30 antibiotic treatment trials, and none of the 10 ancillary treatment trials used this technique for evaluation. The procedure requires technical expertise and is invasive, which may account in part for its low rate of utilization, particularly in treatment evaluations (Laine, Maättä, Varonen, et al., 1998; van Buchem, Peeters, Beaumont, et al., 1995). Anatomy of the sinus cavities limits current sinus puncture sampling to aspirates of the maxillary sinuses, and as such, use of this reference standard in research leads to direct conclusions regarding maxillary sinus infections and not infections of other sinuses (Gwaltney, Scheld, Sande, et al., 1992). Data comparing microbial flora from infected maxillaryand frontal sinuses in individual patients correlated well but are very limited (Antila, Suonpaa, and Lehtonen, 1997).

### Duration of Symptoms

One of the criteria for paper inclusion was study of patients with acute bacterial rhinosinusitis defined as symptoms of 4 weeks duration or less. Review of the literature revealed that many of the papers only specified "acute" without providing specific time periods. This was true for studies of the diagnostic tests (Evidence Tables 3-6) as well as studies of both antibiotic (Evidence Tables 15-17) and ancillary (Evidence Tables 22-24) treatments. In some instances, the duration of symptoms was reported as a mean value. In these cases, studies reporting mean estimates of 4 weeks or less were included. The lack of clearer definition of the populations used in these research studies raises questions regarding the validity of directly comparing the results of different studies and applying these results to specific patient populations.

### Patient Age

Most studies of diagnostic tests focused on adult populations. In many studies, patients under 18 years of age were also included (usually teenagers), but the reported results did not distinguish these distinct age groups. Two studies comparing radiography with puncture did include patients as young as 7 and 10 years old (McNeill, 1962, and Revonta, 1980, respectively) but did not separately report the pediatric population findings. One study from Sweden (Jannert, Andreasson, Helin, et al., 1982) compared clinical examination and radiography in a solely pediatric population. Other pediatric population studies (Wald, Chiponis, and Ledesma-Medina, 1986; Wald, Reilly, Casselbrant, et al., 1984) reported on the results of diagnostic studies in their patients but did not perform all tests on all patients, precluding use of these data for diagnostic test comparisons.

Most studies on antibiotic treatment of rhinosinusitis used adult populations. Two studies focused specifically on pediatric populations (Wald, Chiponis, and Ledesma-Medina, 1986; Wald, Reilly, Casselbrant, et al., 1984). Although adult medicine in the United States usually includes patients over 18, many of the trials also included some younger patients, from as young as 10 years old (Wallace, Marsh, and Talbot, 1985), within their study populations. In these studies, however, reported results did not distinguish between the adult and pediatric patients.

Among studies of ancillary treatments, two studies focused specifically on pediatric populations, each testing different ancillary medications (Barlan, Erkan, Bakir et al., 1997; McCormick, John, Swischuk, et al., 1996). Most of the other ancillary treatment trials included some pediatric patients (most over 9 years of age) but did not separately analyze the outcomes for these patients as compared with the adults.

## Evidence Found Regarding Key Questions

Evidence for the key questions addressed in this evidence report are derived from two supplemental analyses: Meta-analyses of Diagnostic Tests (Attachment B) and Meta-analyses of Antibiotic Treatments (Attachment C). Details of these analyses can be found in those attachments. The main results are summarized here.

1. What is the prevalence of acute bacterial infection in patients presenting with acute rhinosinusitis in primary care and specialty settings?

Prevalence is defined as the proportion of subjects in a population with a defined condition at a given time. Therefore, it is clear that determinations of the prevalence of acute bacterial rhinosinusitis will be affected by definition of the condition, criteria used for diagnosis, and the population chosen for study. Lack of consensus in the definition and criteria for diagnosis of acute bacterial rhinosinusitis has led to difficulty in determining the prevalence of this condition. For this evidence report, criteria used to identify studies on acute bacterial rhinosinusitis included enrollment of patients with sinus symptoms lasting less than 4 weeks. In addition, a sinus puncture aspirate positive for bacterial infection was defined as the reference standard for diagnosis. Although sinus puncture techniques are limited to evaluation of maxillary sinus aspirates, evaluation of the studies using this diagnostic reference standard permits comparisons of prevalence estimates using a standardized method for diagnosis in patients with acute disease. We therefore reviewed these data for prevalence determinations.

The diagnostic studies that used sinus aspiration/puncture as a reference test provided evidence that approximately one-half of such patients in a general medical clinic will have aspiration-proven sinusitis (Kuusela, Kurri, and Sirola, 1982; Laine, Maättä, Varonen, et al., 1998; van Buchem, Peeters, Beaumont, et al., 1995), whereas in otolaryngology clinics, the prevalence of bacterial rhinosinusitis in patients with nasal symptoms or maxillary pain may be as high as 83 percent (Savolainen, Pietola, Kiukaanniemi, et al., 1997). Although the prevalence of acute bacterial rhinosinusitis in actual primary care settings could be lower than that observed in clinic-based studies, at least two of these studies documented efforts to evaluate relatively unselected patients (Savolainen, Pietola, Kiukaanniemi, et al., 1997; van Buchem, Peeters, Beaumont, et al., 1995). The study by Berg and Carenfelt (1988) looking at patients presenting to the emergency department reported puncture-positive sinusitis in 44 percent of patients. Estimates from the antibiotic treatment trials that used sinus puncture for verification of bacterial rhinosinusitis (Evidence Table 16) reported prevalence estimates from 34 to 87 percent. In pediatric populations, studies have reported a prevalence of acute bacterial rhinosinusitis of 70 to 80 percent (Wald, Chiponis, and Ledesma-Medina, 1986; Wald, Reilly, Casselbrant, et al., 1984).

The wide variation in prevalence estimates among these studies, all of which used the diagnostic reference standard, highlights the difficulty in assessing prevalence and comparing estimates from different studies. Although some of the variation may result from differences in sinus puncture technique, aspirate processing, and bacteriologic evaluation, other factors (e.g., patient characteristics, geographic location, seasonal variation) which can affect disease development and population selection may play a role (Axelsson and Brorson, 1972).

As noted above, primary care vs. referral/specialty clinics would be expected to draw different populations. Add to that the potential selection bias due to research protocols, such as the use of sinus puncture. In addition to the aforementioned limitation of sinus puncture to maxillary sinus evaluation, studies have raised concerns that patients' fears and researchers' ethical concerns may be potential sources of selection bias. Laine, Maättä, Varonen, et al. (1998) reported increasing difficulty recruiting patients because of the use of sinus puncture in their protocol. Citing ethical concerns, van Buchem, Peeters, Beaumont, et al. (1995) reported a change in protocol for later patient enrollees such that sinus puncture was performed only in patients with radiographic findings suggestive of rhinosinusitis. Sinus puncture may be the most valid reference standard for diagnosing patients, but the pain, need for referral, and cost attendant to puncture preclude its routine use in primary care settings and have prompted use of alternative tests for diagnosis. Using four-view sinus radiography as the diagnostic criterion, Williams, Simel, Roberts, et al. (1992) reported that 38 percent of the 247 patients seen in an outpatient veterans hospital setting presenting with symptoms suggestive of rhinosinusitis had evidence of sinus infection. In this study, not only were the criteria for diagnosis different, but the population was preselected. The patients enrolled in this study were reported to be approximately 1 percent of all the patients presenting to the participating clinics during the study period.

Similar preselection was reported in the study by Aitkin and Taylor (1998), which used clinical criteria to determine the prevalence of acute bacterial rhinosinusitis in a pediatric outpatient clinic. In their study, the overall prevalence was estimated at 9.3 percent, although in patients presenting with cold/cough symptoms, the prevalence was 17.3 percent. Clearly, prescreening (to varying extents) can significantly affect prevalence estimates.

Good evidence on the prevalence of acute bacterial rhinosinusitis in the general population and in general primary care practices is lacking. As studies evaluate the prevalence in larger populations, the methods for diagnosis are less well defined. Gwaltney (1996) estimated the prevalence of acute bacterial rhinosinusitis based on estimates of viral infections and estimates of the frequency of bacterial infections presumed to complicate the common cold. Again, however, this latter estimate is from studies (Berg, Carenfelt, Rystedt, et al., 1986; Dingle, Badge, and Jordan, 1964) in which sinus aspirate cultures were not performed.

In contrast to extrapolating from smaller studies to the entire population, alternative approaches to directly ascertain community prevalence include surveying individuals' rhinosinusitis (e.g., National Health Interview Survey) or using reimbursement claims data (e.g., National Ambulatory Medical Care Survey, National Hospital Discharge Survey). These approaches have several limitations. For example, the National Health Interview Survey does not specifically assess acute bacterial rhinosinusitis, and hospital discharge data (National Hospital Discharge Survey) clearly represent a selected population not typical for the majority of cases of acute bacterial rhinosinusitis. In addition, both the National Ambulatory Medical Care Survey and the National Hospital Discharge Survey, although based on clinically assessed cases, are financial reimbursement estimates and as such do not focus directly on the clinical aspects of the condition.

Although additional examples and prevalence estimates can be presented, depending on one's specific goal in determining the disease prevalence, different studies may provide the "best currently available" estimate. It is evident from the confusion, however, that increased information regarding the comparability of diagnostic tests is needed. In addition, it is critical that studies report in detail the methods used in the selection of patients to permit better clarification of the changing universe of patients being evaluated and to allow for validation and use of the data.

2. What is the diagnostic value of clinical features/imaging modalities for identifying acute rhinosinusitis and acute bacterial rhinosinusitis?

Sinus aspiration and culture make up the reference standard for the diagnosis of bacterial rhinosinusitis. In addition to needle aspiration, alternative sampling procedures for microbiologic culture have included nasal swabs and endoscopic sampling. Clinical criteria may include elements of the patient's history and physical findings such as facial pain, nasal discharge, olfactory disturbance, or fever. Sometimes, several clinical criteria are combined to obtain a clinical risk score. Imaging modalities have included sinus radiography (using two to four radiographs all including the occipitomental [Water's] view), computed tomography, magnetic resonance imaging, ultrasound scanning (A-mode), and transillumination. Imaging studies assess mucosal wall thickness, sinus fluid, and sinus opacity.

Attachment B presents a detailed description of the meta-analysis of diagnostic tests and the results. The key results are reproduced here. We found only one study comparing computed tomography with sinus radiograph (Burke, Guertler, and Timmons, 1994). This study of 29 patients reported that sinus computed tomography is more sensitive than sinus radiography in diagnosing sinusitis. This study did not use sinus puncture as the reference standard, and the comparison was based on a subset of patients with a clinical diagnosis of sinusitis.

### Sinus Radiograph Compared with Sinus Puncture

Six studies compared sinus radiographs with sinus puncture (Kuusela, Kurri, and Sirola, 1982; Laine, Maättä, Varonen, et al., 1998; McNeill, 1962; Revonta, 1980; Savolainen, Pietola, Kiukaanniemi, et al., 1997; van Buchem, Peeters, Beaumont, et al., 1995). Each of the studies used a series of three or four radiographs; all included the occipitomental (Water's) view. Because three studies provided more than one comparison of test performance, 10 values of sensitivity and specificity were available for analysis.

Figure 5 displays these 10 values of sensitivity and specificity and the SROC curve derived from them. The 10 data points appear to be well described by the curve. Shown as dark gray ellipses are the five observations of sensitivity and specificity using the criterion "sinus fluid or opacity" to define positive radiographs. Shown as light gray ellipses are the three observations based on the criterion "sinus fluid or opacity or mucous membrane thickening" to define positive radiographs. The remaining two estimates are shown as white ellipses: One of these studies used the criterion "opacification of sinus," and the explicit criteria defining a positive radiograph were not available for one estimate.

Figure 5. SROC curve analysis of sinus radiography compared with that of sinus puncture

Each of the comparisons is plotted as an ellipse. The size of the ellipse is proportional to study size. 95% confidence intervals (CI) are shown. The "X" represents the estimate and the rectange represents the 95% CI of the random effects average. The curve line is the SROC curve.

Adding "mucous membrane thickening" as one of the criteria for a positive radiograph increased the sensitivity of radiographs and decreased their specificity. The random effects estimates for sensitivity and specificity, using "fluid or opacity" as the definition of a positive radiograph, were 0.73 (95 percent confidence interval [CI], 0.60-0.83) and 0.80 (0.71-0.87), respectively. With the definition of positive radiograph "sinus fluid or opacity or mucous membrane thickening," the estimates for sensitivity and specificity were 0.90 (0.68-0.97) and 0.61 (0.20-0.91), respectively. These random-effects estimates and confidence intervals are displayed as "X's " and rectangles in Figure 6. With positive radiographs restricted to "opacification of sinus," specificity increased only slightly to 0.85 (0.76-0.91), but sensitivity decreased dramatically to 0.41 (0.33-0.49). The area under the weighted SROC curve was 0.83.

Figure 6. Subgroup SROC curve analysis of sinus radiography compared with that of sinus puncture

### Clinical Criteria Compared with Sinus Puncture

A single study compared clinical criteria with sinus puncture (Berg and Carenfelt, 1988). This study reported data on clinicians' overall impression and also provided a risk score derived from the number of findings present from the following four-item list: purulent rhinorrhea with unilateral predominance, local pain with unilateral predominance, bilateral purulent rhinorrhea, and presence of pus in the nasal cavity.

Figure 7 plots the five values of sensitivity and specificity derived from this report. The four-item risk score (shown with dark gray ellipses) appears to have better discrimination than the overall clinical impression (white ellipse); the SROC curve, fit only to the risk score thresholds, has an area-under-the-curve of 0.91.

Figure 7. SROC curve analysis of clinical criteria compared with that of sinus puncture

Unfortunately, characteristics of this study throw into question its internal validity. First, the reference test, sinus puncture and aspiration, is poorly described because it is not clear whether radiography was used in conjunction with aspiration in identifying those with sinusitis. Second, it is unclear how to use both "purulent rhinorrhea with unilateral predominance" and "bilateral purulent rhinorrhea" as independent risk-score predictors of sinusitis.

### Clinical Examination Compared with Sinus Radiography

Three studies evaluated clinical examination in comparison to sinus radiographs. One study compared an otolaryngologist's overall clinical impression with sinus radiography (Axelsson and Runze, 1976). The study by Jannert, Andreasson, Helin, et al. (1982) evaluated a clinical risk score for children in which individuals could have 0 to 3 of the following findings: purulent nasal secretions on examination, history of upper respiratory infection during the 2 weeks prior to presenting symptoms, and sinus pain or tenderness. The study by Williams, Simel, Roberts, et al. (1992) evaluated a clinical risk score for adults in which individuals could have 0 to 5 of the following findings: maxillary toothache, abnormal transillumination, poor response to decongestants, purulent secretions on examination, and colored nasal discharge by history. The Williams, et al., (1992) study also included data for overall clinical impressions of "intermediate" or "high" probability of bacterial rhinosinusitis. There were therefore 11 values of sensitivity and specificity available for analysis.

Figure 8 displays these 11 values of sensitivity and specificity and the SROC curve. The data points are well described by the SROC curve. The risk score results, shown as gray ellipses, appear to have similar discrimination to the overall impressions of clinicians, shown as white ellipses. The area under the weighted SROC curve was 0.74.

Figure 8. SROC curve analysis of clinical criteria compared with that of sinus radiography

### Ultrasound Compared with Sinus Puncture or Radiography

Five reports provided data comparing ultrasound of the sinuses with sinus aspiration (Kuusela, Kurri, and Sirola, 1982; Laine, Maättä, Varonen, et al., 1998; Revonta, 1992; Savolainen, Pietola, Kiukaanniemi, et al., 1997; van Buchem, Peeters, Beaumont, et al., 1995). Reports provided data on more than one set of patients or for more than one diagnostic cut-point, so there were 10 values of sensitivity and specificity available for analysis (Figure 9). Of note, these points do not appear well described by the SROC curve, implying that variability in test performance is present. Ultrasound performance appeared to be poorest in the study by Laine, Maättä, Varonen, et al. (1998) (shown as a white ellipse in Figure 9); this was the only study in which untrained primary care physicians performed and interpreted the ultrasounds.

Figure 9. SROC curve analysis of ultrasonography compared with that of sinus puncture

Three reports provided data for five comparisons of ultrasound to sinus radiograph (Figure 10) (Berg and Carenfelt, 1985; Jensen and von Sydow, 1987; Rohr, Spector, Siegel, et al., 1986). It is difficult to interpret these comparisons because the five data points fall close together in the SROC plot, and it is unclear how well the SROC curve describes them or how the SROC curve can be extrapolated.

Figure 10. SROC curve analysis of ultrasonography compared with that of sinus radiography

### Clinical Examination Compared with Ultrasound

A single study compared findings on clinical examination with ultrasound (van Duijn, Brouwer, and Lamberts, 1992). Although this study provided data on sensitivity and specificity of individual clinical symptoms and signs, it provided no data for an overall clinical impression or risk score. However, summarizing data from this study, a published meta-analysis reported a sensitivity of 0.36 (95 percent CI, interval 0.29-0.43) and specificity of 0.90 (0.85-0.93) for clinical examination compared with ultrasound (de Bock, Houwing-Duistermaat, Springer, et al., 1994).

3. Given a (clinical) diagnosis of acute bacterial rhinosinusitis, are antibiotics effective in resolving symptoms and in preventing complications or recurrence?

The evidence to answer this question and question 4 is based on a meta-analysis of randomized controlled trials of antibiotic treatment for acute bacterial rhinosinusitis recently published by EPC members (de Ferranti, Ioannidis, Lau, et al., 1998). Attachment C presents a detailed description of the meta-analysis of antibiotic treatment trials and the results. The key results are reproduced here.

Six studies compared any antibiotics against placebo (Axelsson, Chidekel, Greblius, et al., 1970; Ganaça and Trabulsi, 1973; Lindbaek, Hjortdahl, and Johnson, 1996a; Stalman, van Essen, van der Graaf, et al., 1997; van Buchem, Knottnerus, Schrijnemackers, et al., 1997; Wald, Chiponis, and Ledesma-Medina, 1986) (Evidence Table 13 and Figure 11). Antibiotics were significantly more effective than placebo, reducing treatment failures by almost one-half. However, symptoms improved or were cured in 69 percent of patients without any antibiotic treatment at all (95 percent CI, 57 to 79 percent). Although the observed heterogeneity did not reach statistical significance, there was a suggestion that one trial (Stalman, van Essen, van der Graaf, et al., 1997) that included patients simply on the basis of sinusitis-like symptoms without further diagnostic documentation had the highest cure or improvement rates in the placebo group (85 percent at 10 days) and showed absolutely no benefit from antibiotics, whereas trials with more tightly defined patient populations and lower spontaneous improvement rates showed a more clear benefit from antibiotics.

Figure 11. Meta-analysis of antibiotics vs. placebo randomized controlled trials

4a. In treatment of acute bacterial rhinosinusitis, what is the efficacy of antibiotics compared with that of placebo, and among the various antibiotics, what is their comparative efficacy?

Fourteen trials compared newer antibiotics, most of which have an expanded spectrum of activity, to amoxicillin (Evidence Table 14 and Figure 12). First, the agents of our comparative arms were heterogeneous. By and large, they are all substantially more expensive than amoxicillin or folate inhibitors. However, their antibacterial profile is not identical. Some of the newer agents have a very broad spectrum that should readily encompass β-lactamase producing strains of H. influenzae and M. catarrhalis (e.g., amoxicillin-clavulanic acid, cefuroxime axetil, and cefixime). Others, such as the macrolides (azithromycin, clarithromycin, and roxithromycin) are not exceptional in this respect. The pooled failure rate in patients treated with amoxicillin was low (11 percent; 95 percent CI, 8-14), and the further decrease in clinical failures with broad-spectrum antibiotics was not clinically important. Treating 100 patients with amoxicillin would lead to only 0.85 more failures (95 percent CI, 3.1 more to 1.4 fewer failures).

Figure 12. Meta-analysis of amoxicillin vs. newer, more expensive antibiotics

Similar results were obtained through analysis of the failure data of newer antibiotic vs. folate inhibitors (Evidence Table 15 and Figure 13); treatment failures occurred at an essentially identical rate with other antibiotics as with folate inhibitors. However, data on folate inhibitors were limited and of poor quality. An analysis with respect to cures gave comparable results with risk ratios close to one, both for any other antibiotic vs. amoxicillin and any other antibiotic vs. folate inhibitors. The risk differences of clinical cure using amoxicillin or folate inhibitors compared with other antibiotics were not clinically important (3.2 percent [95 percent CI, -1.5 to 7.8 percent], and 1.2 percent [95 percent CI, -10 to 12.4 percent], respectively). The results were comparable when a trial comparing penicillin with azithromycin was added to the amoxicillin comparisons: risk ratio for clinical cures is 1.05 [95 percent CI, 0.99 to 1.11], and risk ratio for clinical failures is 0.82 [95 percent CI, 0.62 to 1.11].

Figure 13. Meta-analysis of folate inhibitors versus newer, more expensive antibiotics

There was no statistically significant heterogeneity of treatment effects in the amoxicillin comparisons; however, there was some evidence of heterogeneity between the studies that compared folate inhibitors with other antibiotics (p=0.09 for clinical cures; p=0.18 for clinical failures), possibly because trimethoprim-sulfamethoxazole seemed less effective than pivampicillin/pivmecillinam in one study (Osman and Menday, 1983).

A number of sensitivity analyses showed that the results were similar when the selection of studies was restricted according to various criteria (see Attachment B). In all sensitivity analyses, there was an estimated 11 to 20 percent risk reduction in clinical failures with other antibiotics over amoxicillin, which was not statistically significant, possibly because of the small numbers of patients. Still, this reduction was clinically negligible (less than 1 failure averted per 100 patients). Sensitivity analyses were less informative for folate inhibitors because the data were sparse.

Radiographic and bacteriologic data were not available for many trials (Evidence Tables 14 and 15). Rates of radiographic failures within 48 hours of the end of treatment were not significantly different between patients treated with other antibiotics and patients treated with amoxicillin, penicillin, or folate inhibitors. Likewise, rates of bacteriologic failure were not significantly different between patients treated with newer antibiotics and those treated with amoxicillin or folate inhibitors, although the majority of samples were obtained using nasal swabs, and the data therefore are not reliable.

4b. What evidence do these comparative studies provide regarding side effects?

The common side effects of amoxicillin and folate inhibitors are well known: skin rash, diarrhea, and gastrointestinal disturbances. There is no evidence suggesting that the side effects of these antibiotics are different for patients with acute bacterial rhinosinusitis.

There was no significant difference between regimens in the rate of withdrawal from treatment, either between other antibiotics and amoxicillin or between other antibiotics and folate inhibitors. In some instances, rash or gastrointestinal side effects led to discontinuation of the medications, whereas in other cases they were reported as minor adverse events (Evidence Tables 19 and 20). The reported adverse reactions numbered under 20 percent in the majority of trials. However, in a few studies, the percentages were higher (up to 50 percent in one study, Lindbaek, Hjortdahl, Johnsen, 1996a), mostly reported as gastrointestinal related. With some agents (e.g., macrolides, quinolones, tetracyclines), drug interactions may be a problem. Adverse reactions from interactions generally were not specifically identified, perhaps in part because most studies did not standardize the use of ancillary medications.

5a. Are there data to support the use of other types of treatments for acute rhinosinusitis and acute bacterial sinusitis, specifically: decongestants, steroids, antihistamines, drainage, flushing, others?

Search of the literature revealed few reliable studies regarding ancillary treatment of acute bacterial sinusitis. Ten randomized controlled trials were found (Evidence Table 22). Several different medication types used in these studies included proteolytic enzyme (bromelain), -adrenergic agonists (xylometazoline, oxymetazoline), mucolytic agents (bromhexine), glucocorticoids (budesonide, flunisolide, and antihistamine (loratadine). In most of the studies, these medications were used in conjunction with antibiotics. Although some of the studies tested different mechanisms for administering the treatments (e.g., nasal bellow vs. nasal spray; Wiklund, Stierna, Berglund, et al., 1994), no randomized trials comparing other nondrug treatments (e.g., sinus irrigation) were identified. The studies were carried out in both general medical and specialty clinics. Several studies combined patients with both acute and chronic sinusitis in the study population. Two of the studies were carried out in pediatric populations (Barlan, Erkan1, Bakir, et al., 1997; McCormick, John, Swischuk, et al., 1996).

Results of the randomized controlled studies of ancillary treatments are listed in Evidence Table 24. Three studies looked at bromelain (a proteolytic enzyme) as compared with placebo for patients who were also given antibiotics. These studies reported the same commercial source for bromelain, although the measured outcomes differed somewhat, and results therefore were not combined. All three studies reported higher positive outcomes in the patients receiving bromelain, although it was statistically significant (95 percent confidence level) only in one study (Seltzer, 1967). The remainder of the ancillary therapy studies looked at different treatments and reported varying efficacy.

5b. What is the efficacy of antibiotics compared with that of other types of treatment?

None of the randomized trials of ancillary treatments compared antibiotic to nonantibiotic therapy. In most studies, patients were treated with 7 to 21 days of antibiotics in conjunction with the assessed ancillary treatments. One study did not give antibiotics to all patients (Lewison, 1970) but reported that antibiotics were given to patients in either trial arm when bacterial infection was "obvious."

5c. What evidence do any comparative studies provide regarding side effects?

Three of the ten ancillary treatment trials reported patients discontinuing treatment because of major adverse reactions. Two of the studies assessed steroid preparations (Barlan, Erkan, Bakir, et al., 1997; Melzer, Orgel, Backhaus, et al., 1993); the third assessed a combination of drugs (McCormick, John, Swischuk, et al., 1996). In all studies, however, discontinuation was the result of adverse reactions to the antibiotics, not to the ancillary medications. Among the studies that provided information, two reported patients with minor side effects (Evidence Table 24).

## Input from Patient Representatives

To complete the decision analysis, we derived utilities from information provided by the two patients on our technical expert advisory group. These patients had a history of presumed acute bacterial rhinosinusitis. They were briefed on the purpose of the evidence report, informed about the study questions, and provided a status report on the work.

Both patients had had several episodes of presumed acute bacterial rhinosinusitis in the past several years. Both had been treated with antibiotics on several occasions but also had received ancillary therapies. Both reported that their episodes of rhinosinusitis appeared to be related to other conditions, such as environmental or seasonal allergies or upper respiratory illness. From their descriptions, it was clear that the severity of the episodes differed greatly, even for the same patient. Both reported initially using over-the-counter medications and self-treatment prior to coming to the physician's office. They both noted the presence of fever as a factor likely to bring them to a physician's office.

When asked about their sources for information, they reported using magazines, the Internet, and information from their physicians on various visits. Interest in obtaining information regarding medical conditions was mentioned as a factor increasing use of the Internet for medical information. One patient was interested in reading the final evidence report, and the other declined.

When the various diagnostic tests were discussed, both declined to undergo extensive testing (particularly invasive testing: puncture or endoscopy), although they reported that this would be affected by the severity of their symptoms and other pressures affecting their thresholds for symptom tolerance (e.g., need to care for a child, need to be at work, and so on). As these factors increased, so did both patients' interest in more definitive diagnosis and treatment at the initial physician visit.

In discussions of treatment options, the trust in their treating physician came out as an important factor in acceptance of a "watchful waiting" approach (e.g., treatment with ancillary medication, not antibiotics). Both, however, noted a preference for followup that did not entail a return office visit (e.g., obtaining a prescription for later or calling the physician back). Both patients were aware of (and in some cases experienced with) the potential individual adverse effects of antibiotic treatment (allergic reaction, vaginitis, interference with birth control). Although both expressed a concern regarding the development of antibiotic resistance, they expressed the initial need for "self-preservation" with regard to obtaining antibiotics for their individual episodes.

In discussing the utility of accurate diagnosis and treatment, both stressed that episodes varied and as such the value placed on these processes would vary by episode. In addition, it was noted that the utility was relative to other experiences with other episodes of rhinosinusitis or other illnesses. When sinusitis was viewed in light of experience with another illness such as pneumonia, the "severity evaluation" was recalibrated and as such the utility of the processes of diagnosis and treatment also changed.

## Decision and Cost-Effectiveness Analyses

Supplemental decision and cost-effectiveness analyses were performed to guide the use of the evidence in this report (Attachment D). A detailed description of the model and data used can be found in that section. Key results are summarized here.

A cost-effectiveness analysis was performed comparing the strategies of using sinus radiography to guide treatment -- using a set of clinical criteria to guide treatment, initial symptomatic treatment, and empirical antibiotic treatment with amoxicillin or a folate inhibitor.

The result is essentially a "toss-up" in terms of symptom days for empirical, clinical criteria-guided, and radiography-guided treatments. Symptomatic treatment alone provided fewer symptom-free days overall but the very lowest prevalence of acute bacterial rhinosinusitis. In terms of cost, a choice between clinical criteria and initial symptomatic treatment is a toss-up throughout the range of prevalence. Empirical treatment is more costly at all but the highest range of prevalence. Radiography is considerably more costly at any prevalence. Initial symptomatic treatment is the most cost-effective strategy to minimize symptom days at a prevalence of up to 25 percent, use of clinical criteria to guide treatment is most cost effective between a prevalence of 25 and 83 percent, and empirical antibiotic treatment with amoxicillin or a folate inhibitor is cost effective only at a prevalence greater than 83 percent. Performing sinus radiography is never a cost-effective strategy at any prevalence.

The prevalence thresholds for various strategies are moderately sensitive to the severity of sinus symptoms as reflected in quality-of-life adjustments. With mild symptoms, the range of prevalence in which clinical criteria-guided treatment is most cost effective is 49 to 97 percent. With severe symptoms, however, clinical criteria are most cost effective at a prevalence range from 31 to 90 percent.

At the base case prevalence estimate of 50 percent, empirical, clinical criteria-guided, and radiography-guided treatment all yield approximately 6.4 symptom-free days over a 14-day course. Symptomatic treatment yields only 5.0 symptom-free days. Symptomatic and clinical criteria-guided treatments both yield costs of $25; empirical treatment is somewhat more costly at $37; and radiography-guided treatment is much more costly at $132. Clinical criteria-guided treatment is most cost effective at $4.03 per symptom-free day, with a marginal cost-effectiveness of $0.21 over symptomatic treatment, which has a cost-effectiveness of $5.01 per symptom-free day. Empirical treatment is slightly less cost effective at $5.64 but has a marginal cost-effectiveness of $42.36 compared with that of clinical criteria-guided treatment. Radiography-guided treatment is much less cost effective at $20.52 per symptom-free day and can be eliminated by strict dominance.

With mild symptoms, all strategies yielded very similar effectiveness, at 12.0 to 12.2 quality-adjusted days. Thus, the marginal cost-effectiveness of clinical criteria-guided treatment was greater than above, at $1.52 per quality-adjusted day. The marginal cost-effectiveness of empirical treatment over clinical criteria-guided treatment rose substantially to $378 per quality-adjusted day.

Sensitivity analysis showed that lowered efficacy of amoxicillin or folate inhibitor, resulting from increased antibiotic resistance, had a substantial effect on cost-effectiveness. With poorer antibiotic efficacy, symptomatic treatment was most cost effective at all levels of symptom severity and at all prevalences. Only if the goal of treatment is to minimize duration of any symptoms was clinical criteria-guided treatment most cost effective at a prevalence above 86 percent.

If newer, more expensive antibiotics are used or are necessary because of antibiotic resistance, then symptomatic treatment is most cost effective. It is never cost effective to treat initially with expensive antibiotics prior to a period of watchful waiting.

At the prevalence of acute bacterial rhinosinusitis likely to be encountered in most primary care settings, either strategy of initial symptomatic treatment or the use of clinical criteria to guide treatment is an effective and cost-effective approach for uncomplicated patients. Given our finding that most patients' symptoms resolve without antibiotic treatment and that serious complications are rare, watchful waiting (7 to 10 days after onset of "sinus" symptoms) is a reasonable strategy. If antibiotics are to be given, amoxicillin or a folate inhibitor should be the initial choice. The severity of the patient's symptoms should also be taken into consideration in the management decision.