# Appendix B. Peer Reviewers

The evidence report partner organizations nominated individuals to participate in the peer review of the evidence report. Additional individuals with appropriate methodologic and clinical expertise were identified by the EPC. Two reviewers chose to remain anonymous. Review of the evidence report by these individuals does not represent endorsement of the report. We are grateful to the peer reviewers for generously offering their time and participation.

## American Academy of Family Physicians Nominated Reviewers

- Hanan Bell, PhD
- Co-director, AAFP-University of Washington
- Clinical Policy Program

- Alfred Berg, MD, MPH
- Professor and Associate Chair
- Department of Family Medicine
- University of Washington

- Charles Driscoll, MD
- Chair, Commission on Clinical Policy and Research
- American Academy of Family Physicians

- Douglas Long, MD
- West Endfield, ME

- William Phillips, MD, MPH
- Clinical Professor
- Department of Family Medicine
- University of Washington School of Medicine

## American Academy of Otolaryngology-Head and Neck Surgery Nominated Reviewers

- Jack Anon, MD
- Associate Clinical Professor
- University of Pittsburgh College of Medicine
- Department of Otolaryngology
- Chairman, Rhinology and Paranasal Sinus Committee
- American Academy of Otolaryngology-Head and Neck Surgery

- James Hadley, MD
- Clinical Associate Professor of Surgery (Otolaryngology)
- University of Rochester Medical Center

- Donald Leopold, MD
- Director of Rhinology
- Otolaryngology-Head and Neck Surgery
- Johns Hopkins Outpatient Center

- Robert Naclerio, MD
- Professor and Chief
- Sinus Disease/Pediatric Otolaryngology
- University of Chicago, Pritzker School of Medicine

## American Academy of Pediatrics Nominated Reviewers

- William Clayton Bordley, MD, MPH
- Assistant Professor of Pediatric and Emergency Medicine
- University of North Carolina, Chapel Hill

- Michael Marcy, MD
- Clinical Professor of Pediatrics
- University of California, Los Angeles

## American College of Physicians Nominated Reviewers

- Anne-Marie Audet, MD, MSc, SM
- Associate Director for Quality Improvement
- MassPRO

- Preston Winters, MD
- White Plains, NY

## Additional Peer Reviewers

- Rowena Dolor, MD
- Director, Primary Care Research Consortium
- Duke Clinical Research Institute

- Thomas Hines, MD
- Acting Chief, Division of Family Medicine
- Tufts University School of Medicine

- Jack Lasche, Jr., MD
- Chief of Pediatrics
- Harvard Vanguard Medical Associates

- Pamela McInnes, DDS, MSc(Dent)
- Chief, Respiratory Diseases Branch
- National Institute of Allergy and Infectious Diseases

- Jay Piccirillo, MD
- Assistant Professor of Otolaryngology, Medicine, and Occupational Therapy
- Director, Clinical Outcomes Research
- Washington University School of Medicine

- David Samson
- Associate Director
- Technology Evaluation Center
- Evidence-based Practice Center
- Blue Cross Blue Shield Association

- Helena Varonen, MD
- Stakes, National Research and Development Center for Welfare and Health
- Helsinki, Finland

- David Witsell, MD
- Assistant Professor
- Division of Otolaryngology-Head and Neck Surgery
- Duke University Medical Center