# Appendix A. Evidence Report Staff and Technical Expert Advisory Group

## Evidence-based Practice Center Staff

- EPC/Project Director: Joseph Lau, MD
- Project Manager: Deirdre Devine, M.Lit
- Assistant Project Director: Deborah Zucker, MD, PhD
- Statistician: Norma Terrin, PhD
- Research Associate: Priscilla Chew, MPH
- Technical Editor: Thomas A. Lang, MA
- Research Assistant: David Liu, BA
- AHCPR NRSA Research Fellows: Eric A. Engels, MD, MPH; Ethan Balk, MD

## Technical Expert Advisory Group

- Michael Barza, MD
- Infectious Diseases, New England Medical Center (NEMC)

- Michael S. Benninger, MD
- Otolaryngology, Henry Ford Hospital
- American Academy of Otolaryngology-Head and Neck Surgery

- Larry Culpepper, MD
- Family Medicine, Boston Medical Center
- American Academy of Family Physicians

- Aidan Long, MD
- Allergy, NEMC

- Anne Meneghetti, MD
- Blue Cross and Blue Shield of Massachusetts

- Rosalie Phillips, MPH
- Tufts Managed Care Institute

- Eli Rebeiz, MD
- Otolaryngology, NEMC

- Carol Sakala, PhD, MSPH
- Educational Development Center, Inc.

- Ellen R. Wald, MD
- Pediatric Infectious Diseases, University of Pittsburgh
- American Academy of Pediatrics

- John W. Williams, Jr., MD,MHS
- Internal Medicine, South Texas Veterans Health Care System
- American College of Physicians

- John B. Wong, MD
- Decision/Cost-effectiveness Analysis, NEMC

## Patient Representatives

- Gladys Luna
- Lucy T. Porro

## Partner Organizations

- American Academy of Family Physicians
- American Academy of Otolaryngology-Head and Neck Surgery
- American Academy of Pediatrics
- American College of Physicians

## Evidence Report Staff and Technical Expert Advisory Group

- Ethan Balk, MD
- NRSA Research Fellow
- Division of Clinical Care Research
- New England Medical Center

- Michael Barza, MD
- Professor of Medicine
- Chairman, Division of Infectious Diseases and Geographical Medicine
- Tufts University School of Medicine

- Michael S. Benninger, MD
- Immediate Past Chair, Board of Governors
- Board of Directors
- American Academy of Otolaryngology-Head and Neck Surgery
- President, American Rhinologic Society
- Chairman, Department of Otolaryngology-Head & Neck Surgery
- Henry Ford Hospital

- Priscilla Chew, MPH
- Research Associate
- New England Medical Center EPC

- Larry Culpepper, MD
- Professor and Chairman
- Department of Family Medicine
- Boston University Medical Center

- Deirdre DeVine, M.Lit
- Project Manager, New England Medical Center EPC
- Administrator, New England Cochrane Center
- Division of Clinical Care Research
- New England Medical Center

- Eric Engels, MD, MPH
- NRSA Research Fellow
- Division of Clinical Care Research
- New England Medical Center

- Carla T. Herrerias, BS, MPH
- Program Manager
- Division of Quality Care
- American Academy of Pediatrics

- Susan Elaine Sedory Holzer, MA
- Director of Outcomes Research
- American Academy of Otolaryngology-Head and Neck Surgery Foundation
- One Prince Street
- Alexandria, VA 22314

- Joseph Lau, MD
- Director, New England Medical Center EPC
- Director, New England Cochrane Center
- Associate Professor of Medicine
- Tufts University School of Medicine

- Aidan Long, MD
- Assistant Professor of Medicine
- Tufts University School of Medicine

- David Liu, BA
- Research Assistant
- New England Medical Center EPC

- Gladys Luna
- Waltham, MA

- Anne Meneghetti, MD
- Assistant Professor of Medicine
- Tufts University School of Medicine
- Adjunct Instructor of Medicine
- Boston University School of Medicine
- Director of Medical Policy
- Blue Cross and Blue Shield of Massachusetts

- Rosalie Phillips, MPH
- Executive Director
- Tufts Managed Care Institute

- Lucy Porro
- South Boston, MA

- Eli Rebeiz, MD
- Associate Professor of Otolaryngology
- Director, Head and Neck Cancer Surgery
- Department of Otolaryngology
- Tufts University School of Medicine

- Carol Sakala, PhD, MSPH
- Senior Scientist
- Center for Applied Ethics and Professional Practice

- Norma Terrin, PhD
- Statistician, New England Medical Center EPC
- Associate Professor of Medicine
- Tufts University School of Medicine

- Ellen R. Wald, MD
- Professor of Pediatric and Otolaryngology
- Interim Chairperson, Department of Pediatrics
- Chief, Division of Allergy, Immunology and Infectious Diseases
- University of Pittsburgh School of Medicine
- Children's Hospital of Pittsburgh

- John W. Williams, Jr., MD, MHS
- Associate Professor of Medicine
- South Texas Veterans Health Care System
- University of Texas Health Science Center - San Antonio

- John B. Wong, MD
- Associate Professor of Medicine
- Tufts University School of Medicine
- Chief, Division of Clinical Decision Making, Medical Informatics, and Telemedicine
- New England Medical Center

- Deborah Zucker, MD, PhD
- Assistant Professor of Medicine
- Tufts University School of Medicine