# Appendixes

Appendix A. Evidence Report Staff and Technical Expert Advisory Group

Appendix B. Peer Reviewers