# Acronyms

AA | Arachidonic acid
Ab | Antibody
AHRQ | Agency for Healthcare Research and Quality
Al | Adequate intake
ALA | Alpha-linolenic acid
AMDR | Acceptable macronutrient distribution ranges
ANCOVA | Analysis of covariance
ANOVA | Analysis of variance
Ca | Calcium
CCT | Controlled clinical trial
CI | Confidence interval
CRP | C-reactive protein
CSFII | Continuing Food Survey of Intakes by Individuals
d | day
D6D | Delta-6 Desaturase
DGLA | Dihomo-gamma-linolenic acid
DHA | Docosahexaenoic acid
DPA | Docosapentaenoic acid
DRI | Dietary Reference Intake
Ds-DNA | Double-stranded DNA
EF | Effect size
EFA | Essential fatty acid
EPA | Eicosapentaenoic acid
EPC | Evidence-Based Practice Center
ESR | Erythrocyte sedimentation rate
FNB | Food and Nutrition Board
g | grams
GI | Gastrointestinal
GLA | Gamma-linolenic acid
HDL | High density lipoprotein
IBD | Inflammatory bowel disease
IL-1ß | Interleukin 1ß
JRA | Juvenile rheumatoid arthritis
IOM | Institute of Medicine
LA | Linoleic acid
LC PUFA | Long-chain polyunsaturated fatty acid
LDL | Low density lipoprotein
MA | Metaanalysis
MANOVA | Multivariate analysis of variance
MeSH Term | Medical Subject Headings Term
mg/dl | Milligrams per deciliter
min | Minutes
Mo | Month
n | Number
n-3 | Omega-3
n-6 | Omega-6
NA | Not applicable
NHANES III | The Third National Health and Nutrition Examination
NCI | National Cancer Institute
NEI | National Eye Institute
NEMC | New England Medical Center
NHANES | National Health and Nutrition Examination
NHLBI | National Heart, Lung and Blood Institute
NIAAA | National Institute of Alcohol Abuse and Alcoholism
NIAID | National Institute of Allergy and Infectious Diseases
NIAMS | National Institute of Arthritis and Musculoskeletal and Skin Diseases
NICHD | National Institute of Child Health and Human Development
NIDDK | National Institute of Diabetes and Digestive and Kidney Diseases
NIH | National Institutes of Health
NNH | Number needed to harm
NR | Not reported
NSAIDS | Non-Steroidal Anti-Inflammatory Drugs
ODS | Office of Dietary Supplements
PG | Prostaglandin
PGD | Prostaglandin-D
PGE | Prostaglandin-E
PGF | Prostaglandin-F
PGL | Prostaglandin-L
PGH | Prostaglandin-H
PUFA | Polyunsaturated fatty acid
QRF | Quality review form
RA | Rheumatoid arthritis
RCT | Randomized controlled trial
RDA | Recommended daily allowances
RXT | Randomized crossover trial
Sd | Standard deviation
SCEPC | Southern California Evidence-Based Practice Center
SLE | Systemic lupus erythematosus
SEM | Standard errors of the means
TEP | Technical expert panel
TNF-a | Tumor necrosis factor-a
TX | Treatment
TXA | Thromboxane-A
UCLA | University of California, Los Angeles
VLCFA | Very long chain fatty acid
VLN-3FA | Very long chain n-3 fatty acids
wk | Week