# Listing of Excluded Studies

### Rejected on Abstract Review

Anonymous Dietary fats and oils in human nutrition; report of an expert consultation held in Rome. FAO Food and Nutrition Paper 1977;
Anonymous The effect of omega-3 fatty acids. Therapiewoche 1990;40:12–18.
Anonymous Fish, diabetes, and the arterial wall. Lancet 1989;2:1332-2574274
Anonymous Fish oil for type 2 diabetes. Health News 2000;6:7-
Anonymous Fish oils and diabetic microvascular disease. Lancet 1990;335:508–509.1968531
Anonymous Increasing fish oil intake - Any net benefits? Drug & Therapeutics Bulletin 1996;34:60–62.
Anonymous Italian Society of Dietetics and Clinical Nutrition. XII national conference - lipids in dietetics and clinical nutrition, Torino, Italy, 16-November, 1995. Minerva Gastroenterologica e Dietologica 1997;169–219.
Anonymous Lectures given at the 9th Aachen Dietetics Further Education Meeting, 21–23 September, 2001. Ernahrung and Medizin 2002;
Anonymous Management of hyperlipidaemia. Drug & Therapeutics Bulletin 1996;34:89–93.
Anonymous Nutrition and chronic inflammatory bowel disease. Medizinische Welt 2001;52:74–75.
Anonymous Update on inflammatory bowel disease. Pharmaceutical Journal 2001;267:574–575.
Abrahamsson H, Gustafson A, Ohlson R: Polyunsaturated fatty acids in hyperlipoproteinemia. 1. Influences of a sucrose-rich diet on fatty acid composition of serum lipoprotein lipids. Nutrition and Metabolism 1974;4377748
Adam O: Nutritional influences on eicosanoid biosynthesis - clinical consequences. Fett Wissenschaft Technologie 1994;95.
Aldhous MC, Meister D, Subrata Ghosh, Ghosh S: Modification of enteral diets in inflammatory bowel disease. Symposium on Dietary influences on mucosal immunity, Harrogate, UK 2000;457–461.
Alekseeva R I, Sharafetdinov K h, Plotnikova O A, Meshcheriakova V A, Mal'tsev G I, Kulakova S N. Effects of diet therapy including eiconol on clinical and metabolic parameters in patients with type 2 diabetes mellitus. Voprosy Pitaniia. 2000;69:36-39. [pmid: 11247166].
Alfin-Slater R B, Aftergood L. Essential fatty acids reinvestigated. Physiological Reviews. 1968;48:758-784. [pmid: 4879916].
Anadere I, Schmitt Y, Schneider H, Walitza E. The effect of omega-3 polyunsaturated fatty acids on hemorheological parameters of patients under chronic hemodialysis treatment. Clinical Hemorheology. 1992;12:243-254.
Andersson Agneta: Fatty acid composition in skeletal muscle. Influence of physical activity and dietary fat quality. Dissertation Abstracts International 67-
Astrup A: Healthy lifestyles in Europe: prevention of obesity and type II diabetes by diet and physical activity. Public Health Nutrition 2001;56:
Aued Pimentel S, Caruso MSF: Gamma-linolenic acid: sources, and perspectives on its therapeutic application. Boletim da Sociedade Brasileira de Ciencia e Tecnologia de Alimentos 1999;54:
Avula C, Lawrence R, Jolly C, Fernandes G: Role of n-3 polyunsaturated fatty acids (PUFA) in autoimmunity, inflammation, carcinogenesis, and apoptosis. Recent.Research.Developments.in.Lipids 2000;
Ayling RM, Preedy VR, Grimble G, Watson R: Nutritional management of diabetes mellitus. Nutrition in the infant: problems and practical procedures 2001;36:-
Ba Jaber AS, Al Faris NA: Effects of high carbohydrate, high insoluble fiber and low fatty acids diets on patients with non-insulin-dependent diabetes mellitus. Bulletin of Faculty of Agriculture, University of Cairo 1997;22:
Ba Jaber AS, Al Faris NA, Al Robean K: Short-term effect of soluble fiber in fat diets on plasma glucose and lipids in patients with non-insulin dependent diabetes mellitus. Bulletin of Faculty of Agriculture, University of Cairo 1997;25:
Baggio B. Fatty acids, calcium and bone metabolism. Journal of Nephrology. 2002;15:601-4. [pmid: 12495271].
Bamba T: Lifestyle guidance and diet for inflammatory bowel disease (IBD) patients. JMAJ Japan Medical Association Journal 2002;4:
Bang H O, Dyerberg J, Nielsen A B. Plasma lipid and lipoprotein pattern in Greenlandic West-coast Eskimos. Lancet. 1971;1:1143-1145. [pmid: 4102857].
Barsottelli E, Berra B: Omega-3 Fatty acids and prevention of thrombosis and atherosclerosis. Critical evaluation of data from the literature. Rivista Italiana delle Sostanza Grasse 1994;42:
Bartels M, Nagel E, Pichlmayr R. What is the role of nutrition in ulcerative colitis? A contribution to the current status of diet therapy in treatment of inflammatory bowel diseases. Langenbecks Archiv fur Chirurgie. 1995;380:37722. [pmid: 7707850].
Bassaganya Riera J, Hontecillas R, Wannemuehler MJ: Nutritional impact of conjugated linoleic acid: a model functional food ingredient. In Vitro Cellular and Developmental Biology Plant 2002;50:
Beare Rogers J, Nera EA, Levin OL, et al: 20th International Conference on the Biochemistry of Lipids, Aberdeen, Scotland, September 6–8, 1977 1977, xi + 44pp mimeographed.:-
Beitz J, Schimke E, Liebaug U, et al. Influence of a cod liver oil diet in healthy and insulin-dependent diabetic volunteers on fatty acid pattern, inhibition of prostacyclin formation by low density lipoprotein (LDL) and platelet thromboxane. Klinische Wochenschrift. 1986;64:793-799. [pmid: 3531705].
Belch J, Muir A: n-6 and n-3 essential fatty acids in rheumatoid arthritis and other rheumatic conditions. Proceedings of the Nutrition Society 1998;563–569.
Belluzzi A. Lipid treatment in inflammatory bowel disease. Nestle Nutrition Workshop Series Clinical & Performance Program. 1999;2:199-211.
Belluzzi A: N-3 and n-6 fatty acids for the treatment of autoimmune diseases. European Journal of Lipid Science and Technology 2001;6:
Belluzzi A, Campieri M, Brignola C, Gionchetti P, Miglioli M, Barbara L. Polyunsaturated fatty acid pattern and fish oil treatment in inflammatory bowel disease. Gut. 1993;34:1289-1290. [pmid: 8406171].
Berdanier CD, Bodwell CE, Erdman JW: Interacting effects of carbohydrate and lipid on metabolism. Nutrient interactions 1988;
Berry EM, Valagussa F, Marchioli R: Are diets high in omega-6 polyunsaturated fatty acids unhealthy? Evidence and perspectives on n 3 polyunsaturated fatty acids in cardiovascular disease. European-Heart-Journal-Supplements 2001;
Betteridge D J. Lipids, diabetes, and vascular disease: The time to act. Diabetic Medicine. 1989;6:195-218. [pmid: 2523781].
Bhathena S J. Relationship between fatty acids and the endocrine system. Biofactors. 2000;13:35-39. [pmid: 11237196].
Bhathena SJ, Chow CK: Dietary fatty acids and fatty acid metabolism in diabetes. Fatty acids in foods and their health implications 2000;488:-
Bisson LF, Watkins TR: Metabolic Syndrome X and the French paradox.Wine: nutritional and therapeutic benefits 1997;66:-
Bitton A. Medical management of ulcerative proctitis, proctosigmoiditis, and left-sided colitis. Seminars in Gastrointestinal Disease. 2001;12:263-274. [pmid: 11726080].
Bodem S H. Is fish oil effective against IgA-nephropathy?. Pharmazeutische Zeitung. 1995;140:67-68.
Boissonneault G, Chow C: Dietary fat, immunity and inflammatory disease. Fatty.acids.in.foods.and.their.health.implications 2000;-
Brennan G M, McVeigh G E, Johnston G D, Hayes J R. Dietary fish oil augments EDRF production or release in patients with non-insulin dependent diabetes mellitus. British Journal of Clinical Pharmacology. 1992;33:531. [pmid: 8436250].
Brown A. Lupus erythematosus and nutrition: a review of the literature. Journal of Renal Nutrition. 2000;10:170-183. [pmid: 11070144].
Brunner EJ, Wunsch H, Marmot MG: What is an optimal diet? Relationship of macronutrient intake to obesity, glucose tolerance, lipoprotein cholesterol levels and the metabolic syndrome in the Whitehall II study. International Journal of Obesity 2001;30:
Burakoff R. Inflammatory bowel disease workshop. Vail, Colorado, March 22 and 23, 1998. Less commonly used therapies for IBD or treatments on the fringe. Inflammatory Bowel Diseases. 1998;4:308-313. [pmid: 9836084].
Burden M L, Samanta A, Spalding D, Burden A C. A comparison of the glycaemic and insulinaemic effects of an Asian and a European meal. Practical Diabetes. 1994;11:208-211.
Campbell Joy Marlene: Influence of oligosaccharides and fish oil on gastrointestinal tract characteristics and metabolic profiles of humans, pigs, and rats. Dissertation Abstracts International 4798-
Caprilli R, Taddei C, Viscido A. In favour of prophylactic treatment for post-operative recurrence in Crohn's disease. Italian Journal of Gastroenterology & Hepatology. 1998;30:219-225. [pmid: 9675663].
Carpentier Y A. Dietary intake and hyperlipoproteinemias. Revue Medicale de Bruxelles. 1997;18:32-36. [pmid: 9132916].
Castiglioni A, Savazzi G M. Clinical significance of consumption of polyunsaturated n-3 fatty acids of marine origin. Recenti Progressi in Medicina. 1991;82:59-60. [pmid: 2028079].
Caterina R, de BG, De Caterina R, Valagussa F, Marchioli R: n-3 Fatty acids and the inflammatory response -biological background. Evidence and perspectives on n.3 polyunsaturated fatty acids in cardiovascular disease. European-Heart-Journal 2001;
Caterina Rde Caprioli R, Giannessi D, Sicari R, et al: The use of fish oil in human chronic glomerular disease. n 3 fatty acids and vascular disease: background and pathophysiology, hyperlipidaemia, renal diseases, ischaemic heart disease 1993;51:
Cerrato P L. Omega-3 fatty acids: nothing fishy here!. RN. 1999;62:59-60. [pmid: 10481733].
Chambers Kathleen Mailie: Assessment of the nutritional properties of regular and low linolenic acid canola oil in non-insulin-dependent (Type ii) Diabetes mellitus subjects. Masters Abstracts International 519-
Chandrasekaran A, Radhakrishna B, Uma B, Gopalan C, Krishnaswamy K: Rheumatic diseases. Nutrition.in.major.metabolic.diseases 2000;11:-
Chaumerliac P, Pehuet-Figoni M, Escourolle H, Giauque J P, Luton J P. Lipid disorders in diabetes mellitus. Pathophysiology and therapeutic implications. I.- Physiologic review of the metabolism of VLDLs, HDLs and LDLs. Semaine des Hopitaux. 1991;67:1528-1540.
Chen S S C. Soybeans and health. Journal of the Chinese Nutrition Society. 1994;19:335-345.
Cheng I K P. Non-immune therapy of IgA glomerulonephritis. Nephrology. 1997;3:109-111.
Chowienczyk P J, Watts G F. Endothelial dysfunction, insulin resistance and non-insulin-dependent diabetes. Endocrinology & Metabolism, Supplement. 1997;4:225-232.
Chutkan R K. Inflammatory bowel disease. Primary Care; Clinics in Office Practice. 2001;28:539-556. [pmid: 11483443].
Cimmino M. Regional differences in the occurrence and severity of rheumatoid arthritis in Europe. Cpd Rheumatology. 1999;1:28-32.
Clamp A: Investigations into the mechanisms by which fats modulate the inflammatory response to cytokines. Dissertation.Abstracts.International 56-
Cleland L G, James M J. Adulthood - prevention: Rheumatoid arthritis. Medical Journal of Australia. 2002;176:S119-S12. [pmid: 12064974].
Comas Maria: Patron plasmatico de los acidos grasos poliinsaturados en las diferentes fases evolutivas de la enfermedad inflamatori intestinal: Su relacion con factores clinicos, biologicos y nutricionales. Dissertation Abstracts International 694-
Connor SL, Connor WE, Rivlin RS: Are fish oils beneficial in the prevention and treatment of coronary artery disease? Fats and oil consumption in health and disease: current concepts and controversies 53:
Connor WE, Connor SL, Bendich A, Deckelbaum RJ: n-3 fatty acids from fish and plants: primary and secondary prevention of cardiovascular disease. Preventive nutrition: the comprehensive guide for health professionals 2001; 73:-
Coppo R, Amore A, Emancipator S N, et al. Idiopathic IgA nephropathy. Clinic pathological conference. Giornale Italiano di Nefrologia. 1999;16:79-93.
Costain L: Mediterranean diet. Family Medicine London 2001;10:
Crapo P, Vinik AI: Nutrition controversies in diabetes management. Journal of the American Dietetic Association 1987;
Crotty Band Jewell D P. Drug therapy of ulcerative colitis. British Journal of Clinical Pharmacology. 1992;34:189-198. [pmid: 1389944]. [pmcid: 1381388].
Danao-Camara T, Shintani T. The dietary treatment of inflammatory arthritis: case reports and review of the literature. Hawaii Medical Journal. 1999;58:126-131. [pmid: 10377605].
Das U. Oxidants, anti-oxidants, essential fatty acids, eicosanoids, cytokines, gene/oncogene expression and apoptosis in systemic lupus erythematosus. Journal of the Association of Physicians of India. 1998;46:630-634. [pmid: 12152850].
Das U N, Kumar K V, Mohan I K. Lipid peroxides and essential fatty acids in patients with diabetes mellitus and diabetic nephropathy. Journal of Nutritional Medicine. 1994;4:149-155.
Das UN, Suresh Y, Huang YS, Ziboh VA: Prevention of alloxan-induced cytotoxicity and diabetes mellitus by gamma-linolenic acid and other polyunsaturated fatty acids both in vitro and in vivo. gamma Linolenic acid: recent advances in biotechnology and clinical applications 2001;31 :-
Davids Rebecca Susanne: Identifying food constituents that may improve cardiovascular disease risk factors in persons with or at risk for type 2 diabetes mellitus. Masters Abstracts International 39-04:1135-
De Deckere E, Korver O, Verschuren P, Katan M. Health aspects of fish and n-3 polyunsaturated fatty acids from plant and marine origin. European Journal of Clinical Nutrition. 1998;52:749-753. [pmid: 9805223].
De Vita S, Bombardieri S: The diet therapy of rheumatic diseases. Recenti Progressi.in Medicina 1992:707–718.
Donadio J V. The emerging role of omega-3 polyunsaturated fatty acids in the management of patients with IgA nephropathy. Journal of Renal Nutrition. 2001;11:122-128. [pmid: 11466662].
Donadio JV, Jr, De Caterina R, Endres S(ed Kristensen SD, Schmidt EB: An overview of n-3 fatty acids in clinical renal diseases.n 3 fatty acids and vascular disease: background and pathophysiology, hyperlipidaemia, renal diseases, ischaemic heart disease 1993;31:-
Dreval AV, Pokrovski, VB: [Essential fatty acids in the prevention and treatment of vascular complications of diabetes mellitus. Voprosy Pitaniia 1992;6–14.
Egan L J, Sandborn W J. Drug therapy of inflammatory bowel disease. Drugs of Today. 1998;34:431-446. [pmid: 15010706].
Engelmann GJ: Het effect van polyonverzadigde vetzuren in het dieet van insuline dependente diabetespatienten (Type i) Op de lipidensamenstelling en de deformeerbaarheid van erythrocyten met behulp van h.P.L.C. Dissertation Abstracts International 2459-
Eritsland J, Seljeflot I, Abdelnoor M, Arnesen H, Torjesen P A. Long-term effects of n-3 fatty acids on serum lipids and glycaemic control. Scandinavian Journal of Clinical & Laboratory Investigation. 1994;54:273-280. [pmid: 7939369].
Erlangen C B. Long term feeding with a chemically defined diet. Infusionstherapie und Klinische Ernahrung - Sonderheft. 1975;3:4-6. [pmid: 1184191].
Ernst E. Fish oil for ulcerative colitis. Fortschritte der Medizin. 1992;110:14. [pmid: 1582643].
Esteve Comas M, Nunez MC, Fernandez Banares F, et al: Abnormal plasma polyunsaturated fatty acid pattern in non-active inflammatory bowel disease. Gut 1993;8244103
Esteves E A, Monteiro J B R. Beneficial effects of soy isoflavones on chronic diseases. Revista de Nutricao. 2001;14:43-52.
Evans M F. Can we prevent high-risk patients from getting type 2 diabetes?. Canadian Family Physician. 2002;48:279-281. [pmid: 11889887]. [pmcid: 2213974].
Ezaki O, Takahashi M, Shigematsu T, et al. Long-term effects of dietary alpha-linolenic acid from perilla oil on serum fatty acids composition and on the risk factors of coronary heart disease in Japanese elderly subjects. Journal of Nutritional Science & Vitaminology. 1999;45:759-772. [pmid: 10737229].
Fasching P, Ratheiser K, Waldhausl W, Rohac M, Vierhapper H. Fish oil as lipostatic factor. Vasa - Supplementum. 1990;30:62-63. [pmid: 2075591].
Fatati G, Croccolino D, Puxeddu A. Omega-3 fatty acids in the treatment of dyslipidemia. Rivista Italiana di Biologia e Medicina. 1996;16:59-62.
Fineberg S E. The treatment of hypertension and dyslipidemia in diabetes mellitus. Primary Care; Clinics in Office Practice. 1999;26:951-964. [pmid: 10523469].
Fitzgerald TK, Manderson L: Dietary change among Cook Islanders in New Zealand. Shared wealth and symbol 1986;-
Foerste A: Fish-oil preparations. Composition, general evaluation, and application possibilities. Fortschritte der Medizin 1988;106:
Folwaczny C, Endres S. Fish oil to prevent recurrence of Crohn disease?. Zeitschrift fur Gastroenterologie. 1997;35:651-653. [pmid: 9381747].
Fontaine F, Brassinne A, Delforge M, et al. Review on inflammatory bowel disease: Crohn disease and ulcero-hemorrhagic recto-colitis. Revue Medicale de Liege. 1993;48:593-618. [pmid: 7904768].
Frayn K N. Effects of fat on carbohydrate absorption: More is not necessarily better. British Journal of Nutrition. 2001;86:1-2. [pmid: 11432758].
Gaby A. Alternative treatments for rheumatoid arthritis. Alternative Medicine Review. 1999;4:392-402. [pmid: 10608912].
Gans ROB, Bilo HJG, Schouten JA, Rauwerda JA: Fish oil and plasma fibrinogen. [Letter]
Gassull Duro M A. Have long-chain PUFA any therapeutic action in IBD?. Pediatrika. 1998;18:25-28.
Gassull M A. Dietary fat intake and inflammatory bowel disease. Current Gastroenterology Reports. 2001;3:358-61. [pmid: 11470006].
Gassull MA, Green CJ, Elia M, Russell CA, Wilson JHP: New insights in nutritional therapy in inflammatory bowel disease. Proceedings of the 11th Nutricia Symposium 136:
Gatti A, Bonavita M, De Matteo A, et al. Use of the association between statins and EPA-DHA in the treatment of diabetes mellitus. Quaderni di Medicina e Chirurgia. 1997;13:61-64.
Geerling B J. Improved antioxidant status after supplementation with n-3 fatty acids and or antioxidants in addition to a regular diet in patients with Crohn's disease in a double blind placebo controlled study. European Journal of Gastroenterology & Hepatology. 1998;10:23-24.
Geerling B J, Badart-Smook A, van Deursen C, et al. Nutritional supplementation with N-3 fatty acids and antioxidants in patients with Crohn's disease in remission: effects on antioxidant status and fatty acid profile. Inflammatory Bowel Diseases. 2000;6:77-84. [pmid: 10833065].
Geerling B J, Stockbrugger R W, Brummer R J. Nutrition and inflammatory bowel disease: an update. Scandinavian Journal of Gastroenterology. 1999;230:95-105. [pmid: 10582762].
Gerster H. The use of n-3 PUFAs (fish oil) in enteral nutrition. International Journal for Vitamin & Nutrition Research. 1995;65:3-20. [pmid: 7657477].
Giese L A. A study of alternative health care use for gastrointestinal disorders. Gastroenterology Nursing. 2000;23:19-27. [pmid: 11096804].
Grand R J, Ramakrishna J, Calenda K A. Therapeutic strategies for pediatric Crohn disease. Clinical & Investigative Medicine - Medecine Clinique et Experimentale. 1996;19:373-380. [pmid: 8889277].
Green K: Type 1 diabetes and bone mass: Interrelationships with nutrient intake and physical activity in children and with dietary fish oil in weanling rats. Masters Abstracts International 39:1136-
Griffiths A: Nutrition in inflammatory bowel disease. Current.Opinion.in.Clinical.Nutrition.and.Metabolic.Care 2000;33:
Grimminger F, Walmrath D, Seeger W, Lasch H G. Antiinflammatory effects of omega-3-lipidinfusion in clinical and experimental studies. Medizinische Welt. 1993;44:207-216.
Guesnet P, Alessandri JM, Durand G: Metabolism, biological functions and nutritonal importance of polyenoic fatty acids. Summary of Third ICEFAP Congress (Adelaide, Australia, 1–5 March 1992). Cahiers de Nutrition et de Dietetique 1993;20:
Gulati P D, Rao M B, Vaishnava H. Letter: Diet for diabetics. Lancet. 1974;2:297-298. [pmid: 4135730].
Gwynn C K, O'Neil K M. The effects of fish-oil supplementation in a diabetic CAPD patient using intraperitoneal insulin. Dialysis & Transplantation. 1989;18:614-616.
Haban P, Simoncic R, Klvanova I, Ozdin L, Zidekova E. The effect of n-3 fatty acid administration on selected indicators of cardiovascular disease risk in patients with type 2 diabetes mellitus. Bratislavske Lekarske Listy. 1998;99:37-42. [pmid: 9588078].
Hahnefeld M. Diabetes-associated dyslipoproteinemia. Therapiewoche Schweiz. 1992;8:575-581.
Hamazaki T. Intravenous infusion of n-3 polyunsaturated fatty acids. Proceedings of the Society for Experimental Biology and Medicine. 1992;200:171-173. [pmid: 1315967].
Hamazaki T, Tateno S, Shishido H. Eicosapentaenoic acid and IgA nephropathy. Lancet. 1984;1:1017-1018. [pmid: 6143935].
Hanck C, Singer M V. What is the role of nutrition in ulcerative colitis?. Langenbecks Archiv fur Chirurgie. 1995;380:1-3. [pmid: 7707845].
Hanefeld M. Dyslipoproteinemia in diabetes. Therapiewoche. 1992;42:1550-1559.
Harting J W. New developments in the pharmacotherapy of inflammatory bowel disease. Pharmaceutisch Weekblad - Scientific Edition. 1992;14:275-286. [pmid: 1437510].
Hasegawa S, Kano K, Motoki T. Mechanism of elevation in plasma glucagon/insulin ratio by soybean protein intake. Soy Protein Research, Japan. 1998;7:86-907.
Hauben M. Comment: evening primrose oil in the treatment of rheumatoid arthritis--proper application of statistical analysis. Annals of Pharmacotherapy. 1994;28:973. [pmid: 7832860].
Hazra A, Tripathi S K, Ghosh A. Pharmacology and therapeutic potential of the n-3 polyunsaturated fatty acids, eicosapentaenoic acid (EPA) and docosahexaenoic acid (DHA) in fish oils. Indian Journal of Pharmacology. 1999;31:247-264.
Henderson C, Panush R. Diets, dietary supplements, and nutritional therapies in rheumatic diseases. Rheumatic Disease Clinics of North America. 1999;25:937-968. [pmid: 10573768].
Hess E. Are there environmental forms of systemic autoimmune diseases?. Environmental Health Perspectives. 1999;107:S11. [pmid: 10502535].
Hirai K, Higuchi H, Inatsugi N, Yosikawa S: Therapeutic potential of n-3 poly unsaturated fatty acid for three cases of Crohn's disease. Japanese Journal of Nutrition 1998;10:
Hjermann I. The influence of dietary change on hemostatic risk variables. Annals of Epidemiology. 1992;2:525-527. [pmid: 1342303].
Ho K K L. IgA nephropathy: In Hong Kong. Hong Kong Practitioner. 2001;23:453-456.
Holler C, Auinger M, Ulberth F, Irsigler K. Eicosanoid precursors: potential factors for atherogenesis in diabetic CAPD patients?. Peritoneal Dialysis International. 1996;16:S3.
Horn H R. Case reports in type 2 diabetes. Cardiology Review. 1998;15:38-39.
Horrobin D F. The use of gamma-linolenic acid in diabetic neuropathy. Agents & Actions - Supplements. 1992;37:120-144. [pmid: 1321553].
Horrobin DF, Huang YS, Ziboh VA: gamma-Linolenic acid in diabetes. gamma Linolenic acid: recent advances in biotechnology and clinical applications 2001;36:-
Huang YS, Ziboh VA, Huang YS, Ziboh VA: gamma Linolenic acid: recent advances in biotechnology and clinical applications 2001;-
Hunter J O. Nutritional factors in inflammatory bowel disease. European Journal of Gastroenterology & Hepatology. 1998;10:235-237. [pmid: 9585027].
Huve J: Administration of omega-3 fatty acids and/or zinc for diabetics. 9 7:
Ilowite N. Premature atherosclerosis in systemic lupus erythematosus. Journal of Rheumatology. 2000;27:S9. [pmid: 10782851].
Ireland PD, Niall M, Sadler S, Deluise M, Traianedes K, O' Dea K: Dietary composition and its role in the treatment of type 2 diabetes. Proceedings of the Nutrition Society of Australia 1985;200-
Jacobs J, Rasker J, Bijlsma J. Alternative medicine in rheumatology: Threat or challenge?. Clinical & Experimental Rheumatology. 2001;19:117-119. [pmid: 11326470].
Jacotot B: Nutritional interest in the consumption of olive oil. OCL Oleagineux, Corps Gras, Lipides 1997;14:
Jacotot B: Olive oil and disease prevention. Nutrition Clinique et Metabolisme 1996;9:
Jain S, Gaiha M, Bhattacharjee J, Anuradha S. Effects of low-dose omega-3 fatty acid substitution in type-2 diabetes mellitus with special reference to oxidative stress--a prospective preliminary study. Journal of the Association of Physicians of India. 2002;50:1028-1033. [pmid: 12421024].
Jamal G A. Pathogenesis of diabetic neuropathy: The role of the n-6 essential fatty acids and their eicosanoid derivatives. Diabetic Medicine. 1990;7:574-579. [pmid: 2146062].
Jamal G A. The use of gamma linolenic acid in the prevention and treatment of diabetic neuropathy. Diabetic Medicine. 1994;11:145-149. [pmid: 8200197].
Jamal G A, Carmichael H. The effect of gamma-linolenic acid on human diabetic peripheral neuropathy: a double-blind placebo-controlled trial. Diabetic Medicine. 1990;7:319-323. [pmid: 2159860].
Jamal GA, Carmichael H, Weir AI: Gamma-linolenic acid in diabetic neuropathy. Lancet 1986;1:1098-
Jayson M. Dietary therapy for rheumatoid arthritis. British Journal of Rheumatology. Nov. 1993;32:1030. [pmid: 8110230].
Jones D B, Haitas B, Bown E G, et al. Platelet aggregation in non-insulin-dependent diabetes is associated with platelet fatty acids. Diabetic Medicine. 1986;3:52-55. [pmid: 2951137].
Julius U, Hanefeld M. Integrated drug therapy in metabolic syndrome. Internist. 1996;37:722-730. [pmid: 8766266].
Kalden J. Diet in rheumatology. Internist. 1996;37:1068-1068.
Kaminskas A, Levaciov M, Lupinovic V, Kuchinskene Z: The effect of linseed oil on the fatty acid composition of blood plasma low- and very low-density lipoproteins and cholesterol in diabetics. Voprosy Pitaniia 1992;13–14.
Katan M B. Fats for diabetics. Lancet. 1994;343:1518. [pmid: 7911867].
Katsilambros N, Phipippides P, Boletis J, Mavroudis K, Frangaki D, Chaniotis D: Blood sugar changes in diabetics after a test meal containing vegetables and olive oil. Acta Diabetologica Latina 1982;2:
Kaur K, Mittal P, Singh H, Chhatwal S. Newer drugs in the treatment of idiopathic ulcerative colitis (IUC). Journal International Medical Sciences Academy. 1998;11:112-115.
Keelan Monika Maria: Dietary omega(3) Fatty acids and cholesterol modify intestinal transport, enterocyte membrane lipid composition and enterocyte lipid synthesis ($\Omega$3 fatty acids). Dissertation Abstracts International 2361-
Klahr S, Harris K. Role of dietary lipids and renal eicosanoids on the progression of renal disease. Kidney International. 1989;27:S27-S31. [pmid: 2699998].
Klimes I, Sebokova E. The importance of diet therapy in the prevention and treatment of manifestations of metabolic syndrome X. Vnitrni Lekarstvi. 1995;41:136-140. [pmid: 7725639].
Knapp H R, Yurawecz M P, Mossoba M M, Kramer J K G, Pariza M W, Nelson G. Conjugated linoleic acid as a nutraceutical: observations in the context of 15 years on n-3 polyunsaturated fatty acid research. Advances in conjugated linoleic acid research, volume 1. 1999;28.
Kolasinski S. Complementary and alternative therapies for rheumatic disease. Hospital Practice. 2001;36:31-39. [pmid: 11327343].
Korber J, Karaus M, Hampel K E. Drug therapy of chronic inflammatory bowel disease. Medizinische Welt. 1996;47:51-54.
Kremer J, Robinson D. Studies of dietary supplementation with omega 3 fatty acids in patients with rheumatoid arthritis. World Review of Nutrition & Dietetics. 1991;66:367-382. [pmid: 2053351].
Kromhout D, Valagussa F, Marchioli R: ‘Protective nutrients’ and up-to-date dietary recommendations Evidence and perspectives on n 3 polyunsaturated fatty acids in cardiovascular disease. European-Heart-Journal-Supplements 2001;3: clinical-
Kruger M C, Potgieter H C, et al. Calcium, gamma-linolenic acid (GLA) and eicosapentaenoic acid (EPA) supplementation in osteoporosis. Osteoporosis International. 1996;6:250.
Kulakova SN, Gapparova KM, Pogozheva AV, Levachev MM: Evaluation of the influence of omega-3 polyunsaturated fatty acids of fish and vegetable origin on the the fatty acid composition of erythrocyte lipids in patients with ischaemic heart disease complicated by impaired glucose tolerance. Voprosy Pitaniya 1999; 15:5–6, 26.
Ladodo KS, Levachev MM, Naumova VI, et al: Experiment on the use of fish oil Polyenin pediatric practice. Voprosy Pitaniya 1996;13:-
Lazebnik L B, Vertkin A L, Malichenko S B, Li E D, Konev Iu V, Romanovskaia T V, Goncharov L F. Experience in the use of eiconol (a complex of unsaturated fatty acids) in non-insulin-dependent diabetes mellitus. Klinicheskaia Meditsina. 1996;74:29-33. [pmid: 8926697].
Lecerf J M. Treatments of hyperlipoproteinemia. Gazette Medicale. 1993;100:16-18.
Lee T, Arm J, Horton C, Crea A, Mencia-Huerta J, Spur B: Effects of dietary fish oil lipids on allergic and inflammatory diseases. Allergy Proceedings 1991:299–303.
Leeuw IH de Gaal L, V Rillaerts E, Dalemans C: Short-term effects of PUFA-enrichment in the diet of insulin-dependent diabetic patients. Diabete et Metabolisme 1986;13:
Lefkowith J, Klahr S. Polyunsaturated fatty acids and renal disease. Proceedings of the Society for Experimental Biology & Medicine. 1996;213:13-23. [pmid: 8820819].
Lemann M. Novel therapeutic approaches to inflammatory bowel disease. Semaine des Hopitaux. 1998;74:759-760.
Linn T, Klor HU: Clinical therapy with fish oil. Aktuelle Ernahrungsmedizin 1989;21:
Lissner L, Heitmann BL, Bengtsson C, Asp NG, Frayn K, Vessby B: Population studies of diet and obesity. Diet and the metabolic syndrome 13:
Liu S: Dietary fat and exercise influence regulation of glucose metabolism in skeletal muscle. Dissertation Abstracts International 6601-
Locker F: The effect of diet and vitamin d on mineral metabolism in primary hyperparathyroidism. Dissertation Abstracts International 57:4134-
Lorenz-Meyer H. Fish oil for prevention of Crohn disease recurrence. Zeitschrift fur Gastroenterologie. 1997;35:XX-XXI. [pmid: 9487646].
Lovejoy J C. Dietary fatty acids and insulin resistance. Current Atherosclerosis Reports. 1999;1:215-220. [pmid: 11122713].
Maes B. IgA nephropathy. Tijdschrift voor Geneeskunde. 2000;56:1496-1508.
Magaro M, Zoli A, Altomonte L, et al. Effect of fish oil on neutrophil chemiluminescence induced by different stimuli in patients with rheumatoid arthritis. Annals of the Rheumatic Diseases. 1992;51:877-880. [pmid: 1632662]. [pmcid: 1004772].
Malaguarnera M, Giugno I, Ruello P, Vinci E, Panebianco M P, Motta M. Current treatment of hypertriglyceridemia. [Italian]. Recenti Progressi in Medicina. 2000;91:379-387. [pmid: 10932925].
Malichenko S B, Lazebnik L B, Vertkin A L, Konev Iu V, Romanovskaia T V, Smirnova O I. The effects of eiconol in elderly patients with non-insulin-dependent diabetes mellitus. Terapevticheskii Arkhiv. 1996;68:15-18. [pmid: 9026935].
Mann J I, Hockaday T D, Hockaday J M, Turner R C. A prospective study of modified-fat and low-carbohydrate dietary advice in the treatment of maturity-onset diabetes. Proceedings of the Nutrition Society. 1976;35:72A-73A. [pmid: 972890].
March L, Stenmark J. Non-pharmacological approaches to managing arthritis. Medical Journal of Australia. 2001;175:S102-S107. [pmid: 11795555].
Marsch-Ziegler U. Chronic inflammatory intestine disease. Aspects for current therapy. Zeitschrift fur Allgemeinmedizin. 1994;70:53-56.
Mathus-Vliegen E M H. The role of diets in the treatment of inflammatory bowel diseases. Pharmaceutisch Weekblad. 2000;135:1314-1318.
Matzkies F. Essential fatty acids. Fortschritte der Medizin. 1980;98:940-944. [pmid: 7429383].
McGill E J. Lipid-lowering dietary advice in diabetes. Practical Diabetes International. 1995;12:157-158.
Messina M, Messina V. Soyfoods, soybean isoflavones, and bone health: a brief overview. Journal of Renal Nutrition. 2000;10:63-68. [pmid: 10757817].
Metzner C, Ulrich Merzenich G: Nutrition therapy of the metabolic syndrome and diabetes mellitus with natural substances (dietary fibre, fatty acids). VitaMinSpur 2001;13:
Miller B. A pathogenetically substantiated treatment for chronic inflammatory bowel disease - Does it come into view?. Zeitschrift fur Gastroenterologie. 1993;31:30-34. [pmid: 8197797].
Misra A. Insulin resistance syndrome: Current perspective and its relevance in Indians. Indian Heart Journal. 1998;50:385-395. [pmid: 9835197].
Miura S, Tsuzuki Y, Hokari R, Ishii H. Modulation of intestinal immune system by dietary fat intake: relevance to Crohn's disease. Journal of Gastroenterology & Hepatology. 1998;13:1183-1190. [pmid: 9918423].
Miyares Gomez A I. Nutritional factors involved in the treatment of inflammatory bowel disease. Revista Espanola de Pediatria. 1993;51:241-291.
Mizushima S, Moriguchi E H, Ishikawa P, et al. Fish intake and cardiovascular risk among middle-aged Japanese in Japan and Brazil. Journal of Cardiovascular Risk. 1997;4:191-199. [pmid: 9475674].
Moretti G, Mancarella P, Marin V: Diet and cardiovascular diseases in fishermen and farmers in an Italian northern sea town. Igiene Moderna 1999;12:
Mori T A. Fish oils, dyslipidaemia and glycaemic control in diabetes. Practical Diabetes International. 1999;16:223-226.
Mori T A, Puddey I B, Burke V, et al. Effect of omega 3 fatty acids on oxidative stress in humans: GC-MS measurement of urinary F2-isoprostane excretion. Redox Report. 2000;5:45-46. [pmid: 10905544].
Morris M C, Sacks F, Rosner B. Fish oil to reduce blood pressure: A meta-analysis. Annals of Internal Medicine. 1994;120:10.
Muller SD: Actual aspects about nutritionmedical therapy of hyperlipoproteinaemia. Ernahrungsforschung 2001;57:
Muller S, Pfeuffer C: Dietetic treatment of inflammatory rheumatic and rheuma-like diseases. VitaMinSpur 2000;1:
Muls E, Furst P: Nutrition recommendations for the person with diabetes. Consensus roundtable on nutrition support of tube fed patients with diabetes
Murthy R, Murthy M. Omega-3 fatty acids as anti-inflammatory agents: A classical group of nutraceuticals. Journal of Nutraceuticals, Functional & Medical Foods. 1999;2:53-72.
Myrup B, Rossing P, Jensen T, et al. Lack of effect of fish oil supplementation on coagulation and transcapillary escape rate of albumin in insulin-dependent diabetic patients with diabetic nephropathy. Scandinavian Journal of Clinical & Laboratory Investigation. 2001;61:349-356. [pmid: 11569481].
Nachman P H, Martin J. Developments in the immunotherapy of glomerular disease. Journal of Pharmacy Practice. 2002;15:472-489.
Nagel E, Bartels M, Pichlmayr R. Influence of nutrition in ulcerative colitis - The significance of nutritional care in inflammatory bowel disease. Langenbecks Archiv fur Chirurgie. 1995;380:4-11. [pmid: 7707850].
Nakazawa A, Hibi T. Is fish oil (n-3 fatty acids) effective for the maintenance of remission in Crohn's disease?. Journal of Gastroenterology. 2000;35:173-175. [pmid: 10680676].
Nettleton JA: Omega-3 fatty acids and health. 1995;xiii + 359
Nordoy A. Statins and omega-3 fatty acids in the treatment of dyslipidemia and coronary heart disease. Minerva Medica. 2002;93:357-363. [pmid: 12410168].
O'Dea K. Westernization and non-insulin-dependent diabetes in Australian Aborigines. Ethnicity & Disease. 1991;1:171-187. [pmid: 1668799].
O'Keefe S J. Nutrition and gastrointestinal disease. Scandinavian Journal of Gastroenterology - Supplement. 1996;220:52-59. [pmid: 8898436].
O'Morain C A. Does nutritional therapy in inflammatory bowel disease have a primary or an adjunctive role?. Scandinavian Journal of Gastroenterology - Supplement. 1990;172:29-34. [pmid: 2112781].
O'Sullivan M A, O'Morain C A. Nutritional therapy in Crohn's disease. Inflammatory Bowel Diseases. 1998;4:45-53. [pmid: 9552228].
Odugbesan O, Barnett A H. Use of a seaweed-based dressing in management of leg ulcers in diabetics: A case report. Practical Diabetes. 1987;4:46-47.
Okuda Y, Mizutani M, Tanaka K, Isaka M, Yamashita K. Is eicosapentaenoic acid beneficial to diabetic patients with arteriosclerosis obliterans. Diabetologia Croatica. 1992;21:13-17.
Opara EC, Hubbard VS: Essential fatty acids (EFA): role in pancreatic hormone release and concomitant metabolic effect. Journal of Nutritional Biochemistry 1993;102:
Otsuji S, Kamada T, Yamashita T, et al. The influence of dietary sardine oil (eicosapentaenoic acid) on the erythrocyte membrane fluidity in diabetic patients. Rinsho Byori - Japanese Journal of Clinical Pathology. 1984;32:764-771. [pmid: 6094886].
Ozdemir I, Bolu E. Clinical applications of fish oil. Bulletin of Gulhane Military Medical Academy. 1990;32:681-692.
Panchenko V M, Karabasova M A, Liutova L V, et al. Influence polyunsaturated fatty acids omega-3 on coagulation and fibrinolysis systems in patients with NIDDM. Klinicheskaia Meditsina. 2002;80:40-43. [pmid: 11898721].
Pav J, Rames I, Formanek M. Parameters of fat matabolism and their relation to the compensation of diabetes mellitus. Vnitrni Lekarstvi. 1972;18:246-252. [pmid: 5012420].
Pedersen J I. More on trans fatty acids. British Journal of Nutrition. 2001;85:249-250. [pmid: 11299071].
Pelikanova T, Kohout M, Valek J, et al. The effect of fish oil on the secretion and effect of insulin in patients with type II diabetes. Casopis Lekaru Ceskych. 1992;131:668-672. [pmid: 1473127].
Peppercorn MA: Drug therapy of inflammatory bowel disease, part II: Patient management recommendations. Drug Therapy 1992;22:43–48+53.
Peppercorn M A. Medical therapies for ulcerative colitis. Article three in the series. Practical Gastroenterology. 1992;16:11-19.
Peppercorn M A. Newer agents for the treatment of inflammatory bowel disease. P & T. 1993;18:583-588.
Pinelli L, Alfonsi L, Mormile R, Piccoli R. Diet for young diabetics: Standard and mediterranean. Annales de Pediatrie. 1998;45:571-577.
Pinelli L, Mormile R, Alfonsi L, et al: The role of nutrition in prevention of complications in insulin-dependent diabetes mellitus. Proceedings of the First Workshop on Insulin dependent Diabetes Mellitus in Children and Adolescents, 1997;25:
Pinelli L, Mormile R, Gonfiantini E, et al. Recommended dietary allowances (RDA) in the dietary management of children and adolescents with IDDM: an unfeasible target or an achievable cornerstone?. Journal of Pediatric Endocrinology & Metabolism. 1998;11:S46.
Plessas S T, Athanasiadis N, Papadakis S. omega-3 polyunsaturated fatty acids and eicosanoids. Sources, biochemistry and functions in physiological conditions and in cardiovascular disease current status. Review of Clinical Pharmacology & Pharmacokinetics, International Edition. 1998;16:5-29.
Podell R. Nutritional treatment of rheumatoid arthritis. Can alterations in fat intake affect disease course?. Postgraduate Medicine. 1972;1985:65-69.
Pogozheva AV, Tutelyan VA, Gapparova KM, Trushina EN, Myagkova MA: The influence of antiatherosclerotic diet with inclusion PUFA omega-3 of a vegetative and sea origin on parameters of cellular and humoral immunity in patients with ishemic heart disease complicated by impaired carbohydrates tolerance. Voprosy Pitaniya 2000;16.
Present D N, Ginsberg A L, Arora S, Kaplan M. New drugs improve prognosis for patients with IBD. Internal Medicine. 1993;14:20-30.
Press A G, Ramadori G. Therapy of chronic enteritis. Part II. Indications for therapy. Therapiewoche. 1994;44:962-970.
Prier A: Effects of dietetic manipulations on the course of rheumatoid arthritis. Presse Medicale 1988:1181–1183.
Prindiville TP, Cantrell MC, Gershwin ME, German JB, Keen CL: Autoimmune diseases of the digestive tract.Nutrition and immunology: principles and practice 2000; 140:-
Prokopiuk M, Wierzbicki P, Kade G. IgA nephropathy--advances of therapy. Polskie Archiwum Medycyny Wewnetrznej. 2001;106:1079-1086. [pmid: 12026523].
Pullman-Mooar S, Laposata M, Lem D, et al: Alteration of the cellular fatty acid profile and the production of eicosanoids in human monocytes by gamma-linolenic acid. Arthritis & Rheumatism 1990:1526–1533.2171540
Putz K: Dietary aspects of osteoporosis. VitaMinSpur 2001;
Raheja B, Bhakta V, Chandiramani A, et al. Use of fish oil locally in the management of diabetic foot-preliminary observations. Journal of the Diabetic Association of India. 1989;29:47-48.
Raheja B S. Essential fatty acids, atherosclerosis and diabetes. Journal of the Diabetic Association of India. 1990;30:20.
Rahman M A, Stork J E, Dunn M J. The roles of eicosanoids in experimental glomerulonephritis. Kidney International - Supplement. 1987;22:S40-S48. [pmid: 3323619].
Rao S, Erasmus R T. Pilot study on plasma fatty acids in poorly controlled non insulin dependent diabetic Melanesians. East African Medical Journal. 1996;73:816-818. [pmid: 9103692].
Rasmussen O, Lauszus F F, Christiansen C, Thomsen C, Hermansen K. Differential effects of saturated and monounsaturated fat on blood glucose and insulin responses in subjects with non-insulin-dependent diabetes mellitus. American Journal of Clinical Nutrition. 1996;63:249-253. [pmid: 8561067].
Rasmussen O W, Lauszus F F, Christiansen C S, Thomsen C H, Hermansen K. Saturated and monounsaturated fats in patients with insulin-dependent diabetes. Different effects on blood glucose and insulin response in NIDDM. Ugeskrift for Laeger. 1998;160:842-846. [pmid: 9469983].
Rasmussen O W, Thomsen C H, Hansen K W, Vesterlund M, Winther E, Hermansen K. [Favourable effect of olive oil in patients with non-insulin-dependent diabetes. The effect on blood pressure, blood glucose and lipid levels of a high-fat diet rich in monounsaturated fat compared with a carbohydrate-rich diet. Ugeskrift for Laeger. 1995;157:1028-1032. [pmid: 7879301].
Rastegar S: Identifying and characterizing agents in soy that have a potential role in diabetes development. Masters Abstracts International 36–01: 94-
Reseland J E, Anderssen S A, Solvoll K, et al. Effect of long-term changes in diet and exercise on plasma leptin concentrations. American Journal of Clinical Nutrition. 2001;73:240-245. [pmid: 11157319].
Riemersma RA, Armstrong R, Kelly RW, Wilson R: Essential fatty acids and eicosanoids: invited papers from the Fourth International Congress, Edinburgh, Scotland, UK, July 20–24, 1997. 1998;432
Rivellese A A, De Natale C, Lilli S. Type of dietary fat and insulin resistance. Annals of the New York Academy of Sciences. 2002;967:329-335. [pmid: 12079860].
Rivlin RS: Fats and oil consumption in health and disease: current concepts and controversies. Proceedings of a symposium held at the Rockefellar University, New York, USA, 24–25 April, 1995. American Journal of Clinical Nutrition 1997;
Roberts J, Davies B, McKeigue P, Davey G. Specific and combined use of exercise training and omega-3 fatty acids as interventions for insulin resistance. Journal of Sports Sciences. 1998;16:59.
Robinson D R. Alleviation of autoimmune disease by dietary lipids containting Omega-3 fatty acids. Rheumatic Disease Clinics of North America. 1991;17:213-222+viii. [pmid: 1862233].
Robinson DR, Colvin RB, Hirai A, et al: Dietary marine lipids modify autoimmune diseases. Health effects of polyunsaturated fatty acids in seafoods 1986;16 ref.:-
Robinson DR, Xu LL, Olesiak W, et al: Suppression of autoimmune disease by purified n-3 fatty acids. Health effects of dietary fatty acids 1991;5:-
Roesli Rully: Study on the prevalence of non-insulin-dependent diabetes mellitus and impaired glucose tolerance in a rural area of west java, indonesia. Dissertation Abstracts International 656-
Rohrbach J, Reinelt D. Polyunsaturated fatty acids in the serum of patients with various diseases. Zeitschrift fur die Gesamte Innere Medizin und Ihre Grenzgebiete. 1968;23:656-659. [pmid: 5705450].
Rontoyannis GP, Simopoulos AP: Diet and exercise in the prevention of cardiovascular disease. Nutrition and fitness in health and disease. World Review of Nutrition and Dietetics 1993;72:
Rossing P, Hansen B V, Nielsen F S, Myrup B, Holmer G, Parving H H. Fish oil in diabetic nephropathy. Diabetes Care. 1996;19:1214-1219. [pmid: 8908382].
Rutgeerts P J. Postoperative recurrence prophylaxis in Crohn's disease. An update. Research & Clinical Forums. 1998;20:49-55.
Sailer D. Diet as therapy - Changes in therapeutic concepts?. Fortschritte der Medizin. 1988;106:52-55. [pmid: 3215613].
Samsonov MA, Isaev VA: Latest in the prevention and treatment of atherosclerosis, ischaemic heart disease, hypertension and other disorders. Voprosy Pitaniya 1995;-
Sathe S R, Raheja B S. Fish oil in the management of diabetic foot. Journal of the Diabetic Association of India. 1994;34:51-54.
Savage GP, Webster G, Plows E: Nutritional trends for the future. Proceedings of a Continuing Education Seminar, Orakei Basin, Auckland, New Zealand, 15th November 1994. 1994;-
Schacky Cvon Baumann K, Angerer P, Von Schacky C : The effect of n-3 fatty acids on coronary atherosclerosis: results from SCIMO, an angiographic study, background and implications. Prevention and treatment of vascular disease: a nutrition based approach, Aarhus, Denmark, 18 20 May, 2000 2000;
Schaller J. Aggressive treatment in childhood rheumatic diseases. Clinical & Experimental Rheumatology. 1994;12:S97-S105. [pmid: 7955637].
Scheurlen C. Dietary therapy in Crohn disease. Internist. 1990;31:433. [pmid: 2376488].
Scheurlen M, Steinhilber D, Daiss W, Clemens M, Schmidt H, Jaschonek K. Effects of an elemental diet containing fish oil on neutrophil LTB4 synthesis and membrane lipid composition. Progress in Clinical & Biological Research. 1989;301:505-509. [pmid: 2477858].
Schiele J, Nowack R, Julian B A, van der Woude F J. Treatment of immunoglobulin A nephropathy. Annales de Medecine Interne. 1999;150:127-136. [pmid: 10392261].
Schleiffer T, Brass H. Lipid metabolism of chronic renal failure and diabetic nephropathy - Update. Nieren- und Hochdruckkrankheiten. 1992;21:58-71.
Schmidt E B, Moller J M, Svaneborg N, Dyerberg J. Safety aspects of fish oils. Experiences with an n-3 concentrate of re-esterified triglycerides (Pikasol(TM)). Drug Investigation. 1994;7:215-220.
Schmitz PG, O' Donnell MP, Kasiske BL, Keane WF: Glomerular hemodynamic effects of dietary polyunsaturated fatty acid supplementation. Journal of Laboratory and Clinical Medicine 1991;43:1856576
Schwab D, Raithel M, Hahn E G. Enteral nutrition in acute Crohn disease. Zeitschrift fur Gastroenterologie. 1998;36:983-995. [pmid: 9880825].
Selby W. Current management of inflammatory bowel disease. Journal of Gastroenterology & Hepatology. 1993;8:70-83. [pmid: 8094984].
Seppanen R, Reunanen A: Diet habits of diabetics and nondiabetics in Finland. Naringsforskning 1979;
Sharma R K, Sural S. Current management of glomerular diseases. Journal of Internal Medicine of India. 1999;2:155-160.
Shen Chwan Li: Effect of dietary polyunsaturated fatty acids on prostaglandin e(2) Aand insulin-like growth factor-i in bone modeling. Dissertation Abstracts International 56–09, Section: B:4663-
Siamopoulou A, Challa A, Kapoglou P, Cholevas V, Mavridis A, Lapatsanis P. Effects of intranasal salmon calcitonin in juvenile idiopathic arthritis. An observational study. Calcified Tissue International. 2001;69:25-30. [pmid: 11685430].
Silvis N, Vorster HH, Mollentze WF, Jagar Jde Huisman HW, De Jager J: Metabolic and haemostatic consequences of dietary fibre and N-3 fatty acids in black type 2 (NIDDM) diabetic subjects: a placebo controlled study. International Clinical Nutrition Review 1990;
Simonsen N: Nutritional Determinants of Rheumatoid Arthritis. Dissertation.Abstracts.International
Simopoulos AP, Pavlou KN, Simopoulos AP, Pavlou KN: Nutrition and fitness 2: metabolic studies in health and disease 2001;-
Simpser E, Daum F, Dinari G, et al: Nutrition in pediatric inflammatory bowel disease . Pediatric nutrition 1998;40:-
Singer P, Gnauck G, Honigmann G, et al: The fatty acid pattern of adipose tissue and liver triglycerides according to fat droplet size in liver parenchymal cells of diabetic subjects. Diabetologia 1974;4375642
Singer P, Honigmann G, Schliack V. Decrease of eicosapentaenoic acid in fatty liver of diabetic subjects. Prostaglandins & Medicine. 1980;5:183-200. [pmid: 6251498].
Singer P, Honigmann G, Schliack V. On the fatty acids of the triglycerides in inflammatory liver diseases of diabetics without and with hyperlipoproteinemia. Zeitschrift fur die Gesamte Innere Medizin und Ihre Grenzgebiete. 1981;36:513-519. [pmid: 7293284].
Singh G. Fish oils in rheumatoid arthritis. Annals of Internal Medicine. 1988;108:904-905. [pmid: 3369779].
Singh R B, Rastogi S S, Rao P V, et al. Diet and lifestyle guidelines and desirable levels of risk factors for the prevention of diabetes and its vascular complications in Indians: a scientific statement of The International College of Nutrition. Indian Consensus Group for the Prevention of Diabetes. Journal of Cardiovascular Risk. 1997;4:201-208. [pmid: 9475675].
Sircar S, Kansra U. Choice of cooking oils--myths and realities. Journal of the Indian Medical Association. 1998;96:304-307. [pmid: 10063298].
Socha P, Ryzko J, Koletzko B, et al. The influence of fish oil therapy in children with inflammatory bowel disease on the fatty acid status. Pediatria Wspolczesna. 2002;4:413-416.
Song T: Soy isoflavones: Database development, estrogenic activity of glycitein and hypocholesterolemic effect of daidzein. Dissertation Abstracts International 59:5638-
Sorokin E L, Smoliakova G P, Bachaldin I L. Clinical efficacy of eiconol in patients with diabetic retinopathy. Vestnik Oftalmologii. 1997;113:37-39. [pmid: 9381643].
Soustre Y, Laurent B, Schrezenmeir J, Pfeuffer M, Miller G, Parodi P: Trans fatty acids. Bulletin of the International Dairy Federation 2002;-
Stender S, Jensen T, Deckert T. Experience with fish oil treatment with special emphasis on diabetic nephropathy. Journal of Diabetic Complications. 1990;4:70-71. [pmid: 2145305].
Stone N J, Van Horn L. Therapeutic Lifestyle Change and Adult Treatment Panel III. Evidence Then and Now. Current Atherosclerosis Reports. 2002;4:433-443. [pmid: 12361490].
Stotland B R, Lichtenstein G R. Newer treatments for inflammatory bowel disease. Primary Care; Clinics in Office Practice. 1996;23:577-608. [pmid: 8888346].
Stotland B R, Lichtenstein G R. Newer treatments for inflammatory bowel disease. Drugs of Today. 1998;34:177-192. [pmid: 15094873].
Sugano M, Ikeda A. Regulation of soybean protein of alpha-linolenic acid metabolism: effect of diabetes. Report of the Soy Protein Research Committee Japan. 1995;6 ref:18-206.
Takazakura E, Ohsawa K, Hamamatsu K, et al: Prevention and treatment of diabetic nephropathy; Decreased microalbuminuria after six months treatment with eicosapentaenoic acid (EPA) ethyl ester. Conference: The Third International Symposium on treatment of Diabetes Mellitus 13 JUL 1988 to 15 JUL 1988; Nagoya, JAPAN 1990;562–566.
Tamas D, Gyorgyi C, Katalin T, et al: Polyunsaturated fatty acids in plasma lipids of obese children with and without metabolic cardiovascular syndrome. Lipids 2000;
Tjornum T E. Olive oil for patients with diabetes. Ugeskrift for Laeger. 1995;157:2457-2458. [pmid: 7762108].
Tjornum T E. Olive oil to diabetics--again. Ugeskrift for Laeger. 1995;157:3637. [pmid: 7652987].
Tobin A. Fish oil supplementation and ulcerative colitis. Annals of Internal Medicine. 1992;117:535-536. [pmid: 1503362].
Toeller M. Nutritional therapy in diabetes mellitus. Aktuelle Ernahrungsmedizin. 2002;27:101-107.
Tonstad S. Drug therapy of hyperlipidemia--unanswered questions. Tidsskrift for Den Norske Laegeforening. 1997;117:674-677. [pmid: 9102959].
Tonstad S. Indications for lipid-lowering drugs. Unanswered questions. Tidsskrift for Den Norske Laegeforening. 1997;117:674-677. [pmid: 9102959].
Tonstad S, Leren T P, Ose L. Diagnosis and treatment of severe hyperlipidemia. Tidsskrift for Den Norske Laegeforening. 1997;117:4241-4244. [pmid: 9441469].
Turpin G, Bruckert E. Management of atherogenic hyperlipidemia. Annales de Cardiologie et d Angeiologie. 1998;47:627-632. [pmid: 9864558].
Uauy R, Mena P, Valenzuela A. Essential fatty acids as determinants of lipid requirements in infants, children and adults. European Journal of Clinical Nutrition. 1999;53:S 7. [pmid: 10365982].
Ueki M, Matsui T, Yamada M, et al. Randomized controlled trial of amino acid based diet versus oligopeptide based diet in enteral nutritional therapy of active Crohn's disease. Japanese Journal of Gastroenterology. 1994;91:1415-1425.
Uhlig T. Clinical application of omega 3 fatty acids (fish oil). Deutsche Medizinische Wochenschrift. 1995;120:1262-1263. [pmid: 7671791].
Uusitupa M, Louheranta A, Lindstrom J, et al: The Finnish Diabetes Prevention Study. Diet and the metabolic syndrome
Valensi P, Attalah M, Behar A, Attali J R. Capillary permeability in diabetes. [French]. Sang Thrombose Vaisseaux. 1994;6:473-481.
Valtuena S, Sette S, Branca F. Influence of Mediterranean diet and Mediterranean lifestyle on calcium and bone metabolism. International Journal for Vitamin & Nutrition Research. 2001;71:189-202. [pmid: 11582842].
Vanbeber Anne Duffy: The effect of omega-3, omega-6, and omega-9 fatty acid supplements on the serum fatty acid profile and immune response of renal dialysis patients (Fish oil). Dissertation Abstracts International 4133-
Vaupel N. Substitution of Omega-3 fatty acids in type I and type II diabetics. Fortschritte der Medizin. 1996;114:32.
Venter CS, van Eyssen E: More legumes for better overall health. SAJCN South African Journal of Clinical Nutrition 2001;S32–3.
Vergroesen AJ, Crawford M: Role of fats in human nutrition. 2002;Hardback.:-
Vessby B. Dietary fat and insulin action in humans. British Journal of Nutrition. 2000;83:S6. [pmid: 10889798].
Voigt J, Hagemeister H: Dietary influence on a desirable fatty acid composition in milk from dairy cattle. New trends in animal nutrition, 28 29 June, 2001, Jachranka, Poland 2001;
Volkert R. Omega 3 fatty acids. Fish oil capsules as drugs. Zeitschrift fur Allgemeinmedizin 1990;66:776.
Von Ritter C. Inflammatory bowel disease. Pathophysiology and medical treatment. Radiologe. 1998;38:3-7. [pmid: 9530772].
Wahlqvist M L, Lo C S, Myers K A. Fish intake and arterial wall characteristics in healthy people and diabetic patients. Lancet. 1989;2:944-946. [pmid: 2571863].
Wahlqvist M L, Lo C S, Myers K A. Relationships between fish intake and arterial wall characteristics. Proceedings of the Nutrition Society of Australia. 1988;3 ref:1013.
Wahrburg U. Mediterranean diet and its role in the prevention and treatment of diet-related diseases. Internistische Praxis. 2001;41:815-826.
Wardle E N. Alternative therapies for vasculitis and proliferative nephritides: The role of cyclic AMP elevating agents. Renal Failure. 1998;20:7-13. [pmid: 9509556].
Wardle E N. IgA nephropathy. New England Journal of Medicine Online. 2003;348:79-81. [pmid: 12510692].
Wardle E N. Rationales for treating IgA nephropathies. Renal Failure. 2000;22:1-16. [pmid: 10718276].
Watkins B, Seifert M: Conjugated linoleic acid and bone biology. Journal of the American College of Nutrition 2000;478S–486S.
Watson J, Madhok R, Wijelath E, et al: Mechanism of action of polyunsaturated fatty acids in rheumatoid arthritis. Biochemical.Society Transactions. 1990;284–285.
Weber N: Oleic acid-rich fats in nutrition. Schriftenreihe des Bundesministeriums fur Ernahrung, Landwirtschaft und Forsten 1997;-
Wijendran Vasuki: Long chain polyunsaturated fatty acid metabolism in normal pregnancy and pregnancy complicated with gestational diabetes mellitus. Dissertation Abstracts International 2617-
Wilhelmi G. Potential effects of nutrition including additives on healthy and arthrotic joints. I. Basic dietary constituents. Zeitschrift fur Rheumatologie. 1993;52:174-179. [pmid: 8368023].
Wolfram G: Diet therapy in metabolic diseases 1996 20 years of rational dietetics in Germenay 1976-1996 1996;
Wolfram G: Omega3- and omega6-Fatty acids - biochemical specialities and biological effects. Fett Wissenschaft Technologie 1989;
Woo J, Ho S C, Yu A L. Lifestyle factors and health outcomes in elderly Hong Kong chinese aged 70 years and over. Gerontology. 2002;48:234-240. [pmid: 12053113].
Wright J, Furst P: Effect of high-carbohydrate versus high-monounsaturated fatty acid diet on metabolic control in diabetes and hyperglycemic patients. Consensus roundtable on nutrition support of tube fed patients with diabetes
Yam D, Friedman J, Bott-Kanner G, Genin I, Shinitzky M, Klainman E. Omega-3 fatty acids reduce hyperlipidaemia, hyperinsulinaemia and hypertension in cardiovascular patients. Journal of Clinical & Basic Cardiology. 2002;5:229-231.
Yamamoto S. Essential unsaturated fatty acids. Nippon Rinsho - Japanese Journal of Clinical Medicine. 1999;57:2242-2246. [pmid: 10540869].
Yeh Lan Lan Liang: The relationship of serum fatty acid distributions to the risk of coronary heart disease and dietary intake (Fatty acids). Dissertation Abstracts International 2793-
Yszko J S, Yszko J, Pawlak K, liwiec M. Effect of treating glomerulonephritis with omega 3 fatty acids for selected parameters of hemostasis, blood platelet function and lipid metabolism. Przeglad Lekarski. 1996;53:600-603. [pmid: 8999460].
Yurawecz MP, Mossoba MM, Kramer JKG, Pariza MW, Nelson GJ: Advances in conjugated linoleic acid research, volume 1. 1999;-
Zaccagna C A, Zullo G. The erectile dysfunction. Alimentary approach by metabolic supplementation with PUFA - 3. Gazzetta Medica Italiana. 2002;161:53-61.
Zak A, Zeman M, Tvrzicka E, et al: Glucose tolerance, insulin secretion, plasma lipid fatty acids, and the hypolipidemic effects of fish oil. Dietary lipids and insulin action Second International Smolenice Insulin Symposium 378–379.
Zeman M, Zak A, Tvrzicka E, Buchtikova M, Stipek S, Pousek L. [Insulinemia, fatty acids in plasma lipids and lipoproteins and oxidation of VLDL and LDL in hyperlipidemia. Sbornik Lekarsky. 2000;101:77-82. [pmid: 10953635].
Zurier R, Rossetti R, Furse R, Huang Y, Ziboh V: Gamma-Linolenic acid, inflammatory arthritis, and immune responses. Gamma.Linolenic.acid:.recent.advances.in.biotechnology.and.clinical.applications. 2001;38:-

### Rejected RAND's Search Unsuccessful

Adam O: The role of dietary fat] in the prevention and therapy of nutrition-related diseases: the point of view of a rheumatologist. 7th Aachen dietetic continuing education 6:
Castiglioni A, Savazzi G M. The prevention and treatment of diabetic nephropathy. European Journal of Internal Medicine. 1993;4:181-192.
Corda Christophe: Contribution a l'etude du role des acides gras polyinsatures de la serie omega-3 dans la prevention de la nephrotoxicite de la ciclosporine a chez des patients ayant beneficie d'une greffe de rein: Etude randomisee en double aveugle contre placebo. Dissertation Abstracts International 53: 693-
Donnellan Christopher Edward: The effect of different dietary fatty acids upon the development of obesity and insulin resistance. Dissertation Abstracts International 61–04:1023-
Heller A, Koch T. Omega-3 fatty acids as adjuvant therapy in inflammatory diseases. Anaesth Intensivmedizin. 1996;10:517-28.
Lau C, Morley K, McMahon H, Belch J. Maxepa reduced non-steroidal anti-inflamatory drug requirement in patients with mild rheumatoid arthritis. Hung Rheumatol. 1991;32:126a.
Lee T, Austen K. Arachidonic acid metabolism by the 5-lipoxygenase pathway, and the effects of alternative dietary fatty acids. Advances in Immunology. 1986;39:145-175. [pmid: 3098061].
Tulleken J. Long chain omega-3 polyunsaturated fatty acids in rheumatoid arthritis. The Netherlands. Rijksuniversiteit Groningen 1991;

### Rejected Condition

Abate N, Jialal I. Therapy and clinical trials. Current Opinion in Lipidology. 2002;13:457-460. [pmid: 12151863].
Adam O. Nutrition as adjuvant therapy for chronic polyarthritis. Zeitschrift fur Rheumatologie. 1993;52:275-280. [pmid: 8259718].
Adam O, Schubert A, Adam A, Antretter N, Forth W. Effects of omega-3 fatty acids on renal function and electrolyte excretion in aged persons. European Journal of Medical Research. 1998;3:111-118. [pmid: 9512978].
Almallah Y Z, El Tahir A, Heys S D, Richardson S, Eremin O. Distal procto-colitis and n-3 polyunsaturated fatty acids. the mechanism(s) of natural cytotoxicity inhibition. European Journal of Clinical Investigation. 2000;30:58-65. [pmid: 10620003].
Arrington J L, McMurray D N, Switzer K C, Fan Y Y, Chapkin R S. Docosahexaenoic acid suppresses function of the CD28 costimulatory membrane receptor in primary murine and Jurkat T cells. Journal of Nutrition. 2001;131:1147-1153. [pmid: 11285317].
Assmann G, Backer Gde Bagnara S, Betteridge J, et al: International consensus statement on olive oil and the Mediterranean diet: implications for health in Europe. European Journal of Cancer Prevention 1997;30:9466113
Baird D, Umbach D, Lansdell L, et al. Dietary intervention study to assess estrogenicity of dietary soy among postmenopausal women. J Clin Endocrinol Metab. 1995;80:1685-90. [pmid: 7745019].
Baker PW, Gibbons GF: Effect of dietary fish oil on the sensitivity of hepatic lipid metabolism to regulation by insulin. Journal of Lipid Research 2000;48:10787432
Barham J B, Edens M B, Fonteh A N, Johnson M M, Easter L, Chilton F H. Addition of eicosapentaenoic acid to gamma-linolenic acid-supplemented diets prevents serum arachidonic acid accumulation in humans. Journal of Nutrition. 2000;130:1925-1931. [pmid: 10917903].
Berlin E, Bhathena S J, Judd J T, et al. Effects of omega-3 fatty acid and vitamin E supplementation on erythrocyte membrane fluidity, tocopherols, insulin binding, and lipid composition in adult men. Journal of Nutritional Biochemistry. 1992;3:392-400.
Bhathena S J, Berlin E, Judd J T, et al. Effects of omega 3 fatty acids and vitamin E on hormones involved in carbohydrate and lipid metabolism in men. American Journal of Clinical Nutrition. 1991;54:684-688. [pmid: 1832814].
Bordin P, Bodamer O A, Venkatesan S, Gray R M, Bannister P A, Halliday D. Effects of fish oil supplementation on apolipoprotein B100 production and lipoprotein metabolism in normolipidaemic males. European Journal of Clinical Nutrition. 1998;52:104-109. [pmid: 9505154].
Borkman M, Storlien L H, Pan D A, Jenkins A B, Chisholm D J, Campbell L V. The relation between insulin sensitivity and the fatty-acid composition of skeletal-muscle phospholipids. New England Journal of Medicine. 1993;42:4. [pmid: 8418404].
Bourre JM, Dumont O, Piciotti M, et al: Essentiality of omega-3 fatty acids for brain structure and function, in Simopoulos AP, Kifer RR, Martin RE, Barlow SM (eds): Health effects of omega-3 polyunsaturated fatty acids in seafoods. Basel, Karger, World Rev Nutr Diet; 1991:103–117.
Broadhurst C L. Balanced intakes of natural triglycerides for optimum nutrition. an evolutionary and phytochemical perspective. Medical Hypotheses. 1997;49:247-261. [pmid: 9293470].
Brooks Angela Todd: The influence of ground flaxseed or flaxseed oil on indicators for diabetes in adults. Masters Abstracts International 40–05: 1222-
Brzezinski A, Adlercreutz. Short term effects of phytoestrogen-rich diet on postmenopausal women. Menopause. 1997;4:89-94.
Burn J H. Early observations and their importance today. I. Diabetes in childhood, II. Theophylline in myasthenia gravis, III. Properties of cod liver oil. Journal of Pharmacy & Pharmacology. 1978;30:779-782. [pmid: 32243].
Burnett J R, Watts G F. Therapeutic considerations for postprandial dyslipidaemia. Diabetes, Obesity & Metabolism. 2001;3:143-156. [pmid: 11412278].
Campbell J M, Fahey G C, Demichele S J, Garleb K A. Metabolic characteristics of healthy adult males as affected by ingestion of a liquid nutritional formula containing fish oil, oligosaccharides, gum arabic and antioxidant vitamins. Food & Chemical Toxicology. 1997;35:1165-1176. [pmid: 9449222].
Campos F G, Waitzberg D L, Habr Gama A, et al. Impact of parenteral n-3 fatty acids on experimental acute colitis. British Journal of Nutrition. 2002;87:S83-S88. [pmid: 11898774].
Candela M, Cherubini G, Chelli F, Danieli G, Gabrielli A. Fish-oil fatty acid supplementation in mixed cryoglobulinemia: a preliminary report. Clinical & Experimental Rheumatology. 1994;12:509-513. [pmid: 7842531].
Carroll D N, Roth M T. Evidence for the cardioprotective effects of omega-3 fatty acids. Annals of Pharmacotherapy. 2002;36:1950-1956. [pmid: 12452760].
Caughey G E, Mantzioris E, Gibson R A, Cleland L G, James M J. The effect on human tumor necrosis factor alpha and interleukin 1beta production of diets enriched in n-3 fatty acids from vegetable oil or fish oil. American Journal of Clinical Nutrition. 1996;63:116-122. [pmid: 8604658].
Chan DC, Watts GF, Barrett PH, Beilin LJ, Mori TA: Effect of atorvastatin and fish oil on plasma high-sensitivity C-reactive protein concentrations in individuals with visceral obesity. Clinical Chemistry 2002;48:12029003
Clarke S D. Polyunsaturated fatty acid regulation of gene transcription: a molecular mechanism to improve the metabolic syndrome. Journal of Nutrition. 2001;131:1129-1132. [pmid: 11285313].
Clarke S D, Baillie R, Jump D B, Nakamura M T. Fatty acid regulation of gene expression. Its role in fuel partitioning and insulin resistance. Annals of the New York Academy of Sciences. 1997;827:178-187. [pmid: 9329753].
Cleland L, James M, Neumann M, D'Angelo M, Gibson R. Linoleate inhibits EPA incorporation from dietary fish-oil supplements in human subjects. Am J Clin Nutr. 1992;55:395-9. [pmid: 1310374].
Craig WJ: Phytochemicals: guardians of our health. Journal of the American Dietetic Association 1997;97:Suppl-204
Dagnelie P C, Rietveld T, Swart G R, Stijnen T, van den Berg J W. Effect of dietary fish oil on blood levels of free fatty acids, ketone bodies and triacylglycerol in humans. Lipids. 1994;29:41-45. [pmid: 8139394].
Dam R M, van Willett W C, Rimm E B, Stampfer M J, Hu F B, van Dam R M. Dietary fat and meat intake in relation to risk of type 2 diabetes in men. Diabetes Care. 2002;25:417-424. [pmid: 11874924].
Das U N. GLUT-4, tumor necrosis factor, essential fatty acids and daf-genes and their role in insulin resistance and non-insulin dependent diabetes mellitus. Prostaglandins Leukotrienes & Essential Fatty Acids. 1999;60:13-20. [pmid: 10319913].
Davey G. Randomised controlled trial of a 12-week exercise intervention and omega-3 fatty acids in improving insulin sensitivity among South Asians and Europeans. Clinical Science. 1997;93:25P.
de Lorenzo A, Petroni M L, Luca P P, de Andreoli A, et al. Use of quality control indices in moderately hypocaloric Mediterranean diet for treatment of obesity. Diabetes, Nutrition and Metabolism. 2001;14:181-188. [pmid: 11716286].
Delarue J, Couet C, Cohen R, Brechot J F, Antoine J M, Lamisse F. Effects of fish oil on metabolic responses to oral fructose and glucose loads in healthy humans. American Journal of Physiology - Endocrinology & Metabolism. 1996;270:E353-E362. [pmid: 8779959].
DeMarco D, Santoli D, Zurier R. Effects of fatty acids on proliferation and activation of human synovial compartment lymphocytes. Journal of Leukocyte Biology. 1994;56:612-615. [pmid: 7964169].
Denke M A. Dietary prescriptions to control dyslipidemias. Circulation. 2002;105:132-135. [pmid: 11790687].
DiGiacomo R, Kremer J, Shah D. Fish-oil dietary supplementation in patients with Raynauds phenomenom: A double-blind, controlled, prospective study. Am J Med. 1989;86:158-164. [pmid: 2536517].
Dolecek TA, Grandits G: Dietary polyunsaturated fatty acids and mortality in the Multiple Risk Factor Intervention Trial (MRFIT) , in Simopoulos AP, Kifer RR, Martin RE, Barlow SM (eds): Health effects of omega-3 polyunsaturated fatty acids in seafoods. Basel, Karger, World Rev Nutr Diet; 1991:205–216.
Dubois C, Cara L, Armand M, et al. Effects of pea and soybean fibre on postprandial lipaemia and lipoproteins in healthy adults. European Journal of Clinical Nutrition. 1993;47:508-520. [pmid: 8404786].
Durrington P N, Bhatnagar D, Mackness M I, et al. An omega-3 polyunsaturated fatty acid concentrate administered for one year decreased triglycerides in simvastatin treated patients with coronary heart disease and persisting hypertriglyceridaemia. Heart (British Cardiac Society). 2001;85:544-548. [pmcid: 203028]. [pmid: 15340886].
Ekblond A, Mellemkjaer L, Tjonneland A, et al. A cross-sectional study of dietary habits and urinary glucose excretion - a predictor of non-insulin-dependent diabetes mellitus. European Journal of Clinical Nutrition. 2000;54:434-439. [pmid: 10822293].
Emeis J J, van Houwelingen A C, van den Hoogen C M, Hornstra G. A moderate fish intake increases plasminogen activator inhibitor type-1 in human volunteers. Blood. 1989;74:233-237. [pmid: 2473797].
Endres S, Ghorbani R, Kelley V, et al. The effect of dietary supplementation with n-3 polyunsaturated fatty acids on the synthesis of interleukin-1 and tumor necrosis factor by mononuclear cells. N Engl J Med. 1989;320:265-71. [pmid: 2783477].
Fisher W R. Hypertriglyceridemia in diabetes. An approach to management. Journal of the Florida Medical Association. 1991;78:747-750. [pmid: 1765754].
Franceschini G, Paoletti R. Pharmacological management of hypertriglyceridemic patients. Cardiovascular Risk Factors. 1992;2:343-347.
Friedberg C E, Janssen M J, Heine R J, Grobbee D E. Fish oil and glycemic control in diabetes. A meta-analysis. Diabetes Care. 1998;21:494-500. [pmid: 9571330].
Ginsberg H N, Illingworth D R. Postprandial dyslipidemia. an atherogenic disorder common in patients with diabetes mellitus. American Journal of Cardiology. 2001;88:9H-15H. [pmid: 11576520].
Gletsu N A, Clandinin M T. Impact of dietary fatty acid composition on insulin action at the nucleus. Annals of the New York Academy of Sciences. 1997;827:188-199. [pmid: 9329754].
Gohlke H. Diet and body weight. Zeitschrift fur Kardiologie. 2002;91:12-24. [pmid: 12436761].
Goulet O, de Potter S, Antebi H, et al. Long-term efficacy and safety of a new olive oil-based intravenous fat emulsion in pediatric patients. a double-blind randomized study. American Journal of Clinical Nutrition. 1999;70:338-345. [pmid: 10479195].
Grimb le R, Tappia P. Modulation of pro-inflammatory cytokine biology by unsaturated fatty acids. Zeitschrift fur Ernahrungswissenschaft. 1998;37:57-65. [pmid: 9558730].
Grundt H, Nilsen D W, Hetland O, et al. Improvement of serum lipids and blood pressure during intervention with n-3 fatty acids was not associated with changes in insulin levels in subjects with combined hyperlipidaemia. Journal of Internal Medicine. 1995;237:249-259. [pmid: 7891046].
Guarner F, Vilaseca J, Malagelada J R. Dietary manipulation in experimental inflammatory bowel disease. Agents & Actions. 1992;35:C10-C14. [pmid: 1442325].
Gustafsson I-B, Ohrvall M, Ekstrand B, Vessby B. Moderate amounts of n-3 fatty acid enriched seafood products are effective in lowering serum triglycerides and blood pressure in healthy subjects. Journal of Human Nutrition & Dietetics. 1996;9:135-145.
Haglund O, Wallin R, Wretling S, Hultberg B, Saldeen T. Effects of fish oil alone and combined with long chain (n-6) fatty acids on some coronary risk factors in male subjects. Journal of Nutritional Biochemistry. 1998;9:629-635.
Hall A V, Parbtani A, Clark W F, et al. Abrogation of MRL/lpr lupus nephritis by dietary flaxseed. American Journal of Kidney Diseases. 1993;22:326-332. [pmid: 8352261].
Harding W R, Russell C E, Davidson F, Prior IA M. Dietary surveys from the Tokelau Island Migrant Study. Ecology of Food and Nutrition. 1986;19:83-97.
Healy D A, Wallace F A, Miles E A, Calder P C, Newsholme P. Effect of low-to-moderate amounts of dietary fish oil on neutrophil lipid composition and function. Lipids. 2000;35:763-768. [pmid: 10941877].
Henderson WR: Omega-3 supplementation in CF. 6th North American Cystic Fibrosis Conference 1992;-
Horrobin D. Essential fatty acid and prostaglandin metabolism in Sjogren's syndrome, systemic sclerosis and rheumatoid arthritis. Scandinavian Journal of Rheumatology Supplement. 1986;61:242-245. [pmid: 3296151].
Hughes D, Pinder A. n-3 Polyunsaturated fatty acids inhibit the antigen-presenting function of human monocytes. American Journal of Clinical Nutrition. 2000;71:357S-360S. [pmid: 10617997].
Hughes Da P A. Influence of n-3 polyunsaturated fatty acids (PUFA) on the antigen-presenting function of human monocytes. Biochemical.Society Transactions. 1966;24:389S. [pmid: 8878933].
Jabbar M A, Zuhri-Yafi M I, Larrea J. Insulin therapy for a non-diabetic patient with severe hypertriglyceridemia. Journal of the American College of Nutrition. 1998;17:458-461. [pmid: 9791843].
Joannic J L, Auboiron S, Raison J, Basdevant A, Bornet F, Guy-Grand B. How the degree of unsaturation of dietary fatty acids influences the glucose and insulin responses to different carbohydrates in mixed meals. American Journal of Clinical Nutrition. 1997;65:1427-1433. [pmid: 9129472].
Jula A, Marniemi J, Huupponen R, Virtanen A, Rastas M, Ronnemaa T. Effects of diet and simvastatin on serum lipids, insulin, and antioxidants in hypercholesterolemic men. a randomized controlled trial. JAMA. 2002;287:598-605. [pmid: 11829698].
Jump DB. The biochemistry of n-3 polyunsaturated fatty acids. Journal of Biological Chemistry 2002;78.11748246
Jump D B, Clarke S D, Thelen A, Liimatta M, Ren B, Badin M V. Dietary fat, genes, and human health. Advances in Experimental Medicine & Biology. 1997;422:167-176. [pmid: 9361824].
Kelley D S, Nelson G J, Branch L B, Taylor P C, Rivera Y M, Schmidt P C. Salmon diet and human immune status. European Journal of Clinical Nutrition. 1992;46:397-404. [pmid: 1639047].
Kelley V E. Dietary effects on the progression of autoimmune glomerulonephritis. Clinics in Immunology & Allergy. 1986;6:367-381.
Knapp H, Fitzgerald G. The antihypertensive effect of fish oil: A controlled lstudy of polyunsaturated fatty acid supplementation in essential hypertension. N Engl J Med. 1989;320:1037. [pmid: 2648152].
Koletzko B. Relevance of essential fatty acids in medicine and nutrition. Aktuelle Endokrinologie und Stoffwechsel. 1986;7:18-27.
Kothny W, Angerer P, Stork S, Von Schacky C. Short term effects of omega-3 fatty acids on the radial artery of patients with coronary artery disease. Atherosclerosis. 1998;140:181-186. [pmid: 9733230].
Krauss RM, Eckel RH, Howard B, et al. Revision 2000: a statement for healthcare professionals from the nutrition committee of the American Heart Association. Journal of Nutrition 2001;205.11208950
Kriketos A D, Robertson R M, Sharp T A, et al. Role of weight loss and polyunsaturated fatty acids in improving metabolic fitness in moderately obese, moderately hypertensive subjects. Journal of Hypertension. 2001;19:1745-1754. [pmid: 11593093].
Kris-Etherton P M, Harris W S, Appel L J. Fish consumption, fish oil, omega-3 fatty acids, and cardiovascular disease. Circulation. 2002;106:2747-2757. [pmid: 12438303].
Lahoz C, Alonso R, Porres A, Mata P: Diets enriched in monounsaturated fatty acids and polyunsaturated omega 3 fatty acids decrease blood pressure without modifying plasma insulin concentration in healthy subjects. Medicina Clinica Barcelona 1999;40.
Lardinois C K. The role of omega 3 fatty acids on insulin secretion and insulin sensitivity. Medical Hypotheses. 1987;24:243-248. [pmid: 3320694].
Lardinois C K, Starich G H, Mazzaferri E L. The postprandial response of gastric inhibitory polypeptide to various dietary fats in man. Journal of the American College of Nutrition. 1988;7:241-247. [pmid: 3392357].
Leaf A, Weber P C. Cardiovascular effects of n-3 fatty acids. N Engl J Med. 1988;318:549-57. [pmid: 3277056].
Leiba A, Amital H, Gershwin M, Shoenfeld Y. Diet and lupus. Lupus. 2001;10:246-248. [pmid: 11315362].
Leigh-Firbank E C, Minihane A M, Leake D S, et al. Eicosapentaenoic acid and docosahexaenoic acid from fish oils. Differential associations with lipid responses. British Journal of Nutrition. 2002;87:435-445. [pmid: 12010583].
Louheranta A M, Turpeinen A K, Schwab U S, Vidgren H M, Parviainen M T, Uusitupa M I J. A high-stearic acid diet does not impair glucose tolerance and insulin sensitivity in healthy women. Metabolism, Clinical and Experimental. 1998;44 ref.:5:529-553444.
Lovegrove J A, Brooks C N, Murphy M C, Gould B J, Williams C M. Use of manufactured foods enriched with fish oils as a means of increasing long-chain n-3 polyunsaturated fatty acid intake.[comment]. British Journal of Nutrition. 1997;78:223-236. [pmid: 9301413].
Mackness M I, Bhatnagar D, Durrington P N, et al. Effects of a new fish oil concentrate on plasma lipids and lipoproteins in patients with hypertriglyceridaemia. European Journal of Clinical Nutrition. 1994;48:859-865. [pmid: 7889894].
Mann JI, Asp NG, Frayn K, Vessby B. Can dietary intervention produce long-term reduction in insulin resistance? Diet and the metabolic syndrome 25.
Mantzioris E, Cleland L, Gibson R, Neumann M, Demasi M, James M J. Biochemical effects of a diet containing foods enriched with n-3 fatty acids. American Journal of Clinical Nutrition. 2000;72:42-48. [pmid: 10871559].
Margolis S, Dobs AS. Nutritional management of plasma lipid disorders. Journal of the American College of Nutrition 1989;8:Suppl–45S
Marotta F, Chui D H, Safran P, Rezakovic I, Zhong G G, Ideo G. Shark fin enriched diet prevents mucosal lipid abnormalities in experimental acute colitis. Digestion. 1995;56:46-51. [pmid: 7895932].
Matalas AL, Franti CE, Grivetti LE. Comparative study of diet and disease prevalence in Greek Chians part I rural and urban residents of chios. Ecology of Food and Nutrition 1999;
Matalas A L, Franti C E, Grivetti L E. Comparative study of diets and disease prevalence in Greek Chians part II Chian immigrants to Athens and to the United States. Ecology of Food and Nutrition. 1999;38:381-414.
Maurin A C, Chavassieux P M, Vericel E, Meunier P J. Role of polyunsaturated fatty acids in the inhibitory effect of human adipocytes on osteoblastic proliferation. Bone. 2002;31:260-266. [pmid: 12110443].
Meydani S N, Endres S, Woods M M, et al. Effect of oral n-3 fatty acid supplementation on the immune response of young and older women. Advances in Prostaglandin, Thromboxane, & Leukotriene Research. 1991;21A:245-248. [pmid: 1825548].
Meydani S, Lichtenstein A, Cornwall S, et al. Immunologic effects of national cholesterol education panel step-2 diets with and without fish-derived N-3 fatty acid enrichment. J Clin Invest. 1993;92:105-13. [pmcid: 293543]. [pmid: 8325975].
Mori T A, Bao D Q, Burke V, Puddey I B, Watts G F, Beilin L J. Dietary fish as a major component of a weight-loss diet: effect on serum lipids, glucose, and insulin metabolism in overweight hypertensive subjects. American Journal of Clinical Nutrition. 1999;70:817-825. [pmid: 10539741].
Mori T A, Burke V, Puddey I B, et al. Purified eicosapentaenoic and docosahexaenoic acids have differential effects on serum lipids and lipoproteins, LDL particle size, glucose, and insulin in mildly hyperlipidemic men. American Journal of Clinical Nutrition. 2000;71:1085-1094. [pmid: 10799369].
Mori T. The effect of fish oil on plasma lipids, platelet, and neutrophil function in patients with vascular disease. Australian & New Zealand Journal of Medicine. 1991;21:516. [pmid: 1825545].
Morris M C, Manson J E, Rosner B, Ruing J E, Willett W C, Hennekens C H. Fish consumption and cardiovascular disease in the physicians' health study. A prospective study. American Journal of Epidemiology. 1995;142:166-175. [pmid: 7598116].
Mueller B A, Talbert R L. Biological mechanisms and cardiovascular effects of omega-3 fatty acids. Clinical Pharmacy. 1988;7:795-807. [pmid: 3058376].
Murkies A, Lombard C, Strauss B, Wilcox G, Burger H, Morton M. Dietary flour supplementation decreases post-menopausal hot flushes. effect of soy and wheat. Maturitas. 1995;21:189-95. [pmid: 7616867].
Naughton J M, O'Dea K, Sinclair A J. Animal foods in traditional Australian aboriginal diets: polyunsaturated and low in fat. Lipids. 1986;21:684-690. [pmid: 3796233].
Niculescu D, Tomescu E, Ionescu C, et al. Ultrastructural changes in cartilage after intra-articular administration of osmium tetroxide and the sodium salts of fish oil fatty acids. Scandinavian Journal of Rheumatology. 1976;5:133-140. [pmid: 981989].
Nydahl M, Gustafsson IB, Ohrvall M, Vessby B. Similar effects of rapeseed oil (canola oil) and olive oil in a lipid-lowering diet for patients with hyperlipoproteinemia. Journal of the American College of Nutrition 1995;41.
Okumura T, Fujioka Y, Morimoto S, et al. Eicosapentaenoic acid improves endothelial function in hypertriglyceridemic subjects despite increased lipid oxidizability. American Journal of the Medical Sciences. 2002;324:247-253. [pmid: 12449445].
Parke DV. The role of nutrition in the prevention and treatment of degenerative disease. Saudi Medical Journal 1994;48 ref.:
Pedersen A, Marckmann P, Sandstrom B. Postprandial lipoprotein, glucose and insulin responses after two consecutive meals containing rapeseed oil, sunflower oil or palm oil with or without glucose at the first meal. British Journal of Nutrition. 1999;82:97-104. [pmid: 10743481].
Pestka JJ, Zhou HR, Jia QS, Timmer AM. Dietary fish oil suppresses experimental immunoglobulin A nephropathy in mice. Journal of Nutrition 2002;
Pieke B, von Eckardstein A, Gulbahce E, et al. Treatment of hypertriglyceridemia by two diets rich either in unsaturated fatty acids or in carbohydrates. effects on lipoprotein subclasses, lipolytic enzymes, lipid transfer proteins, insulin and leptin. International Journal of Obesity & Related Metabolic Disorders: Journal of the International Association for the Study of Obesity. 2000;24:1286-1296. [pmid: 11093290].
Pschierer V, Richter W O, Schwandt P. Primary chylomicronemia in patients with severe familial hypertriglyceridemia responds to long-term treatment with (n-3) fatty acids. Journal of Nutrition. 1995;125:1490-1494. [pmid: 7782902].
Radack K, Deck C, Huster G. Dietary supplementation with low-dose fish oils lowers fibrinogen levels. a randomized, double-blind controlled study. Ann Intern Med. 1989;9:757-758. [pmid: 2802434].
Raptis S, Dollinger H C, von Berger L, et al. Effect of lipids on insulin, growth hormone and exocrine pancreatic secretion in man. European Journal of Clinical Investigation. 1975;5:521-526. [pmid: 1201769].
Richter W O, Jacob B G, Ritter M M, Schwandt P. Treatment of primary chylomicronemia due to familial hypertriglyceridemia by omega-3 fatty acids. Metabolism. Clinical & Experimental. 1992;41:1100-1105. [pmid: 1406295].
Robertson M D, Jackson K G, Fielding B A, Williams C M, Frayn K N. Acute effects of meal fatty acid composition on insulin sensitivity in healthy post-menopausal women. British Journal of Nutrition. 2002;88:635-640. [pmid: 12493085].
Robinson DR, Kremer JM: Rheumatoid arthritis and inflammatory mediators, in Simopoulos AP, Kifer RR, Martin RE, Barlow SM (eds): Health effects of omega-3 polyunsaturated fatty acids in seafoods. Basel, Karger, World Rev Nutr Diet; 1991:44–47.
Rossetti R, Seiler C, DeLuca P, Laposata M, Zurier R. Oral administration of unsaturated fatty acids: Effects on human peripheral blood T lymphocyte proliferation. Journal of Leukocyte Biology. 1997;62:438-443. [pmid: 9335312].
Saso L, Valentini G, Casini M, et al. Inhibition of protein denaturation by fatty acids, bile salts and other natural substances: A new hypothesis for the mechanism of action of fish oil in rheumatic diseases. Japanese Journal of Pharmacology. 1999;79:89-99. [pmid: 10082322].
Sawazaki S, Hamazaki T, Yazawa K, Kobayashi M. The effect of docosahexaenoic acid on plasma catecholamine concentrations and glucose tolerance during long-lasting psychological stress: a double-blind placebo-controlled study. Journal of Nutritional Science and Vitaminology. 1999;45:655-665. [pmid: 10683816].
Schimke E, Honigmann G, Hildebrandt R. Effect of linolenic acid-rich diet on lipoproteins in diabetic subjects. Deutsche Gesundheitswesen. 1984;39:223-225.
Schwab U S, Niskanen L K, Maliranta H M, Savolainen M J, Kesaniemi Y A, Uusitupa M I. Lauric and palmitic acid-enriched diets have minimal impact on serum lipid and lipoprotein concentrations and glucose metabolism in healthy young women. Journal of Nutrition. 1995;125:466-473. [pmid: 7876922].
Sebokova E, Klimes I, Hermann M, et al. Modulation of the hypolipidemic effect of fish oil by inhibition of adipose tissue lipolysis with Acipimox, a nicotinic acid analog. Dietary lipids and insulin action Second International Smolenice Insulin Symposium 20:183–191.
Sherertz E F. Improved acanthosis nigricans with lipodystrophic diabetes during dietary fish oil supplementation. Archives of Dermatology. 1988;124:1094-1096. [pmid: 3389852].
Silva J M, Souza I, Silva R, Tavares P, Teixeira F, Silva P S. The triglyceride lowering effect of fish oils is affected by fish consumption. International Journal of Cardiology. 1996;57:75-80. [pmid: 8960947].
Simopoulos AP. Nutrients in the control of metabolic diseases. World Review of Nutrition and Dietetics 1992;
Simopoulos AP, Johnston PK, Sabate J. Essential fatty acids in health and chronic disease. Third International Congress on Vegetarian Nutrition 98:
Sinclair H M. Essential fatty acids in perspective. Human Nutrition - Clinical Nutrition. 1984;38:245-260. [pmid: 6469703].
Singer P, Wirth M, Berger I, et al. Influence on serum lipids, lipoproteins and blood pressure of mackerel and herring diet in patients with type IV and V hyperlipoproteinemia. Atherosclerosis. 1985;56:111-118. [pmid: 2992534].
Soucy J, LeBlanc J. The effects of a beef and fish meal on plasma amino acids, insulin and glucagon levels. Nutrition Research 1999;22 ref.:
Sperling R, Benincaso A, Knoell C, Larkin J, Austen K, Robinson D. Dietary omega-3 polyunsaturated fatty acids inhibit phosphoinositide formation and chemotaxis in neutrophils. J Clin Invest. 1993;91:651-60. [pmcid: 288002]. [pmid: 8381824].
Stammers T, Sibbald B, Freeling P. Fish oil in osteoarthritis. Lancet. 1989;121:503. [pmid: 2570209].
Storlien L H, Kriketos A D, Calvert G D, Baur L A, Jenkins A B. Fatty acids, triglycerides and syndromes of insulin resistance. Prostaglandins Leukotrienes & Essential Fatty Acids. 1997;57:379-385. [pmid: 9430382].
Storlien L H, Kriketos A D, Jenkins A B, et al. Does dietary fat influence insulin action?. Annals of the New York Academy of Sciences. 1997;827:287-301. [pmid: 9329762].
Storlien LH, Pan DA, Kriketos AD, et al. Skeletal muscle membrane lipids and insulin resistance. Lipids 1996;31.
Tchorzewski H, Banasik M, Glowacka E, Lewkowicz P. Modification of innate immunity in humans by active components of shark liver oil. Polski Merkuriusz Lekarski. 2002;13:329-332. [pmid: 12557443].
Tezabwala B U, Bennett M, Grundy S M. Immunotoxicity of polyunsaturated fatty acids in serum-free medium. Immunopharmacology & Immunotoxicology. 1995;17:365-383. [pmid: 7650296].
Toft I, Bonaa K H, Ingebretsen O C, ordoy A, Jenssen T. Effects of n-3 polyunsaturated fatty acids on glucose homeostasis and blood pressure in essential hypertension. A randomized, controlled trial.[comment]. Annals of Internal Medicine. 1995;123:911-918. [pmid: 7486485].
Urakaze M, Hamazaki T, Yano S, Kashiwabara H, Oomori K, Yokoyama T. Effect of fish oil concentrate on risk factors of cardiovascular complications in renal transplantation. Transplantation Proceedings 1989;21.
Vialettes B. The CHO in fat ratio and glucose tolerance. Cahiers de Nutrition et de Dietetique. 2001;36:327-330.
Wardle E N. Eicosanoids and renal allograft rejection. Nephron. 1995;70:151-154. [pmid: 7566297].
Weisburger JH. Dietary fat and risk of chronic disease. mechanistic insights from experimental studies. Journal of the American Dietetic Association 1997;97.
Williams C M, Moore F, Morgan L, Wright J. Effects of n-3 fatty acids on postprandial triacylglycerol and hormone concentrations in normal subjects. British Journal of Nutrition. 1992;68:655-666. [pmid: 1493133].
Xu N, Zhang G Z, Chen S H. The effect of eicosapentaenoic acid enriched marine oil on the platelet function in hypercoagulable state. Chung-Hua Nei Ko Tsa Chih Chinese Journal of Internal Medicine. 1990;29:406-409.
Yam D, Eliraz A, Berry EM. Diet and disease - the Israeli paradox. possible dangers of a high omega-6 polyunsaturated fatty acid diet. Israel Journal of Medical Sciences 1996;135.8960090
Yaqoob P, Pala H, Cortina-Borja M, Newsholme E, Calder P. Encapsulated fish oil enriched in alpha-tocopherol alters plasma phospholipid and mononuclear cell fatty acid compositions but not mononuclear cell functions. Eur J Clin Invest. 2000;30:260-74. [pmid: 10692004].
Zak A, Hrabak P, Zeman M, Svarcova H, Vrana A, Mares P. Effect of fish oils on plasma lipids, glucose tolerance and insulin secretion in persons with endogenous hypertriglyceridemia. Casopis Lekaru Ceskych. 1988;127:881-884. [pmid: 3048693].
Zak A, Hrabak P, Zeman M, Svarcova H, Vrana A, Mares P. Effect of fish oils on plasma lipids, glucose tolerance and insulin secretion in persons with endogenous hypertriglyceridemia. Casopis Lekaru Ceskych. 1988;127:881-884. [pmid: 3048693].
Zak A, Zeman M, Tvrzicka E, Pisarikova A, Sindelkova E, Vrana A. Glucose tolerance, insulin secretion, plasma lipid fatty acids, and the hypolipidemic effects of fish oil. Annals of the New York Academy of Sciences. 1993;683:378-379. [pmid: 8352471].
Zampelas A, Murphy M, Morgan L M, Williams C M. Postprandial lipoprotein lipase, insulin and gastric inhibitory polypeptide responses to test meals of different fatty acid composition: comparison of saturated, n-6 and n-3 polyunsaturated fatty acids. European Journal of Clinical Nutrition. 1994;48:849-858. [pmid: 7889893].
Zurier R, Rossetti R, Seiler C, Laposata M. Human peripheral blood T lymphocyte proliferation after activation of the T cell receptor: Effects of unsaturated fatty acids. Prostaglandins Leukotrienes and Essential Fatty Acids. 1999;60:371-375. [pmid: 10471124].

### Rejected Topic

Anonymous Principles of nutrition for the patient with diabetes mellitus.Diabetes 1967:16:7386054348
Abushufa R, Reed P, Weinkove C, Wales S, Shaffer J. Essential fatty acid status in patients on long-term home parenteral nutrition. Journal of Parenteral & Enteral Nutrition. 1995;19:286-290. [pmid: 8523627].
Adachi J D, Bensen W G, Bell M J, et al. Salmon calcitonin nasal spray in the prevention of corticosteroid-induced osteoporosis. British Journal of Rheumatology. 1997;36:255-259. [pmid: 9133941].
Agurs-Collins T D, Kumanyika S K, Ten Have T R, Adams-Campbell L L. A randomized controlled trial of weight reduction and exercise for diabetes management in older African-American subjects. Diabetes Care. 1997;20:1503-1511. [pmid: 9314625].
Anderson E J, Richardson M, Castle G, et al. Nutrition interventions for intensive therapy in the Diabetes Control and Complications Trial. The DCCT Research Group. Journal of the American Dietetic Association. 1993;93:768-772. [pmid: 8320402].
Anderssen S A, Hjermann I, Urdal P, Torjesen P A, Holme I. Improved carbohydrate metabolism after physical training and dietary intervention in individuals with the atherothrombogenic syndrome'. Oslo Diet and Exercise Study (ODES). A randomized trial. Journal of Internal Medicine. 1996;240:203-209. [pmid: 8918511].
Andersson A, Sjodin A, Olsson R, Vessby B. Effects of physical exercise on phospholipid fatty acid composition skeletal muscle. American Journal of Physiology - Endocrinology & Metabolism. 1998;274:E432-E438.
Arai Y, Uehara M, Kimira M, Watanabe S. Effects of soybean isoflavones on bone mineral density and bone metabolism in women: correlation among isoflavone concentrations in biological fluid, sex-hormone binding globulin and bone biomarkers. Soy Protein Research. 2001;26:135-14126.
Arai Y, Uehara M, Oshima K, Takada N, Kimira M, Watanabe S. Effects of soybean isoflavones on bone mineral density and bone metabolism in human. Soy.Protein.Research, Japan. 2000;28 ref:79-86.
Arisaka M, Arisaka O, Yamashiro Y. Fatty acid and prostaglandin metabolism in children with diabetes mellitus. II. The effect of evening primrose oil supplementation on serum fatty acid and plasma prostaglandin levels. Prostaglandins Leukotrienes & Essential Fatty Acids. 1991;43:197-201. [pmid: 1871184].
Arnaiz-Villena A, Vicario J L, Serrano-Rios M. Glomerular basement membrane antibodies and HLA-DR2 in Spanish rapeseed oil disease. New England Journal of Medicine. 1982;307:1404-1405. [pmid: 6957715].
Astrup A, Ryan L, Grunwald G K, et al. The role of dietary fat in body fatness: evidence from a preliminary meta-analysis of ad libitum low-fat dietary intervention studies. British Journal of Nutrition. 2000;83:S25-S32. [pmid: 10889789].
Austin H A, Boumpas D T. Treatment of lupus nephritis. Seminars in Nephrology. 1996;16:527-535. [pmid: 9125797].
Baart de la Faille H. Lupus therapy. Clinical Investigator. 1994;72:749-753. [pmid: 7865977].
Bang H O, Dyerberg J. Plasma lipids and lipoproteins in Greenlandic west coast Eskimos. Acta Medica Scandinavica. 1972;192:85-94. [pmid: 5052396].
Bantle J P. Current recommendations regarding the dietary treatment of diabetes mellitus. Endocrinologist. 1994;4:189-195.
Bassi A, Avogaro A, Crepaldi C, et al. Short-term diabetic ketosis alters n-6 polyunsaturated fatty acid content in plasma phospholipids. Journal of Clinical Endocrinology & Metabolism. 1996;81:1650-1653. [pmid: 8636382].
Baur L A, O'Connor J, Pan D A, Kriketos A D, Storlien L H. The fatty acid composition of skeletal muscle membrane phospholipid. its relationship with the type of feeding and plasma glucose levels in young children. Metabolism: Clinical & Experimental. 1998;47:106-112. [pmid: 9440487].
Belch J, Hill A. Evening primrose oil and borage oil in rheumatologic conditions. American Journal of Clinical Nutrition. 2000;71:352S-356S. [pmid: 10617996].
Belluzzi A, Brignola C, Campieri M, et al. Short report: zinc sulphate supplementation corrects abnormal erythrocyte membrane long-chain fatty acid composition in patients with Crohn's disease. Alimentary Pharmacology & Therapeutics. 1994;8:127-130. [pmid: 7865646].
Belury M A. Dietary conjugated linoleic acid in health: physiological effects and mechanisms of action. Annual Review of Nutrition. 2002;22:505-531. [pmid: 12055356].
Beri D, Malaviya A N, Shandilya R, Singh R R. Effect of dietary restrictions on disease activity in rheumatoid arthritis. Annals.of.the.Rheumatic.Diseases. 1988;47:69-72. [pmid: 3278696]. [pmcid: 1003447].
Biernat J, Iwanicka Z, Szymczak J, Wasikowa R. Effect of essential unsaturated fatty acids diet on selected indices of lipid metabolism in children with diabetes mellitus. Przeglad Lekarski. 1982;39:353-356. [pmid: 7122918].
Bisschop P H, de Metz. Dietary fat content alters insulin-mediated glucose metabolism in healthy men. American Journal of Clinical Nutrition. 2001;73:554-559. [pmid: 11237931].
Bloomgarden Z T. International Diabetes Federation Meeting 1997: Nephropathy, retinopathy and glycation. Diabetes Care. 1998;21:1560-1566. [pmid: 9727909].
Bohannon NJ V. Lipid metabolism in type II diabetes. Postgraduate Medicine. 1992;92:105-113. [pmid: 1495873].
Bohov P, Gelienova K, Sebokova E, Klimes I. Abnormal serum fatty acid composition in non-insulin-dependent diabetes mellitus. Annals of the New York Academy of Sciences. 1993;683:367-370. [pmid: 8352467].
Bomalaski J S, Goldstein C S, Dailey A T, Douglas S D, Zurier R B. Uptake of fatty acids and their mobilization from phospholipids in cultured monocyte-macrophages from rheumatoid arthritis patients. Clinical Immunology & Immunopathology. 1986;39:198-212. [pmid: 2870830].
Bourn D M, Mann J I, McSkimming B J, Waldron M A, Wishart J D. Impaired glucose tolerance and NIDDM. Does a lifestyle intervention program have an effect? Diabetes Care. 1994;17:1311-1319.
Brand J C, Snow B J, Nabhan G P, Truswell A S. Plasma glucose and insulin responses to traditional Pima Indian meals. American Journal of Clinical Nutrition. 1990;51:416-420. [pmid: 2178389].
Bruce W R, Wolever T M, Giacca A. Mechanisms linking diet and colorectal cancer: the possible role of insulin resistance. Nutrition & Cancer. 2000;37:19-26. [pmid: 10965515].
Brynes A E, Edwards C M, Jadhav A, Ghatei M A, Bloom S R, Frost G S. Diet-induced change in fatty acid composition of plasma triacylglycerols is not associated with change in glucagon-like peptide 1 or insulin sensitivity in people with type 2 diabetes. American Journal of Clinical Nutrition. 2000;72:1111-1118. [pmid: 11063437].
Brzeski M. Evening primrose oil in patients with rheumatoid arthritis and side-effects of non-steroidal anti-inflammatory drugs. British Journal of Rheumatology. 1991;30:370-372. [pmid: 1913008].
Buller H, Chin S, Kirschner B, et al. Inflammatory bowel disease in children and adolescents: Working group report of the first World Congress of Pediatric Gastroenterology, Hepatology, and Nutrition. Journal of Pediatric Gastroenterology & Nutrition. 2002;35:S151-S158. [pmid: 12192184].
Calle Pascual A L. Diet and day-to-day variability in a sample of Spanish adults with IDDM or NIDDM. Hormone and Metabolic Research. 1997;29:450-453. [pmid: 9370114].
Calle-Pascual A L, Manzano P, Camarero E, et al. Diabetes nutrition and complications trial (DNCT): Food intake and targets of diabetes treatment in a sample of Spanish people with diabetes. Diabetes Care. 1997;20:1078-1080. [pmid: 9203440].
Calle-Pascual A L, Saavedra A, Benedi A, et al. Changes in nutritional pattern insulin sensitivity and glucose tolerance during weight loss in obese patients from a Mediterranean area. Hormone & Metabolic Research. 1995;27:499-502. [pmid: 8770626].
Cattran D, Delmore T, Roscoe J, Cole E C C, Charron R, Ritchie S. A randomized controlled trial of prednisone in patients with idiopathic membranous nephropathy. N Engl J Med. 1989;320:210-5. [pmid: 2643046].
Celaya S, Sanz A, Homs C, et al. Experience with an enteral diet with fiber and a high fat content in ICU patients with glucose intolerance. Nutricion Hospitalaria. 1992;7:260-269. [pmid: 1327177].
Chaintreuil J, Monnier L, Colette C, et al. Effects of dietary gamma-linolenate supplementation on serum lipids and platelet function in insulin-dependent diabetic patients. Human Nutrition - Clinical Nutrition. 1984;38:121-130. [pmid: 6323358].
Christiansen E, Schnider S, Palmvig B, Tauber-Lassen E, Pedersen O. Intake of a diet high in trans monounsaturated fatty acids or saturated fatty acids. Effects on postprandial insulinemia and glycemia in obese patients with NIDDM. Diabetes Care. 1997;20:881-887. [pmid: 9135961].
Clarke S D. Nonalcoholic steatosis and steatohepatitis. I. Molecular mechanism for polyunsaturated fatty acid regulation of gene transcription. American Journal of Physiology - Gastrointestinal & Liver Physiology. 2001;281:G865-G869. [pmid: 11557505].
Clarke S D, Jump D B. Dietary polyunsaturated fatty acid regulation of gene transcription. Annual Review of Nutrition. 1994;14:83-98. [pmid: 7946534].
Clifton P M, Nestel P J. Relationship between plasma insulin and erythrocyte fatty acid composition. Prostaglandins Leukotrienes & Essential Fatty Acids. 1998;59:191-194. [pmid: 9844992].
Collier G R, Wolever T M, Wong G S, Josse R G. Prediction of glycemic response to mixed meals in noninsulin-dependent diabetic subjects. American Journal of Clinical Nutrition. 1986;44:349-352. [pmid: 3751955].
Costacou T, Levin S, Mayer Davis EJ: Dietary patterns among members of the Catawba Indian nation. Journal of the American Dietetic Association 2000:22:
Costantino L, Rastelli G, Vianello P, Cignarella G, Barlocco D. Diabetes complications and their potential prevention: Aldose reductase inhibition and other approaches. Medicinal Research Reviews. 1999;19:3-23. [pmid: 9918192].
Cunnane S C, Ainley C C, Keeling P W, Thompson R P, Crawford M A. Diminished phospholipid incorporation of essential fatty acids in peripheral blood leucocytes from patients with Crohn's disease: correlation with zinc depletion. Journal of the American College of Nutrition. 1986;5:451-458. [pmid: 3097102].
D'Amico G, Remuzzi G, Maschio G, et al. Effect of dietary proteins and lipids in patients with membranous nephropathy and nephrotic syndrome. Clinical Nephrology. 1991;35:237-242. [pmid: 1873936].
Dahlquist G G, Blom L G, Persson L A, Sandstrom A I, Wall S G. Dietary factors and the risk of developing insulin dependent diabetes in childhood. BMJ. 1990;300:1302-1306. [pmid: 2369660]. [pmcid: 1663017].
Das U N. Essential fatty acid metabolism in patients with essential hypertension, diabetes mellitus and coronary heart disease. Prostaglandins Leukotrienes & Essential Fatty Acids. 1995;52:387-391. [pmid: 7644560].
Das U N. Metabolic syndrome X is common in South Asians, but why and how?. Nutrition. 2002;18:774-776. [pmid: 12297221].
Das U N, Kumar K V, Prabha P S, Murthy B V, Neela P. Oxy-radicals, lipid peroxides and essential fatty acids in patients with glomerular disorders. Prostaglandins Leukotrienes & Essential Fatty Acids. 1993;49:603-607. [pmid: 8415810].
Das U N, Kumar K V, Ramesh G. Essential fatty acid metabolism in south Indians. Prostaglandins Leukotrienes & Essential Fatty Acids. 1994;50:253-255. [pmid: 7915035].
De Leeuw I H, Van Gaal L, Rillaerts E, Dalemans C. Effects of the relative enrichment of polyunsaturated fatty acids in insulin-dependent diabetic patients. Diabete et Metabolisme. 1986;12:246-249. [pmid: 3803678].
Decsi T, Minda H, Hermann R, et al. Polyunsaturated fatty acids in plasma and erythrocyte membrane lipids of diabetic children. Prostaglandins Leukotrienes & Essential Fatty Acids. 2002;67:203-210. [pmid: 12401433].
Decsi T, Molnar D, Koletzko B. Long-chain polyunsaturated fatty acids in plasma lipids of obese children. Lipids. 1996;37:305-331. [pmid: 11942482].
Desai S, Allen E, Deodhar A. Miller Fisher syndrome in adult onset Still's disease: Case report and review of the literature of other neurological manifestations. Rheumatology. 2002;41:216-222. [pmid: 11886973].
Dimitriadis E, Griffin M, Collins P, Johnson A, Owens D, Tomkin G H. Lipoprotein composition in NIDDM: effects of dietary oleic acid on the composition, oxidisability and function of low and high density lipoproteins. Diabetologia. 1996;39:667-676. [pmid: 8781762].
Dohi K, Kanauchi M. Etiology and therapy of chronic primary glomerulonephritis. Nippon Naika Gakkai Zasshi - Journal of Japanese Society of Internal Medicine. 1998;87:1271-1276. [pmid: 9745275].
Donaghue K C, Pena M M, Chan A K, et al. Beneficial effects of increasing monounsaturated fat intake in adolescents with type 1 diabetes. Diabetes Research & Clinical Practice. 2000;48:193-199. [pmid: 10802158].
Dorfler H, Rauh G, Bassermann R. Lipoatrophic diabetes. Clinical Investigator. 1993;71:264-269. [pmid: 8471812].
Dreval A V, Anykina N V, Tishin D P, et al. Effect of soybean protein isolate on energy substrate oxidation in patients with insulin-dependent diabetes mellitus. Problemy Endokrinologii. 1994;40:21-25. [pmid: 8197084].
Dullaart R P, Beusekamp B J, Meijer S, Hoogenberg K, van Doormaal J J, Sluiter W J. Long-term effects of linoleic-acid-enriched diet on albuminuria and lipid levels in type 1 (insulin-dependent) diabetic patients with elevated urinary albumin excretion. Diabetologia. 1992;35:165-172. [pmid: 1547922].
Dullaart R P, Hoogenberg K, Riemens S C, et al. Cholesteryl ester transfer protein gene polymorphism is a determinant of HDL cholesterol and of the lipoprotein response to a lipid-lowering diet in type 1 diabetes. Diabetes. 1997;46:2082-2087. [pmid: 9392500].
Dutta-Roy A K. Insulin mediated processes in platelets, erythrocytes and monocytes/macrophages: effects of essential fatty acid metabolism. Prostaglandins Leukotrienes & Essential Fatty Acids. 1994;51:385-399. [pmid: 7708803].
Ebbesson S O, Kennish J, Ebbesson L, Go O, Yeh J. Diabetes is related to fatty acid imbalance in Eskimos. International Journal of Circumpolar Health. 1999;58:108-119. [pmid: 10429340].
Edelman S V. Type II diabetes mellitus. Advances in Internal Medicine. 1998;43:449-500. [pmid: 9506190].
El Boustani S, Descomps B, Monnier L, et al. In vivo conversion of dihomogamma linolenic acid into arachidonic acid in man. Progress in Lipid Research. 1986;25:67-71.
Ernest I, Linner E, Svanborg A. Carbohydrate-rich, fat-poor diet in diabetes. American Journal of Medicine. 1965;39:594-600. [pmid: 5319129].
Esteve Comas M, Ramirez M, Fernandez Banare s F, et al. Plasma polyunsaturated fatty acid pattern in active inflammatory bowel disease. Gut. 1992;33:1365-69. [pmid: 1446861]. [pmcid: 1379605].
Esteve M, Navarro E, Klaassen J, et al. Plasma and mucosal fatty acid pattern in colectomized ulcerative colitis patients. Digestive Diseases & Sciences. 1998;43:1071-1078. [pmid: 9590424].
Fasching P, Ratheiser K, Schneeweiss B, Rohac M, Nowotny P, Waldhausl W. No effect of short-term dietary supplementation of saturated and poly- and monounsaturated fatty acids on insulin secretion and sensitivity in healthy men. Annals of Nutrition & Metabolism. 1996;40:116-122. [pmid: 8773736].
Ferro-Luzzi A, James W P, Kafatos A. The high-fat Greek diet: a recipe for all?. European Journal of Clinical Nutrition. 2002;56:796-809. [pmid: 12209368].
Feskens E J, Bowles C H, Kromhout D. Inverse association between fish intake and risk of glucose intolerance in normoglycemic elderly men and women. Diabetes Care. 1991;14:935-941. [pmid: 1797505].
Feskens E JM, Virtanen S M, Rasanen L, et al. Dietary factors determining diabetes and impaired glucose tolerance: A 20- year follow-up of the Finnish and Dutch cohorts of the Seven Countries Study. Diabetes Care. 1995;18:1104-1112. [pmid: 7587845].
Fischbach W. Drug therapy for inflammatory bowel disease. Leber, Magen, Darm. 1992;22:49-55. [pmid: 1350043].
Fisher R L. Newer therapies for inflammatory bowel disease. Chinese Journal of Gastroenterology. 1992;9:230-232.
Florent C H. Inflammatory bowel diseases (IBD): Therapeutic actualities. Acta Endoscopica. 1995;25:571-574.
French M A, Parrott A M, Kielo E S, et al. Polyunsaturated fat in the diet may improve intestinal function in patients with Crohn's disease. Biochimica et Biophysica Acta. 1997;1360:262-270. [pmid: 9197469].
Fujita H, Yamagami T, Ohshima K. Long-term ingestion of a fermented soybean-derived Touchi-extract with alpha-glucosidase inhibitory activity is safe and effective in humans with borderline and mild type-2 diabetes. Journal of Nutrition. 2001;131:2105-2108. [pmid: 11481402].
Garaulet M, Perez-Llamas F, Perez-Ayala M, et al. Site-specific differences in the fatty acid composition of abdominal adipose tissue in an obese population from a Mediterranean area: relation with dietary fatty acids, plasma, lipid profile, serum, insulin and central obesity. American Journal of Clinical Nutrition. 2001;74:585-591. [pmid: 11684525].
Garg A. High-monounsaturated fat diet for diabetic patients. Is it time to change the current dietary recommendations?. Diabetes Care. 1994;17:242-246. [pmid: 8174456].
Garg A. High-monounsaturated-fat diets for patients with diabetes mellitus: a meta-analysis. American Journal of Clinical Nutrition. 1998;67:582S. [pmid: 9497173].
Garg A, Grundy S M. Diabetic dyslipidemia and its therapy. Diabetes Reviews. 1997;5:425-433.
Garg A, Klimes I, Howard BV, Storlien LH, Sebokova E: Dietary monounsaturated fatty acids for patients with diabetes mellitus. Annals New York Academy of Sciences 27:199–206.8352441
Gatti E, Noe D, Pazzucconi F, et al. Differential effect of unsaturated oils and butter on blood glucose and insulin response to carbohydrate in normal volunteers. European Journal of Clinical Nutrition. 1992;46:161-166. [pmid: 1559521].
Geerling B J, Dagnelie P C, Badart-Smook A, Russel M G, Stockbrugger R W, Brummer R J. Diet as a risk factor for the development of ulcerative colitis. American Journal of Gastroenterology. 2000;95:1008-1013. [pmid: 10763951].
Georgopoulos A. Postprandial triglyceride metabolism in diabetes mellitus. Clinical Cardiology. 1999;22:II28-II33. [pmid: 10376194].
Georgopoulos A, Bantle J P, Noutsou M, Hoover H A. A high carbohydrate versus a high monounsaturated fatty acid diet lowers the atherogenic potential of big VLDL particles in patients with type 1 diabetes. Journal of Nutrition. 2000;130:2503-2507. [pmid: 11015481].
Gilbertson H R, Thorburn A W, Brand-Miller J C, Chondros P, Werther G A. Effect of low-glycemic-index dietary advice on dietary quality and food choice in children with type 1 diabetes. American Journal of Clinical Nutrition. 2003;77:83-90. [pmid: 12499327].
Glassock R J. Concluding remarks and summary of the 7th International Symposium on IgA Nephropathy (Singapore 1–2 October 1996). Nephrology. 1997;3:131-135.
Goodfriend T L, Ball D L, Elliott M E, et al. Fatty acids may regulate aldosterone secretion and mediate some of insulin's effects on blood pressure. Prostaglandins Leukotrienes & Essential Fatty Acids. 1993;48:43-50. [pmid: 8424122].
Gorska A, Nawrocki A, Urban M, Florys B. Composition of phospholipid fatty acids in erythrocyte membranes of children with chronic juvenile arthritis: Clinical and biochemical correlations. Medical Science Monitor. 2000;6:30-39. [pmid: 11208280].
Griffin M E, Dimitriadis E, Lenehan K, et al. Non-insulin-dependent diabetes mellitus: dietary monounsaturated fatty acids and low-density lipoprotein composition and function. QJM. 1996;89:211-216. [pmid: 8731565].
Grober U. Orthomolecular medicine: Usefulness of micronutrients in diabetes mellitus. Deutsche Apotheker Zeitung. 2002;142:46-52.
Hallgren B, Lundquist C G, Svanborg A. The fatty acid composition of mitochondrial lipids from musculus pectoralis minor in non-diabetics and diabetics. Acta Medica Scandinavica. 1966;179:447-452. [pmid: 5908681].
Halpern G. Anti-inflammatory effects of a stabilized lipid extract of Perna canaliculus (Lyprinolrho). Allergie et Immunologie. 2000;32:272-278. [pmid: 11094640].
Hansen T M, Lerche A, Kassis V. Treatment of rheumatoid arthritis with prostaglandin E1 precursors cis-linoleic acid and gamma-linolenic acid. Scandinavian Journal of Rheumatology. 1983;12:85-88. [pmid: 6304871].
Harding A H, Sargeant L A, Welch A, et al. Fat consumption and HbA(1c) levels. the EPIC-Norfolk study. Diabetes Care. 2001;24:1911-1916. [pmid: 11679456].
Hauner H. Nutritional therapy in diabetic nephropathy. Aktuelle Ernahrungsmedizin. 2001;5:519-525.
Healey J H, Paget S A, Williams-Russo. A randomized controlled trial of salmon calcitonin to prevent bone loss in corticosteroid-treated temporal arteritis and polymyalgia rheumatica. Calcified.Tissue International. 1996;58:73-80. [pmid: 8998681].
Heine R J, Mulder C, Popp-Snijders C, van der Meer J, van der Veen E A. Linoleic-acid-enriched diet: long-term effects on serum lipoprotein and apolipoprotein concentrations and insulin sensitivity in noninsulin-dependent diabetic patients. American Journal of Clinical Nutrition. 1989;49:448-456. [pmid: 2923077].
Hernell O, Holmgren G, Jagell S F, Johnson S B, Holman R T. Suspected faulty essential fatty acid metabolism in Sjogren-Larsson syndrome. Pediatric.Research. 1982;16:45-49. [pmid: 7070875].
Higashi K, Shige H, Ito T, et al. Effect of a low-fat diet enriched with oleic acid on postprandial lipemia in patients with type 2 diabetes mellitus. Lipids. 2001;36:1-6. [pmid: 11214722].
Hirai K, Nomura M, Nakajima Y, Minamoto K, Abe H. Serum levels of retinol, inorganic phosphate and polyunsaturated fatty acid and their relationship in diabetic patients with early nephropathy. Nutrition Research 1994;
Hirayama T. National burden of disease of urinary organs--an epidemiological consideration. Hinyokika Kiyo - Acta Urologica Japonica. 1987;33:1550-1555. [pmid: 3445843].
Hockaday T D, Hockaday J M, Mann J I, Turner R C. Prospective comparison of modified fat-high-carbohydrate with standard low-carbohydrate dietary advice in the treatment of diabetes. one year follow-up study. British Journal of Nutrition. 1978;39:357-362. [pmid: 629924].
Hornych A, Oravec S, Girault F, Forette B, Horrobin D F. The effect of gamma-linolenic acid on plasma and membrane lipids and renal prostaglandin synthesis in older subjects. Bratislavske Lekarske Listy. 2002;103:101-107. [pmid: 12190041].
Horrobin D. Essential fatty acid metabolism in diseases of connective tissue with special reference to scleroderma and to Sjogren's syndrome. Medical Hypotheses. 1984;14:233-247. [pmid: 6088955].
Horrobin D F. Essential fatty acids in the management of impaired nerve function in diabetes. Diabetes. 1997;46:S90-S93. [pmid: 9285506].
Horrobin D F. Fatty acid metabolism in health and disease. the role of delta-6-desaturase. American Journal of Clinical Nutrition. 1993;57:732S-737S. [pmid: 8386433].
Horrobin D F. Nutritional and medical importance of gamma-linolenic acid. Progress in Lipid Research. 1992;31:163-194. [pmid: 1334266].
Horrobin D F, Campbell A, McEwen C G. Treatment of the Sicca syndrome and Sjogren's syndrome with E.F.A., pyridoxine and vitamin C. Progress in Lipid Research. 1981;20:253-254. [pmid: 7342089].
Horrobin D F, Cunnane S C. Interactions between zinc, essential fatty acids and prostaglandins. relevance to acrodermatitis enteropathica, total parenteral nutrition, the glucagonoma syndrome, diabetes, anorexia nervosa and sickle cell anaemia. Medical Hypotheses. 1980;6:277-296. [pmid: 6253772].
Horrobin D F, Jantti J. Effects of evening primrose oil in rheumatoid arthritis. Annals of the Rheumatic Diseases. 1989;48:965-966. [pmid: 2688567]. [pmcid: 1003927].
Horrobin D F, Manku M S. How do polyunsaturated fatty acids lower plasma cholesterol levels?. Lipids. 1983;18:558-562. [pmid: 6312241].
Houtsmuller A J, Hal-Ferwerda J, Zahn K J, Henkes H E. Favorable influences of linoleic acid on the progression of diabetic micro- and macroangiopathy in adult onset diabetes mellitus. Progress in Lipid Research. 1981;20:377-386. [pmid: 7342100].
Houtsmuller A J, Zahn K J, Henkes H E. Unsaturated fats and progression of diabetic retinopathy. Documenta Ophthalmologica. 1980;48:363-371. [pmid: 6995054].
Howard B V. Dietary fatty acids, insulin resistance, and diabetes. Annals of the New York Academy of Sciences. 1997;827:215-220. [pmid: 9329756].
Jalili T, Wildman R E C, Medeiros D M. Nutraceutical roles of dietary fiber. Journal of Nutraceuticals, Functional & Medical Foods. 2000;2:19-34.
Jang Y, Lee J H, Kim O Y, Park H Y, Lee S Y. Consumption of whole grain and legume powder reduces insulin demand, lipid peroxidation, and plasma homocysteine concentrations in patients with coronary artery disease -- randomized controlled clinical trial. Arteriosclerosis, Thrombosis, and Vascular Biology. 2001;21:2065-2071. [pmid: 11742886].
Jantti J, Nikkari T, Solakivi T, Vapaatalo H, Isomaki H. Evening primrose oil in rheumatoid arthritis. Changes in serum lipids and fatty acids. Annals of the Rheumatic Diseases. 1989;48:124-127. [pmid: 2649022]. [pmcid: 1003697].
Jiang R, Manson J E, Stampfer M J, Liu S, Willett W C, Hu F B. Nut and peanut butter consumption and risk of type 2 diabetes in women. JAMA. 2002;288:2554-2560. [pmid: 12444862].
Joe L A, Hart L L. Evening primrose oil in rheumatoid arthritis. Annals of Pharmacotherapy. 1993;27:1475-1477. [pmid: 8305783].
Jones D B, Carter R D, Haitas B, Mann J I. Low phospholipid arachidonic acid values in diabetic platelets. British Medical Journal Clinical Research Ed. 1983;286:173-175. [pmid: 6401517]. [pmcid: 1546357].
Jones D B, Carter R D, Mann J I. Indirect evidence of impairment of platelet desaturase enzymes in diabetes mellitus. Hormone & Metabolic Research. 1986;18:341-344. [pmid: 3013745].
Jones G, Riley M, Dwyer T. Maternal diet during pregnancy is associated with bone mineral density in children. a longitudinal study. European Journal of Clinical Nutrition. 2000;54:749-756. [pmid: 11083482].
Julius U, Hanefeld M. Management of lipid disorders in diabetes mellitus. Munchener Medizinische Wochenschrift. 1994;136:46-50.
Karamanos B, Thanopoulou A, Angelico F, et al. Nutritional habits in the Mediterranean Basin. The macronutrient composition of diet and its relation with the traditional Mediterranean diet. Multi-centre study of the Mediterranean Group for the Study of Diabetes (MGSD). European Journal of Clinical Nutrition. 2002;56:983-991. [pmid: 12373619].
Kast R. Borage oil reduction of rheumatoid arthritis activity may be mediated by increased cAMP that suppresses tumor necrosis factor-alpha. International.Immunopharmacology. 2001;1:2197-2199. [pmid: 11710548].
Katsilambros N. Mediterranean diet and diabetes mellitus. Cahiers de Nutrition et de Dietetique. 1996;31:209-211.
Kearney M T, Chowienczyk P J, Brett S E, Sutcliffe A, Ritter J M, Shah A M. Acute haemodynamic effects of lipolysis-induced increase of free fatty acids in healthy men. Clinical Science. 2002;102:495-500. [pmid: 11980566].
Keen H, Payan J, Allawi J, et al. Treatment of diabetic neuropathy with gamma-linolenic acid. The gamma-Linolenic Acid Multicenter Trial Group. Diabetes Care. 1993;16:8-15. [pmid: 8380765].
Keller U, Turkalj I, Laager R, Bloesch D, Bilz S. Effects of medium- and long-chain fatty acids on whole body leucine and glucose kinetics in man. Metabolism, Clinical and Experimental 2002;36.
Khoshoo V, Reifen R, Neuman M G, Griffiths A, Pencharz P B. Effect of low- and high-fat, peptide-based diets on body composition and disease activity in adolescents with active Crohn's disease. Journal of Parenteral & Enteral Nutrition. 1996;20:401-405. [pmid: 8950740].
Kimberly R. Treatment. Corticosteroids and anti-inflammatory drugs. Rheumatic Diseases Clinics of North America. 1988;14:203-221. [pmid: 3041489].
Kleijnen J. Evening primrose oil. BMJ 1994:824–825.
Knauf V C, Facciotti D. Genetic engineering of foods to reduce the risk of heart disease and cancer. Advances in Experimental Medicine & Biology. 1995;369:221-228. [pmid: 7598011].
Korelitz B I. Where do we stand on drug treatment for ulcerative colitis?. Annals of Internal Medicine. 1992;116:692-694. [pmid: 1347677].
Kotaniemi A, Piirainen H, Paimela L, et al. Is continuous intranasal salmon calcitonin effective in treating axial bone loss in patients with active rheumatoid arthritis receiving low dose glucocorticoid therapy?. Journal of Rheumatology. 1996;23:1875-1879. [pmid: 8923359].
Kreider R, Ferreira M, Greenwood M, Wilson M, Almada A L. Effects of conjugated linoleic acid supplementation during resistance training on body composition, bone density, strength, and selected hematological markers. Journal of Strength & Conditioning Research. 2002;16:325-334. [pmid: 12173945].
Kuroki F, Iida M, Matsumoto T, Aoyagi K, Kanamoto K, Fujishima M. Serum n3 polyunsaturated fatty acids are depleted in Crohn's disease. Digestive Diseases & Sciences. 1997;42:1137-1141. [pmid: 9201073].
Laaksonen D E, Lakka T A, Lakka H M, et al. Serum fatty acid composition predicts development of impaired fasting glycaemia and diabetes in middle-aged men. Diabetic Medicine. 2002;19:456-464. [pmid: 12060056].
Laitinen J, Uusitupa M, Ahola I, Siitonen O. Metabolic and dietary determinants of serum lipids in obese patients with recently diagnosed non-insulin-dependent diabetes. Annals of Medicine. 1994;26:119-124. [pmid: 8024729].
Laitinen J H, Ahola I E, Sarkkinen E S, Winberg R L, Harmaakorpi-Iivonen P A, Uusitupa M I. Impact of intensified dietary therapy on energy and nutrient intakes and fatty acid composition of serum lipids in patients with recently diagnosed non-insulin-dependent diabetes mellitus. Journal of the American Dietetic Association. 1993;93:276-283. [pmid: 8382712].
Lauritsen K, Laursen L S, Kjeldsen J, Bukhave K, Rask-Madsen J. Inhibition of eicosanoid synthesis and potential therapeutic benefits of ‘dual pathway inhibition’. Pharmacology & Toxicology, Supplement. 1994;75:9-13. [pmid: 7816794].
Lerman-Garber I, Gulias-Herrero A, Palma M E, et al. Response to high carbohydrate and high monounsaturated fat diets in hypertriglyceridemic non-insulin dependent diabetic patients with poor glycemic control. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 1995;8:339-345.
Lerman-Garber I, Ichazo-Cerro S, Zamora-Gonzalez J, Cardoso-Saldana G, Posadas-Romero C. Effect of a high-monounsaturated fat diet enriched with avocado in NIDDM patients. Diabetes Care. 1994;17:311-315. [pmid: 8026287].
Lesnichi A V. Use of unsaturated fatty acids in diabetes mellitus. Problemy Endokrinologii. 1972;18:20-22. [pmid: 4654761].
Lichtenstein A H, Ausman L M, Jalbert S M, et al. Efficacy of a Therapeutic Lifestyle Change/Step 2 diet in moderately hypercholesterolemic middle-aged and elderly female and male subjects. Journal of Lipid Research. 2002;43:264-273. [pmid: 11861668].
Lopez Ledesma R, Frati Munari A C, Hernandez Dominguez B C, et al. Monounsaturated fatty acid (avocado) rich diet for mild hypercholesterolemia. Archives of Medical Research. 1996;27:519-523. [pmid: 8987188].
Louis Eand Belaiche J. The immunopathology and therapeutic perspectives of Chrohn's disease. Medecine et Hygiene. 1991;49:3402-3406.
Lovejoy J C, Champagne C M, Smith S R, et al. Relationship of dietary fat and serum cholesterol ester and phospholipid fatty acids to markers of insulin resistance in men and women with a range of glucose tolerance. Metabolism. Clinical & Experimental. 2001;50:86-92.
Lovejoy J C, Most M M, Lefevre M, Greenway F L, Rood J C. Effect of diets enriched in almonds on insulin action and serum lipids in adults with normal glucose tolerance or type 2 diabetes. American Journal of Clinical Nutrition. 2002;76:1000-1006. [pmid: 12399271].
Lovejoy J C, Smith S R, Champagne C M, et al. Effects of diets enriched in saturated (palmitic), monounsaturated (oleic), or trans (elaidic) fatty acids on insulin sensitivity and substrate oxidation in healthy adults. Diabetes Care. 2002;25:1283-1288. [pmid: 12145222].
Madigan C, Ryan M, Owens D, Collins P, Tomkin G H. Dietary unsaturated fatty acids in type 2 diabetes. higher levels of postprandial lipoprotein on a linoleic acid-rich sunflower oil diet compared with an oleic acid-rich olive oil diet. Diabetes Care. 2000;23:1472-1477. [pmid: 11023139].
Madsen J R, Laursen L S, Lauritsen K. [Chronic inflammatory bowel disease. Nordisk Medicin. 1992;107:254-260. [pmid: 1408722].
Mallick N P. Dietary protein and progression of chronic renal disease. Large randomised controlled trial suggests no benefit from restriction. BMJ British Medical Journal. 1994;309:1101-1102.
Mani U V, Desai S, Iyer U. Studies on the long-term effect of spirulina supplementation on serum lipid profile and glycated proteins in NIDDM patients. Journal of Nutraceuticals, Functional and Medical Foods. 2000;2:25-32.
Marckmann P. Dietary treatment of thrombogenic disorders related to the metabolic syndrome. British Journal of Nutrition. 2000;83:S121-S126. [pmid: 10889802].
Marinides G N. Progression of chronic renal disease and diabetic nephropathy. A review of clinical studies and current therapy. Journal of Medicine. 1993;24:266-288. [pmid: 8258740].
Matsueda K. Therapeutic efficacy of elemental enteral alimentation in Crohn's disease. Journal of Gastroenterology. 2000;35:19. [pmid: 10779210].
Matsui T, Ueki M, Yamada M, Sakurai T, Yao T. Indications and options of nutritional treatment for Crohn's disease. A comparison of elemental and polymeric diets. Journal of Gastroenterology 1995;30.8563903
Mayer-Davis E J, Levin S, Bergman R N, et al. Insulin secretion, obesity, and potential behavioral influences. results from the Insulin Resistance Atherosclerosis Study (IRAS). Diabetes/Metabolism Research Reviews. 2001;17:137-145.
Mayer Davis E J, Monaco J H, Hoen H M, et al. Dietary fat and insulin sensitivity in a triethnic population\the role of obesity. The Insulin Resistance Atherosclerosis Study (IRAS). American Journal of Clinical Nutrition. 1997;65:79-87. [pmid: 8988917].
McAuley K A, Williams S M, Mann J I, et al. Intensive lifestyle changes are necessary to improve insulin sensitivity. a randomized controlled trial. Diabetes Care. 2002;25:445-452. [pmid: 11874928].
McCarty M F. Toward practical prevention of type 2 diabetes. Medical Hypotheses. 2000;54:786-793. [pmid: 10859688].
McCarty M F, Rubin E J. Rationales for micronutrient supplementation in diabetes. Medical Hypotheses. 1984;13:139-151. [pmid: 6325854].
McKendry R. Treatment of Sjogren's syndrome with essential fatty acids, pyridoxine and vitamin C. Prostaglandins Leukotrienes & Medicine 1982:403–408.
Merrin P K, Elkeles R S. Treatment of diabetes. The effect on serum lipids and lipoproteins. Postgraduate Medical Journal. 1991;67:931-937. [pmid: 1758807].
Metcalf PA, Stevens J, Shimakawa T, et al. Comparison of diets of NIDDM and non-diabetic African Americans and whites. the atherosclerosis risk in communities study. Nutrition Research 1998;
Mikhailidis D P, Jeremy J Y, Dandona P. The role of prostaglandins, leukotrienes and essential fatty acids in the pathogenesis of the complications associated with diabetes mellitus. [Review] [19 refs]. Prostaglandins Leukotrienes & Essential Fatty Acids. 1988;33:205-206. [pmid: 3070569].
Milne R M, Mann J I, Chisholm A W, Williams S M. Long-term comparison of three dietary prescriptions in the treatment of NIDDM. Diabetes Care. 1994;17:74-80. [pmid: 8112194].
Mironova M A, Klein R L, Virella G T, Lopes-Virella M F. Anti-modified LDL antibodies, LDL-containing immune complexes, and susceptibility of LDL to in vitro oxidation in patients with type 2 diabetes. Diabetes. 2000;49:1033-1041. [pmid: 10866057].
Miwa H, Yamamoto M, Futata T, Kan K, Asano T. Thin-layer chromatography and high-performance liquid chromatography for the assay of fatty acid compositions of individual phospholipids in platelets from non-insulin-dependent diabetes mellitus patients. effect of eicosapentaenoic acid ethyl ester administration. Journal of Chromatography B. Biomedical Applications. 1996;677:217-223. [pmid: 8704924].
Moncada S, Higgs E A. Arachidonate metabolism in blood cells and the vessel wall. Clinics in Haematology. 1986;15:273-292. [pmid: 3015465].
Murata M, Kaji H, Iida K, Okimura Y, Chihara K. Dual action of eicosapentaenoic acid in hepatoma cells. up-regulation of metabolic action of insulin and inhibition of cell proliferation. Journal of Biological Chemistry 2001;276.11390373
Murphy N J, Schraer C D, Thiele M C, et al. Dietary change and obesity associated with glucose intolerance in Alaska Natives. Journal of the American Dietetic Association. 1995;95:676-682. [pmid: 7759744].
Nakamura H, Faludi G, Spitzer J J. Changes of individual free fatty acids during glucose tolerance test. Diabetes. 1967;16:175-180. [pmid: 6019597].
Nakamura N, Hamazaki T, Jokaji H, Minami S, Kobayashi M. Effect of HMG-CoA reductase inhibitors on plasma polyunsaturated fatty acid concentrations in patients with hyperlipidemia. International Journal of Clinical & Laboratory Research. 1998;28:192-195. [pmid: 9801932].
Nicholson AS, Sklar M, Barnard ND, Gore S, Sullivan R, Browning S. Toward improved management of NIDDM. a randomized, controlled, pilot intervention using a lowfat, vegetarian diet. Preventive Medicine 1999;
Niemann J, Lippert C. Prospective development of the food industry and healthy nutrition. Elelmezesi Ipar 1990;
Nishida T, Miwa H, Shigematsu A, Yamamoto M, Iida M, Fujishima M. Increased arachidonic acid composition of phospholipids in colonic mucosa from patients with active ulcerative colitis. Gut. 1987;28:1002-1007. [pmid: 3117625]. [pmcid: 1433134].
Nobmann E D, Byers T, Lanier A P, Hankin J H, Jackson M Y. The diet of Alaska Native adults 1987-1988. American Journal of Clinical Nutrition. 1992;55:1024-1032. [pmid: 1570796].
Novak E. Maintaining remission of Crohn's disease. CMAJ. 1988;139:14. [pmid: 3383034].
O'Morain C, O'sullivan M. Nutritional support in Crohn's disease. current status and future directions. Journal of Gastroenterology 1995;30.8563867
Odes H S. The pharmacological treatment of inflammatory bowel diseases. Recent concepts and advances. Archives of Gastroenterohepatology. 1993;12:170-173.
Oguogho A, Aghajanian A A, Sinzinger H. Prostaglandin synthesis in human lymphatics from precursor fatty acids. Lymphology. 2000;33:62-66. [pmid: 10897472].
Owen R W, Giacosa A, Hull W E, Haubner R, Spiegelhalder B, Bartsch H. The antioxidant/anticancer potential of phenolic compounds isolated from olive oil. European Journal of Cancer. 2000;36:1235-1247. [pmid: 10882862].
Parfitt V J, Desomeaux K, Bolton C H, Hartog M. Effects of high monounsaturated and polyunsaturated fat diets on plasma lipoproteins and lipid peroxidation in type 2 diabetes mellitus. Diabetic Medicine. 1994;11:85-91. [pmid: 8181259].
Parfitt V J, Hopton M, Taberner J, Bolton C, Hartog M. The effects of high monounsaturated and polyunsaturated fat diets on vascular endothelium and the coagulation system in non-insulin dependent diabetes mellitus--related to changes in lipid peroxidation?. Biochemical Society Transactions. 1993;21:103S. [pmid: 8359361].
Pedrera J D, Lopez M J, Canal M L, et al. Quantitative phalangeal bone ultrasound is normal after long-term gluten-free diet in young coeliac patients. European.Journal.of.Gastroenterology.and.Hepatology. 2001;13:1169-1173. [pmid: 11711772].
Pelikanova T, Kazdova L, Chvojkova S, Base J. Serum phospholipid fatty acid composition and insulin action in type 2 diabetic patients. Metabolism. Clinical & Experimental. 2001;50:1472-1478.
Peppercorn M A. A 66-year-old woman with ulcerative colitis. Journal of the American Medical Association. 1998;279:949-954. [pmid: 9544770].
Pereira S P, Cassell T B, Engelman J L, Sladen G E, Murphy G M, Dowling R H. Plasma arachidonic acid-rich phospholipids in Crohn's disease. response to treatment. Clinical Science. 1996;91:509-512. [pmid: 8983878].
Perez-Jimenez F, Lopez-Miranda J, Pinillos M D, et al. A Mediterranean and a high-carbohydrate diet improve glucose metabolism in healthy young persons. Diabetologia. 2001;44:2038-2043. [pmid: 11719836].
Perry T L, Mann J I, Lewis-Barned N J, Duncan A W, Waldron M A, Thompson C. Lifestyle intervention in people with insulin-dependent diabetes mellitus (IDDM). European Journal of Clinical Nutrition. 1997;51:757-763. [pmid: 9368810].
Pi-Sunyer F X, Maggio C A, McCarron D A, et al. Multicenter randomized trial of a comprehensive prepared meal program in type 2 diabetes. Diabetes Care. 1999;22:191-197. [pmid: 10333932].
Poisson J P, Narce M. Lipid metabolism. Current Opinion in Lipidology. 2000;11:329-330. [pmid: 10882350].
Poppitt S D, Keogh G F, Prentice A M, et al. Long-term effects of ad libitum low-fat, high-carbohydrate diets on body weight and serum lipids in overweight subjects with metabolic syndrome. American Journal of Clinical Nutrition. 2002;75:11-20. [pmid: 11756055].
Pottathil R, Huang S W, Chandrabose K A. Essential fatty acids in diabetes and systemic lupus erythematosus (SLE) patients. Biochemical & Biophysical Research Communications. 1985;128:803-808. [pmid: 3838895].
Prescott J, Owens D, Collins P, Johnson A, Tomkin G H. The fatty acid distribution in low density lipoprotein in diabetes. Biochimica et Biophysica Acta, Molecular and Cell Biology of Lipids. 1999;1439:110-116.
Randle PJ. Regulatory interactions between lipids and carbohydrates. the glucose fatty acid cycle after 35 years. Diabetes Metabolism Reviews 1998;174.
Rao S, Erasmus R T. A pilot study on plasma fatty acids in poorly controlled non insulin dependent (type 2) Melanesian diabetics. Central African Journal of Medicine. 1996;42:295-297. [pmid: 9130405].
Recht L, Helin P, Rasmussen J, Jacobsen J, Lithman T, Schersten B. Hand handicap and rheumatoid arthritis in a fish-eating society (the Faroe Islands). Journal of Internal Medicine 1990:49–55.2137159
Requirand P, Gibert P, Tramini P, Cristol J P, Descomps B. Serum fatty acid imbalance in bone loss. example with periodontal disease. Clinical Nutrition. 2000;19:271-276. [pmid: 10952799].
Riccardi G, Rivellese A. Effects of dietary fiber and carbohydrate on glucose and lipoprotein metabolism in diabetic patients. Diabetes Care. 1991;14:1115-25. [pmid: 1663443].
Riley M D, Dwyer T. Microalbuminuria is positively associated with usual dietary saturated fat intake and negatively associated with usual dietary protein intake in people with insulin-dependent diabetes mellitus. American Journal of Clinical Nutrition. 1998;67:50-57. [pmid: 9440375].
Riserus U, Arner P, Brismar K, Vessby B. Treatment with dietary trans10cis12 conjugated linoleic acid causes isomer-specific insulin resistance in obese men with the metabolic syndrome. Diabetes Care. 2002;25:1516-1521. [pmid: 12196420].
Rocca A S, LaGreca J, Kalitsky J, Brubaker P L. Monounsaturated fatty acid diets improve glycemic tolerance through increased secretion of glucagon-like peptide-1. Endocrinology. 2001;142:1148-1155. [pmid: 11181530].
Rossetti R, Seiler C, Laposata M, Zurier R. Differential regulation of human T lymphocyte protein kinase C activity by unsaturated fatty acids. Clinical Immunology & Immunopathology. 1995;76:220-224. [pmid: 7554442].
Rossing P. Promotion, prediction, and prevention of progression in diabetic nephropathy. Danish Medical Bulletin. 1998;45:354-369. [pmid: 9777288].
Rowe B R, Bain S C, Pizzey M, Barnett A H. Rapid healing of ulcerated necrobiosis lipoidica with optimum glycaemic control and seaweed-based dressings. British Journal of Dermatology. 1991;125:603-604. [pmid: 1760369].
Royall D, Jeejeebhoy K N, Baker J P, et al. Comparison of amino acid v peptide based enteral diets in active Crohn's disease. Clinical and nutritional outcome. Gut. 1994;35:783-787. [pmid: 8020806]. [pmcid: 1374879].
Ruiz-Gutierrez V, Stiefel P, Villar J, Garcia-Donas M A, Acosta D, Carneado J. Cell membrane fatty acid composition in type 1 (insulin-dependent) diabetic patients. relationship with sodium transport abnormalities and metabolic control. Diabetologia. 1993;36:850-856. [pmid: 8405757].
Ryan E A, Pick M E, Marceau C. Use of alternative medicines in diabetes mellitus. Diabetic Medicine. 2001;18:242-245. [pmid: 11318847].
Ryan M, McInerney D, Owens D, Collins P, Johnson A, Tomkin G H. Diabetes and the Mediterranean diet. a beneficial effect of oleic acid on insulin sensitivity, adipocyte, glucose transport and endothelium-dependent vasoreactivity. QJM. 2000;93:85-91. [pmid: 10700478].
Sabino KCC, Gayer CRM, Vaz LCA, Santos LRL, Felzenszwalb I, Coelho MGP. In vitro and in vivo toxicological study of the Pterodon pubescens seed oil. Toxicology.Letters 1999;29.
Sakamaki N, Kikutani N, Iguchi M, et al. Studies on fat contents and fatty acids composition in foods for dietary therapy of diabetes. Annual Report of the Tokyo Metropolitan Research Laboratory of Public Health. 1996;11:202-206.
Salamone L, Cauley J, Black D, et al. Effect of a lifestyle intervention on bone mineral density in premenopausal women. a randomized trial. American Journal of Clinical Nutrition. 1999;70:97-103. [pmid: 10393145].
Salmeron J, Hu F B, Manson J E, et al. Dietary fat intake and risk of type 2 diabetes in women. American Journal of Clinical Nutrition. 2001;73:1019-1026. [pmid: 11382654].
Sanchez E, Jansen S, Castro P, et al: Mediterranean diet improves lipid profile in smoking males better than the American Cholesterol Program diet (NCEP-I). Medicina Clinica Barcelona 1999;39:
Sanfelippo ML, Swenson RS, Reaven GM: Reduction of plasma triglycerides by diet in subjects with chronic renal failure. Kidney International 1977;39:
Sarzi-Puttini P, Comi D, Boccassini L, et al. Diet therapy for rheumatoid arthritis. A controlled double-blind study of two different dietary regimens. Scandinavian Journal of Rheumatology. 2000;29:302-307. [pmid: 11093596].
Schalch A, Ybarra J, Adler D, Deletraz M, Lehmann T, Golay A. Evaluation of a psycho-educational nutritional program in diabetic patients. Patient Education & Counseling. 2001;44:171-178. [pmid: 11479057].
Scheffer P G, Bakker S J L, Popp-Snijders C, Heine R J, Schutgens R B H, Teerlink T. Composition of LDL as determinant of its susceptibility to in vitro oxidation in patients with well-controlled type 2 diabetes. Diabetes/Metabolism Research Reviews. 2001;17:459-466.
Schiff M. Emerging treatments for rheumatoid arthritis. American Journal of Medicine. 1997;102:11S-15S. [pmid: 9217554].
Schmidt L E, Arfken C L, Heins J M. Evaluation of nutrient intake in subjects with non-insulin-dependent diabetes mellitus. Journal of the American Dietetic Association. 1994;94:773-774. [pmid: 8021420].
Schwab U, Uusitupa M, Karhapaa P, et al: Effects of two fat-modified diets on glucose and lipid metabolism in healthy subjects. Dietary lipids and insulin action Second International Smolenice Insulin Symposium 1:279–280.
Schwarz J M, Linfoot P, Dare D, Aghajanian K. Hepatic de novo lipogenesis in normoinsulinemic and hyperinsulinemic subjects consuming high-fat, low-carbohydrate and low-fat, high-carbohydrate isoenergetic diets. American Journal of Clinical Nutrition. 2003;77:43-50. [pmid: 12499321].
Schwingshandl J, Rippel S, Unterluggauer M, Borkenstein M. Effect of the introduction of dietary sucrose on metabolic control in children and adolescents with type I diabetes. Acta Diabetologica. 1994;31:205-209. [pmid: 7888690].
Seigneur M, Freyburger G, Gin H, et al. Serum fatty acid profiles in type I and type II: metabolic alterations of fatty acids of the main serum lipids. Diabetes Research & Clinical Practice. 1994;23:169-177. [pmid: 7924877].
Shanahan F. Probiotics: Science or snake oil?. Clinical Perspectives in Gastroenterology. 2001;4:47-50.
Shoda R, Matsueda K, Yamato S, Umeda N, Shanahan F. Epidemiologic analysis of Crohn disease in Japan: increased dietary intake of n-6 polyunsaturated fatty acids and animal protein relates to the increased incidence of Crohn disease in Japan. American Journal of Clinical Nutrition. 1996;63:741-745. [pmid: 8615358].
Sidery M B, Gallen I W, Macdonald I A. The initial physiological responses to glucose ingestion in normal subjects are modified by a 3 d high-fat diet. British Journal of Nutrition. 1990;64:705-713. [pmid: 2124925].
Sidossis LS, Stuart CA, Shulman GI, Lopaschuk GD, Wolfe RR: Glucose plus insulin regulate fat oxidation by controlling the rate of fatty acid entry into the mitochondria. Journal of Clinical Investigation 1996;28:
Siguel E N, Lerman R H. Prevalence of essential fatty acid deficiency in patients with chronic gastrointestinal disorders. Metabolism: Clinical & Experimental. 1996;45:12-23.
Sileghem A. Intranasal calcitonin for the prevention of bone erosion and bone loss in rheumatoid arthritis. Annals of the Rheumatic Diseases. 1992;51:761-764. [pmid: 1616360]. [pmcid: 1004742].
Simopoulos A P. Is insulin resistance influenced by dietary linoleic acid and trans fatty acids?. Free Radical Biology & Medicine. 1994;17:367-372. [pmid: 8001841].
Singer P, Gnauck G, Honigmann G, Schliack V. Fatty acid pattern of the triglycerides in severe diabetic macroangiopathy. Deutsche Gesundheitswesen. 1978;33:2179-2183.
Singer P, Gnauck G, Honigmann G, Schliack V, Laeuter J. The fatty acid composition of triglycerides in arteries, depot fat and serum of amputated diabetics. Atherosclerosis. 1977;28:87-92. [pmid: 911372].
Singer P, Honigmann G, Buntrock P, Schliack V. Eicosapentaenoic acid in liver, serum and adipose tissue triglycerides in relation to the form of fatty liver in diabetics. Deutsche Gesundheitswesen. 1981;36:1264-1272.
Singer P, Honigmann G, Schliack V. Fatty infiltration of the liver and fatty acid composition of the liver and adipose tissue triglycerides in diabetics without or with arterial hypertension. Deutsche Gesundheitswesen. 1981;36:1693-1699.
Singer P, Honigmann G, Schliack V. Negative correlation of eicosapentaenoic acid and lipid accumulation in hepatocytes of diabetics. Biomedica Biochimica Acta. 1984;43:S438-S442. [pmid: 6097238].
Smedman A, Vessby B. Conjugated linoleic acid supplementation in humans - Metabolic effects. Lipids. 2001;36:773-781. [pmid: 11592727].
Smith U. Carbohydrates, fat, and insulin action. American Journal of Clinical Nutrition. 1994;59:686S-689S. [pmid: 8116551].
Soriguer F, Serna S, Valverde E, et al. Lipid, protein, and calorie content of different Atlantic and Mediterranean fish, shellfish, and molluscs commonly eaten in the south of Spain. European Journal of Epidemiology. 1997;13:451-463. [pmid: 9258553].
Staprans I, Pan XianMang Hardman D A, Feingold K R, Pan X M. Effect of oxidized lipids in the diet on oxidized lipid levels in postprandial serum chylomicrons of diabetic patients. Diabetes Care. 1999;22:300-306. [pmid: 10333949].
Stojceva-Taneva O, Polenakovic M, Grozdanovski R, Sikole A. Lipids, protein intake, and progression of diabetic nephropathy. Nephrology Dialysis Transplantation. 2001;16:90-91.
Storlien LH, Hulbert AJ, Else PL: Polyunsaturated fatty acids, membrane function and metabolic diseases such as diabetes and obesity. Current Opinion in Clinical Nutrition and Metabolic Care 1998;46:
Strain G W, Champagne C, Roman S H. An ethnic comparison of nutritional patterns and health habits in elderly patients with diabetes. Journal of Nutrition for the Elderly. 1998;18:37-47.
Straznicky N E, Barrington V E, Branley P, Louis W J. A study of the interactive effects of oral contraceptive use and dietary fat intake on blood pressure, cardiovascular reactivity and glucose tolerance in normotensive women. Journal of Hypertension. 1998;16:357-368. [pmid: 9557929].
Sukumar P, Loo A, Magur E, Nandi J, Oler A, Levine R A. Dietary supplementation of nucleotides and arginine promotes healing of small bowel ulcers in experimental ulcerative ileitis. Digestive Diseases and Sciences. 1997;42:1530-1536. [pmid: 9246059].
Suryaprabha P, Das U N, Ramesh G, Kumar K V, Kumar G S. Reactive oxygen species, lipid peroxides and essential fatty acids in patients with rheumatoid arthritis and systemic lupus erythematosus. Prostaglandins Leukotrienes & Essential.Fatty Acids. 1991;43:251-255.
Swinburn B A, Metcalf P A, Ley S J. Long-term (5-year) effects of a reduced-fat diet intervention in individuals with glucose intolerance. Diabetes Care. 2001;24:619-624. [pmid: 11315819].
Takayasu K, Tada T, Okada F, Yoshikawa I. Human plasma fatty acid composition: the features of hyperlipoproteinemia and the influence of -linolenate and clofibrate. Japanese Circulation Journal. 1971;35:1059-1069. [pmid: 5172104].
Teahon K, Venkatesan S. Fatty acid profile of plasma lipids from patients with Crohn's disease before and after 4 weeks on elemental diet ([double prime] 0 28 [double prime] or [double prime] Vivonex [double prime]). Biochemical Society Transactions. 1991;19:322S. [pmid: 1783157]. [pmcid: 370910].
Theander E, Horrobin D, Jacobsson L, Manthorpe R. Gammalinolenic acid treatment of fatigue associated with primary sjogren's syndrome. Scandinavian Journal of Rheumatology. 2002;31:72-79. [pmid: 12109650].
Thomsen C, Rasmussen O W, Hansen K W, Vesterlund M, Hermansen K. Comparison of the effects on the diurnal blood pressure, glucose, and lipid levels of a diet rich in monounsaturated fatty acids with a diet rich in polyunsaturated fatty acids in type 2 diabetic subjects. Diabetic Medicine. 1995;12:600-606. [pmid: 7554782].
Tilvis R S, Miettinen T A. Fatty acid compositions of serum lipids, erythrocytes, and platelets in insulin-dependent diabetic women. Journal of Clinical Endocrinology & Metabolism. 1985;61:741-745. [pmid: 4031016].
Tilvis R S, Taskinen M R, Miettinen T A. Effect of insulin treatment on fatty acids of plasma and erythrocyte membrane lipids in type 2 diabetes. Clinica Chimica Acta. 1988;171:293-303.
Tinahones F J, Pareja A, Soriguer F, Gomez Zumaqueroz J M, Esteva I. Metabolic effects of a diet deficient in essential fatty acids. Diabetes, Nutrition and Metabolism. 1998;11:325-329.
Toeller M, Klischan A, Heitkamp G, et al. Nutritional intake of 2868 IDDM patients from 30 centers in Europe. EURODIAB IDDM Complications Study Group. Diabetologia. 1996;39:929-939. [pmid: 8858215].
Torrioli E, Citti C, Picchi L: Clinical and therapeutic studies of synthetic salmon calcitonin in some osteopathies. Clinica.Terapeutica 1982:123–129.
Traianedes K, Collier G R, O'Dea K. Ingestion of different types of fat in the evening meal does not affect metabolic responses to a standard breakfast. American Journal of Clinical Nutrition. 1990;52:442-445. [pmid: 2203250].
Trichopoulou A, Georgiou E, Bassiakos Y, et al. Energy intake and monounsaturated fat in relation to bone mineral density among women and men in Greece. Preventive Medicine. 1997;26:395-400. [pmid: 9144765].
Tsihlias E B, Gibbs A L, McBurney M I, Wolever T M. Comparison of high- and low-glycemic-index breakfast cereals with monounsaturated fat in the long-term dietary management of type 2 diabetes. American Journal of Clinical Nutrition. 2000;72:439-449. [pmid: 10919939].
Tuna N, Frankhauser S, Goetz F C. Total serum fatty acids in diabetes: relative and absolute concentrations of individual fatty acids. American Journal of the Medical Sciences. 1968;255:120-131. [pmid: 5639552].
Tuomilehto J, Lindstrom J, Eriksson J G. Changes in diet and physical activity prevented type 2 diabetes mellitus in people with impaired glucose tolerance. Evidence Based Medicine. 2001;6:176.
Tuomilehto J, Lindstrom J, Eriksson J G, et al. Prevention of type 2 diabetes mellitus by changes in lifestyle among subjects with impaired glucose tolerance. New England Journal of Medicine. 2001;344:1343-1350. [pmid: 11333990].
Uccella R, Contini A, Sartorio M. Action of evening primrose oil on cardiovascular risk factors in insulin-dependent diabetics. Clinica Terapeutica. 1989;129:381-388. [pmid: 2548804].
Uesugi T, Fukui Y, Yamori Y. Beneficial effects of soybean isoflavone supplementation on bone metabolism and serum lipids in postmenopausal japanese women: a four-week study. Journal of the American College of Nutrition. 2002;21:97-102. [pmid: 11999549].
Uusitupa M, Schwab U, Makimattila S, et al. Effects of two high-fat diets with different fatty acid compositions on glucose and lipid metabolism in healthy young women. American Journal of Clinical Nutrition. 1994;59:1310-1316. [pmid: 8198055].
van Doormaal J J, Idema I G, Muskiet F A, Martini I A, Doorenbos H. Effects of short-term high dose intake of evening primrose oil on plasma and cellular fatty acid compositions, alpha-tocopherol levels, and erythropoiesis in normal and type 1 (insulin-dependent) diabetic men. Diabetologia. 1988;31:576-584. [pmid: 3065111].
van Doormaal J J, Muskiet F A, van Ballegooie E, Sluiter W J, Doorenbos H. The plasma and erythrocyte fatty acid composition of poorly controlled, insulin-dependent (type I) diabetic patients and the effect of improved metabolic control. Clinica Chimica Acta. 1984;144:203-212.
van Epps-Fung M, Williford J, Wells A, Hardy R W. Fatty acid-induced insulin resistance in adipocytes. Endocrinology Philadelphia. 1997;138:4338-4345.
van Oostrom A J, Cabezas M C, Rabelink T J. Insulin resistance and vessel endothelial function. Journal of the Royal Society of Medicine. 2002;95:S61. [pmid: 12216328].
Vassilopoulos D, Zurier R, Rossetti R, Tsokos G. Gammalinolenic acid and dihomogammalinolenic acid suppress the CD3mediated signal transduction pathway in human T cells. Clinical Immunology & Immunopathology. 1997;83:237-244. [pmid: 9175912].
Vazquez I M, Millen B, Bissett L, Levenson S M, Chipkin S R, Buena Salud. A preventive nutrition intervention in Caribban Lations with type 2 diabetes. American Journal of Health Promotion. 1998;13:116-119. [pmid: 10346658].
Vessby B, Aro A, Skarfors E, Berglund L, Salminen I, Lithell H. The risk to develop NIDDM is related to the fatty acid composition of the serum cholesterol esters. Diabetes. 1994;43:1353-1357. [pmid: 7926311].
Vessby B, Unsitupa M, Hermansen K, et al. Substituting dietary saturated for monounsaturated fat impairs insulin sensitivity in healthy men and women: The KANWU Study. Diabetologia. 2001;44:312-319. [pmid: 11317662].
Wahrburg U, Kratz M, Cullen P. Mediterranean diet, olive oil and health. European Journal of Lipid Science and Technology. 2002;104:698-705.
Walker KZ, O' Dea K: Is a low fat diet the optimal way to cut energy intake over the long term in overweight people? Nutrition Metabolism and Cardiovascular Diseases 2001;
Walker K Z, O'Dea K, Nicholson G C, Muir J G. Dietary composition, body weight, and NIDDM: Comparison of high-fiber, high-carbohydrate, and modified-fat diets. Diabetes Care. 1995;18:401-403. [pmid: 7555486].
Wallace A J, Sutherland W H F, Mann J I, Williams S M. The effect of meals rich in thermally stressed olive and safflower oils on postprandial serum paraoxonase activity in patients with diabetes. European Journal of Clinical Nutrition. 2001;55:951-958. [pmid: 11641743].
Wallace D J. Systemic lupus erythematosus and Sjogren's syndrome. Current Opinion in Rheumatology. 1994;6:459-460. [pmid: 7993700].
Watson J, Byars M L, McGill P, Kelman A W. Cytokine and prostaglandin production by monocytes of volunteers and rheumatoid arthritis patients treated with dietary supplements of blackcurrant seed oil. British Journal of Rheumatology. 1993;32:1055-1058. [pmid: 8252313].
Watts G F. Coronary disease, dyslipidaemia and clinical trials in type 2 diabetes mellitus. Practical Diabetes International. 2000;17:54-59.
Welch I M, Bruce C, Hill S E, Read N W. Duodenal and ileal lipid suppresses postprandial blood glucose and insulin responses in man: possible implications for the dietary management of diabetes mellitus. Clinical Science. 1987;72:209-216. [pmid: 3545642].
West K M. Diet therapy of diabetes: an analysis of failure. Annals of Internal Medicine. 1973;79:425-434. [pmid: 4594083].
Williams D E M, Prevost A T, Whichelow M J, Cox B D, Day N E, Wareham N J. A cross-sectional study of dietary patterns with glucose intolerance and other features of the metabolic syndrome. British Journal of Nutrition. 2000;83:257-266. [pmid: 10884714].
Williams W V, Rosenbaum H, Zurier R B. Effects of unsaturated fatty acids on expression of early response genes in human T lymphocytes. Pathobiology. 1996;64:27-31. [pmid: 8856792].
Wing R R, Marcus M D, Salata R, Epstein L H, Miaskiewicz S, Elaine H B. Effects of a very-low-calorie diet on long-term glycemic control in obese type 2 diabetic subjects. Archives of Internal Medicine. 1991;151:1334-1340. [pmid: 2064484].
Wolever T M S, Mehling C. High-carbohydrate-low-glycaemic index dietary advice improves glucose disposition index in subjects with impaired glucose tolerance. British Journal of Nutrition. 2002;87:477-487. [pmid: 12010586].
Wuesten O, Balz C H, Kloer H U, Bretzel R G, Linn T. Enhancement of beta-cell sensitivity to glucose by oral fat load. Hormone & Metabolic Research. 2001;33:548-553. [pmid: 11561215].
Wyatt R J, Hogg R J. Evidence-based assessment of treatment options for children with IgA nephropathies. Pediatric Nephrology. 2001;16:156-167. [pmid: 11261686].
Yamamoto K, Asakawa H, Tokunaga K, et al. Long-term ingestion of dietary diacylglycerol lowers serum triacylglycerol in type II diabetic patients with hypertriglyceridemia. Journal of Nutrition. 2001;131:3204-3207. [pmid: 11739866].
Yaqoob P, Knapper J A, Webb D H, Williams C M, Newsholme E A, Calder P C. Effect of olive oil on immune function in middle-aged men. American Journal of Clinical Nutrition. 1998;67:129-135. [pmid: 9440387].
Young T K, Gerrard J M, O'Neil J D. American Journal of Physical Anthropology. 1999;109:9-18. [pmid: 10342461].
Zock P L, Mensink R P, Harryvan J, De Vries J J H M, Katan M B. Fatty acids in serum cholesteryl esters as quantitative biomarkers of dietary intake in humans. American Journal of Epidemiology. 1997;145:1114-1122. [pmid: 9199541].

### Rejected Population

Bonnema S J, Jespersen L T, Marving J, Gregersen G. Supplementation with olive oil rather than fish oil increases small arterial compliance in diabetic patients. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 1995;8:81-87.
Cameron N E, Cotter M A. Effects of antioxidants on nerve and vascular dysfunction in experimental diabetes. Diabetes Research & Clinical Practice. 1999;45:137-146. [pmid: 10588366].
Cathcart E, Gonnerman W A. Fish oil fatty acids and experimental arthritis. Rheum Dis Clin North Am. 1991;17:235-42. [pmid: 1713702].
Clandinin M T, Cheema S, Field C J, Baracos V E. Dietary lipids influence insulin action. Annals of the New York Academy of Sciences. 1993;683:151-163. [pmid: 8352437].
Edrees GMF, Othman AB, Amer MA: Influence of zinc supplementation and soybean feeding in controlling some diabetic disorders. Egyptian Journal of Food Science 1991;20 ref.:1–2, 217.
Field C J, Goruk S D, Wierzbicki A A, Clandinin M T. The effect of dietary fat content and composition on adipocyte lipids in normal and diabetic states. International Journal of Obesity. 1989;13:747-756. [pmid: 2621049].
Gerbi A, Maixent JM, Barbey O, et al: Neuroprotective effect of fish oil in diabetic neuropathy. Lipids 1999;7:
Haines A P, Sanders T A, Imeson J D, et al. Effects of a fish oil supplement on platelet function, haemostatic variables and albuminuria in insulin-dependent diabetics. Thrombosis Research. 1986;43:643-655. [pmid: 3020732].
Lungershausen Y K, Howe P R C, Clifton P M, et al. Evaluation of an omega-3 fatty acid supplement in diabetics with microalbuminuria. Annals of the New York Academy of Sciences. 1997;827:369-381. [pmid: 9329768].
Mori T A, Vandongen R, Masarei J R, Rouse I L, Dunbar D. Comparison of diets supplemented with fish oil or olive oil on plasma lipoproteins in insulindependent diabetics. Metabolism: Clinical & Experimental. 1991;40:241-246. [pmid: 2000036].
Ogborn M R, Nitschmann E, Bankovic-Calic N, Weiler H A, Aukema H. Dietary flax oil reduces renal injury, oxidized LDL content, and tissue n-6/n-3 FA ratio in experimental polycystic kidney disease. Lipids. 2002;37:1059-65. [pmid: 12558056].
Ohtake T, Kimura M, Takemura H, Hishida A: Effects of dietary lipids on daunomycin-induced nephropathy in mice: comparison between cod liver oil and soybean oil. Lipids 2002;4:
Reifen R. Nutrition and autoimmunity. Israel Journal of Medical Sciences. 1997;33:269-272. [pmid: 9347878].
Robinson D R, Knoell C T, Urakaze M, et al. Suppression of autoimmune disease by omega-3 fatty acids. Biochemical Society Transactions. 1995;23:287-291. [pmid: 7672312].
Robinson D X L, Tateno S, Guo M, Colvin R. Suppression of autoimmune disease by dietary n-3 fatty acids. Journal of Lipid Research. 1993;34:1435-1444. [pmid: 8409774].
Shohat J, Boner G. Role of lipids in the progression of renal disease in chronic renal failure: evidence from animal studies and pathogenesis. Israel Journal of Medical Sciences. 1993;29:228-239. [pmid: 8491578].
Stiefel P, Ruiz-Gutierrez V, Gajon E, et al. Sodium transport kinetics, cell membrane lipid composition, neural conduction and metabolic control in type 1 diabetic patients. Changes after a low-dose n-3 fatty acid dietary intervention. Annals of Nutrition & Metabolism. 1999;43:113-120. [pmid: 10436310].
Tariq T, Close C, Dodds R, Viberti G C, Lee T, Vergani D. The effect of fish-oil on the remission of type 1 (insulin-dependent) diabetes in newly diagnosed patients. Diabetologia. 1989;32:765. [pmid: 2687061].
Thaiss F, Schoeppe W, Germann P, Stahl RAK: Dietary fish oil intake: effects on glomerular prostanoid formation, hemodynamics, and proteinuria in nephrotoxic serum nephritis. Journal of Laboratory and Clinical Medicine 1990;33 ref.:
Watkins B, Lippman H, Le Bouteiller L, Li Y, Seifert M. Bioactive fatty acids: role in bone biology and bone cell function. Progress in Lipid Research. 2001;40:125-148. [pmid: 11137570].
Weise WJ, Natori Y, Levine JS, et al: Fish oil has protective and therapeutic effects on proteinuria in passive Heymann nephritis. Kidney International 1993;48:
Yagasaki K: Evaluation of therapeutic potential of dietary manipulations and food factors against nephritis and cancer by in vivo and in vitro disease models. Nippon Eiyo Shokuryo Gakkaishi = Journal of the Japanese Society of Nutrition and Food Science 2000;45:

### Rejected Study Design Descriptive

Anonymous II: International conference on the health effects of omega-3 polyunsaturated fatty acids in seafoods. Zeitschrift fur Arztliche Fortbildung 1991;85:196-
Anonymous Inflammatory bowel diseases: Medecine et Chirurgie Digestives 1991;20:365–371.
Anonymous Something fishy for them joints? Hospitals & Health Networks 1995;69:12-
American Diabetes Association: Evidence-based nutrition principles and recommendations for the treatment and prevention of diabetes and related complications. Journal of the American Dietetic Association 2002;7:
Ballou S P. Systemic lupus erythematosus. Controversies in management. Postgraduate Medicine. 1987;81:157-164. [pmid: 3295833].
Barth C. Prognostic risk factors as an indication for the early treatment of IgA nephritis. Deutsche Medizinische Wochenschrift. 2000;125:1009. [pmid: 11004913].
Benedek T. Treatment of systemic lupus erythematosus: from cod-liver oil to cyclosporin. Lancet. 1998;352:901-902. [pmid: 9743005].
Cotton P. New approaches may aid patients with inflammatory bowel disease. JAMA. 1990;263:3121-3122. [pmid: 2348514].
Daniel H, Metzger B. The pathogenesis and therapy of chronic inflammatory bowel diseases. Deutsche Apotheker Zeitung. 1990;130:2461-2468.
Das U N. Insulin resistance and hyperinsulinaemia: Are they secondary to an alteration in the metabolism of essential fatty acids?. Medical Science Research. 1994;22:243-245.
Donadio J V, Bergstralh E J, Offord K P, Holley K E, Spencer D C. Clinical and histopathologic associations with impaired renal function in IgA nephropathy. Mayo Nephrology Collaborative Group. Clinical Nephrology. 1994;41:65-71. [pmid: 8004831].
Ernst E. Complementary/alternative medicine in rheumatology-between negligence, ignorance and arrogance. Osteoarthritis & Cartilage. 2002;10:671-672. [pmid: 12202118].
Funk C. Current drug therapy of colitis. Ars Medici. 1990;80:466-473.
Gassull M A. Polyunsaturated fatty acids in inflammatory bowel diseases. Pediatrika. 1997;17:75-76.
Harrison R, Harrison B, Volker D, Garg M. Fish oils are beneficial to patients with established rheumatoid arthritis. Journal of Rheumatology. 2001;28:2563-2565. [pmid: 11708441].
Hart F, Karmali R, Birtwistle S, McEwen L. Dietary fatty acids and rheumatoid arthritis. Lancet. 1985;1:699-700. [pmid: 2858647].
Hogg R J. A randomized, placebo-controlled, multicenter trial evaluating alternate-day prednisone and fish oil supplements in young patients with immunoglobulin A nephropathy. American Journal of Kidney Diseases. 1995;26:792-796. [pmid: 7485134].
Howard W J. Is it time for a clinical trial of dietary fish oil supplementation in individuals with NIDDM?. Annals of the New York Academy of Sciences. 1993;683:341-342. [pmid: 8352457].
Korelitz B I, Stenson W F, Cort D, et al. Fish oil supplementation in ulcerative colitis. Deutsche Medizinische Wochenschrift. 1993;118:925.
Kremer J: Omega-3 fatty acids in rheumatoid arthritis. Delaware.Medical Journal 1988:679–681.
Kromhout Dand Feskens E J. Nutrition and diabetes: the role of fat. Acta Cardiologica. 1993;48:444-445. [pmid: 8284971].
Lauritzen K, Fabech B, Bager S, Larsen C. Fish oil. Ugeskrift for Laeger. 2002;164:1062-1063. [pmid: 11894715].
Lorenz-Meyer H, Purrmann J, Scheurlen C, et al. Ergebnisse der Studie zur Erhaltung der Remission bei Morbus Crohn mit o-3 FS bzw. einer kohlenhydratarmen Kost. Z Gastroenterol. 1992;30:654.
Luostarinen R, Wallin R, Wibell L, Saldeen T. Vitamin E supplementation counteracts the fish oil-induced increase of blood glucose in humans. Nutrition Research. 1995;15:953-968.
Petrie K J, Cundy T. Alternative medicine recommendations to patients with Type 2 diabetes visiting health product shops and pharmacies. Diabetic Medicine. 2002;19:1035. [pmid: 12647848].
Shanahan F, Targan S. Medical treatment of inflammatory bowel disease. Annual Review of Medicine. 1992;43:125-133. [pmid: 1580577].
Siguel E. Low- and high-fat, peptide-based diets in adolescents with active Crohn's disease. Journal of Parenteral & Enteral Nutrition. 1997;21:304.
Singer P. Third International Congress on Essential Fatty Acids and Eicosanoids. Aktuelle Ernahrungsmedizin Klinik und Praxis. 1992;17:244-245.
Stotland B R, Cirigliano M D, Lchtenstein G R. Medical therapies for inflammatory bowel disease. Hospital Practice. 1998;33:141-168. [pmid: 9606359].

### Rejected Study Design Review/Meta-Analysis

Anonymous Fish oil: Alternative Medicine Review 2000;5:576–580.
Anonymous Fish oil supplements: Geneesmiddelenbulletin 1999;33:37–42.
Anonymous Fish oils in rheumatoid arthritis: Lancet 1987;2:720–721.
Anonymous Minerva: BMJ 1996;312:322-
Anonymous Nonspecific immunosuppressive therapies still the mainstay for SLE: Drugs & Therapy Perspectives 1996;8:5–9.
Adam O. Anti-inflammatory diet in rheumatic diseases. European Journal of Clinical Nutrition. 1995;49:703-717. [pmid: 8536649].
Adam O. immun system: Rheumatism. Aktuelle Ernahrungsmedizin. 2002;27:245-249.
Alarcon de la Lastra Barranco M, Motilva V, Herrerias J. Mediterranean diet and health: Biological importance of olive oil. Current Pharmaceutical Design. 2001;7:933-950. [pmid: 11472248].
Albertazzi P, Coupland K. Is there a role in postmenopausal osteoporosis prevention?. Maturitas. 2002;42:13-22. [pmid: 12020975].
Alexander J. Immunonutrition: The role of omega-3 fatty acids. Nutrition. 1998;14:627-633. [pmid: 9684267].
Anderson J W, Smith B M, Washnock C S. Cardiovascular and renal benefits of dry bean and soybean intake. American Journal of Clinical Nutrition. 1999;70:464S-474S. [pmid: 10479219].
Andreani D, Di Mario U, Pozzilli P. Prediction, prevention, and early intervention in insulin-dependent diabetes. Diabetes-Metabolism Reviews. 1991;7:61-77. [pmid: 1935536].
Angelin B, Palmblad J: Fish liver oil instead of pharmaceuticals? Lakartidningen 1988;
Ariza-Ariza R, Mestanza-Peralta M, Cardiel M. Omega-3 fatty acids in rheumatoid arthritis: An overview. Seminars in Arthritis & Rheumatism. 1998;27:366-370. [pmid: 9662755].
Axelrod L. Omega-3 fatty acids in diabetes mellitus. Gift from the sea?. Diabetes. 1989;38:539-543. [pmid: 2653924].
Bagdade J D. HDL and reverse cholesterol transport in diabetes. Diabetes Reviews. 1997;5:392-409.
Barre D. Potential of evening primrose, borage, black currant, and fungal oils in human health. Annals.of.Nutrition.and.Metabolism. 2001;45:47-57. [pmid: 11359029].
Barrett P H, Watts G F. HDL kinetics, fish oils and diabetes. Atherosclerosis. 2001;159:243-244. [pmid: 11689229].
Barrett P H, Watts G F. Kinetic studies of lipoprotein metabolism in the metabolic syndrome including effects of nutritional interventions. Current Opinion in Lipidology. 2003;14:61-68. [pmid: 12544663].
Bates E J. Eicosanoids, fatty acids and neutrophils: Their relevance to the pathophysiology of disease. Prostaglandins Leukotrienes & Essential Fatty Acids. 1995;53:75-86.
Belaiche J, Louis E. Management of postoperative Crohn's disease recurrence. Acta Endoscopica. 1999;29:253-262.
Belch J. Fish oil and rheumatoid arthritis: Does a herring a day keep rheumatologists away?. Annals of the Rheumatic Diseases. 1990;49:71-72. [pmid: 2180386]. [pmcid: 1003976].
Belch J J F. Is there a role for natural remedies in rheumatoid arthritis?. Scottish Medical Journal. 1992;37:100-102. [pmid: 1411475].
Belluzzi A. N-3 and n-6 fatty acids for the treatment of autoimmune diseases. European.Journal.of.Lipid.Science.and.Technology. 2001;103:399-407.
Belluzzi A. N-3 fatty acids for the treatment of inflammatory bowel diseases. Proceedings of the Nutrition Society. 2002;61:391-395. [pmid: 12296296].
Belluzzi A, Boschi S, Brignola C, Munarini A, Cariani G, Miglio F. Polyunsaturated fatty acids and inflammatory bowel disease. American Journal of Clinical Nutrition. 2000;71:339S-342S. [pmid: 10617993].
Belluzzi A, Boschi S, Miglio F, et al: Long-chain fatty acids for the treatment of inflammatory bowel disease. Essential fatty acids and eicosanoids. invited papers from the Fourth International Congress, Edinburgh, Scotland, UK, July 20 24, 1997 1998;30:
Belluzzi A, Miglio F: n-3 Fatty acids in the treatment of Crohn's Disease. Medicinal Fatty Acids in Inflammation 1998;91–101.
Berry E M. Dietary fatty acids in the management of diabetes mellitus. American Journal of Clinical Nutrition. 1997;66:991S-997S. [pmid: 9322579].
Berry E M. Who's afraid of n-6 polyunsaturated fatty acids? Methodological considerations for assessing whether they are harmful. Nutrition Metabolism & Cardiovascular Diseases. 2001;11:181-188.
Best J D, O'Neal D N. Diabetic dyslipidaemia: Current treatment recommendations. Drugs. 2000;59:1101-1111. [pmid: 10852642].
Bickston S J, Cominelli F. Inflammatory Bowel disease: Short- and long- term treatments. Disease-a-Month. 1998;44:144-172. [pmid: 9580743].
Bickston S J, Cominelli F. Recent developments in the medical therapy of inflammatory bowel disease. Current Opinion in Gastroenterology. 1998;14:6-10.
Bilo H J, Gans R O. Fish oil: a panacea?. Biomedicine & Pharmacotherapy. 1990;44:169-174.
Bilo H J, Homan van der Heide J J, Gans R O, Donker A J. Omega-3 polyunsaturated fatty acids in chronic renal insufficiency. Nephron. 1991;57:385-393. [pmid: 2046820].
Blok W, Katan M, Van der Meer J. Modulation of inflammation and cytokine production by dietary (n-3) fatty acids. Journal of Nutrition. 1996;126:1515-1533. [pmid: 8648424].
Boucher B J. Inadequate vitamin D status: Does it contribute to the disorders comprising syndrome ‘X’?. British Journal of Nutrition. 1998;79:315-327. [pmid: 9624222].
Buchanan H M, Preston S J, Brooks P M, Buchanan W W. Is diet important in rheumatoid arthritis?. British Journal of Rheumatology. 1991;30:125-134. [pmid: 2012942].
Burke A, Lichtenstein G R, Rombeau J L. Nutrition and ulcerative colitis. Baillieres Clinical Gastroenterology. 1997;11:153-174.
Cabre E, Gassull M A. Nutrition in inflammatory bowel disease: Impact on disease and therapy. Current Opinion in Gastroenterology. 2001;17:342-349. [pmid: 17031181].
Cabre Gelada I, Esteve Comas I. Polysaturated fatty acids and their metabolites in chronic inflammatory bowel disease. Gastroenterologia y Hepatologia. 1995;18:515-525. [pmid: 8548588].
Calder J, Issenman R, Cawdron R. Health information provided by retail health food outlets. Canadian Journal of Gastroenterology. 2000;14:767-771. [pmid: 11064312].
Calder P C. Polyunsaturated fatty acids, inflammation, and immunity. Lipids. 2001;36:1007-1024. [pmid: 11724453].
Calder P. Dietary fatty acids and the immune system. Lipids. 1999;34:S137-S140. [pmid: 10419124].
Calder P. Dietary modification of inflammation with lipids. Proceedings of the Nutrition Society. 2002;61:345-358. [pmid: 12296294].
Calder P. n-3 polyunsaturated fatty acids and cytokine production in health and disease. Annals of Nutrition & Metabolism. 1997;41:203-234. [pmid: 9363294].
Calder P. N-3 polyunsaturated fatty acids, inflammation and immunity: Pouring oil on troubled waters or another fishy tale?. Nutrition Research. 2001;21:309-341.
Calder P C, Yaqoob P, Thies F, Wallace F A, Miles E A. Fatty acids and lymphocyte functions. British Journal of Nutrition. 2002;87:S31-S48. [pmid: 11895154].
Calder P, Zurier R. Polyunsaturated fatty acids and rheumatoid arthritis. Current Opinion in Clinical Nutrition & Metabolic Care. 2001;4:115-121. [pmid: 11224655].
Callegari P E, Zurier R B. Botanical lipids: potential role in modulation of immunologic responses and inflammatory reactions. Rheumatic Diseases Clinics of North America. 1991;17:415-425. [pmid: 1862248].
Campieri M, Gionchetti P, Belluzzi A, Brignola C, Miglioli M, Barbara L. Medical treatment of inflammatory bowel disease. Current Opinion in Gastroenterology. 1992;8:663-675.
Casellas F, Guarner F. Eicosanoids in inflammatory bowel disease. Therapeutic implications. Clinical Immunotherapeutics. 1996;6:333-340.
Cathcart E S, Gonnerman W A, Leslie C A, Hayes K C. Dietary n-3 fatty acids and arthritis. Journal of Internal Medicine Supplement. 1989;225:217-223. [pmid: 2468344].
Chowdhury M N. IgA nephropathy and fish oil. Bangladesh Renal Journal. 2000;19:16-26.
Clark W. Treatment of lupus nephritis: Immunosuppression, general therapy, dialysis and transplantation. Clinical & Investigative Medicine. 1994;17:588-601. [pmid: 7895423].
Clark W F, Parbtani A. Omega-3 fatty acid supplementation in clinical and experimental lupus nephritis. American Journal of Kidney Diseases. 1994;23:644-647. [pmid: 8172205].
Clarke S D. Polyunsaturated fatty acid regulation of gene transcription: a mechanism to improve energy balance and insulin resistance. British Journal of Nutrition. 2000;83:S59-S66. [pmid: 10889793].
Cleland L G, Hill C L, James M J. Diet and arthritis. Baillieres Clinical Rheumatology. 1995;9:771-785.
Cleland L, James M. Adulthood prevention: Rheumatoid arthritis. Medical Journal of Australia. 2002;176:S119-S120. [pmid: 12064974].
Cleland L, James M. Fish oil and rheumatoid arthritis: Antiinflammatory and collateral health benefits. Journal of Rheumatology. 2000;27:2305-2307. [pmid: 11036821].
Cleland L G, James M J. Rheumatoid arthritis and the balance of dietary N-6 and N-3 essential fatty acids. British Journal of Rheumatology. 1997;36:513-515. [pmid: 9189049].
Cole T, Hawkey C J. New treatments in inflammatory bowel disease. British Journal of Hospital Medicine. 1992;47:581-590. [pmid: 1591558].
Collier G R, Sinclair A J. Role of N-6 and N-3 fatty acids in the dietary treatment of metabolic disorders. Annals of the New York Academy of Sciences. 1993;683:322-330. [pmid: 8352454].
Connor W E. Diabetes, fish oil, and vascular disease. Annals of Internal Medicine. 1995;123:950-952. [pmid: 7486492].
Connor W E, DeFrancesco C A, Connor S L. N-3 fatty acids from fish oil. Effects on plasma lipoproteins and hypertriglyceridemic patients. Annals of the New York Academy of Sciences. 1993;683:16-34. [pmid: 8352438].
Cortot A, Desreumaux P. Crohn's disease: How to prevent a flare-up. Drugs of Today. 1999;35:119-131.
Cukier C, Waitzberg DL: Biological activity of fish oil. Arquivos.de Gastroenterologia 1996:173–178.
D'Amico G. Treatment of IgA nephropathy. An overview Nephrology. 1997;3:S725-S730.
D'Haens G, Rutgeerts P. Maintenance and prophylactic therapy for Crohn's disease. Current Opinion in Gastroenterology. 1997;13:312-316.
Darlington L G. Dietary therapy for rheumatoid arthritis. Clinical & Experimental Rheumatology. 1994;12:235-239. [pmid: 8070155].
Darlington L. Do diets rich in polyunsaturated fatty acids affect disease activity in rheumatoid arthritis?. Annals.of.the.Rheumatic.Diseases. 1988;47:169-72. [pmid: 3281607]. [pmcid: 1003472].
Darlington L G, Ramsey N W. Review of dietary therapy for rheumatoid arthritis. British Journal of Rheumatology. 1993;32:507-514. [pmid: 8508288].
Darlington L G, Ramsey N W. Review of dietary therapy for rheumatoid arthritis. Comprehensive Therapy. 1994;20:490-494. [pmid: 7805365].
Darlington L, Stone T. Antioxidants and fatty acids in the amelioration of rheumatoid arthritis and related disorders. British Journal of Nutrition. 2001;85:251-269. [pmid: 11299072].
Das U. Beneficial action(s) of eicosapentaenoic acid/docosahexaenoic acid and nitric oxide in systemic lupus erythematosus. Medical Science Research. 1995;23:723-726.
Das U N. Beneficial effect(s) of n-3 fatty acids in cardiovascular diseases: but, why and how?. Prostaglandins Leukotrienes & Essential Fatty Acids. 2000;63:351-362.
Das U. Essential fatty acids: Biology and their clinical implications. Asia Pacific Journal of Pharmacology. 1991;6:317-330.
Das U N. Essential fatty acids in health and disease. Journal of the Association of Physicians of India. 1999;47:906-911. [pmid: 10778663].
Das U: Hypothesis: can glucose-insulin-potassium regimen in combination with polyunsaturated fatty acids suppress lupus and other inflammatory conditions? Prostaglandins,.Leukotrienes.and.Essential.Fatty.Acids 2001;55:
Das U. Interaction(s) between essential fatty acids, eicosanoids, cytokines, growth factors and free radicals: Relevance to new therapeutic strategies in rheumatoid arthritis and other collagen vascular diseases. Prostaglandins Leukotrienes & Essential Fatty Acids. 1991;44:201-210.
Das U N. Interaction(s) between nutrients, essential fatty acids, eicosanoids, free radicals, nitric oxide, anti-oxidants and endothelium and their relationship to human essential hypertension. Medical Science Research. 2000;28:75-83.
Das U N. The lipids that matter from infant nutrition to insulin resistance. Prostaglandins Leukotrienes & Essential Fatty Acids. 2002;67:1-12.
Das UN: Nutritional factors in the pathobiology of human essential hypertension. Nutrition 2001;139:
Daviglus M, Sheeshka J, Murkin E. Health benefits from eating fish. Comments on Toxicology. 2002;8:345-374.
de Caterina R. Omega 3 fatty acids in renal diseases. World Review of Nutrition & Dietetics. 1994;76:137-142. [pmid: 7856224].
De Caterina R, Endres S, Kristensen S D, Schmidt E B. n-3 fatty acids and renal diseases. American Journal of Kidney Diseases. 1994;24:397-415. [pmid: 8079965].
De Leeuw I H. Is there a place for N-3 fatty acids in the treatment of diabetic patients?. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 1991;4:149-153.
De Strihou C V Y. Fish oil for IgA nephropathy?. New England Journal of Medicine. 1994;331:1227-1229. [pmid: 7935665].
Dean J D, Durrington P N. Treatment of dyslipoproteinaemia in diabetes mellitus. Diabetic Medicine. 1996;13:297-312. [pmid: 9162604].
DeLuca P, Rothman D, Zurier R. Marine and botanical lipids as immunomodulatory and therapeutic agents in the treatment of rheumatoid arthritis. Rheumatic Disease Clinics of North America. 1995;21:759-777. [pmid: 8619098].
Dieleman L A, Heizer W D. Nutritional issues in inflammatory bowel disease. Gastroenterology Clinics of North America. 1998;27:435-451. [pmid: 9650026].
Diethelm U: Nutrition and chronic polyarthritis. Schweizerische Rundschau.fur Medizin Praxis 1993:359–363.
Dillon J J. Fish oil therapy for IgA nephropathy: efficacy and interstudy variability. Journal of the American Society of Nephrology. 1997;8:1739-1744. [pmid: 9355077].
Dillon J J. Treating IgA nephropathy. Journal of the American Society of Nephrology. 2001;12:846-847. [pmid: 11274247].
Donadio J V. n-3 Fatty acids and their role in nephrologic practice. Current Opinion in Nephrology & Hypertension. 2001;10:639-642. [pmid: 11496058].
Donadio J. Omega-3 polyunsaturated fatty acids: a potential new treatment of immune renal disease. Mayo Clinic Proceedings. 1991;66:1018-1028. [pmid: 1921484].
Donadio J V. Use of fish oil to treat patients with immunoglobulin a nephropathy. American Journal of Clinical Nutrition. 2000;71:5S.
Donadio J V, Bergstralh E J, Grande J P, Rademcher D M. Proteinuria patterns and their association with subsequent end-stage renal disease in IgA nephropathy. Nephrology Dialysis Transplantation. 2002;17:1197-1203.
Donadio J V, Grande J P. IgA nephropathy. New England Journal of Medicine Online. 2002;347:738-748.
Driss F, Darcet P, Lagarde M, et al. Polyunsaturated fatty acids: drug or food?. World Review of Nutrition & Dietetics. 1984;43:170-173. [pmid: 6089448].
Empey L R, Fedorak R N. Prostaglandins in inflammatory bowel disease therapy. Canadian Journal of Gastroenterology. 1993;7:173-178.
Endres S, De Caterina R, Schmidt E B, Kristensen S D. n-3 Polyunsaturated fatty acids: Update 1995. European Journal of Clinical Investigation. 1995;25:629-638. [pmid: 7498235].
Endres S, Eisenhut T, Sinha B: n-3 polyunsaturated fatty acids in the regulation of human cytokine synthesis. Biochemical.Society Transactions 1995:277–281.
Endres S, Lorenz R, Loeschke K. Lipid treatment of inflammatory bowel disease. Current Opinion in Clinical Nutrition & Metabolic Care. 1999;2:117-120. [pmid: 10453341].
Endres S, von Schacky C. n-3 polyunsaturated fatty acids and human cytokine synthesis. Current Opinion in Lipidology. 1996;7:48-52. [pmid: 8925190].
Ergas D, Eilat E, Mendlovic S, Sthoeger Z. n-3 fatty acids and the immune system in autoimmunity. Israel Medical Association Journal Imaj. 2002;4:34-38.
Ernst E. Complementary and alternative medicine in rheumatology. Best Practice & Research in Clinical Rheumatology. 2000;14:731-749.
Ernst E, Chrubasik S. Phyto-anti-inflammatories: A systemic review of randomized, placebocontrolled, double-blind trials. Rheumatic Disease Clinics of North America. 2000;26:13-27. [pmid: 10680191].
Ernst E, Nielsen G, Schmidt E. Fish oils and rheumatoid arthritis. Ugeskrift for Laeger. 1994;156:3490-3495. [pmid: 8066865].
Esteve-Comas M, Gassull M A, Jeppesen P B, Hoy C-E, Mortensen P B. Abnormal fatty acid status in patients with Crohn disease. American Journal of Clinical Nutrition. 2001;73:661-662. [pmid: 11237956].
Farmer A, Montori V, Dinneen S, Clar C: Fish oil in people with type 2 diabetes mellitus. Cochrane Database of Systematic Reviews 2001;CD003205
Farrell R J, Peppercorn M A. Ulcerative colitis. Lancet. 2002;359:331-340. [pmid: 11830216].
Feehally J. Immunoglobulin A nephropathy: fish oils and beyond. [Review] [27 refs]. Current Opinion in Nephrology & Hypertension. 1996;5:442-446. [pmid: 8937814].
Fernandes G, Venkatraman J. Role of omega-3 fatty acids in health and disease. Nutrition Research. 1993;13:S19-S45.
Feskens E J, Kromhout D. Epidemiologic studies on Eskimos and fish intake. Annals of the New York Academy of Sciences. 1993;683:9-15. [pmid: 8352476].
Fisher S E. Nutritional therapy of chronic ulcerative colitis. Journal of Pediatric Gastroenterology & Nutrition. 1993;16:224. [pmid: 8095523].
Fleming C R, Jeejeebhoy K N. Advances in clinical nutrition. Gastroenterology. 1994;106:1365-1373. [pmid: 8174895].
Floege J, Feehally J. IgA nephropathy: Recent developments. Journal of the American Society of Nephrology. 2000;11:2395-2403. [pmid: 11095664].
Floege J, Mertens P. Therapy of patients with IgA-nephropathy: a critical appraisal. Kidney & Blood Pressure Research. 2000;23:207-209. [pmid: 11031723].
Flynn M A T. Dietary fat and chronic diseases. Bahrain Medical Bulletin. 1998;20:77-80.
Fogazzi G B, Sheerin N S. IgA-associated renal diseases. Current Opinion in Nephrology & Hypertension. 1996;5:134-140. [pmid: 8744534].
Forbes A: Crohn's disease -- the role of nutritional therapy. Alimentary Pharmacology and Therapeutics 2002;
Fortin P, Lew R, Liang M, et al. Validation of a meta-analysis: The effects of fish oil in rheumatoid arthritis. Journal of Clinical Epidemiology. 1995;48:1379-1390. [pmid: 7490601].
Franz M J, Bantle J P, Beebe C A, et al. Evidence-based nutrition principles and recommendations for the treatment and prevention of diabetes and related complications. Diabetes Care. 2002;25:148-198. [pmid: 11772915].
Friedman A L. Etiology, pathophysiology, diagnosis, and management of chronic renal failure in children. Current Opinion in Pediatrics. 1996;8:147-151. [pmid: 8723809].
Friedman M, Brandon D L. Nutritional and health benefits of soy proteins. Journal of Agricultural & Food Chemistry. 2001;49:1069-1086. [pmid: 11312815].
Fung S M, Ferrill M J, Norton L L. Fish oil therapy in IgA nephropathy. Annals of Pharmacotherapy. 1997;31:112-115. [pmid: 8997477].
Garg A. Treatment of diabetic dyslipidemia. American Journal of Cardiology. 1998;81:47B-51B. [pmid: 9526814].
Garg A, Grundy SM: Treating dyslipidemia in patients with non-insulin-dependent diabetes mellitus. Cardiovascular Reviews & Reports 1988;9:30–36+39.
Gerster H. The use of n-3 PUFAs (fish oil) in enteral nutrition. International Journal for Vitamin.& Nutrition Research. 1995;65:3-20. [pmid: 7657477].
Geusens P. Lipoids: Omega-3-polyunsaturated fatty acids, their anti-inflammatory role, example of rheumatoid polyarthritis. Nutrition Clinique et Metabolisme. 1996;10:33-34.
Gibson R A. The effect of diets containing fish and fish oils on disease risk factors in humans. Australian & New Zealand Journal of Medicine. 1988;18:713-722. [pmid: 3072953].
Gil A. Polyunsaturated fatty acids and inflammatory diseases. Biomedicine & Pharmacotherapy. 2002;56:388-396.
Glassock R J. The treatment of IgA nephropathy: status at the end of the millenium. Journal of Nephrology. 1999;12:288-296. [pmid: 10630691].
Gorson D M, Tobin A, Stenson W F. Fish oil supplementation and ulcerative colitis. Annals of Internal Medicine. 1992;117:535-536. [pmid: 1503362].
Graham T O, Kandil H M. Nutritional factors in inflammatory bowel disease. Gastroenterology Clinics of North America. 2002;31:203-218. [pmid: 12122732].
Grande J P, Donadio J V. Role of dietary fish oil supplementation in IgA nephropathy. Mechanistic implications. Minerva Urologica e Nefrologica. 2001;53:201-209. [pmid: 11753248].
Grassi M, Raffa S, Damiani V C, Fontana M. Current orientation in medical management of ulcerative colitis. Clinica Terapeutica. 1995;146:327-341. [pmid: 7796565].
Griffiths A M. Inflammatory bowel disease. Nutrition. 1998;14:788-791. [pmid: 9785363].
Grimble R F. Modification of inflammatory aspects of immune function by nutrients. Nutrition Research. 1998;18:1297-1317.
Grimm H, Mayer K, Mayser P, Eigenbrodt E. Regulatory potential of n-3 fatty acids in immunological and inflammatory processes. British Journal of Nutrition. 2002;87:S59-S67. [pmid: 11895155].
Harris W S. Dietary fish oil and blood lipids. Current Opinion in Lipidology. 1996;7:3-7. [pmid: 8925185].
Hawkey CJ, Mahida YR, Hawthorne AB: Therapeutic interventions in gastrointestinal disease based on an understanding of inflammatory mediators. Agents & Actions 1992;Spec:6
Heine G, Sester U, Kohler H, et al. IgA nephropathy [3] (multiple letters). New England Journal of Medicine. 2003;348:79-81. [pmid: 12510050].
Heine R J. Dietary fish oil and insulin action in humans. Annals of the New York Academy of Sciences. 1993;683:110-121. [pmid: 8352434].
Heller A, Koch T, Schmeck J, Van Ackern C. Lipid mediators in inflammatory disorders. Drugs. 1998;55:487-496. [pmid: 9561339].
Hitchens K. Managing inflammatory bowel disease. American Druggist. 1997;214:58-65.
Hodgson H J. Keeping Crohn's disease quiet. New England Journal of Medicine. 1996;334:1599-1600. [pmid: 8628343].
Hogg R J, Waldo B. Advances in treatment: immunoglobulin A nephropathy. Seminars in Nephrology. 1996;16:511-516. [pmid: 9125795].
Horrobin D F. Essential fatty acids and the complications of diabetes mellitus. Wiener Klinische Wochenschrift. 1989;101:289-293. [pmid: 2658333].
Horrobin D: Low prevalences of coronary heart disease (CHD), psoriasis, asthma and rheumatoid arthritis in Eskimos. are they casued by high dietary intake of eicosapentaenoic acid (EPA), a genetic variation of essential fatty acid (EFA) metabolism or a combination of. Medical.Hypotheses 1987;26:
Horrobin D F. The roles of essential fatty acids in the development of diabetic neuropathy and other complications of diabetes mellitus. Prostaglandins Leukotrienes & Essential Fatty Acids. 1988;31:181-197.
Horrocks L, Keo Y. Health benefits of docosahexaenoic acid (DHA). Pharmacological Research. 1999;40:211-225. [pmid: 10479465].
Hu F B. The role of n-3 polyunsaturated fatty acids in the prevention and treatment of cardiovascular disease. Drugs of Today. 2001;37:49-56. [pmid: 12783097].
Hu F B, van Dam R M, Liu S. Diet and risk of Type II diabetes: the role of types of fat and carbohydrate. [Review] [111 refs]. Diabetologia. 2001;44:805-817. [pmid: 11508264].
Hubbard R, Mejia A, Horning M. The potential of diet to alter disease processes. Nutrition Research. 1994;14:1853-1895.
Hummell D S. Dietary lipids and immune function. Progress in Food & Nutrition Science. 1993;17:287-329. [pmid: 8140252].
Illingworth D R. N-3 fatty acids and prevention of atherosclerosis. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 1989;2:71-81.
Ilowite N T. Hyperlipidemia and the rheumatic diseases. Current Opinion in Rheumatology. 1996;8:455-458. [pmid: 8941449].
Imai E, Kawamura T. Current therapeutic strategies for IgA nephropathy. Current Opinion in Cardiovascular, Pulmonary & Renal Investigational Drugs. 2000;2:330-338.
Ioannou Y, Isenberg D. Current concepts for the management of systemic lupus erythematosus in adults: A therapeutic challenge. Postgraduate Medical Journal. 2002;78:599-606. [pmid: 12415083].
Isseroff R. Fish again for dinner! the role of fish and other dietary oils in the therapy of skin disease. Journal.of.the.American.Academy.of.Dermatology. 1988;19:1073-80. [pmid: 3060485].
James M, Cleland L. Dietary n-3 fatty acids and therapy for rheumatoid arthritis. Seminars in Arthritis & Rheumatism. 1997;27:85-97. [pmid: 9355207].
James M J, Cleland L G, Gibson R A, Hawkes J S. Strategies for increasing the antiinflammatory effect of fish oil. Prostaglandins Leukotrienes & Essential Fatty Acids. 1991;44:123-126.
James M, Gibson R, Cleland L. Dietary polyunsaturated fatty acids and inflammatory mediator production. American Journal of Clinical Nutrition. 2000;71:343S-348S. [pmid: 10617994].
Jensen T. Dietary supplementation with omega-3 fatty acids in insulin-dependent diabetes mellitus, in Simopoulos AP, Kifer RR, Martin RE, Barlow SM (eds). Health effects of omega-3 polyunsaturated fatty acids in seafoods. Basel, Karger, World Rev Nutr Diet;1991:417-424.
Jensen T. Dietary supplementation with omega 3 fatty acids in insulin-dependent diabetes mellitus. World Review of Nutrition & Dietetics. 1991;66:417-424. [pmid: 2053358].
Jorquera Plaza F, Espinel Diez J, Olcoz Goni J L. Inflammatory bowel disease: importance of nutrition today]. Nutricion Hospitalaria. 1997;12:289-298. [pmid: 9477654].
Julian B A. Treatment of IgA nephropathy. Seminars in Nephrology. 2000;20:277-285. [pmid: 10855937].
Julian B A, Bake A W L. Treatment options in IgA nephropathy. Nephrology. 1997;3:103-108.
Kasim S E. Dietary marine fish oils and insulin action in type 2 diabetes. Annals of the New York Academy of Sciences. 1993;683:250-257. [pmid: 8352447].
Katsilambros N L. Nutrition in diabetes mellitus. Experimental & Clinical Endocrinology & Diabetes. 2001;109:8. [pmid: 11573131].
Katz S. Update in medical therapy in inflammatory bowel disease: A clinician's view. Digestive Diseases. 1999;17:163-171. [pmid: 10697665].
Kehn P, Fernandes G. The importance of omega-3 fatty acids in the attenuation of immune-mediated diseases. Journal of Clinical Immunology. 2001;21:99-101. [pmid: 11332659].
Kelly D G, Fleming C R. Nutritional considerations in inflammatory bowel diseases. Gastroenterology Clinics of North America. 1995;24:597-611. [pmid: 8809238].
Kelly G S. Insulin resistance: Lifestyle and nutritional interventions. Alternative Medicine Review. 2000;5:109-132. [pmid: 10767668].
Kettler D. Can manipulation of the ratios of essential fatty acids slow the rapid rate of postmenopausal bone loss?. Alternative Medicine Review. 2001;6:61-77. [pmid: 11207457].
Kim Y I. Can fish oil maintain Crohn's disease in remission?. Nutrition Reviews. 1996;54:248-252. [pmid: 8961753].
Korelitz BI: Ulcerative colitis: Guidelines for optimal treatment. Drug Therapy 1993;23:43–44+47.
Koretz RL: Maintaining remissions in Crohn's disease. a fat chance to please. Gastroenterology 1997;112:
Korstanje M, Bilo H, Peltenburg H, Stoof T. Fish-oil; food or drug?. Nederlands Tijdschrift voor Geneeskunde. 1991;135:828-833. [pmid: 1828538].
Kremer J. Clinical studies of omega-3 fatty acid supplementation in patients who have rheumatoid arthritis. Rheumatic Disease Clinics of North America. 1991;17:391-402. [pmid: 1862247].
Kremer J. Effects of modulation of inflammatory and immune parameters in patients with rheumatic and inflammatory disease receiving dietary supplementation of n-3 and n-6 fatty acids. Lipids. 1996;31:S243-S247. [pmid: 8729127].
Kremer J. n-3 Fatty acid supplements in rheumatoid arthritis. American Journal of Clinical Nutrition. 2000;71:349S-351S. [pmid: 10617995].
Kremer J M, Robinson D R. Studies of dietary supplementation with omega-3 fatty acids in patients with rheumatoid arthritis, in Simopoulos AP, Kifer RR, Martin RE, Barlow SM (eds). Health effects of omega-3 polyunsaturated fatty acids in seafoods. Basel, Karger, World Rev Nutr Diet;1991:367-382.
Kubitschek J. Cardiovascular diseases: Fish oil improved arterial compliance in 20 patients with type II diabetes mellitus. Deutsche Apotheker Zeitung. 1995;135:69.
Kyriakopoulos A: Rheumatoid arthritis and fish oil. Annals of Internal Medicine 1987:941-
Lackey V A, Noble T A. Omega-3 fatty acid supplementation in noninsulin-dependent diabetes. DICP. 1990;24:258-260. [pmid: 2316234].
Landgraf R. PUFA supplementation and hypertension in type 1 diabetes. Annals of the New York Academy of Sciences. 1993;683:331-336. [pmid: 8352455].
Larkin J. Alternative medicine and rheumatoid arthritis. Rheumatology Review. 1994;3:61-71.
Lau C, Gallacher C, Ross P, Belch J. Rheumatoid arthritis: Fish oil? or snake oil?. British Journal of Rheumatology. 1991;30:72-73. [pmid: 1991228].
Le Goff P, Baron D, Youinou P. Effects of dietary modification with fatty acids in rheumatoid arthritis. Rhumatologie. 1992;44:145-149.
Lee T, Arm J. Benefits from oily fish. May help in coronary artery disease and several inflammatory conditions. BMJ.British Medical Journal. 1988;297:1421-1422.
Lefebvre P J, Scheen A J. Management of non-insulin-dependent diabetes mellitus. Drugs. 1992;44:29-38. [pmid: 1280575].
Lichenstein G R. Medical therapies for inflammatory bowel disease. Current Opinion in Gastroenterology. 1994;10:390-403.
Lichtenstein A H, Schwab U S. Relationship of dietary fat to glucose metabolism. Atherosclerosis. 2000;150:227-243. [pmid: 10856515].
Lin C-Y. Treatment of IgA nephropathy. Springer Seminars in Immunopathology. 1994;16:121-127. [pmid: 7997942].
Ling S, Griffiths A. Nutrition in inflammatory bowel disease. Current Opinion in Clinical Nutrition & Metabolic Care. 2000;3:339-344. [pmid: 11151077].
Linn F V, Peppercorn M A. Drug therapy for inflammatory bowel disease: Part II. American Journal of Surgery. 1992;164:178-185. [pmid: 1636900].
Locatelli F, Pozzi C, Del Vecchio L, et al. New therapeutic approaches in primary IgA nephropathy. Advances in Nephrology From the Necker Hospital. 1999;29:73-91. [pmid: 10561738].
Lombard L, Augustyn M N, Ascott-Evans B H. The metabolic syndrome - Pathogenesis, clinical features and management. Cardiovascular Journal of Southern Africa. 2002;13:181-186.
Lorenz R, Loeschke K. Placebo-controlled trials of omega 3 fatty acids in chronic inflammatory bowel disease. World Review of Nutrition & Dietetics. 1994;76:143-145. [pmid: 7856225].
Malasanos T H, Stacpoole P W. Biological effects of omega-3 fatty acids in diabetes mellitus. Diabetes Care. 1991;14:1160-1179. [pmid: 1773702].
Mangge H, Hermann J, Schauenstein K. Diet and rheumatoid arthritis A review. Scandinavian Journal of Rheumatology. 1999;28:201-209. [pmid: 10503555].
Mazieres B, Cantagrel A. Rheumatoid arthritis. Modern treatments. European Journal of Internal Medicine, Supplement. 1992;3:91-101.
McCarthy G M, Kenny D. Dietary fish oil and rheumatic diseases. Seminars in Arthritis & Rheumatism. 1992;21:368-375. [pmid: 1626282].
McCarty M F. A central role for protein kinase C overactivity in diabetic glomerulosclerosis: implications for prevention with antioxidants, fish oil, and ACE inhibitors. Medical Hypotheses. 1998;50:155-165. [pmid: 9572571].
McCarty M F. Complementary measures for promoting insulin sensitivity in skeletal muscle. Medical Hypotheses. 1998;51:451-464. [pmid: 10052864].
McCarty M: Upregulation of lymphocyte apoptosis as a strategy for preventing and treating autoimmune disorders: a role for whole-food vegan diets, fish oil and dopamine agonists. Medical.Hypotheses 2001;
McCarty M, Russell A: Niacinamide therapy for osteoarthritis--does it inhibit nitric oxide synthase induction by interleukin 1 in chondrocytes? Medical Hypotheses 1999:350–360.
McCowen K C, Pei Ra Ling, Bistrian B R, Jeppesen P B, Hoy C-E, Mortensen P B. Arachidonic acid concentrations in patients with Crohn disease [1] (multiple letters). American Journal of Clinical Nutrition. 2000;71:1008-1009. [pmid: 10731511].
Meier R. Chronic inflammatory bowel diseases and nutrition. Schweizerische Medizinische Wochenschrift - Supplementum. 1996;79:14S-24S. [pmid: 8701255].
Meletis C, Bramwell B. Rheumatoid arthritis. Etiology and naturopathic treatments. Alternative & Complementary Therapies. 2001;7:347-354.
Meltzer E, Arber N. Inflammatory bowel disease - Current and future medical therapy. Ceska a Slovenska Gastroenterologie. 2000;54:187-195.
Mera S L. Diet and disease. British Journal of Biomedical Science. 1994;51:189-206. [pmid: 7881318].
Messina M. Legumes and soybeans: overview of their nutritional profiles and health effects. American Journal of Clinical Nutrition. 1999;70:450S.
Messina M. Soy foods and soybean isoflavones and menopausal health. Nutrition in Clinical Care. 2002;5:272-82. [pmid: 12557810].
Miller M L. Treatment of systemic lupus erythematosus in adults and children. Current Opinion in Rheumatology. 1990;2:712-716. [pmid: 2265068].
Milly Tand, Simoncic R. Is fish oil supplementation (n-3 fatty acids) important for the diabetic?. Bratislavske Lekarske Listy. 1993;94:521-525. [pmid: 8004470].
Montori V M, Farmer A, Wollan P C. Dinneen SF: Fish oil supplementation in type 2 diabetes: a quantitative systematic review. Diabetes Care. 2000;23:1407-1415. [pmid: 10977042].
Murch S H, Walker-Smith J A. Medical management of chronic inflammatory bowel disease. Baillieres Clinical Gastroenterology. 1994;8:133-148.
Murch S H, Walker-Smith J A. Nutrition in inflammatory bowel disease. Baillieres Clinical Gastroenterology. 1998;12:719-738.
Murphy N G, Zurier R B. Treatment of rheumatoid arthritis. Current Opinion in Rheumatology. 1991;3:441-448. [pmid: 1883697].
Murray F: Fish oils in rheumatoid arthritis. Lancet 1987: 1157–1158.
Mutanen M, Freese R. Fats, lipids and blood coagulation. Current Opinion in Lipidology. 2001;12:25-29. [pmid: 11176199].
Nestel P J. Polyunsaturated fatty acids (n-3, n-6). American Journal of Clinical Nutrition. 1987;45:1161-7. [pmid: 3554967].
Nolin L, Courteau M. Management of IgA nephropathy evidence-based recommendations. Kidney International - Supplement. 1999;70:S56-S62. [pmid: 10369196].
Nosari I, Cortinovis F, Lepore G, Maglio M L, Pagani G. Utilization of omega-3 fatty acids in diabetic patients. [Italian]. Clinica Terapeutica. 1994;144:213-221. [pmid: 8181217].
O'Morain C, Tobin A, McColl T, Suzuki Y. Fish oil in the treatment of ulcerative colitis. Canadian Journal of Gastroenterology. 1990;4:420-423.
O'Morain C A. Nutritional therapy in ambulatory patients. Digestive Diseases & Sciences. 1987;32:95S-99S. [pmid: 2826093].
Okuyama H, Kobayashi T, Watanabe S: Dietary fatty acids - the N-6/N-3 balance and chronic elderly diseases. Excess linoleic acid and relative N-3 deficiency syndrome seen in Japan. Progress in Lipid Research 1996;
Palmblad J. Omega3 and omega6 fatty acids and inflammation. Scandinavian Journal of Nutrition/Naringsforskning. 1996;40:125-128.
Pan C G. Glomerulonephritis in childhood. Current Opinion in Pediatrics. 1997;9:154-159. [pmid: 9204243].
Panush R: Nutritional therapy for rheumatic diseases. Annals of Internal Medicine 1987:619–621.
Parke A L. Gastrointestinal disorders and rheumatic diseases. Current Opinion in Rheumatology. 1993;5:79-84. [pmid: 8435293].
Patavino T, Brady D M. Natural medicine and nutritional therapy as an alternative treatment in systemic lupus erythematosus. Alternative Medicine Review. 2001;6:460-471. [pmid: 11703166].
Peet M, Edwards R W. Lipids, depression and physical diseases. Current Opinion in Psychiatry. 1997;10:477-480.
Pelton R. Treating arthritis naturally. American Druggist. 1999;216:60-62.
Peppercorn M A. Advances in drug therapy for inflammatory bowel disease. Annals of Internal Medicine. 1990;112:50-60. [pmid: 2152845].
Pepping J. Omega-3 essential fatty acids. Am J Healht-Syst Pharm. 1999;56:719-724.
Peterson D B. Long-chain fatty acids and cardiovascular disease risk in non-insulin-dependent diabetes. Nutrition. 1998;14:316-318. [pmid: 9583379].
Petri M. Diet and systemic lupus erythematosus: From mouse and monkey to woman?. Lupus. 2001;10:775-777. [pmid: 11789485].
Pike M: Antiinflammatory effects of dietary lipid modification. Journal of Rheumatology 1989:718–720.
Podell R N. Nutritional treatment of rheumatoid arthritis. Can alterations in fat intake affect disease course?. Postgraduate Medicine. 1985;77:65-72. [pmid: 3991393].
Podolsky D K. Inflammatory bowel disease. New England Journal of Medicine. 2002;347:417-429. [pmid: 12167685].
Popova D. The diet in diabetes mellitus - Composition and comparative analysis. Bulgarian Medicine. 1997;5:32-34.
Popp-Snijders C, Bilo H J, Heine R J. Fish oil and glycemic control: importance of dose. Diabetes Care. 1990;13:80-81. [pmid: 2298115].
Popp-Snijders C, Schouten J A, Heine R J, van der Veen E A. Dietary (n-3) polyunsaturated fatty acids lower plasma triacyglycerol concentrations in non-insulin-dependent diabetes mellitus. Atherosclerosis. 1986;61:253-256. [pmid: 3768093].
Prince M J, Deeg M A. Do n-3 fatty acids improve glucose tolerance and lipemia in diabetics?. Current Opinion in Lipidology. 1997;8:7-11. [pmid: 9127704].
Prokhorovich E A, Zharov E I, Martynov A I, Vertkin A L, Martynov D A, Svetova Iu B. An experimental and clinical study of the biological action of marine fish fats. Kardiologiia. 1990;30:99-102. [pmid: 2123953].
Raccah D, Coste T, Gerbi A, Vague P. Polyunsatured fatty acids and diabetes. Cahiers de Nutrition et de Dietetique. 1997;32:349-358.
Rachmilewitz D. New forms of treatment for inflammatory bowel disease. Gut. 1992;33:1301-1302. [pmid: 1446848]. [pmcid: 1379592].
Raheja B S, Sadikot S M, Phatak R B. Insulin resistance in syndrome X. Lancet. 1993;342:554-555. [pmid: 8102689].
Raheja B S, Sadikot S M, Phatak R B, Rao M B. Significance of the N-6/N-3 ratio for insulin action in diabetes. Annals of the New York Academy of Sciences. 1993;683:258-271. [pmid: 8352448].
Rampton D S. New drugs for inflammatory bowel disease. European Journal of Internal Medicine. 1996;7:141-148.
Rapport L, Lockwood B. (5) flaxseed and flaxseed oil. Pharmaceutical Journal. 2001;266:287-289.
Rebstock W. Modern concepts in therapy of glomerulonephritis. Nieren- und Hochdruckkrankheiten. 1998;27:258-261.
Rhodes J, Thomas G, Evans B K. Inflammatory bowel disease management. Some thoughts on future drug developments. Drugs. 1997;53:189-194. [pmid: 9028740].
Richter B, Clar C, Berger M. The Cochrane collaboration and its possible impact on diabetes care. Diabetes Care. 2000;23:1217-1218. [pmid: 10977007].
Richter W O, Bertsch S, Muller S-D. Omega-3 fatty acids in diabetic hypertriglyceridemia. Deutsche Apotheker Zeitung. 2001;141:43-62.
Ringertz B: Dietary treatment of rheumatoid arthritis. Annals of Medicine 1991:
Rivellese A A. Monounsaturated and marine omega-3 fatty acids in NIDDM patients. Annals of the New York Academy of Sciences. 1997;827:302-309. [pmid: 9329763].
Robin J: Potential value of eicosapentaenoic acid. Allergie.et Immunologie. 1987:13
Rodgers J: n-3 Fatty acids in the treatment of ulcerative colitis, in Anonymous Medicinal Fatty Acids in Inflammation. Basel, Birkhauser Verlag; 1998:103–109.
Roediger W E W. Dietary therapy for Crohn's and ulcerative colitis: The importance of fatty acids and sulphur amino acids. Cme Journal Gastroenterology, Hepatology & Nutrition. 2001;4:55-57.
Rombeau J L. Nutritional-metabolic aspects of inflammatory bowel disease. Current Opinion in Gastroenterology. 1993;9:566-570.
Ross E. The role of marine fish oils in the treatment of ulcerative colitis. Nutrition Reviews. 1993;51:47-49. [pmid: 8455803].
Rostoker G. Therapy of IgA nephropathy. Biodrugs. 1998;9:279-301. [pmid: 18020566].
Rubba P, Iannuzzi A. N-3 to n-6 fatty acids for managing hyperlipidemia, diabetes, hypertension and atherosclerosis: is there evidence?. European Journal of Lipid Science and Technology. 2001;103:407-418.
Rustan A C, Nenseter M S, Drevon C A. Omega-3 and omega-6 fatty acids in the insulin resistance syndrome. Lipid and lipoprotein metabolism and atherosclerosis. Annals of the New York Academy of Sciences. 1997;827:310-326. [pmid: 9329764].
Sadikot S M. Diabetes, obesity and insulin resistance/hyperinsulinemia. Journal of the Diabetic Association of India. 1993;33:62-74.
Sanderson I R. Diet and gut inflammation. Current Opinion in Gastroenterology. 1997;13:518-524.
Sarkkinen E, Uusitupa M: The role of fish oil in the prevention and treatment of diseases. Duodecim 1996:1755–1763.
Sasinka M, Filka J, Podracka L, Roland R, Gayova E, Vargova V. Does non-immunological therapy and diet determining factors in the treatment of autoimmune diseases?. Vnitrni Lekarstvi. 1992;38:1018-1027. [pmid: 1481369].
Schacky Cvon, Von Schacky C: Omega-3 fatty acids, Mediterranean diet, low-fat diet -- what actually does protect against myocardial infarction? MMW Fortschritte der Medizin 2002;3–4, 37.
Scheinman J I, Trachtman H, Lin C-Y, Langman C B, Chan J C M. IgA nephropathy. To treat or not to treat?. Nephron. 1997;75:251-258. [pmid: 9069444].
Schmidt E B, Dyerberg J. Omega-3 fatty acids. Current status in cardiovascular medicine. Drugs. 1994;47:405-424. [pmid: 7514972].
Schmitz P G, Antony K A. Omega-3 fatty acids in ESRD: Should patients with ESRD eat more fish?. Nephrology Dialysis Transplantation. 2002;17:11-14.
Seidman E, LeLeiko N, Ament M, et al. Nutritional issues in pediatric inflammatory bowel disease. Journal of Pediatric Gastroenterology & Nutrition. 1991;12:424-438. [pmid: 1678007].
Sewell K L. Immunotherapy and other novel therapies, including biologic response modifiers, apheresis, and dietary modifications. Current Opinion in Rheumatology. 1993;5:293-298. [pmid: 7685614].
Siguel E. Deficiencies and abnormalities of essential fats in gastrointestinal and coronary artery disease. Journal of Clinical Ligand Assay. 2000;23:104-111.
Silvis N. Nutritional recommendations for individuals with diabetes mellitus. South African Medical Journal. 1992;81:162-166. [pmid: 1734559].
Simopoulos A. Essential fatty acids in health and chronic disease. American Journal of Clinical Nutrition. 1999;70:560S-569S. [pmid: 10479232].
Simopoulos A. The importance of the ratio of omega-6/omega-3 essential fatty acids. Biomedicine & Pharmacotherapy. 2002;56:365-379.
Simopoulos A. Omega-3 fatty acids in health and disease and in growth and development. American Journal of Clinical Nutrition. 1991;54:438-463. [pmid: 1908631].
Simopoulos A. Omega-3 fatty acids in inflammation and autoimmune diseases. Journal of the American College of Nutrition. 2002;21:495-505. [pmid: 12480795].
Simopoulos A P. Omega-6/omega-3 fatty acid ratio and trans fatty acids in non-insulin-dependent diabetes mellitus. Annals of the New York Academy of Sciences. 1997;827:327-338. [pmid: 9329765].
Simopoulos AP, Kifev RR, Martin RE, Barlow SM: Health effects of omega-3 polyunsaturated fatty acids in seafoods. World Review of Nutrition and Dietetics 1991;xxiv-
Sinclair H M. Food fats, good and bad. British Journal of Clinical Practice. 1987;41:1033-1036. [pmid: 3332841].
Sinclair R. Good, bad or essential fats: what is the story with Omega-3?. Nutrition.and.Food.Science. 2000;9:4-5.
Sirtori C R, Galli C. N-3 fatty acids and diabetes. Biomedicine & Pharmacotherapy. 2002;56:397-406.
Socha P, Ryzko J. Application of fish oil to the treatment of inflammatory bowel disease. Pediatria Polska. 1998;73:929-935.
Sorisky A, Robbins D C. Fish oil and diabetes. The net effect. Diabetes Care. 1989;12:302-304. [pmid: 2651056].
Spencer-Green G. Drug treatment of arthritis: Update on conventional and less conventional methods. Postgraduate Medicine. 1993;93:129-140. [pmid: 8493195].
Sperling R I. Dietary omega-3 fatty acids: Effects on lipid mediators of inflammation and rheumatoid arthritis. Rheumatic Disease Clinics of North America. 1991;17:373-389. [pmid: 1862246].
Sperling R I. Diet therapy in rheumatoid arthritis. Current Opinion in Rheumatology. 1989;1:33-38. [pmid: 2701663].
Sperling R: Eicosanoids in rheumatoid arthritis. Rheumatic Diseases Clinics of North America 1995:741–758.
Stein Gand, Funfstuck R. (omega)3-Unsaturated fatty acids in the treatment of mesangioproliferative glomerulonephritis?. Nieren- und Hochdruckkrankheiten. 1997;26:353-356.
Stenson W F, Alpers D H. Nutritional therapy in inflammatory bowel disease: A historical overview. Current Opinion in Gastroenterology. 1997;13:135-139.
Stoll B A. Essential fatty acids, insulin resistance, and breast cancer risk. Nutrition & Cancer. 1998;31:72-77. [pmid: 9682252].
Stone N J. Fish consumption, fish oil, lipids, and coronary heart disease. Circulation. 1996;94:2337-2340. [pmid: 8901708].
Swinburn B A. Effect of dietary lipid on insulin action. Clinical studies. Annals of the New York Academy of Sciences. 1993;683:102-109. [pmid: 8352433].
Teitelbaum J E, Walker W A. Review: The role of omega 3 fatty acids in intestinal inflammation. Journal of Nutritional Biochemistry. 2001;12:21-32. [pmid: 11179858].
Tidow-Kebritchi S. Effects of diets containing fish oil and vitamin E on rheumatoid arthritis. Nutrition Reviews. 2001;59:335-338. [pmid: 11669239].
Topping D L, Illman R J, Storer G B. Dietary (n-3) polyunsaturated fatty acids and the control of hypertriglyceridaemia in insulin-dependent and insulin-independent diabetics. Atherosclerosis. 1986;61:255-256. [pmid: 3516164].
Trentham D E. Novel therapies. Current Opinion in Rheumatology. 1990;2:506-509. [pmid: 2203433].
Tritos N A, Mantzoros C S. Clinical Review 97: Syndromes of severe insulin resistance. Journal of Clinical Endocrinology & Metabolism. 1998;83:3025-3030. [pmid: 9745395].
Tulleken J, van Rijswijk M. Fish oil in the treatment of rheumatoid arthritis patients. Nederlands Tijdschrift voor Geneeskunde. 1988;132:1875-1877. [pmid: 2847060].
Van Der Merwe C F. A different and physiological approach to manipulating the inflammatory response. European Journal of Gastroenterology & Hepatology. 1993;5:433-436.
van Riel P L C M, van de Putte L B A. Clinical assessment and clinical trials in rheumatoid arthritis. Current Opinion in Rheumatology. 1994;6:132-139. [pmid: 8024957].
van Ypersele de Strihou. Fish oil for IgA nephropathy?. New England Journal of Medicine. 1994;331:1227-1229. [pmid: 7935665].
Velardo B, Lagarde M, Guichardant M, et al. Decrease of platelet activity after intake of small amounts of eicosapentaenoic acid in diabetics. Thrombosis & Haemostasis. 1982;48:344. [pmid: 6298968].
Vergroesen A J. Physiological effects of dietary linoleic acid. Nutrition Reviews. 1977;35:1-5. [pmid: 840443].
Vessby B. Dietary supplementation with N-3 polyunsaturated fatty acids in type 2 diabetes. Effects on glucose homeostasis. Annals of the New York Academy of Sciences. 1993;683:244-249. [pmid: 8352446].
Vessby B: Effects of omega-3 fatty acids on glucose and lipid metabolism in non-insulin-dependent diabetes mellitus, in Simopoulos AP, Kifer RR, Martin RE, Barlow SM (eds): Health effects of omega-3 polyunsaturated fatty acids in seafoods. Basel, Karger, World Rev Nutr Diet; 1991:407–416.
Vessby B. Effects of omega 3 fatty acids on glucose and lipid metabolism in non-insulin-dependent diabetes mellitus. World Review of Nutrition & Dietetics. 1991;66:407-416. [pmid: 2053357].
Vessby B. n-3 fatty acids and blood glucose control in diabetes mellitus. Journal of Internal Medicine Supplement. 1989;225:207-210. [pmid: 2650692].
Wardle E. Fish oils and glomerulonephritis. Nephrology Dialysis Transplantation. 2002;17:2033.
Wardle E N. Fish oils and nephritis or hypertension. Nephron. 1987;46:399. [pmid: 3658075].
Wardle E N. IgA nephropathy To treat or not to treat?. Nephron. 1998;79:221. [pmid: 9647506].
Wasielewski S. Fewer relapses in Crohn's disease with fish-oil capsules?. Deutsche Apotheker Zeitung. 1996;136:37-39.
Watkins B, Li Y, Lippman H, Seifert M. Omega-3 polyunsaturated fatty acids and skeletal health. Experimental Biology & Medicine. 2001;226:485-497. [pmid: 11395919].
Wilhelmi G: Potential effects of nutrition including additives on healthy and arthrotic joints. I. Basic dietary constituents. Zeitschrift fur Rheumatologie 1993:174–179.
Williams C N. Special issues in nutritional therapy of inflammatory bowel disease. Canadian Journal of Gastroenterology. 1993;7:196-199.
Wolf J M, Lashner B A. Inflammatory bowel disease: sorting out the treatment options. Cleveland Clinic Journal of Medicine. 2002;69:621-626. [pmid: 12184470].
Woo K T. IgA nephritis: a review of the pathogenetic mechanisms and the rationale for therapy. Annals of the Academy of Medicine, Singapore. 1989;18:702-706. [pmid: 2560358].
Yen P: Fish facts. Geriatric Nursing 1993:52–53.
Yetiv J. Clinical applications of fish oils. Journal of the American Medical Association. 1988;260:665-670. [pmid: 3292794].
Yoshikawa N, Iijima K, Ito H. IgA nephropathy in children. Nephron. 1999;83:1-12. [pmid: 10461030].
Yoshikawa N, Tanaka R, Iijima K. Pathophysiology and treament of lgA nephropathy in children. Pediatric Nephrology. 2001;16:446-457. [pmid: 11405121].
Young R J, Vanderhoof J A. Nutrition in pediatric inflammatory bowel disease. Nutrition. 2000;16:78-80. [pmid: 10674247].
Yunus M B. Investigational therapy in rheumatoid arthritis: A critical review. Seminars in Arthritis & Rheumatism. 1987;17:163-184.
Zachos M, Griffiths A M. Enteral feeding and Crohn disease. Current Opinion in Gastroenterology. 2001;17:167-170. [pmid: 11224674].
Ziboh V, Gershwin M, German J, Keen C: Nutritional modulation of inflammation by polyunsaturated fatty acids/eicosanoids. Nutrition.and.immunology:.principles.and.practice 2000;81:-
Zimmerman K F, Schlesinger P A, Bloss T J, Stillman M T. Fish-oil supplementation and rheumatoid arthritis. Annals of Internal Medicine. 1987;107:262-263. [pmid: 3605917].
Zimmerman R, Radhakrishnan J, Valeri A, Appel G. Advances in the treatment of lupus nephritis. Annual Review of Medicine. 2001;52:63-78. [pmid: 11160768].
Zurier B. Essential fatty acids and inflammation. Annals of the Rheumatic Diseases. 1991;50:745-746. [pmid: 1772287]. [pmcid: 1004548].

### Rejected Inappropriate Study Design

Adler A I, Boyko E J, Schraer C D, Murphy N J. Lower prevalence of impaired glucose tolerance and diabetes associated with daily seal oil or salmon consumption among Alaska natives. Diabetes Care. 1994;17:1498-1501. [pmid: 7882827].
Albrink M J Ullrich I H Blehschmidt N GThe beneficial effect of fish oil supplements on serum lipids and clotting functions of patients with type II diabetes mellitus Diabetes 19863543A
Almallah Y Z, Ewen S W, Mowat N A G, et al. Immunohistological modulation after nutritional supplementation with omega-3 essential fatty acids in patients with inflammatory bowel disease. British Journal of Surgery. 1998;85:690-691.
Almallah Y Z, et al. Eicosapentaenoic acid and docosahexaenic acid in the treatment of patients with distal procto-colitis. British Journal of Surgery. 1996;83:2.
Anderson J, Blake J E, Turner J, Smith B. Effects of soy protein on renal function and proteinuria in patients with type 2 diabetes. Am J Clin Nutr. 1998;68:1347S-1353S. [pmid: 9848497].
Arslan G, Brunborg L A, Froyland L, Brun J G, Valen M, Berstad A. Effects of duodenal seal oil administration in patients with inflammatory bowel disease. Lipids. 2002;37:935-940. [pmid: 12530551].
Bagdade J D, Buchanan W E, Levy R A, Subbaiah P V, Ritter M C. Effects of omega-3 fish oils on plasma lipids, lipoprotein composition, and postheparin lipoprotein lipase in women with IDDM. Diabetes. 1990;39:426-431. [pmid: 2318345].
Bagdade J D, Ritter M, Subbaiah P V. Marine lipids normalize cholesteryl ester transfer in IDDM. Diabetologia. 1996;39:487-491. [pmid: 8778000].
Bakker D J, Haberstroh B N, Philbrick D J, Holub B J. Triglyceride lowering in nephrotic syndrome patients consuming a fish oil concentrate. Nutrition Research. 1989;9:27-34.
Belluzzi A, Brignola C, Campieri M, et al: A new enteric coated preparation of omega 3 fatty acids for preventing post-surgical recurrence in Crohn's disease. Digestive Disease Week 1997;(Abstract)
Bilo H J G, Schaap G H, Slagt M E, Popp-Snijders C, Oe P L, Donker A J M. Protein intake variation and omega-3 polyunsaturated fatty acids do not influence carbohydrate metabolism in patients with chronic renal insufficiency. Current Therapeutic Research, Clinical & Experimental. 1988;44:292-303.
Bjerve K S, Brubakk A M, Fougner K J, Johnsen H, Midthjell K, Vik T. Omega-3 fatty acids: essential fatty acids with important biological effects, and serum phospholipid fatty acids as markers of dietary omega 3-fatty acid intake. American Journal of Clinical Nutrition. 1993;57:801S-806S. [pmid: 8475898].
Branten A J W, Klasen I S, Wetzels J F M, et al. Short-term effects of fish oil treatment on urinary excretion of high- and low-molecular weight proteins in patients with IgA nephropathy. Clinical Nephrology. 2002;58:267-274. [pmid: 12400841].
Butani L, Palmer J. Effect of fish oil in a patient with post-transplantation IgA nephropathy. Nephrology Dialysis Transplantation. 2000;15:1264-1265.
Byars M, Watson J, McGill P. Blackcurrant seed oil as a source of polyunsaturated fatty acids in the treatment of inflammatory disease. Biochemical Society Transactions. May. 1992;20:139S. [pmid: 1397534].
Chan P C, Chan K W, Cheng I K, Chan M K. Focal sclerosing glomerulopathy. Risk factors of progression and optimal mode of treatment. International Urology & Nephrology. 1991;23:619-629. [pmid: 1769795].
Chen Y D, Swami S, Skowronski R, Coulston A M, Reaven G M. Effect of variations in dietary fat and carbohydrate intake on postprandial lipemia in patients with noninsulin dependent diabetes mellitus. Journal of Clinical Endocrinology & Metabolism. 1993;76:347-351. [pmid: 8432777].
Cheng I K, Chan P C, Chan M K. The effect of fish-oil dietary supplement on the progression of mesangial IgA glomerulonephritis. Nephrology Dialysis Transplantation. 1990;5:241-246.
Chowdhury Md N, Rashid H U, Rahman H, Jahan S S, Alam M R, Iqbal M. Effect of hilsha fish oil on lipid profile in patients with nephrotic syndrome. Bangladesh Renal Journal. 2001;20:14-19.
Christensen J H, Skou H A, Madsen T, Torring I, Schmidt E B. Heart rate variability and n-3 polyunsaturated fatty acids in patients with diabetes mellitus. Journal of Internal Medicine. 2001;249:545-552. [pmid: 11422661].
Clark W, Parbtani A, Huff M, Reid B, Holub B J, Falardeau P. Omega-3 fatty acid dietary supplementation in systemic lupus erythematosus. Kidney International. 1989;36:653-660. [pmid: 2811063].
Clark W, Parbtani A, Huff M, et al. Flaxseed: a potential treatment for lupus nephritis. Kidney International. 1995;48:475-480. [pmid: 7564115].
Cleland LG, Gibson RA, Neumann M, French JK: The effect of dietary fish oil supplement upon the content of dihomo-gammalinolenic acid in human plasma phospholipids. Prostaglandins Leukotrienes & Essential Fatty Acids 1990;40:12-Sep
D'Amico G, Gentile M G. Effect of dietary manipulation on the lipid abnormalities and urinary protein loss in nephrotic patients. Mineral & Electrolyte Metabolism. 1992;18:203-206. [pmid: 1465059].
Das U. Beneficial effect of eicosapentaenoic and docosahexaenoic acids in the management of systemic lupus erythematosus and its relationship to the cytokine network. Prostaglandins Leukotrienes & Essential Fatty Acids. 1994;51:207-213.
De Caterina R, Caprioli R, Giannessi D, et al. n-3 fatty acids reduce proteinuria in patients with chronic glomerular disease. Kidney International. 1993;44:843-850. [pmid: 8258959].
Dichi I, Dichi J B, Frenhane P, Rodrigues M A, Burini R C, Victoria C R. Reactivation of ulcerative rectocolitis with the use of non-steroidal anti-inflammatory drugs. Report of a case and review of the literature. Arquivos de Gastroenterologia. 1995;32:172-177. [pmid: 8734853].
Dichi I, Dichi J B, Frenhane P, Rodrigues M A M, Burini R C, Victoria C R. Ulcerative colitis associated with non-steroidal anti-inflammatory drug. Report of a case and review of the literature. Arquivos de Gastroenterologia. 1995;32:730-735. [pmid: 8734853].
Donadio J V Jr, Grande J P, et al. The long-term outcome of patients with IgA nephropathy treated with fish oil in a controlled trial. Mayo Nephrology Collaborative Group. Journal of the American Society of Nephrology. 1999;10:1772-1777. [pmid: 10446945].
Donnelly J P, McGrath L T, Brennan G M. Lipid peroxidation, LDL glycosylation and dietary fish oil supplementation in type II diabetes mellitus. Biochemical Society Transactions. 1994;22:34S. [pmid: 8206256].
Fahrer H, Hoeflin F, Lauterburg B H, Peheim E, Levy A, Vischer T L. Diet and fatty acids: Can fish substitute for fish oil?. Clinical & Experimental Rheumatology. 1991;9:403-406. [pmid: 1934691].
Fasching P, Ratheiser K, Waldhausl W, et al. Metabolic effects of fish-oil supplementation in patients with impaired glucose tolerance. Diabetes. 1991;40:583-589. [pmid: 2022303].
Fisher W R, Zech L A, Stacpoole P W. Apolipoprotein B metabolism in hypertriglyceridemic diabetic patients administered either a fish oil- or vegetable oil-enriched diet. Journal of Lipid Research. 1998;39:388-401. [pmid: 9507999].
Fox J, Manitius J, Debska Slizie Rutkowski B, Nowak J, Bautembach S, Owczarzak A. The effect of administering Omega-3 acids on lipids in serum, functional state of erythrocyte membrane and function of the kidneys in patients with primary glomerulonephritis. Przeglad Lekarski. 1996;53:858-861. [pmid: 9163008].
Frenais R, Ouguerram K, Maugeais C, et al. Effect of dietary omega-3 fatty acids on high-density lipoprotein apolipoprotein AI kinetics in type II diabetes mellitus. Atherosclerosis. 2001;157:131-135. [pmid: 11427212].
Friday K E, Childs M T, Tsunehara C H, Fujimoto W Y, Bierman E L, Ensinck J W. Elevated plasma glucose and lowered triglyceride levels from omega-3 fatty acid supplementation in type II diabetes. Diabetes Care. 1989;12:276-281. [pmid: 2707115].
Fujita H, Yamagami T, Ohshima K. Fermented soybean-derived water-soluble Touchi extract inhibits alpha-glucosidase and is antiglycemic in rats and humans after single oral treatments. Journal of Nutrition. 2001;131:1211-1213. [pmid: 11285328].
Geerling B J, Houwelingen A C, Badart-Smook A, Stockbrugger R W, Brummer R J. Fat intake and fatty acid profile in plasma phospholipids and adipose tissue in patients with Crohn's disease, compared with controls. American Journal of Gastroenterology. 1999;94:410-417. [pmid: 10022638].
Glauber H, Wallace P, Griver K, Brechtel G. Adverse metabolic effect of omega-3 fatty acids in non-insulin-dependent diabetes mellitus. Annals of Internal Medicine. 1988;108:663-668. [pmid: 3282462].
Goren A, Stankiewicz H, Goldstein R, Drukker A. Fish oil treatment of hyperlipidemia in children and adolescents receiving renal replacement therapy. Pediatrics. 1991;88:265-268. [pmid: 1861924].
Grimminger F, Fuhrer D, Papavassilis C, et al. Influence of intravenous n-3 lipid supplementation on fatty acid profiles and lipid mediator generation in a patient with severe ulcerative colitis. European Journal of Clinical Investigation. 1993;23:706-715. [pmid: 8307090].
Gruenwald J, Graubaum H, Harde A. Effect of cod liver oil on symptoms of rheumatoid arthritis. Advances in Therapy. 2002;19:101-107. [pmid: 12069368].
Haban P, Simoncic R, Zidekova E, Klvanova J. Effect of application of n-3 polyunsaturated fatty acids on blood serum concentration of von Willebrand factor in type II diabetes mellitus. Medical Science Monitor. 1999;5:661-665.
Haban P, Zidekova E, Klvanova J. Supplementation with long-chain n-3 fatty acids in non-insulin-dependent diabetes mellitus (NIDDM) patients leads to the lowering of oleic acid content in serum phospholipids. European Journal of Nutrition. 2000;39:201-206. [pmid: 11131366].
Hall A V, Parbtani A, Clark W F, et al. Omega-3 fatty acid supplementation in primary nephrotic syndrome: effects on plasma lipids and coagulopathy. Journal of the American Society of Nephrology. 1992;3:1321-1329. [pmid: 1477328].
Hamazaki T, Nakazawa R, Tateno S, et al. Effects of fish oil rich in eicosapentaenoic acid on serum lipid in hyperlipidemic hemodialysis patients. Kidney International. 1984;26:81-84. [pmid: 6090756].
Hamazaki T, Takazakura E, Osawa K, Urakaze M, Yano S. Reduction in microalbuminuria in diabetics by eicosapentaenoic acid ethyl ester. Lipids. 1990;25:541-545. [pmid: 2250591].
Hansen G. Nutritional status of Danish patients with rheumatoid arthritis and effects of a diet adjusted in energy intake, fish content and antioxidants. Ugeskrift for Laeger. 1998;160:3074-3078. [pmid: 9621781].
Hiroyuki F, Tomohide Y, Kazunori O. Efficacy and safety of Touchi extract, an a-glucosidase inhibitor derived from fermented soybeans, in non-insulin-dependent diabetic mellitus. Journal of Nutritional Biochemistry. 2001;12:351-356. [pmid: 11516639].
Holman R T, Johnson S B, Bibus D, Spencer D C, Donadio J V Jr. Essential fatty acid deficiency profiles in idiopathic immunoglobulin A nephropathy. American Journal of Kidney Diseases. 1994;23:648-654. [pmid: 8172206].
Hombrouckx R O, Bogaert A M, Leroy F M, et al. Polyunsaturated fatty acids of the n-3 class in chronic dialysis. ASAIO Journal. 1992;38:M331-M333. [pmid: 1457875].
Honzlova M, Peliskova Z, Trnavsky K. Initial experience with the treatment of rheumatoid arthritis by dietary manipulation. Casopis.Lekaru.Ceskych. 1989;128:149-152. [pmid: 2790922].
Horiuchi, Onouchi T, Takahashi M, To H, Orimo H. Effect of soy protein on bone metabolism in postmenopausal Japanese women. Osteoporosis International. 2000;11:721-724. [pmid: 11095177].
Ilowite N, Copperman N, Leicht T, Kwong T, Jacobson M. Effects of dietary modification and fish oil supplementation on dyslipoproteinemia in pediatric systemic lupus erythematosus. Journal of Rheumatology. 1995;22:1347-1351. [pmid: 7562770].
Jaschonek K, Clemens M R, Scheurlen M. Decreased responsiveness of platelets to a stable prostacyclin analogue in patients with Crohn's disease. Reversal by n-3 polyunsaturated fatty acids. Thrombosis Research. 1991;63:667-672. [pmid: 1723538].
Jorgensen M E, Bjeregaard P, Borch-Johnsen K, et al. Diabetes and impaired glucose tolerance among the inuit population of Greenland. Diabetes Care. 2002;25:1766-1771. [pmid: 12351475].
Kamada T, Yamashita T, Baba Y, et al. Dietary sardine oil increases erythrocyte membrane fluidity in diabetic patients. Diabetes. 1986;35:604-611. [pmid: 3956887].
Kasim S, Stern B, Khilnani S, et al. Omega-3 fish oils increase the serum apoprotein B level and improve blood pressure in non-insulin-dependent diabetes. Circulation. 1987;76:35.
Kasim S E, Stern B, Khilnani S, McLin P, Baciorowski S, Jen K L. Effects of omega-3 fish oils on lipid metabolism, glycemic control, and blood pressure in type II diabetic patients. Journal of Clinical Endocrinology & Metabolism. 1988;67:1-5. [pmid: 3379125].
Kesavulu M M, Kameswararao B, Apparao Ch, Kumar E G, Harinarayan C V. Effect of omega-3 fatty acids on lipid peroxidation and antioxidant enzyme status in type 2 diabetic patients. Diabetes & Metabolism. 2002;28:20-26. [pmid: 11938024].
Kless T, Adam O. Effect of fish oil supplementation on erythrocyte fatty acids of patients with rheumatoid arthritis following a common western diet or a lactovegetarian diet. Aktuelle Ernahrungsmedizin Klinik und Praxis. 1993;18:305-310.
Kremer J, Jubiz W, Michalek A. Fish-oil fatty acid supplementation in active rheumatoid arthritis. A double-blinded, controlled, crossover study. Annals of Internal Medicine. 1987;106:497-503. [pmid: 3030173].
Kutafina EK, Netrebenko OK, Gorelova JU, Levachev MM, Garankina TI: Clinical application of the polyunsaturated n-3 fatty acids usage in pediatric practice. Zeitschrift fur Ernahrungswissenschaft 1998;37:Suppl-7
Kutner N G, Clow P W, Zhang R, Aviles X. Association of fish intake and survival in a cohort of incident dialysis patients. American Journal of Kidney Diseases [Online]. 2002;39:1018-1024.
Lagarde M, Croset M, Vericel E, Calzada C. Effects of small concentrations of eicosapentaenoic acid on platelets. Journal of Internal Medicine Supplement. 1989;225:177-179. [pmid: 2539831].
Landgraf-Leurs M M, Drummer C, Froschl H, Steinhuber R, Von Schacky C, Landgraf R. Pilot study on omega-3 fatty acids in type I diabetes mellitus. Diabetes. 1990;39:369-375. [pmid: 2137803].
Lardinois C K, Starich G H, Mazzaferri E L, DeLett A. Effect of source of dietary fats on serum glucose, insulin, and gastric inhibitory polypeptide responses to mixed test meals in subjects with non-insulin dependent diabetes mellitus. Journal of the American College of Nutrition. 1988;7:129-136. [pmid: 3283195].
Lenzi S, Caprioli R, Rindi P, et al. Omega-3 fatty acid supplementation and lipoprotein(a) concentrations in patients with chronic glomerular diseases. Nephron. 1996;72:383-390. [pmid: 8852484].
Linos A, Kaklamani V G, Kaklamani E, et al. Dietary factors in relation to rheumatoid arthritis: A role for olive oil and cooked vegetables?. American Journal of Clinical Nutrition. 1999;70:1077-1082. [pmid: 10584053].
Linos A, Kaklamanis E, Kontomerkos A, et al. The effect of olive oil and fish consumption on rheumatoid arthritis A case control study. Scandinavian Journal of Rheumatology. 1991;20:419-426. [pmid: 1771399].
Madar Z, Arieli B, Trostler N, Norynberg C: Effect of consuming soybean dietary fiber on fasting and postprandial glucose and insulin levels in type II diabetes. Journal of Clinical Biochemistry and Nutrition 1988;24:
Malyszko J S, Malyszko J, Pawlak D, Buczko W, liwiec M. Hemostasis, platelet functions, serotonin and serum lipids during omega-3 fatty acid treatment in patients with glomerulonephritis. Nephron. 1998;80:94-96. [pmid: 9730718].
Manitius J, Sulikowska B, Fox J, et al. The effect of dietary enrichment with fish-oil on urinary excretion of N-acetyl-beta-D-glucosaminidase and renal function in proteinuric patients with primary glomerulopathies. International Urology & Nephrology. 1997;29:489-495. [pmid: 9406009].
McGrath LT, Brennan GM, McVeigh GE, Hayes JR, Johnston GD: Effect of fish oil and olive oil supplements on HDL and VLDL concentrations in normotriglyceridaemic and hypertriglyceridaemic type 2 diabetic patients. British Journal of Clinical Pharmacology 1993;35:91P-
McManus R M, Jumpson J, Finegood D T, Clandinin M T, Ryan E A. A comparison of the effects of n-3 fatty acids from linseed oil and fish oil in well-controlled type II diabetes. Diabetes Care. 1996;19:463-467. [pmid: 8732710].
Mertens P R, Floege J. Treatment of IgA nephropathies. a critical viewpoint. Deutsche Medizinische Wochenschrift 2000;125:1010.
Meyer K A, Kushi L H, Jacobs D R Jr, Folsom A R. Dietary fat and incidence of type 2 diabetes in older Iowa women. Diabetes Care. 2001;24:1528-1535. [pmid: 11522694].
Miller M E, Anagnostou A A, Ley B, Marshall P, Steiner M. Effect of fish oil concentrates on hemorheological and hemostatic aspects of diabetes mellitus: a preliminary study. Thrombosis Research. 1987;47:201-214. [pmid: 3499006].
Mollsten A V, Dahlquist G G, Stattin E L, Rudberg S. Higher intakes of fish protein are related to a lower risk of microalbuminuria in young Swedish type 1 diabetic patients. Diabetes Care. 2001;24:805-810. [pmid: 11347734].
Molvig J, Pociot F, Worsaae H, et al. Dietary supplementation with omega-3-polyunsaturated fatty acids decreases mononuclear cell proliferation and interleukin-1 beta content but not monokine secretion in healthy and insulin-dependent diabetic individuals. Scandinavian Journal of Immunology. 1991;34:399-410. [pmid: 1656517].
Morcos NC: Modulation of lipid profile by fish oil and garlic combination. Journal of the National Medical Association 1997;59 ref.:10, 673-1067859.
Mori T, VAndongen R, Masarei J. Fish oil-induced changes in apolipoproteins in IDDM subjects. Diabetes Care. 1990;13:725-732. [pmid: 2201495].
Mori T A, Vandongen R, Masarei J R, Dunbar D, Stanton K G. Serum lipids in insulin-dependent diabetics are markedly altered by dietary fish oils. Clinical & Experimental Pharmacology & Physiology. 1988;15:333-337. [pmid: 2856058].
Mori T A, Vandongen R, Masarei J R, Stanton K G, Dunbar D. Dietary fish oils increase serum lipids in insulin-dependent diabetics compared with healthy controls. Metabolism. Clinical & Experimental. 1989;38:404-409. [pmid: 2542722].
Naka Y, Nagata K, Maeda E, et al. Clinical efficacy of eicosapentaenoic acid ethylester on diabetic subjects. Therapeutic Research. 1993;14:335-342.
Navarro E, Esteve M, Olive A, et al. Abnormal fatty acid pattern in rheumatoid arthritis. A rationale for treatment with marine and botanical lipids. Journal of Rheumatology. 2000;27:298-303. [pmid: 10685788].
Nishikawa M, Hishinuma T, Nagata K, Koseki Y, Suzuki K, Mizugaki M. Effects of eicosapentaenoic acid (EPA) on prostacyclin production in diabetics: GC/MS analysis of PGI2 and PGI3 levels. Methods & Findings in Experimental & Clinical Pharmacology. 1997;19:429-433. [pmid: 9385592].
O'Dea K, Sinclair A J. The effects of low-fat diets rich in arachidonic acid on the composition of plasma fatty acids and bleeding time in Australian aborigines. Journal of Nutritional Science & Vitaminology. 1985;31:441-453. [pmid: 3935761].
Okuda Y, Mizutami M, Tanaka K, Isaka M, Yamashita K. Beneficial effects of eicosapentaenoic acid for diabetic patients with arteriosclerosis obliterans. Diabetes Research & Clinical Practice. 1992;18:139-140. [pmid: 1478154].
Okuda Y, Mizutani M, Ogawa M, et al. Long-term effects of eicosapentaenoic acid on diabetic peripheral neuropathy and serum lipids in patients with type II diabetes mellitus. Journal of Diabetes & its Complications. 1996;10:280-287. [pmid: 8887017].
Olness K, Ader R. Conditioning as an adjunct in the pharmacotherapy of lupus erythematosus. Journal of Developmental & Behavioral Pediatrics. 1992;13:124-125. [pmid: 1577957].
Panchenko V M, Ershov A A, Isaev V A, ZImovchenko G S, Chernova G I. Poseidonol in the treatment of hyperlipidemia in patients with type 2 diabetes mellitus. Klinicheskaia Meditsina. 2001;79:47-49. [pmid: 11521381].
Pecis M, de Azevedo M J, Gross J L. Chicken and fish diet reduces glomerular hyperfiltration in IDDM patients. Diabetes Care. 1994;17:665-672. [pmid: 7924775].
Piper C M, Carroll P B, Dunn F L. Diet-induced essential fatty acid deficiency in ambulatory patient with type I diabetes mellitus. Diabetes Care. 1986;9:291-293. [pmid: 3731994].
Popp-Snijders C, Blonk M C. Omega-3 fatty acids in adipose tissue of obese patients with non-insulin-dependent diabetes mellitus reflect long-term dietary intake of eicosapentaenoic and docosahexaenoic acid. American Journal of Clinical Nutrition. 1995;61:360-365. [pmid: 7840075].
Popp-Snijders C, Heine R, van der Veen E: Dietary fish oil augments insulin secretion and insulin clearance in obese and type 2 (non-insulin-dependent) diabetic patients. Diabetologia 1988;31:532A(Abstract)
Popp-Snijders C, Heine R, van der Veen E: Effect of dietary fish oil on erythrocyte composition and insulin sensitivity in obese and non-obese subjects. Diabetologia 1987;30:571A(Abstract)
Popp-Snijders C, Schouten J A, Heine R J, van der Meer J, van der Veen E A. Dietary supplementation of omega-3 polyunsaturated fatty acids improves insulin sensitivity in non-insulin-dependent diabetes. Diabetes Research. 1987;4:141-147. [pmid: 3038454].
Rabini R A, Fumelli P, Galassi R, Giansanti R, Ferretti G, Mazzanti L. Action of dietary polyunsaturated fatty acids on the fluidity of erythrocyte and platelet membrane in NIDDM. Annals of the New York Academy of Sciences. 1993;683:371-372. [pmid: 8352468].
Richard M J, Sirajeddine M K, Cordonnier D, et al. Relationship of omega-3 fatty acid supplementation to plasma lipid peroxidation in predialysis patients with hypertriglyceridaemia. European Journal of Medicine. 1993;2:15-18. [pmid: 8257999].
Rillaerts E G, Engelmann G J, Van Camp K M, De Leeuw I. Effect of omega-3 fatty acids in diet of type I diabetic subjects on lipid values and hemorheological parameters. Diabetes. 1989;38:1412-1416. [pmid: 2620780].
Rylance P B, Gordge M P, Saynor R, Parsons V, Weston M J. Fish oil modifies lipids and reduces platelet aggregability in haemodialysis patients. Nephron. 1986;43:196-202. [pmid: 3724927].
Salomon P, Kornbluth A A, Janowitz H D. Treatment of ulcerative colitis with fish oil n--3-omega-fatty acid: an open trial. Journal of Clinical Gastroenterology. 1990;12:157-161. [pmid: 2109004].
Sampson M J, Davies I R, Brown J C, et al. n-3 polyunsaturated fatty acid supplementation, monocyte adhesion molecule expression and pro-inflammatory mediators in Type 2 diabetes mellitus. Diabetic Medicine. 2001;18:51-58. [pmid: 11168342].
Schaap G, Bilo H, Beukhof J, Gans R, Popp-Snijders C, Donker A. The effects of short-term omega-3 polyunsaturated fatty acid supplementation in patients with chronic renal insufficiency. Curr Ther Res Clin Exp. 1991;49:1061-1070.
Schectman G, Kaul S, Cherayil G D, Lee M, Kissebah A. Can the hypotriglyceridemic effect of fish oil concentrate be sustained?. Annals of Internal Medicine. 1989;110:346-352. [pmid: 2492785].
Schimke E, Hildebrandt R, Beitz J, et al. Influence of a cod liver oil diet in diabetics type I on fatty acid patterns and platelet aggregation. Biomedica Biochimica Acta. 1984;43:S351-S353. [pmid: 6517903].
Schmidt E B, Klausen I C, Kristensen S D, Lervang H H, Faergeman O, Dyerberg J. The effect of n-3 polyunsaturated fatty acids on Lp(a). Clinica Chimica Acta. 1991;198:271-277.
Schmidt E B, Sorensen P J, Pedersen J O, et al. The effect of n-3 polyunsaturated fatty acids on lipids, haemostasis, neutrophil and monocyte chemotaxis in insulin-dependent diabetes mellitus. Journal of Internal Medicine Supplement. 1989;225:201-206. [pmid: 2706043].
Selvais P L, Ketelslegers J M, Buysschaert M, Hermans M P. Plasma endothelin-1 immunoreactivity is increased following long-term dietary supplementation with omega-3 fatty acids in microalbuminuric IDDM patients. Diabetologia. 1995;38:253. [pmid: 7713324].
Shapiro J A, Koepsell T D, Voigt L F, Dugowson C E, Kestin M, Nelson J L. Diet and rheumatoid arthritis in women: A possible protective effect of fish consumption. Epidemiology. 1996;7:256-263. [pmid: 8728438].
Shaw C K. An epidemiologic study of osteoporosis in Taiwan. Annals of Epidemiology. 1993;3:264-271. [pmid: 8275199].
Sheehan J P, Wei I W, Ulchaker M, Tserng K Y. Effect of high fiber intake in fish oil-treated patients with non-insulin-dependent diabetes mellitus. American Journal of Clinical Nutrition. 1997;66:1183-1187. [pmid: 9356537].
Shimizu H, Sato N, Tanaka Y, Kashima K, Ohtani K, Mori M. Effect of eicosapentaenoic acid ethyl on urine albumin excretion in NIDDM. Diabetes Care. 1993;16:1406-1408. [pmid: 8269805].
Spannagl M, Drummer C, Froschl H, et al. Plasmatic factors of haemostasis remain essentially unchanged except for PAI activity during n-3 fatty acid intake in type I diabetes mellitus. Blood Coagulation & Fibrinolysis. 1991;2:259-265. [pmid: 1832569].
Sperling R, Weinblatt M, Robiin J, Ravalese J, Hoover R, House Fea. Effects of dietary supplementation with marine fish oil on leukoeyte lipid mediators and function in rheumatoid rthritis. Arthritis Rheum. 1987;30:988-997. [pmid: 3663263].
Stacpoole P W, Alig J, Ammon L, Crockett S E. Dose-response effects of dietary marine oil on carbohydrate and lipid metabolism in normal subjects and patients with hypertriglyceridemia. Metabolism: Clinical & Experimental. 1989;38:946-956. [pmid: 2677610].
Stacpoole P W, Alig J, Kilgore L L, et al. Lipodystrophic diabetes mellitus. Investigations of lipoprotein metabolism and the effects of omega-3 fatty acid administration in two patients. Metabolism: Clinical & Experimental. 1988;37:944-951. [pmid: 3050365].
Stene L C, Ulriksen J, Magnus P, Joner G. Use of cod liver oil during pregnancy associated with lower risk of Type I diabetes in the offspring.[erratum appears in Diabetologia. Diabetologia. 2000;43:1093-1098. [pmid: 11043854].
Stenson W, Cort D, Beeken Wea. A trial of fish oil supplemented diet in ulcerative colitis. Gastroenterology. 1990;98:A475.
Suci M, Katica D, Kovacevi V. Effect of dietary fish supplementation on lipoprotein levels in patients with hyperlipoproteinemia. Collegium Antropologicum. 1998;22:77-83. [pmid: 10097422].
Sulikowska B, Manitius J, owski T, ysiak W, Rutkowski B. The effect of therapy with small doses of mega-3 polyunsaturated fatty acid on renal reserve and metabolic disturbances in patients with primary IGA glomerulopathy. Polskie Archiwum Medycyny Wewnetrznej. 2002;108:753-760. [pmid: 12476895].
Takahashi R, Inoue J, Ito H, Hibino H. Evening primrose oil and fish oil in non-insulin-dependent-diabetes. Prostaglandins Leukotrienes & Essential Fatty Acids. 1993;49:569-571.
Tilvis R S, Rasi V, Viinikka L, Ylikorkala O, Miettinen T A. Effects of purified fish oil on platelet lipids and function in diabetic women. Clinica Chimica Acta. 1987;164:315-322.
Tobin A. Eicosapentaenoic acid in chronic ulcerative colitis. Gut. 1989;30:A1502. [pmid: 2920922].
Tsujikawa T, Satoh J, Uda K, et al. Clinical importance of n-3 fatty acid-rich diet and nutritional education for the maintenance of remission in Crohn's disease. Journal of Gastroenterology. 2000;35:99-104. [pmid: 10680664].
van Dam R M, Rimm E B, Willett W C, Stampfer M J, Hu F B, van Dam R M. Dietary patterns and risk for type 2 diabetes mellitus in U.S. men. Annals of Internal Medicine. 2002;136:201-209. [pmid: 11827496].
Vessby B, Karlstrom B, Boberg M, Lithell H, Berne C. Polyunsaturated fatty acids may impair blood glucose control in type 2 diabetic patients. Diabetic Medicine. 1992;9:126-133. [pmid: 1563246].
Virstiuk N: English walnuts in the combined treatment of rheumatoid arthritis patients. Likarska.Sprava 1997;Mar-Apr:123–126.
Wakai K, Kawamura T, Matsuo S, Hotta N, Ohno Y. Risk factors for IgA nephropathy: a case-control study in Japan. American Journal of Kidney Diseases. 1999;33:738-745. [pmid: 10196018].
Wijendran V, Bendel R B, Couch S C, Philipson E H, Cheruku S, Lammi-Keefe C J. Fetal erythrocyte phospholipid polyunsaturated fatty acids are altered in pregnancy complicated with gestational diabetes mellitus. Lipids. 2000;35:927-931. [pmid: 10984116].
Williams C M, Moore F, Wright J. Fasting and postprandial triacylglycerol responses to a standard test meal in subjects taking dietary supplements of n-3 fatty acids. Biochemical Society Transactions. 1990;18:909-910. [pmid: 2083725].
Yosefy C, Viskoper J R, Laszt A, et al. The effect of fish oil on hypertension, plasma lipids and hemostasis in hypertensive, obese, dyslipidemic patients with and without diabetes mellitus. Prostaglandins Leukotrienes & Essential Fatty Acids. 1999;61:83-87.
Zak A, Zeman M, Tvrzicka E, Stolba P. Effects of fish oils in patients with type 2 diabetes with associated dyslipidaemia. Casopis Lekaru Ceskych. 1996;135:354-359. [pmid: 8706072].
Zambon S, Friday K E, Childs M T, Fujimoto W Y, Bierman E L, Ensinck J W. Effect of glyburide and omega 3 fatty acid dietary supplements on glucose and lipid metabolism in patients with non-insulin-dependent diabetes mellitus. American Journal of Clinical Nutrition. 1992;56:447-454. [pmid: 1636624].

### Rejected Duplicate

Dunstan D W, Mori T A, Puddey I B, et al. A randomised, controlled study of the effects of aerobic exercise and dietary fish on coagulation and fibrinolytic factors in type 2 diabetics. Thrombosis & Haemostasis. 1999;81:367-372. [pmid: 10102462].
Fox J, Manitius J, Debska Slizien A, et al: Influence of omega-3 acids administration on plasma lipids, functional status of erythrocyte membrane and function of the kidney in patients with primary glomerulopathies. Przeglad Lekarski 1996;13:12, 858–1286113.
Nielsen G, Faarvang K, Tomsen B, Teglbjaerg K, Ernst E: Effects of supplementation with n-3 fatty acids on clinical disease variables in patients with rheumatoid arthritis. European Journal of Clinical Investigation 21.
Tulleken J, Limburg P, Muskiet F, van Rijswijk M. Vitamin E status during dietary fish oil supplementation in rheumatoid arthritis. Arthritis Rheum. 1990;33:1416-9. [pmid: 2206140].

### Rejected Unable to Find Translator

Faarvang K L, Nielsen G L, Thomsen B S, et al. Fish oils and rheumatoid arthritis. A randomized and double-blind study. Ugeskrift for Laeger. 1994;156:3495-3498. [pmid: 8066866].
Shunto S, Takahashi K, Negishi K, et al. Effects of eicosapentaenoic acid on glycemic control and lipid metabolism in healthy and NIDDM subjects. Therapeutic Research. 1992;13:257-265.
Skoldstam L, Berglund U, Eriksson A, Akesson B. A diet rich in polyunsaturated fatty acids is of no help in patients with rheumatoid arthritis. Lakartidningen. 1988;14:4411. [pmid: 3059115].
Vargova V. Will administration of omega-3 unsaturated fatty acids reduce the use of nonsteroidal antirheumatic agents in children with chronic juvenile arthritis?. Casopis.Lekaru.Ceskych. 1998;137:651-653. [pmid: 9929929].

### Rejected No difference in Omega-3 Content

Buonfantino M, Marano M, Di Nuzzi L, Iorio G, Iuliano P, Tufano L. Use of fatty polyunsaturated acids (Fish oil) in diabetic nephropathy: Results of a preliminary study. Rassegna Internazionale di Clinica e Terapia. 1995;75:264-267.
Dichi I, Frenhane P, Dichi J, et al. Comparison of omega-3 fatty acids and sulfasalazine in ulcerative colitis. Nutrition. 2000;16:87-90. [pmid: 10696629].
Gassull M A, Fernandez-Banares F, Cabre E, et al. Fat composition may be a clue to explain the primary therapeutic effect of enteral nutrition in Crohn's disease. results of a double blind randomised multicentre European trial. Gut. 2002;51:164-168. [pmid: 12117873]. [pmcid: 1773299].
Haugen M A, Kjeldsen-Kragh J, Bjerve K S, Hostmark A T, Forre O. Changes in plasma phospholipid fatty acids and their relationship to disease activity in rheumatoid arthritis patients treated with a vegetarian diet. British Journal of Nutrition. 1994;72:555-566. [pmid: 7986787].
Herrmann W, Biermann J, Ratzmann K P, Lindhofer H G. Effect of fish oil concentrate on the lipoprotein profile of patients with type II diabetes mellitus. Medizinische Klinik. 1992;87:12-15. [pmid: 1545765].
Katsuyama H, Ideguchi S, Fukunaga M, Saijoh K, Sunami S. Usual dietary intake of fermented soybeans (Natto) is associated with bone mineral density in premenopausal women. Journal of Nutritional Science & Vitaminology. 2002;48(3):207-15. [pmid: 12350079].
Leiper K, Woolner J, Mullan M M C, et al. A randomised controlled trial of high versus low long chain triglyceride whole protein feed in active Crohn's disease. Gut. 2001;49:790-794. [pmid: 11709513]. [pmcid: 1728544].
Leventhal L J, Boyce E G, Zurier R B. Treatment of rheumatoid arthritis with blackcurrant seed oil. British Journal of Rheumatology. 1994;33:847-852. [pmid: 8081671].
Lopez-Espinoza I, Howard-Williams J, Mann J I, Carter R D, Hockaday T D. Fatty acid composition of platelet phospholipids in non-insulin-dependent diabetics randomized for dietary advice. British Journal of Nutrition. 1984;52:41-47. [pmid: 6743640].
Louheranta A M, Sarkkinen E S, Vidgren H M, Schwab U S, Uusitupa M I. Association of the fatty acid profile of serum lipids with glucose and insulin metabolism during 2 fat-modified diets in subjects with impaired glucose tolerance. American Journal of Clinical Nutrition. 2002;76:331-337. [pmid: 12145003].
Potter S, Baum J, Teng H, Stillman R J, Shay N, Erdman J. Soy protein and isoflavones: their effects on blood lipids and bone density in postmenopausal women. Am J Clin Nutr. 1998;68:1375S-1379S. [pmid: 9848502].
Provenzano C, Vero R, Oliva A, et al. Lispro insulin in type 1 diabetic patients on a Mediterranean or normal diet: a randomized, cross-over comparative study with regular insulin. Diabetes, Nutrition & Metabolism - Clinical & Experimental. 2001;14:133-139.
Rodriguez-Villar C, Manzanares J M, Casals E, et al. High-monounsaturated fat, olive oil-rich diet has effects similar to a high-carbohydrate diet on fasting and postprandial state and metabolic profiles of patients with type 2 diabetes. Metabolism. Clinical & Experimental. 2000;49:1511-1517. [pmid: 11145109].
Sakurai T, Matsui T, Yao T, et al. Short-term efficacy of enteral nutrition in the treatment of active Crohn's disease: a randomized, controlled trial comparing nutrient formulas. Journal of Parenteral & Enteral Nutrition. 2002;26:98-103. [pmid: 11871742].
Summers L K, Fielding B A, Bradshaw H A, et al. Substituting dietary saturated fat with polyunsaturated fat changes abdominal fat distribution and improves insulin sensitivity. Diabetologia. 2002;45:369-377. [pmid: 11914742].

### Rejected No Outcomes or Criteria of Interest

Astorga G. Active rheumatoid arthritis: effect of dietary supplementation with omega-3 oils. A controlled double-blind trial. Revista Medica de Chile. 1991;119:267-272. [pmid: 1842119].
Belluzzi A, Brignola C, Campieri M, et al. Effects of a new fish oil derivative on fatty acid phospholipid-membrane pattern in a group of Crohn's disease patients. Dig Dis Sci. 1994;39:2589-2594. [pmid: 7995183].
Dahlan W, Richelle M, Kulapongse S, Rossle C, Deckelbaum R J, Carpentier Y A. Effects of essential fatty acid contents of lipid emulsions on erythrocyte polyunsaturated fatty acid composition in patients on long-term parenteral nutrition. Clinical Nutrition. 1992;11:262-268. [pmid: 16840007].
Espersen G, Grunnet N, Lervang H, et al. Decreased interleukin-1 beta levels in plasma from rheumatoid arthritis patients after dietary supplementation with n-3 polyunsaturated fatty acids. Clinical Rheumatology. 1992;11:393-395. [pmid: 1458789].
Hillier K. Human colon mucosa: effect of marine oils on lipid fatty acid composition and eicosanoid synthesis in inflammatory bowel disease. British Journal of Clinical Pharmacology. 1988;25:129P-30P.
Hillier K, Jewell R, Dorrell L, Smith C. Incorporation of fatty acids from fish oil and olive oil into colonic mucosal lipids and effects upon eicosanoid synthesis in inflammatory bowel disease. Gut. 1991;32:1151-1155. [pmid: 1955170]. [pmcid: 1379376].
Ikehata A, Hiwatashi N, Kinouchi Y, et al. Effect of intravenously infused eicosapentaenoic acid on the leukotriene generation in patients with active Crohn's disease. American Journal of Clinical Nutrition. 1992;56:938-942. [pmid: 1329484].
Jantti J V, Vapaatalo H, Seppala E, Ruutsalo H M, Isomaki H. Treatment of rheumatoid arthritis with fish oil, selenium, vitamins A and E, and placebo. Scandinavian Journal of Rheumatology. 1991;20:225.
Rubin M, Moser A, Vaserberg N, et al: Structured triacylglycerol emulsion, containing both medium- and long-chain fatty acids, in long-term home parenteral nutrition: a double-blind randomized cross-over study. Nutrition 2000;23:2, 95–10023.
Woodman R J, Mori T A, Burke V, et al. Effects of purified eicosapentaenoic acid and docosahexaenoic acid on platelet, fibrinolytic and vascular function in hypertensive type 2 diabetic patients. Atherosclerosis. 2003;166:85-93. [pmid: 12482554].

### Duplicate Reports of Same Trial

Almallah Y, Ewen S, El Tahir A, et al. Distal proctocolitis and n-3 polyunsaturated fatty acids (n-3 PUFAs): the mucosal effect in situ. Journal of Clinical Immunology. 2000;20:68-76. [pmid: 10798610].
Chan D, Watts G, Barrett P, Beilin L, Redgrave T, Mori T. Regulatory effects of HMG CoA reductase inhibitor and fish oils on apolipoprotein B-100 kinetics in insulin-resistant obese male subjects with dyslipidemia. Diabetes. 2002;51:2377-2386. [pmid: 12145148].
Dunstan D, Mori T, Puddey I, et al. The independent and combined effects of aerobic exercise and dietary fish intake on serum lipids and glycemic control in NIDDM. A randomized controlled study. Diabetes Care. 1997;20:913-921. [pmid: 9167099].
McVeigh G, Brennan G, Cohn J, Finkelstein S, Hayes R, Johnston G. Fish oil improves arterial compliance in non-insulin-dependent diabetes mellitus. Arteriosclerosis & Thrombosis. 1994;14:1425-1429. [pmid: 8068603].
McVeigh G, Brennan G, Johnston G, et al. Dietary fish oil augments nitric oxide production or release in patients with type 2 (non-insulin-dependent) diabetes mellitus. Diabetologia. 1993;36:33-38. [pmid: 8436250].
Mori T, Dunstan D, Burke V, et al. Effect of dietary fish and exercise training on urinary F2-isoprostane excretion in non-insulin-dependent diabetic patients. Metabolism. Clinical & Experimental. 1999;48:1402-1408. [pmid: 10582548].
Nielsen G, Faarvang K, Tomsen B, Teglbjaerg K, Ernst E: Effects of supplementation with n-3 fatty acids on clinical disease variables in patients with rheumatoid arthritis. European Journal of Clinical Investigation 21.