# Acknowledgments

We thank Herbert D. Woolf, PhD, of BASF Corporation for providing us with unpublished data on omega-3 fatty acids. We thank Antonio LaCava, MD, PhD for providing translation of Italian studies, Takahiro Higashi, MD for providing translation of Japanese studies, Markus Rihl, MD for providing translation of German studies, and Anna Maria Björnsdotter, BA, for providing translation of Swedish studies.

Chapter 1 was written in collaboration with the Tufts-New England Medical Center Evidence-based Practice Center.