# Appendix C. Evidence Tables

Evidence Table C.1 Evidence table of clinical effect of omega-3 fatty acids in type II diabetes or metabolic syndrome

First Author, Year | Study Characteristics | Study design Duration | Eligibility Criteria | Concurrent Disease Condition Medication | Arm | Interventions Dosage/Duration | Outcomes Results | Quality Applicability Funding Source
Alekseeva, 2000^65^ | Sample size: 60 | Design: RCT | Inclusion: | Covariates: Duration of diabetes/Obesity: BMI=27, lbs=160/Hyperlipidemia/Hypertension | 1 | Low calorie diet | Total cholesterol (mg/dl at week 4) | Quality:
| Age (mean/range): 58/39–65 | Duration: 4 wk | Controlled diabetes/Hyperlipidemia/Age | | 2 | Linseed oil 18 g/d × 4 wk | Arm 1 mean=251.35 | Jadad: 2
| Race: NR | | Exclusion: NR | | | | Arm 2 mean=253.67 | Concealment of allocation: NR
| % male: NR | | | | | | Mean difference=2.32 (-24.97, 29.60) | Applicability: NR
| # sites: 1 | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2. | Funding source: Government
| Location: Russia | | | | | | Triglyceride (mg/dl at week 4)
| | | | | | | Arm 1 mean=260.18
| | | | | | | Arm 2 mean=313.27
| | | | | | | Mean difference=53.10 (-33.55, 139.74)
| | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2.
| | | | | | | HDL: NR
| | | | | | | LDL: NR
| | | | | | | Fasting blood glucose (mg/dl at week 4)
| | | | | | | Arm 1 mean=176.58
| | | | | | | Arm 2 mean=185.59
| | | | | | | Mean difference=9.01 (-24.30, 42.32)
| | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2.
| | | | | | | HbA1c: NR
Annuzzi, 1991^57^ | Sample size: 8 | Design: RXT | Inclusion: | Covariates: Hypoglycemic treatment/Duration of diabetes/Hb A1c/Obesity: BMI=27, kg=72.7, lbs=160 | 1 | Olive oil 10 g/d × 2 wk | Total cholesterol (mg/dl at month 0.5) | Quality:
| Age (mean/range): 51/45–57 | Duration: 4 wk | Hyperlipidemia/ WHO diabetes criteria | [Cathy: would just make this into a list as follows, but would have the bullets start further over to the left] | 2 | Max EPA (fish oil) 10 g/d × 2 wk | Arm 1 mean=177.61 | Jadad: 2
| Race: NR | X-over: week 8 | Exclusion: | Covariates:• Hypogycemic treatment• Duration of diabetes/Hb A1c• Obesity: BMI=27, kg=72.7, lbs=160 | | | Arm 2 mean=183.78 | Concealment of allocation: ND
| % male: 100 | Run-in: None | Lipid lowering drug use | | | | Mean difference=6.18 (-21.65, 34.00) | Applicability: IIB
| # sites: 1 | Wash-out: None | | | | | Reported testing: Article reports no significant difference between Arm 1 and Arm 2 by using | Funding source: hospital and industry
| Location: Italy | | | | | | Wilcoxon’s signed rank test.
| | | | | | | Triglyceride (mg/dl at month 0.5)
| | | | | | | Arm 1 mean=204.43
| | | | | | | Arm 2 mean=171.68
| | | | | | | Mean difference=-32.74 (-84.26, 18.77)
| | | | | | | Reported testing: Article reports significant difference (p<0.05) between Arm 1 and Arm 2 by using
| | | | | | | Wilcoxon’s signed rank test.
| | | | | | | HDL (mg/dl at month 0.5)
| | | | | | | Arm 1 mean=22.78
| | | | | | | Arm 2 mean=22.78
| | | | | | | Mean difference=0.00 (-3.21, 3.21)
| | | | | | | Reported testing: Article reports no significant difference between Arm 1 and Arm 2 by using
| | | | | | | Wilcoxon’s signed rank test.
| | | | | | | LDL (mg/dl at month 0.5)
| | | | | | | Arm 1 mean=109.65
| | | | | | | Arm 2 mean=132.82
| | | | | | | Mean difference=23.17 (-9.22, 55.56)
| | | | | | | Reported testing: Article reports significant difference (p<0.025) between Arm 1 and Arm 2 by using
| | | | | | | Wilcoxon’s signed rank test.
| | | | | | | Fasting blood glucose (mg/dl at month 0.5)
| | | | | | | Arm 1 mean=153.15
| | | | | | | Arm 2 mean=145.22
| | | | | | | Mean difference=-7.93 (-66.18, 50.32)
| | | | | | | Reported testing: Article reports no significant difference between Arm 1 and Arm 2 by using
| | | | | | | Wilcoxon’s signed rank test.
| | | | | | | HbA1c: NR
Axelrod, 1994^75^ | Sample size: 20 | Design: RCT | Inclusion: | Covariates: Hypoglycemic treatment/Duration of diabetes/Hb A1c/Obesity: BMI=27, kg=72.7, lbs=160 | 1 | Safflower oil 5 g/d × 6 wk | Total cholesterol (mg/dl at week 6): | Quality:
| Age (mean/range): 57/NR | Duration: 12 wk | Age/Controlled diabetes/No weight change in previous 2 or 3 mo./Hb A1c < 9.5% or 10.5%/Hb=13 for men, HB=12 for women/Retinopathy | | 2 | Super EPA (fish oil) 5 g/d × 6 wk | Arm 1=point estimate not reported | Jadad: 4
| Race: Caucasian, Black | | Exclusion: | | | | Arm 2=point estimate not reported | Concealment of allocation: Yes
| % male: NR | | Steroids use/NSAIDs use/Reliable adherence/Bleeding disorder/ASA use/Not moderate or high fish intake/Proliferative retinopathy/Intraocular hemorrhage | | | | Meta-analysis: Not performed; point estimates at follow-up not reported. | Applicability: IB
| # sites: 1 | | | | | | Reported testing: No significant effect (p=0.129) for fish oil (arm 2) using analysis of covariance. | Funding source: private, non-industry hospital
| Location: US | | | | | | LDL (mg/dl at week 6):
| | | | | | | Arm 1=point estimate not reported
| | | | | | | Arm 2=point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates at follow-up not reported.
| | | | | | | Reported testing: No significant effect for fish oil (arm 2) using analysis of covariance.
| | | | | | | HDL (mg/dl at week 6):
| | | | | | | Arm 1=point estimate not reported
| | | | | | | Arm 2=point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates at follow-up not reported.
| | | | | | | Reported testing: No significant effect for fish oil (arm 2) using analysis of covariance.
| | | | | | | Triglycerides (mg/dl at week 6):
| | | | | | | Arm 1=point estimate not reported
| | | | | | | Arm 2=point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates at follow-up not reported.
| | | | | | | Reported testing: Significant (p=0.027) reduction in triglycerides for fish oil using analysis of covariance.
| | | | | | | HgA1c (% at week 6):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates at follow-up not reported.
| | | | | | | Reported testing: Significant (p=0.009) increase in HgA1c for fish oil using analysis of covariance.
| | | | | | | Fasting blood glucose (mg/dl at week 6):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates at follow-up not reported.
| | | | | | | Reported testing: No significant effect for fish oil (arm 2) using analysis of covariance.
Boberg, 1992^76^ | Sample size: 14 | Design: RXT | Inclusion: | Covariates: Hypoglycemic treatment/Duration of diabetes/Hb A1c/Obesity: BMI=27, kg=72.7, lbs=160 | 1 | Olive oil 10 g/d × 8wk | Total cholesterol (mg/dl at week 8): | Quality:
| Age (mean/range): 65/55–75 | Duration: 16 wk | Diet treatment=1 yr | | 2 | Max EPA (fish oil) 10 g/d × 8wk | Arm 1= point estimate not reported | Jadad: 3
| Race: NR | X-over: week 8 | Exclusion: | | | | Arm 2 = point estimate not reported | Concealment of allocation: NR
| % male: 86 | Run-in: None | Lipid lowering drug use | | | | Meta-analysis: Not performed; point estimates before cross-over not reported. | Applicability: IIB
| # sites: 1 | Wash-out: None | | | | | Reported testing: No significant difference between groups using analysis of covariance. | Funding source: Government, private, non-industry
| Location: Sweden | | | | | | LDL (mg/dl at week 8):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates before cross-over not reported.
| | | | | | | Reported testing: Significant (p<0.001) increase in LDL for for fish oil (arm 2) relative to olive oil (arm 1) using analysis of covariance.
| | | | | | | HDL (mg/dl at week 8):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates before cross-over not reported.
| | | | | | | Reported testing: : No significant difference between groups using analysis of covariance.
| | | | | | | Triglycerides (mg/dl at week 8):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates before cross-over not reported.
| | | | | | | Reported testing: Significant (p< 0.001) reduction in triglycerides for fish oil (arm 2) relative to olive oil (arm 1) using analysis of covariance.
| | | | | | | HgA1c (% at week 8):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates before cross-over not reported.
| | | | | | | Reported testing: : No significant difference between groups using analysis of covariance.
| | | | | | | Fasting blood glucose (mg/dl at week 8):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates before cross-over not reported.
| | | | | | | Reported testing: : No significant difference between groups using analysis of covariance.
Borkman, 1989^77^ | Sample size: 10 | Design: RXT | Inclusion: | Covariates: Duration of diabetes/Obesity: BMI=27, kg=72.7, lbs=160/Hypertension | 1 | Safflower oil 10 g/d × 3 wk | Total cholesterol (mg/dl at week 6): | Quality:
| Age (mean/range): 57/43–64 | Duration: 12 wk | NR | | 2 | Max EPA (fish oil) 10 g/d × 3 wk | Arm 1= point estimate not reported | Jadad: 1
| Race: NR | X-over: week 9 | Exclusion: | | | | Arm 2= point estimate not reported | Concealment of allocation: NR
| % male: 70 | | NR | | | | Meta-analysis: Not performed; point estimates before cross-over not reported. | Applicability: IB
| # sites: 1 | | | | | | Reported testing: Testing between arms not reported. | Funding source: Government, hospital
| Location: Australia | | | | | | LDL (mg/dl at week 6):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates before cross-over not reported.
| | | | | | | Reported testing: Testing between arms not reported.
| | | | | | | HDL (mg/dl at week 6):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates before cross-over not reported.
| | | | | | | Reported testing: Testing between arms not reported.
| | | | | | | Triglycerides (mg/dl at week 6):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates before cross-over not reported.
| | | | | | | Reported testing: Testing between arms not reported.
| | | | | | | HgA1c: NR
| | | | | | | Fasting blood glucose (mg/dl at week 6):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates before cross-over not reported.
| | | | | | | Reported testing: Testing between arms not reported.
Chan, 2002^58^ | Sample size: 52 | Design: RCT | Inclusion: | Covariates: Hypertension/Obesity: BMI=27, kg=72.7, lbs=160. | 1 | Placebo/control Dosage/duration not collected | Total cholesterol (mg/dl at month 1.5) | Quality:
| Age (mean/range): 53/NR | Duration: 6 wk | Hyperlipidemia/No weight change in previous 2 or 3 mo | | 2 | Atorvastatin Dosage/duration not collected | Arm 1 mean=223.94 | Jadad: 3
| Race: NR | | Exclusion: | | 3 | Omacor 4 g for 6 wk | Arm 3 mean=212.36 | Concealment of allocation: NR
| % male: 100 | | Lipid lowering drug use/Baseline serum creatinine>0.40 mmol/l or >120 mmol/L/Not moderate or high fish intake/Diabetes/Thyroid abnormalities/Liver disease/Alcohol use | | 4 | Omacor plus Atorvastatin 4 g for 6 wk | Mean difference=-11.58 (-36.35, 13.19) | Applicability: IIB
| # sites: 1 | | | | | | Arm 2 mean=139.00 | Funding source: Government, industry,
| Location: Australia | | | | | | Arm 4 mean=150.58
| | | | | | | Mean difference=11.58 (-9.59, 32.76)
| | | | | | | Reported testing: Article reports significant Atorvastatin main effect (p=0.001) and nonsignificant Fish main effect based on general linear model
| | | | | | | Triglyceride (mg/dl at month 1.5)
| | | | | | | Arm 1 mean=256.64
| | | | | | | Arm 3 mean=132.74
| | | | | | | Mean difference=-123.89 (-366.93, 119.14)
| | | | | | | Arm 2 mean=123.89
| | | | | | | Arm 4 mean=106.20
| | | | | | | Mean difference=-17.70 (-52.99, 17.59)
| | | | | | | Reported testing: Article reports significant Atorvastatin main effect (p=0.002) and Fish main effect (p=0.002) based on general linear model.
| | | | | | | HDL (mg/dl at month 1.5)
| | | | | | | Arm 1 mean=39.38
| | | | | | | Arm 3 mean=38.61
| | | | | | | Mean difference=-0.77 (-6.33, 4.78)
| | | | | | | Arm 2 mean=40.15
| | | | | | | Arm 4 mean=48.26
| | | | | | | Mean difference=8.11 (0.63, 15.59)
| | | | | | | Reported testing: Article reports significant Atorvastatin main effect (p=0.007) and Fish main effect (p=0.041) based on general linear model.
| | | | | | | LDL (mg/dl at month 1.5)
| | | | | | | Arm 1 mean=147.88
| | | | | | | Arm 3 mean=142.09
| | | | | | | Mean difference=-5.79 (-20.88, 9.29)
| | | | | | | Arm 2 mean=71.04
| | | | | | | Arm 4 mean=83.01
| | | | | | | Mean difference=11.97 (-4.51, 28.45)
| | | | | | | Reported testing: Article reports significant Atorvastatin main effect (p=0.001) and nonsignificant Fish main effect based on general linear model
| | | | | | | Fasting blood glucose: NR
| | | | | | | HbA1c: NR
Connor, 1993^78^ | Sample size: 16 | Design: RXT | Inclusion: | Covariates: Hypoglycemic treatment/Obesity: BMI=27, kg=72.7, lbs=160. | 1 | Olive oil 15 g/d × 6 mo | Total cholesterol (mg/dl at month 9): | Quality:
| Age (mean/range): 59/46–72 | Duration: 15 mo | Hyperlipidemia | | 2 | Promega (fish oil) 15 g/d × 6 mo | Arm 1= point estimate not reported | Jadad: 2
| Race: NR | X-over: month 9 | Exclusion: | | | | Arm 2= point estimate not reported | Concealment of allocation: NR
| % male: 81 | Run-in: 3 mo | NR | | | | Meta-analysis: Not performed; point estimates before cross-over not reported. | Applicability: IIIB
| # sites: 1 | Washout: None | | | | | Reported testing: No significant difference between arms using Wilcoxian signed rank test. | Funding source: Government
| Location: US | | | | | | LDL (mg/dl at month 9):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates before cross-over not reported.
| | | | | | | Reported testing: Significant (p=0.0003) difference favoring olive oil (arm 1) using Wilcoxian signed rank test.
| | | | | | | HDL (mg/dl at month 9):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates before cross-over not reported.
| | | | | | | Reported testing: No significant difference between arms using Wilcoxian signed rank test.
| | | | | | | Triglycerides (mg/dl at month 9):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates before cross-over not reported.
| | | | | | | Reported testing: Significant (p=0.0004) difference favoring fish oil (arm 2) using Wilcoxian signed rank test.
| | | | | | | HgA1c (% at month 9)
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates before cross-over not reported.
| | | | | | | Reported testing: No significant difference between arms using Wilcoxian signed rank test.
| | | | | | | Fasting blood glucose (mg/dl at month 9):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates before cross-over not reported.
| | | | | | | Reported testing: No significant difference between arms using Wilcoxian signed rank test.
Dunstan, 1998^59^ | Sample size: 48 | Design: RCT | Inclusion: | Covariates: Hypoglycemic treatment/Duration of diabetes/Obesity: BMI=27, kg=72.7, lbs=160/Hb A1c | 1 | Low-fat and low-sodium diet × 8 wk | Total cholesterol (mg/dl at month 2) | Quality:
| Age (mean/range): 53/NR | Duration: 8 wk | Age/Nonsmoker/Hyperlipidemia/Sedentary | | 2 | Low-fat and low-sodium diet × 8 wk | Arm 1 mean=204.63 | Jadad: 2
| Race: NR | | Exclusion: | | 3 | Fish Approximately 3.6 g/d of omega-3 fatty acids/d × 8 wk | Arm 3 mean=185.33 | Concealment of allocation: NR
| % male: 76 | | Lipid lowering drug use/Not moderate or high fish intake/Proliferative retinopathy/Alcohol use/Liver disease/ReNRl disease/Neuropathy/Cardiovascular disease | | 4 | Fish Approximately 3.6 g/d of omega-3 fatty acids/d × 8 wk | Mean difference=-19.31 (-46.67, 8.06) | Applicability: IIB
| # sites: 1 | | | | | | Arm 2 mean=173.75 | Funding source: Government
| Location: Australia | | | | | | Arm 4 mean=181.47
| | | | | | | Mean difference=7.72 (-19.28, 34.73)
| | | | | | | Reported testing: Article reports no significant differences based on a generalized linear model or a multiple regression model.
| | | | | | | Triglyceride (mg/dl at month 2)
| | | | | | | Arm 1 mean=247.79
| | | | | | | Arm 3 mean=132.74
| | | | | | | Mean difference=-115.04 (-195.84, -34.24)
| | | | | | | Arm 2 mean=168.14
| | | | | | | Arm 4 mean=115.04
| | | | | | | Mean difference=-53.1 (-132.84, 26.65)
| | | | | | | Reported testing: Article reports significant results for a generalized linear model and a multiple regression model.
| | | | | | | HDL (mg/dl at month 2)
| | | | | | | Arm 1 mean=29.73
| | | | | | | Arm 3 mean=34.36
| | | | | | | Mean difference=4.63 (-3.90, 13.16)
| | | | | | | Arm 2 mean=30.50
| | | | | | | Arm 4 mean=30.89
| | | | | | | Mean difference=0.39 (-8.03, 8.80)
| | | | | | | Reported testing: Article reports no significant differences based on a generalized linear model or a multiple regression model.
| | | | | | | LDL (mg/dl at month 2)
| | | | | | | Arm 1 mean=127.41
| | | | | | | Arm 3 mean=132.43
| | | | | | | Mean difference=5.02 (-21.44, 31.48)
| | | | | | | Arm 3 mean=108.10
| | | | | | | Arm 4 mean=127.41
| | | | | | | Mean difference=19.31 (-6.81, 45.42)
| | | | | | | Reported testing: Article reports no significant differences based on a generalized linear model or a multiple regression model.
| | | | | | | Fasting blood glucose (mg/dl at month 2)
| | | | | | | Arm 1 mean=167.57
| | | | | | | Arm 3 mean=176.58
| | | | | | | Mean difference=9.01 (-33.00, 51.02)
| | | | | | | Arm 2 mean=165.77
| | | | | | | Arm 4 mean=169.37
| | | | | | | Mean difference=3.60 (-37.85, 45.06)
| | | | | | | Reported testing: Article reports significant results for a generalized linear model and a multiple regression model.
| | | | | | | HbA1c: NR
Fasching, 1996^79^ | Sample size: 10 | Design: RXT | Inclusion: | Covariates: Duration of diabetes/Obesity: BMI=27, kg=72.7, lbs=160. | 1 | Gemfibrozil 4 mmol/d × 2 wk | Total cholesterol: (at week 10): | Quality:
| Age (mean/range): 61/NR | Duration: 20 wk | Hyperlipidemia/Controlled diabetes/WHO diabetes criteria | | 2 | EPAX 5000 (fish oil) 22 mol/d × 2 wk | Arm 1= point estimate not reported | Jadad: 2
| Race: NR | X-over: week 18 | Exclusion: | | | | Arm 2= point estimate not reported | Concealment of allocation: NR
| % male: 40 | Run-in: 8 wk | Lipid lowering drug use | | | | Meta-analysis: Not performed; point estimates before cross-over not reported. | Applicability: IB
| # sites: 1 | Wash-out: 8wk | | | | | Reported testing: Significant (p=.05) difference between groups, test not specified. | Funding source: Government, hospital
| Location: Australia | | | | | | LDL: (at week 10):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2= point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates before cross-over not reported.
| | | | | | | Reported testing: Significant (p<.02) difference between groups, test not specified.
| | | | | | | HDL: (at week 10):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2= point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates before cross-over not reported.
| | | | | | | Reported testing: No significant difference between groups, test not specified.
| | | | | | | Triglycerides: (at week 10):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2= point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates before cross-over not reported.
| | | | | | | Reported testing: Significant (p<.05) difference between groups, test not specified.
| | | | | | | HgA1c: (at week 10):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2= point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates before cross-over not reported.
| | | | | | | Reported testing: No significant difference between groups, test not specified.
| | | | | | | Fasting blood glucose: (at week 10):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2= point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates before cross-over not reported.
| | | | | | | Reported testing: No significant difference between groups, test not specified.
Goh, 1997^80^ | Sample size: 28 | Design: RXT | Inclusion: | Covariates: Hb A1c. | 1 | Linseed oil Variable dose × 3 mo | Total cholesterol (mg/dl at month 3): | Quality:
| Age (mean/range): 58/NR | Duration: 9 mo | Controlled diabetes/Hb A1c < 9.5% or 10.5% | | 2 | Fish oil Variable dose × 3 mo | Arm 1= point estimate not reported | Jadad: 2
| Race: NR | X-over: month 6 | Exclusion: | | | | Arm 2= point estimate not reported | Concealment of allocation: NR
| % male: NR | Run-in: 3 mo | Lipid lowering drug use | | | | Meta-analysis: Not performed; point estimates before cross-over not reported. | Applicability: NR
| # sites: 1 | Wash-out: None | | | | | Reported testing: No significant difference between arms by ANOVA. | Funding source: Government
| Location: Canada | | | | | | LDL (mg/dl at month 9):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates before cross-over not reported.
| | | | | | | Reported testing: Significant (p=0.0003) difference favoring olive oil (arm 1) using Wilcoxian signed rank test.
| | | | | | | HDL (mg/dl at month 3):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates before cross-over not reported.
| | | | | | | Reported testing: No significant difference between arms by ANOVA.
| | | | | | | Triglycerides (mg/dl at month 3):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates before cross-over not reported.
| | | | | | | Reported testing: Significant (p=0.05) difference favoring fish oil (arm 2) by ANOVA.
| | | | | | | HgA1c (% at month 3)
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates before cross-over not reported.
| | | | | | | Reported testing: No significant difference between arms using Wilcoxian signed rank test.
| | | | | | | HgA1c: NR
| | | | | | | Fasting blood glucose: NR
Hendra, 1990^60^ | Sample size: 80 | Design: RCT | Inclusion: | Covariates: Duration of diabetes/Hypertension/Hypoglycemic treatment/Obesity: BMI=27, kg=72.7, lbs=160 | 1 | Placebo/control Dosage/duration not collected | Total cholesterol (mg/dl at month 1.5) | Quality:
| Age (mean/range): 56/NR | Duration: 1.5 mo | Controlled diabetes/Hyperlipidemia | | 2 | Max EPA (fish oil) 10 g for 6 wk | Arm 1 mean=239.38 | Jadad: 3
| Race: Caucasian, Black, Asian | | Exclusion: | | | | Arm 2 mean=227.80 | Concealment of allocation: NR
| % male: 69 | | PregNRncy/lactating/Cardiovascular disease | | | | Mean difference=-11.58 (-30.89, 7.72) | Applicability: IB
| # sites: 1 | | | | | | Reported testing: Article reports no significant differences (p=0.7) for changes between Arm 1 and Arm 2 with unpaired Student's t tests. | Funding source: industry, hospital
| Location: UK | | | | | | Triglyceride (mg/dl at month 1.5)
| | | | | | | Arm 1 mean=194.69
| | | | | | | Arm 2 mean=150.44
| | | | | | | Mean difference=-44.25 (-89.80, 1.31)
| | | | | | | Reported testing: Article reports significant differences (p<0.001) for changes between Arm 1 and Arm 2 with unpaired Student's t tests.
| | | | | | | HDL (mg/dl at month 1.5)
| | | | | | | Arm 1 mean=46.33
| | | | | | | Arm 2 mean=38.61
| | | | | | | Mean difference=-7.72 (-14.68, -0.76)
| | | | | | | Reported testing: Article reports no significant differences (p=0.6) for changes between Arm 1 and Arm 2 with unpaired Student's t tests.
| | | | | | | LDL (mg/dl at month 1.5)
| | | | | | | Arm 1 mean=162.16
| | | | | | | Arm 2 mean=158.30
| | | | | | | Mean difference=-3.86 (-22.97, 15.25)
| | | | | | | Reported testing: Article reports no significant differences (p=0.085) for changes between Arm 1 and Arm 2 with unpaired Student's t tests.
| | | | | | | Fasting blood glucose (mg/dl at month 1.5)
| | | | | | | Arm 1 mean=203.60
| | | | | | | Arm 2 mean=225.23
| | | | | | | Mean difference=21.62 (-18.06, 61.30)
| | | | | | | Reported testing: Article reports no significant differences (p=0.17) for changes between Arm 1 and Arm 2 with unpaired Student's t tests.
| | | | | | | HbA1c: NR
Hermans^74^ | Sample size: 20 | Design: RCT | Inclusion: Diabetic nephropathy | Covariates: Hypoglycemic treatment/Hb | 1 | Placebo/control NR Dosage NR × 2 mo | Total cholesterol: NR | Quality:
| Age (mean/range): 46/NR | Duration: 2 mo | Exclusion: NR | A1c/Hypertension | 2 | Fish oil 9 g/d × 2 mo | LDL: NR | Jadad: 2
| Race: NR | | | | | | HDL: NR | Concealment of allocation: NR
| % male: NR | | | | | | Triglyceride: (at month 2) | Applicability: NR
| # sites: 1 | | | | | | Arm 1 = point estimate not reported | Funding source: Government
| Location: Belgium | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included; point estimates not reported.
| | | | | | | Reported testing: Testing between groups not reported.
| | | | | | | HgA1c: (at month 2)
| | | | | | | Arm 1 = point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included; point estimates not reported.
| | | | | | | Reported testing: Testing between groups not reported.
| | | | | | | Fasting blood glucose: NR
Jensen, 1989^81^ | Sample size: 18 | Design: RXT | Inclusion: | Covariates: Duration of diabetes/Hypoglycemic treatment | 1 | Olive oil 21 ml/d × 8 wk | Total cholesterol: (at week 10) | Quality
| Age (mean/range): 37 / 22–47 | Duration: 28 wk | Proteinuria/Retinopathy | | 2 | Cod-liver oil (Eskisol) 21 ml/d × 8 wk | Arm 1 = point estimate not reported | Jadad: 2
| Race: NR | X-over: week 20 | Exclusion: NR | | | | Arm 2 = point estimate not reported | Concealment of allocation: NR
| % male: 78 | Run-in: 4 wk | | | | | Meta-analysis: Not included; point estimates not reported before crossover. | Applicability: IIB
| # sites: 1 | Wash-out: 8 wk | | | | | Reported testing: Testing between groups was not significant; either Wilcoxon test for paired differences or paired Student's t-test used. | Funding source: Government
| Location: Denmark | | | | | | LDL: (at week 10)
| | | | | | | Arm 1 = point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included; point estimates not reported before crossover.
| | | | | | | Reported testing: Significant (p<.05) difference between groups; either Wilcoxon test for paired differences or paired Student's t-test used.
| | | | | | | HDL: (at week 10)
| | | | | | | Arm 1 = point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included; point estimates not reported before crossover.
| | | | | | | Reported testing: Testing between groups was not significant; either Wilcoxon test for paired differences or paired Student's t-test used.
| | | | | | | Triglycerides: (at week 10)
| | | | | | | Arm 1 = point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included; point estimates not reported before crossover.
| | | | | | | Reported testing: Significant (p<.05) difference between groups favoring cod-liver oil; either Wilcoxon test for paired differences or paired Student's t-test used.
| | | | | | | Change in HgA1c(at week 10)
| | | | | | | Arm 1 = point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included; point estimates not reported before crossover.
| | | | | | | Reported testing: Statistical testing between groups was not reported
Luo, 1998^82^ | Sample size: NR | Design: RXT | Inclusion: | Covariates: Duration of diabetes/Hb A1c/Obesity: BMI=27, kg=72.7, lbs=160/Hypoglycemic treatment | 1 | Sunflower oil 6g/d × 2 mo | Total cholesterol: (at month 2) | Quality:
| Age (mean/range): 54/NR | Duration: 6 mo | Hb A1c < 9.5% or 10.5%/Fasting blood glucose | | 2 | Fish oil 6 g/d × 2 mo | Arm 1 = point estimate not reported | Jadad: 2
| Race: NR | X-over: month 2 | Exclusion: | | | | Arm 2 = point estimate not reported | Concealment of allocation: Yes
| % male: 10 | Run-in: None | ReNRl disease/Thyroid abnormalities/Liver disease/Lipid lowering drug use/GI disorders | | | | Meta-analysis: Not included; point estimates not reported before crossover. | Applicability: IIB
| # sites: 1 | Wash-out: 2 mo | | | | | Reported testing: No treatment effect by ANOVA. | Funding source: Government, industry
| Location: Portugal | | | | | | LDL: (at month 2)
| | | | | | | Arm 1 = point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included; point estimates not reported before crossover.
| | | | | | | Reported testing: No treatment effect by ANOVA.
| | | | | | | HDL: (at month 2)
| | | | | | | Arm 1 = point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included; point estimates not reported before crossover.
| | | | | | | Reported testing: No treatment effect by ANOVA.
| | | | | | | Triglycerides: (at month 2)
| | | | | | | Arm 1 = point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included; point estimates not reported before crossover.
| | | | | | | Reported testing: Significant (p<.05) treatment effect for arm 2 (fish oil) by ANOVA.
| | | | | | | HgA1c: (at month 2)
| | | | | | | Arm 1 = point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included; point estimates not reported before crossover.
| | | | | | | Reported testing: No treatment effect by ANOVA.
| | | | | | | Fasting blood glucose: (at month 2)
| | | | | | | Arm 1 = point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included; point estimates not reported before crossover.
| | | | | | | Reported testing: No treatment effect by ANOVA.
Maffettone, 1996^73^ | Sample size: 16 | Design: RCT | Inclusion: | Covariates: NR | 1 | Placebo/control Dosage/duration not collected | Total cholesterol: NR | Quality:
| Age (mean/range): 56/NR | Duration: 6 mo | Diabetes type II > 2 years/ elevated triglycerides/age 40–75 | | 2 | Fish oil 2 g for 6 mo | Triglyceride: NR | Jadad: 3
| Race: NR | | Exclusion: | | | | HDL (mg/dl at month 6) | Concealment of allocation: NR
| % male: 40 | | End organ failure/coagulopathy/anticoagulants | | | | Arm 1 mean=36.68 | Applicability: IIB
| # sites: NR | | | | | | Arm 2 mean=34.36 | Funding source: NR
| Location: Italy | | | | | | MD =-2.32 (-10.69, 6.06)
| | | | | | | Reported testing: Article reports no significant differences (p>0.05) for changes between Arm 1 and Arm 2.
| | | | | | | LDL (mg/dl at month 6)
| | | | | | | Arm 1 mean=127.41
| | | | | | | Arm 2 mean=127.02
| | | | | | | Mean difference=-0.39 (-47.32, 46.55)
| | | | | | | Reported testing: Article reports no significant differences (p>0.05) for changes between Arm 1 and Arm 2.
| | | | | | | Fasting blood glucose: NR
| | | | | | | HbA1c: NR
McGrath, 1996^83^ | Sample size: 23 | Design: RXT | Inclusion: | Covariates: Obesity: BMI=27, kg=72.7, lbs=160/Hypoglycemic treatment/Duration of diabetes/Hb A1c | 1 | Olive oil 10g/d × 6 wk | Total cholesterol: (at week 6) | Quality:
| Age (mean/range): 53/44–61 | Duration: 18 wk | NR | | 2 | Max EPA (fish oil) 10 g/d × 6 wk | Arm 1 = point estimate not reported | Jadad: 3
| Race: NR | X-over: week 6 | Exclusion: | | | | Arm 2 = point estimate not reported | Concealment of allocation: NR
| % male: 87 | Run-in: None | Cardiovascular disease/Hypertension/ReNRl disease/Lipid lowering drug use/Antihypertensive meds/Cardiovascular drugs | | | | Meta-analysis: Not included; point estimates not reported before crossover. | Applicability: IIB
| # sites: 1 | Wash-out: 6 wk | | | | | Reported testing: No treatment effect by ANOVA. | Funding source: Government
| Location: UK | | | | | | LDL: (at week 6)
| | | | | | | Arm 1 = point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included; point estimates not reported before crossover.
| | | | | | | Reported testing: No treatment effect by ANOVA.
| | | | | | | HDL: (at week 6)
| | | | | | | Arm 1 = point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included; point estimates not reported before crossover.
| | | | | | | Reported testing: No treatment effect by ANOVA.
| | | | | | | Triglycerides: (at week 6)
| | | | | | | Arm 1 = point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included; point estimates not reported before crossover.
| | | | | | | Reported testing: No treatment effect by ANOVA.
| | | | | | | HgA1c: (at week 6)
| | | | | | | Arm 1 = point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included; point estimates not reported before crossover.
| | | | | | | Reported testing: No treatment effect by ANOVA.
| | | | | | | Fasting blood glucose: (at week 6)
| | | | | | | Arm 1 = point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included; point estimates not reported before crossover.
| | | | | | | Reported testing: No treatment effect by ANOVA.
Meshcheriakova, 2001^66^ | Sample size: 120 | Design: RCT | Inclusion: | Covariates: Duration of diabetes/Obesity: BMI=27, kg=72.7, lbs=160/Hb A1c | 1 | Low-fat and low-sodium diet | Total cholesterol (mg/dl at week 4) | Quality:
| Age (mean/range): 55/39–65 | Duration: 4 wk | Controlled diabetes/Hyperlipedemia/Age | | 2 | Eiconol 8 g for 4 wk | Arm 1 mean=244.40 | Jadad: 1
| Race: NR | | Exclusion: | | 3 | Linseed oil 18 g for 4 wk | Arm 2 and Arm 3 (combined) mean=249.03 | Concealment of allocation: NR
| % male: NR | | NR | | | | Mean difference=4.63 (-15.75, 25.01) | Applicability: NR
| # sites: 1 | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2. | Funding source: Government
| Location: Russia | | | | | | LDL: NR
| | | | | | | HDL: NR
| | | | | | | Triglyceride (mg/dl at week 4)
| | | | | | | Arm 1 mean=283.19
| | | | | | | Arm 2 and Arm 3 (combined) mean=247.79
| | | | | | | Mean difference=-35.40 (-88.83, 18.03)
| | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2.
| | | | | | | HgA1c: NR
| | | | | | | Fasting blood glucose: NR
Morgan, 1995^61^ | Sample size: 40 | Design: RCT | Inclusion: Hyperlipedemia/Controlled diabetes | Covariates: Hb A1c/Hypoglycemic treatment/Duration of diabetes | 1 | Placebo/control Dosage/duration not collected | Total cholesterol (mg/dl at month 3) | Quality:
| Age (mean/range): 54/NR | Duration: 3.0 mo | Exclusion: NR | | 2 | Placebo/control Dosage/duration not collected | Arm 1 mean=263.71 | Jadad: 2
| Race: Caucasian, Black, Hispanic | | | | 3 | Fish oil 18 g for 12 wk | Arm 2 mean=250.58 | Concealment of allocation: NR
| % male: 45 | | | | 4 | Fish oil 18 g for 12 wk | Mean difference=-13.13 (-37.43, 11.18) | Applicability: IB
| # sites: 1 | | | | | | Reported testing: Article reports no significant differences (p>0.05). | Funding source: Hospital, industry
| Location: US | | | | | | Triglyceride (mg/dl at month 3)
| | | | | | | Arm 1 mean=760.17
| | | | | | | Arm 2 mean=413.27
| | | | | | | Mean difference=-346.90 (-656.00, -37.81)
| | | | | | | Reported testing: Article reports significant differences (p=0.0001) between Arm 1 and Arm 2.
| | | | | | | HDL (mg/dl at month 3)
| | | | | | | Arm 1 mean=35.91
| | | | | | | Arm 2 mean=38.61
| | | | | | | Mean difference=2.70 (-6.18, 11.58)
| | | | | | | Reported testing: Article reports no significant differences (p>0.05).
| | | | | | | LDL (mg/dl at month 3)
| | | | | | | Arm 1 mean=149.42
| | | | | | | Arm 2 mean=157.53
| | | | | | | Mean difference=8.11 (-19.46, 35.67)
| | | | | | | Reported testing: Article reports no significant differences (p>0.05).
| | | | | | | Fasting blood glucose (mg/dl at month 3)
| | | | | | | Arm 1 mean=223.42
| | | | | | | Mean difference=-14.41 (-52.95, 24.12)
| | | | | | | Reported testing: Article reports no significant differences (p>0.05).
| | | | | | | HbA1c (% at month 3)
| | | | | | | Arm 1 mean=7.80
| | | | | | | Arm 2 mean=7.70
| | | | | | | Mean difference=-0.10 (-1.25, 1.05)
| | | | | | | Reported testing: Article reports no significant differences (p>0.05).
Morgan,^67^ | Sample size: 25 | Design: RCT | Inclusion: | Covariates: Hypoglycemic treatment/Duration of diabetes/Obesity: BMI=27, kg=72.7, lbs=160/Hyperlipidemia | 1 | Placebo/control Dosage/duration not collected | Total cholesterol (mg/dl at week 12) | Quality:
| Age (mean/range): 54/41–64 | Duration: 5.3 mo | Age/Hyperlipidemia | | 2 | Placebo/control Dosage/duration not collected | Arm 1 (Low dosage placebo) mean=282.00 | Jadad: 4
| Race: Caucasian, Black, Hispanic | | Exclusion: | | 3 | Fish oil 18 g for 12 wk | Arm 3 (Low dosage fish oil) mean=245.00 | Concealment of allocation: Yes
| % male: 40 | | Cardiovascular disease/Liver disease/PregNRncy/lactating/ReNRl disease/Thyroid abnormalities/Alcohol use/Cardiovascular drugs/Hormone replacement treatment | | 4 | Fish oil 9 g for 12 wk | Mean difference=-37.00 (-96.98, 22.98) | Applicability: IB
| # sites: 1 | | | | | | Arm 2 (High dosage placebo) mean=249.00 | Funding source: NR
| Location: US | | | | | | Arm 4 (High dosage fish oil) mean=273.00
| | | | | | | Mean difference=24.00 (-5.75, 53.75)
| | | | | | | Reported testing: Article reports no significant differences (p>0.05).
| | | | | | | Triglyceride (mg/dl at week 12)
| | | | | | | Arm 1 (Low dosage placebo) mean=311.00
| | | | | | | Arm 2 (Low dosage fish oil) mean=195.00
| | | | | | | Mean difference=-116.00 (-267.44, 35.44)
| | | | | | | Arm 1 (High dosage placebo) mean=204.00
| | | | | | | Arm 2 (High dosage fish oil) mean=197.00
| | | | | | | Mean difference=-7.00 (-110.19, 96.19)
| | | | | | | HDL (mg/dl at week 12)
| | | | | | | Arm 1 (Low dosage placebo) mean=23.00
| | | | | | | Arm 3 (Low dosage fish oil) mean=32.00
| | | | | | | Mean difference=9.00 (-3.49, 21.49)
| | | | | | | Arm 2 (High dosage placebo) mean=37.00
| | | | | | | Arm 4 (High dosage fish oil) mean=46.00
| | | | | | | Mean difference=9.00 (-13.03, 31.03)
| | | | | | | Reported testing: Article reports no significant differences (p>0.05).
| | | | | | | LDL (mg/dl at week 12)
| | | | | | | Arm 1 (Low dosage placebo) mean=157.00
| | | | | | | Arm 3 (Low dosage fish oil) mean=165.00
| | | | | | | Mean difference=8.00 (-52.53, 68.53)
| | | | | | | Arm 2 (High dosage placebo) mean=134.00
| | | | | | | Arm 4 (High dosage fish oil) mean=157.00
| | | | | | | Mean difference=23.00 (-31.39, 77.39)
| | | | | | | Reported testing: Article reports no significant differences (p>0.05).
| | | | | | | Fasting blood glucose (mg/dl at week 12)
| | | | | | | Arm 1 (Low dosage placebo) mean=252.00
| | | | | | | Arm 2 (Low dosage fish oil) mean=211.00
| | | | | | | Mean difference=-41.00 (-114.16, 32.16)
| | | | | | | Arm 1 (High dosage placebo) mean=226.00
| | | | | | | Arm 2 (High dosage fish oil) mean=209.00
| | | | | | | Mean difference=-17.00 (-89.43, 55.43)
| | | | | | | Reported testing: Article reports no significant differences (p>0.05).
| | | | | | | HbA1c (% at week 12)
| | | | | | | Arm 1 (Low dosage placebo) mean=8.80
| | | | | | | Arm 2 (Low dosage fish oil) mean=7.50
| | | | | | | Mean difference=-1.30 (-3.42, 0.82)
| | | | | | | Arm 1 (High dosage placebo) mean=7.30
| | | | | | | Arm 2 (High dosage fish oil) mean=8.00
| | | | | | | Mean difference=0.70 (-0.68, 2.08)
| | | | | | | Reported testing: Article reports no significant differences (p>0.05).
Patti, 1999^68^ | Sample size: 1006 | Design: RCT | Inclusion: | Covariates: Hb A1c/Obesity: BMI=27, kg=72.7, lbs=160/Hypoglycemic treatment/Duration of diabetes | 1 | Placebo/control Dosage/duration not collected | Total cholesterol (mg/dl at month 6) | Quality:
| Age (mean/range): 57/NR | Duration: 6.0 mo | Age/WHO diabetes criteria/Disease > 1 year/Controlled diabetes/No weight change in previous 2 or 3 mo/Hyperlipidemia/Diet treatment=1 yr/Postmenopausal women ± hormone replacement | | 2 | Fish oil Variable dose for 6 mo | Arm 1 mean=239.77 | Jadad: 2
| Race: NR | | Exclusion: | | | | Arm 2 mean=220.46 | Concealment of allocation: NR
| % male: 44 | | Lipid lowering drug use/Antiplatelet or anticoagulation/Liver disease/ReNRl disease/Bleeding disorder/Proliferative retinopathy/Intraocular hemorrhage | | | | Mean difference=-19.31 (-57.98, 19.37) | Applicability: IB
| # sites: 1 | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2. | Funding source: Government, industry
| Location: Italy | | | | | | Triglyceride (mg/dl at month 6)
| | | | | | | Arm 1 mean=277.88
| | | | | | | Arm 2 mean=258.41
| | | | | | | Mean difference=-19.47 (-89.24, 50.30)
| | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2.
| | | | | | | HDL (mg/dl at month 6)
| | | | | | | Arm 1 mean=36.68
| | | | | | | Arm 2 mean=34.36
| | | | | | | Mean difference=-2.32 (-10.78, 6.14)
| | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2.
| | | | | | | LDL: NR
| | | | | | | Fasting blood glucose (mg/dl at month 6)
| | | | | | | Arm 1 mean=185.59
| | | | | | | Arm 2 mean=196.40
| | | | | | | Mean difference=10.81 (-28.67, 50.29)
| | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2.
| | | | | | | HbA1c (% at month 6)
| | | | | | | Arm 1 mean=7.70
| | | | | | | Arm 2 mean=8.30
| | | | | | | Mean difference=0.60 (-0.79, 1.99)
| | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2.
Pelikanova, 1993^62^ | Sample size: 20 | Design: RCT | Inclusion: | Covariates: Hb A1c/Obesity: BMI=27, kg=72.7, lbs=160/Malabsortion | 1 | Placebo/control Dosage/duration not collected | Total cholesterol (mg/dl at week 3) | Quality:
| Age (mean/range): 52/40–60 | Duration: 0.8 mo | Age/Hyperlipidemia/Controlled diabetes | | 2 | Fish oil 15 ml for 3 wk | Arm 1 mean=236.68 | Jadad: 1
| Race: NR | | Exclusion: | | | | Arm 2 mean=255.60 | Concealment of allocation: NR
| % male: 100 | | NR | | | | Mean difference=18.92 (-12.96, 50.80) | Applicability: IIB
| # sites: 1 | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2. | Funding source: Government
| Location: Czech Republic | | | | | | Triglyceride (mg/dl at week 3)
| | | | | | | Arm 1 mean=168.14
| | | | | | | Arm 2 mean=131.86
| | | | | | | Mean difference=-36.28 (-101.90, 29.33)
| | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2.
| | | | | | | HDL: NR
| | | | | | | LDL: NR.
| | | | | | | Fasting blood glucose: NR
| | | | | | | HbA1c (% at week 3)
| | | | | | | Arm 1 mean=7.50
| | | | | | | Arm 2 mean=8.40
| | | | | | | Mean difference=0.90 (0.02, 1.78)
| | | | | | | Reported testing: Article reports no significant differences between Arm 1 and Arm 2.
Petersen, 2002^63^ | Sample size: 42 | Design: RCT | Inclusion: | Covariates: Hypoglycemic treatment/Duration of diabetes/Hb A1c/Hypertension | 1 | Placebo/control Dosage/duration not collected | Total cholesterol (mg/dl at month 2) | Quality:
| Age (mean/range): 63/33–85 | Duration: 2.0 mo | Disease > 1 year/Hyperlipidemia/Diabetes onset at 30 years up/Not postmenopausal or hormone replacement | | 2 | Futura 1000 (fish oil) 4 g for 8 wk | Arm 1 mean=209.65 | Jadad: 3
| Race: NR | | Exclusion: | | | | Arm 2 mean=226.64 | Concealment of allocation: NR
| % male: 62 | | Lipid lowering drug use/No fish or fish supplement/Alcohol use | | | | Mean difference=16.99 (-5.97, 39.95) | Applicability: IB
| # sites: 1 | | | | | | Reported testing: Article reports no significant differences (p=0.162) between Arm 1 and Arm 2. | Funding source: government, industry
| Location: Denmark | | | | | | Triglyceride (mg/dl at month 2)
| | | | | | | Arm 1 mean=240.71
| | | | | | | Arm 2 mean=160.18
| | | | | | | Mean difference=-80.53 (-175.69, 14.63)
| | | | | | | Reported testing: Article reports no significant differences (p=0.105) between Arm 1 and Arm 2.
| | | | | | | HDL (mg/dl at month 2)
| | | | | | | Arm 1 mean=42.86
| | | | | | | Arm 2 mean=49.42
| | | | | | | Mean difference=6.56 (0.13, 13.00)
| | | | | | | Reported testing: Article reports no significant differences (p=0.062) between Arm 1 and Arm 2.
| | | | | | | LDL (mg/dl at month 0.5)
| | | | | | | Arm 1 mean=110.81
| | | | | | | Arm 2 mean=132.43
| | | | | | | Mean difference=21.62 (2.79, 40.45)
| | | | | | | Reported testing: Article reports significant differences (p=0.031) between Arm 1 and Arm 2.
| | | | | | | Fasting blood glucose: (at month 0.5)
| | | | | | | Arm 1: point estimate not reported.
| | | | | | | Arm 2: point estimate not reported.
| | | | | | | Meta-analysis: Not included; point estimates not reported.
| | | | | | | Reported testing: Article reports ‘no significant changes.’
| | | | | | | HgA1c: (at month 0.5)
| | | | | | | Arm 1: point estimate not reported.
| | | | | | | Arm 2: point estimate not reported.
| | | | | | | Meta-analysis: Not included; point estimates not reported.
| | | | | | | Reported testing: Article reports 'no significant changes.
Puhakainen, 1995^86^ | Sample size: 9 | Design: RXT | Inclusion: | Covariates: Duration of diabetes/Hb A1c/Obesity: BMI=27, kg=72.7, lbs=160/Hypoglycemic treatment | 1 | Corn and olive oils 12 g/d × 6 wk | Total cholesterol: (at week 6) | Quality:
| Age (mean/range): 53/NR | Duration: 12 wk | NR | | 2 | Max EPA (fish oil) 12 g/d × 6 wk | Arm 1 = point estimate not reported | Jadad: 2
| Race: NR | X-over: week 6 | Exclusion: | | | | Arm 2 = point estimate not reported | Concealment of allocation: NR
| % male: 44 | Run-in: None | Cardiovascular disease | | | | Meta-analysis: Not included; point estimates not reported before crossover. | Applicability: IB
| # sites: 1 | Wash-out: None | | | | | Reported testing: No difference between groups by paired Student's t test . | Funding source: Government
| Location: Finland | | | | | | LDL: (at week 6)
| | | | | | | Arm 1 = point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included; point estimates not reported before crossover.
| | | | | | | Reported testing: No difference between groups by paired Student's t test.
| | | | | | | HDL: (at week 6)
| | | | | | | Arm 1 = point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included; point estimates not reported before crossover.
| | | | | | | Reported testing: No difference between groups by paired Student's t test.
| | | | | | | Triglycerides: (at week 6)
| | | | | | | Arm 1 = point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included; point estimates not reported before crossover.
| | | | | | | Reported testing: Significant (p<.05) difference between groups favoring fish oil by Student's t test.
| | | | | | | HgA1c: (at week 6)
| | | | | | | Arm 1 = point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included; point estimates not reported before crossover.
| | | | | | | Reported testing: Reported testing: No difference between groups by paired Student's t test.
| | | | | | | Fasting blood glucose: (at week 6)
| | | | | | | Arm 1 = point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included; point estimates not reported before crossover.
| | | | | | | Reported testing: Reported testing: No difference between groups by paired Student's t test.
Rivellese, 1996^69^ | Sample size: 904 | Design: RCT | Inclusion: | Covariates: Hypoglycemic treatment/Duration of diabetes/Hb A1c/Obesity: BMI=27, kg=72.7, lbs=160 | 1 | Olive oil Variable dose × 6 mo | Total cholesterol: (mmol/l at month 6) | Quality:
| Age (mean/range): 57/NR | Duration: 6 mo | WHO diabetes criteria/Controlled diabetes/Diet treatment=1 yr/No weight change in previous 2 or 3 mo/Hyperlipidemia/Age/Postmenopausal women ± hormone replacement/Disease > 1 year | | 2 | Fish oil Variable dose × 6 mo | Arm 1= point estimate not reported | Jadad: 2
| Race: NR | | Exclusion: | | | | Arm 2= 5.7 mmol/l | Concealment of allocation: NR
| % male: 44 | | Intraocular hemorrhage/Liver disease/ReNRl disease/Bleeding disorder/Proliferative retinopathy/Antiplatelet or anticoagulation/Lipid lowering drug use | | | | Meta-analysis: Not included; point estimate for Arm 1 not reported. | Applicability: IB
| # sites: 1 | | | | | | Reported testing: Testing between arms was not reported. | Funding source: Government, industry
| Location: Italy | | | | | | LDL (mg/dl at month 6)
| | | | | | | Arm 1 mean=127.41
| | | | | | | Arm 2 mean=127.02
| | | | | | | Mean difference=-0.39 (-47.31, 46.54)
| | | | | | | Reported testing: Article reports no significant differences (p>0.05) for changes between Arm 1 and Arm 2.
| | | | | | | HDL: (mmol/l at month 6)
| | | | | | | Arm 1= 0.25
| | | | | | | Arm 2= 0.19
| | | | | | | Meta-analysis: Not included.
| | | | | | | Reported testing: No significant difference between groups using paired Student's t test.
| | | | | | | Triglycerides: Not reported
| | | | | | | Note: triglyceride contend of specific lipoproteins was reported, but not total serum triglycerides.
| | | | | | | HgA1c: (%at month 6)
| | | | | | | Arm 1 = 6.9
| | | | | | | Arm 2 = 8.3
| | | | | | | Meta-analysis: Not included.
| | | | | | | Reported testing: No difference between groups by paired Student's t test.
| | | | | | | Fasting blood glucose: (mmol/l at month 6)
| | | | | | | Arm 1 = 10.3
| | | | | | | Arm 2 = 10.9
| | | | | | | Meta-analysis: Not included.
| | | | | | | Reported testing: No difference between groups by paired Student's t test.
Sarkkinen, 1996^70^ | Sample size: 31 | Design: RCT | Inclusion: WHO diabetes criteria/WHO Dosage/duration not Age (mean/range): impaired glucose tolerance criteria | Covariates: NR | 1 | Sunflower oil Dosage/duration not collected | Total cholesterol (mg/dl at month 2) | Quality:
| Age (mean/range): 56/NR | Duration: 2 mo | Exclusion: NR | | 2 | Rapeseed (LEAR) oil Dosage/duration NR | Arm 1 mean=232.82 | Jadad: 1
| Race: NR | | | | | | Arm 2 mean=215.06 | Concealment of allocation: NR
| % male: 59 | | | | | | Mean difference=-17.76 (-45.21, 9.69) | Applicability: IB
| # sites: 1 | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2. | Funding source: Government
| Location: Finland | | | | | | Triglyceride (mg/dl at month 2)
| | | | | | | Arm 1 mean=151.33
| | | | | | | Arm 2 mean=128.32
| | | | | | | Mean difference=-23.01 (-80.05, 34.03)
| | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2.
| | | | | | | HDL (mg/dl at month 2)
| | | | | | | Arm 1 mean=49.03
| | | | | | | Arm 2 mean=45.94
| | | | | | | Mean difference=-3.09 (-9.84, 3.67)
| | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2.
| | | | | | | LDL (mg/dl at month 2)
| | | | | | | Arm 1 mean=151.74
| | | | | | | Arm 2 mean=141.70
| | | | | | | Mean difference=-10.04 (-37.38, 17.30)
| | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2.
| | | | | | | Fasting blood glucose: (mg/dl at month 2)
| | | | | | | Arm 1 = point estimate not reported.
| | | | | | | Arm 2 = point estimate not reported.
| | | | | | | Meta-analysis: Not included; point estimates not reported.
| | | | | | | Reported testing: No significant difference between Arm 1 and Arm 2 using Students t test.
| | | | | | | HgA1c: NR
Schectman, 1988^87^ | Sample size: 13 | Design: RXT | Inclusion: | Covariates: Obesity: BMI=27, kg=72.7, lbs=160/Hyperlipidemia/Hypoglycemic treatment/Hypertension | 1 | Safflower oil 12g/d × 4 wk | Total cholesterol: (at week 7) | Quality:
| Age (mean/range): 52/29–66 | Duration: 15 wk | Hyperlipidemia/Diet treatment=1 yr/Controlled diabetes | | 2 | Max EPA (fish oil) 12 g/d × 4 wk | Arms 1, 2 = point estimates not reported. | Jadad: 2
| Race: NR | X-over: week 11 | Exclusion: | | | | Meta-analysis: Not included; point estimates before cross over not reported. | Concealment of allocation: NR
| % male: 69 | Run-in: 3 wk | Liver disease/ReNRl disease/Thyroid abnormalities/Diabetes/Lipid lowering drug use/No fish or fish supplement | | | | Reported testing: A tendency towards an increase with fish oil by ANOVA (p<0.05). | Applicability: IB
| # sites: 1 | Wash-out: 4 wk | | | | | LDL: (at week 7) | Funding source: Government
| Location: US | | | | | | Arms 1, 2 = point estimates not reported.
| | | | | | | Meta-analysis: Not included; point estimates before cross over not reported.
| | | | | | | Reported testing: A tendency towards an increase with fish oil by ANOVA (p<0.05).
| | | | | | | HDL: (at week 7)
| | | | | | | Arms 1, 2 = point estimates not reported.
| | | | | | | Meta-analysis: Not included; point estimates before cross over not reported.
| | | | | | | Reported testing: No significant treatment effect by ANOVA.
| | | | | | | Change in Triglycerides: (at week 7)
| | | | | | | Arms 1, 2 = point estimates not reported.
| | | | | | | Meta-analysis: Not included; point estimates before cross over not reported.
| | | | | | | Reported testing: A tendency towards an increase with fish oil by ANOVA (p<0.05).
| | | | | | | Fasting blood glucose: (at week 7)
| | | | | | | Arms 1, 2 = point estimates not reported.
| | | | | | | Meta-analysis: Not included; point estimates before cross over not reported.
| | | | | | | Reported testing: A tendency towards an increase with fish oil by ANOVA (p<0.05).
| | | | | | | HgA1c. (at week 7)
| | | | | | | Arms 1, 2 = point estimates not reported.
| | | | | | | Meta-analysis: Not included; point estimates before cross over not reported.
| | | | | | | Reported testing: No significant treatment effect by ANOVA.
Schwab, 1998^88^ | Sample size: 31 | Design: RCT | Inclusion: WHO diabetes criteria/WHO impaired glucose tolerance criteria | Covariates: Obesity: BMI=27, kg=72.7, lbs=160/Hypertension | 1 | Sunflower oil Dosage NR × 8 wk | Total cholesterol: (at week 8) | Quality:
| Age (mean/range): 56/47–64 | Duration: 8 wk | Exclusion: | | 2 | Rapeseed (LEAR) oil Dosage NR × 8 wk | Arms 1, 2 = point estimates not reported. | Jadad: 1
| Race: NR | | NR | | | | Meta-analysis: Not included; point estimates before cross over not reported. | Concealment of allocation: NR
| % male: 59 | | | | | | Reported testing: No significant difference between groups by paired Student's t test. | Applicability: IB
| # sites: 1 | | | | | | LDL: (at week 8) | Funding source: Government, nonindustry, private
| Location: Finland | | | | | | Arms 1, 2 = point estimates not reported.
| | | | | | | Meta-analysis: Not included; point estimates before cross over not reported.
| | | | | | | Reported testing: No significant difference between groups by paired Student's t test.
| | | | | | | HDL: (at week 8)
| | | | | | | Arms 1, 2 = point estimates not reported.
| | | | | | | Meta-analysis: Not included; point estimates before cross over not reported.
| | | | | | | Reported testing: No significant difference between groups by paired Student's t test.
| | | | | | | Change in Triglycerides: (at week 8)
| | | | | | | Arms 1, 2 = point estimates not reported.
| | | | | | | Meta-analysis: Not included; point estimates before cross over not reported.
| | | | | | | Reported testing: No significant difference between groups by paired Student's t test.
| | | | | | | Fasting blood glucose: NR
| | | | | | | HgA1c. NR
Shimizu, 1995^56^ | Sample size: 45 | Design: RCT | Inclusion: Normal BUN/Normal serum creatinine | Covariates: Hypertension/Hypoglycemic treatment/Duration of diabetes | 1 | Placebo/control Dosage/duration not collected | Total cholesterol (mg/dl at month 12) | Quality:
| Age (mean/range): 63/NR | Duration: 12 mo | Exclusion: NR | | 2 | EPA-E 900 mg for 12 hr | Arm 1 mean=191.00 | Jadad: 1
| Race: NR | | | | | | Arm 2 mean=203.40 | Concealment of allocation: NR
| % male: 49 | | | | | | Mean difference=12.40 (-2.30, 27.10) | Applicability: IB
| # sites: 1 | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2. | Funding source: unclear
| Location: Japan | | | | | | Triglyceride (mg/dl at month 12)
| | | | | | | Arm 1 mean=162.00
| | | | | | | Arm 2 mean=192.40
| | | | | | | Mean difference=30.40 (-23.37, 84.17)
| | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2.
| | | | | | | HDL (mg/dl at month 12)
| | | | | | | Arm 1 mean=50.00
| | | | | | | Arm 2 mean=55.80
| | | | | | | Mean difference=5.80 (-2.70, 14.30)
| | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2.
| | | | | | | LDL: NR
| | | | | | | Fasting blood glucose: NR
| | | | | | | HbA1c (% at month 12)
| | | | | | | Arm 1 mean=7.76
| | | | | | | Arm 2 mean=7.82
| | | | | | | Mean difference=0.06(-8.44, 8.56)
| | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2.
Sirtori, 1997^89^ | Sample size: 935 | Design: RCT | Inclusion: | Covariates: Obesity: BMI=27, kg=72.7, lbs=160 | 1 | Olive oil Variable dose × 6 mo | Total cholesterol: (at month 6) | Quality:
| Age (mean/range): 59/NR | Duration: 6 mo | Age/Hyperlipidemia/Disease > 1 year/Controlled diabetes | | 2 | Esapent (fish oil) Variable dose × 6 mo | Arms 1, 2 = point estimates not reported. | Jadad: 4
| Race: NR | | Exclusion: | | | | Meta-analysis: Not included; point estimates not reported; graphical data only. | Concealment of allocation: NR
| % male: 62 | | ReNRl disease/Lipid lowering drug use/Cardiovascular disease/Reliable adherence/Alcohol use/Cardiovascular drugs/Insulin treatment/Obesity | | | | Reported testing: No difference between arms by ANOVA. | Applicability: IB
| # sites: 63 | | | | | | LDL: (at month 6) | Funding source: Government
| Location: Italy | | | | | | Arms 1, 2 = point estimates not reported.
| | | | | | | Meta-analysis: Not included; point estimates not reported; graphical data only.
| | | | | | | Reported testing: Significant (p<.048) difference between arms with higher LDL in fish oil arm by ANOVA.
| | | | | | | HDL: (at month 6)
| | | | | | | Arms 1, 2 = point estimates not reported.
| | | | | | | Meta-analysis: Not included; point estimates not reported; graphical data only.
| | | | | | | Reported testing: No difference between arms by ANOVA.
| | | | | | | Change in Triglycerides: (at month 6)
| | | | | | | Arms 1, 2 = point estimates not reported.
| | | | | | | Meta-analysis: Not included; point estimates not reported; graphical data only.
| | | | | | | Reported testing: Significant (p<.0001) difference between arms with lower triglyceride in fish oil arm by ANOVA.
| | | | | | | Fasting blood glucose: : (at month 6)
| | | | | | | Arms 1, 2 = point estimates not reported.
| | | | | | | Meta-analysis: Not included; point estimates not reported; graphical data only.
| | | | | | | Reported testing: No difference between arms by ANOVA.
| | | | | | | HgA1c. : (at month 6)
| | | | | | | Arms 1, 2 = point estimates not reported.
| | | | | | | Meta-analysis: Not included; point estimates not reported; graphical data only.
| | | | | | | Reported testing: No difference between arms by ANOVA.
Sirtori, 1998^64^ | Sample size: 935 | Design: RCT | Inclusion: | Covariates: Obesity: BMI=27, kg=72.7, lbs=160 | 1 | Olive oil Variable dose × 12 mo | Total cholesterol (change from graph data mg/dl at month 6): | Quality:
| Age (mean/range): 59/NR | Duration: 12 mo | Hyperlipidemia/Age/Disease > 1 year/Controlled diabetes | | 2 | Esapent (fish oil)Variable dose for 12 mo | Arm 1: +0.5 | Jadad: 3
| Race: NR | | Exclusion: | | | | Arm 2: -1.0 | Concealment of allocation: NR
| % male: 62 | | Lipid lowering drug use/Reliable adherence/ReNRl disease/Alcohol use/Cardiovascular disease/Cardiovascular drugs/Insulin treatment/Obesity | | | | Meta-analysis: Not included; point estimates not reported; graphical data only. | Applicability: IB
| # sites: 63 | | | | | | Reported testing: No significant difference between groups using repeated measures ANOVA. | Comments: Meta-analysis performed on HgA1c and fasting blood glucose.
| Location: Italy | | | | | | LDL(change mg/dl at month 6) : | Funding source: Government
| | | | | | | Arm 1: point estimate not reported
| | | | | | | Arm 2: +8.16
| | | | | | | Meta-analysis: Not included; point estimates not reported; graphical data only.
| | | | | | | Reported testing: Borderline significant (p=0.046) between fish oil (Arm 1) and olive oil (Arm 2) using repeated measures ANOVA
| | | | | | | HDL (% change mg/dl at month 6):
| | | | | | | Arm 1: + 5%
| | | | | | | Arm 2: + 5%
| | | | | | | Meta-analysis: Not included; point estimates not reported.
| | | | | | | Reported testing: No significant difference between groups using repeated measures ANOVA
| | | | | | | Triglycerides(change from graph data mg/dl at month 6):
| | | | | | | Arm 1: -20
| | | | | | | Arm 2: -62
| | | | | | | Meta-analysis: Not included; point estimates not reported; graphical data only.
| | | | | | | Reported testing: Significant (P<0.0001) difference between fish oil (Arm 1) and olive oil (Arm 2) using repeated measures ANOVA
| | | | | | | Fasting blood glucose (mg/dl at month 6)
| | | | | | | Arm 1 mean=142.90
| | | | | | | Arm 2 mean=147.20
| | | | | | | Mean difference=4.30 (-2.82, 11.42)
| | | | | | | Reported testing: Article reports no significant differences (p>0.05) between Arm 1 and Arm 2
| | | | | | | HbA1c (% at month 6)
| | | | | | | Arm 1 mean=6.88
| | | | | | | Arm 2 mean=7.05
| | | | | | | Mean difference=0.17 (-0.12, 0.46)
| | | | | | | Reported testing: Article reports no significant differences (p>0.05) between Arm 1 and Arm 2.
Vandongen, 1988^90^ | Sample size: 22 | Design: CCT | Inclusion: | Covariates: Duration of diabetes/Obesity: BMI=27, kg=72.7, lbs=160/Hypoglycemic treatment | 1 | Usual diet × 3 wk | Total cholesterol (at week 9): | Quality:
| Age (mean/range): 32/20–41 | Duration: 9 wk | Hyperlipidemia/Age | | 2 | Max EPA (fish oil) 15 g/d × 3 wk | Arm 1 = point estimate not reported | Jadad: 0
| Race: NR | | Exclusion: | | | | Arm 2 = point estimate not reported | Concealment of allocation: NR
| % male: 100 | | NR | | | | Meta-analysis: Not included; point estimates not reported | Applicability: IIB
| # sites: 1 | | | | | | Reported testing: Testing between groups not reported | Funding source: government
| Location: Australia | | | | | | HDL (at week 9)
| | | | | | | Arm 1 = point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included; point estimates not reported
| | | | | | | Reported testing: Testing between groups not reported
| | | | | | | LDL (at week 9):
| | | | | | | Arm 1 = point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included; point estimates not reported
| | | | | | | Reported testing: Testing between groups not reported
| | | | | | | Triglycerides (at week 9):
| | | | | | | Arm 1 = point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included; point estimates not reported
| | | | | | | Reported testing: Testing between groups not reported
| | | | | | | HgA1c (at week 9):
| | | | | | | Arm 1 = point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included; point estimates not reported
| | | | | | | Reported testing: Testing between groups not reported
| | | | | | | Fasting blood glucose (at week 9):
| | | | | | | Arm 1 = point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included; point estimates not reported
| | | | | | | Reported testing: Testing between groups not reported
Vessby, 1990^91^ | Sample size: 14 | Design: RXT | Inclusion: | Covariates: NR | 1 | Olive oil 10 g/d × 8 wk | Total cholesterol (at week 8): | Quality:
| Age (mean/range): NR/39–72 | Duration: 16 wk | Diet treatment=1 yr/Controlled diabetes | | 2 | Max EPA (fish oil)10 g/d × 8 wk | Arm 1= point estimate not reported | Jadad: 3
| Race: NR | X-over: week 8 | Exclusion: | | | | Arm 2= point estimate not reported | Concealment of allocation: NR
| % male: 79 | Run-in: None | Lipid lowering drug use | | | | Meta-analysis: Not performed; point estimates before cross-over not reported. | Applicability: IIB
| # sites: 1 | Wash-out: None | | | | | Reported testing: No significant difference between arms using analysis of variance. | Funding source: Government, non- industry, private
| Location: Sweden | | | | | | LDL(at week 8):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2= point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates before cross-over not reported.
| | | | | | | Reported testing: No significant difference between arms using analysis of variance
| | | | | | | HDL(at week 8):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2= point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates before cross-over not reported.
| | | | | | | Reported testing: No significant difference between arms using analysis of variance
| | | | | | | Triglycerides(at week 8):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2= point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates before cross-over not reported.
| | | | | | | Reported testing: No significant difference between arms using analysis of variance
| | | | | | | HgA1c (at week 8):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2= point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates before cross-over not reported.
| | | | | | | Reported testing: No significant difference between arms using analysis of variance.
| | | | | | | Fasting blood glucose (at week 8):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2= point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates before cross-over not reported
| | | | | | | Reported testing: Significant (p=0.007) difference between fish oil (Arm 1) and olive oil (Arm 2) using analysis of variance.
Westerveld, 1993^71^ | Sample size: 24 | Design: RCT | Inclusion: | Covariates: Duration of diabetes/Hypoglycemic treatment/Hb A1c/Obesity: BMI=27, kg=72.7, lbs=160 | 1 | Olive oil 1656 mg/d × 8 wk | Total cholesterol (at week 8): | Quality:
| Age (mean/range): 57/37–71 | Duration:8 wk | WHO diabetes criteria/Clinically stable/Diet treatment=1 yr | | 2 | EPA-E 1800 mg/d × 8 wk | Arm 1= point estimate not reported | Jadad: 4
| Race: NR | | Exclusion: | | 3 | EPA-E 900 mg/d × 8 wk | Arm 2= point estimate not reported | Concealment of allocation: NR
| % male: 63 | | Cardiovascular disease/Lipid lowering drug use/No fish or fish supplement/GI disorders/Liver disease/ReNRl disease/Bleeding disorder/Antiplatelet or anticoagulation | | | | Arm 3= point estimate not reported | Applicability: IB
| # sites: 1 | | | | | | Meta-analysis: Not performed; point estimates not reported. | Funding source: Government
| Location: Netherlands | | | | | | Reported testing: No significant difference between arms using repeated measures ANOVA.
| | | | | | | LDL (at week 8):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2= point estimate not reported
| | | | | | | Arm 3= point estimate not reported
| | | | | | | Meta -analysis: Not performed; point estimates not reported.
| | | | | | | Reported testing: No significant difference between arms using repeated measures ANOVA.
| | | | | | | HDL(at week 8):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2= point estimate not reported
| | | | | | | Arm 3= point estimate not reported
| | | | | | | Meta -analysis: Not performed; point estimates not reported.
| | | | | | | Reported testing: No significant difference between arms using repeated measures ANOVA.
| | | | | | | Triglyceride (at week 8):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2= point estimate not reported
| | | | | | | Arm 3= point estimate not reported
| | | | | | | Meta-analysis: Not performed; point estimates not reported.
| | | | | | | Reported testing: No significant difference between arms using repeated measures ANOVA.
| | | | | | | HbA1c (% at month 2)
| | | | | | | Arm 1 mean=9.30
| | | | | | | Arm 2 and Arm 3 (combined) mean=8.00
| | | | | | | Mean difference=-1.30 (-3.55, 0.95)
| | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2 and Arm 3.
| | | | | | | Fasting blood glucose (at week 8):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2= point estimate not reported
| | | | | | | Arm 3= point estimate not reported
| | | | | | | Meta -analysis: Not performed; point estimates not reported.
| | | | | | | Reported testing: No significant difference between arms using repeated measures ANOVA.
Woodman, 2002^72^ | Sample size: 51 | Design: RCT | Inclusion: | Covariates: Duration of diabetes/Hb A1c/Obesity: BMI=27, kg=72.7, lbs=160/ 0 | 1 | Placebo/control Dosage/duration not collected | Total cholesterol (mg/dl at week 6) | Quality:
| Age (mean/range): 61/NR | Duration: 1.5 mo | Hyperlipidemia/Age/Hb A1c < 9.5% or 10.5%/Controlled diabetes/Nonsmoker/Clinically stable/Fasting blood glucose/Not on insulin treatment | | 2 | EPA 4 g for 6 wk | Arm 1 mean=177.99 | Jadad: 3
| Race: NR | | Exclusion: | | 3 | DHA 4 g for 6 wk | Arm 2 and Arm 3 (combined) mean=173.24 | Concealment of allocation: NR
| % male: 77 | | NSAIDs use/Liver disease/ReNRl disease/Cardiovascular disease/Not moderate or high fish ntake/Microproteinuria/Neuropathy/Smoking | | | | Mean difference=-4.75 (-22.48, 12.97) | Applicability: IIB
| # sites: 1 | | | | | | Reported testing: Article reports no significant EPA effect (p>0.05) and DHA effect (p>0.05) without adjusting baseline value by using the Bonferroni method. | Funding source: Government
| Location: Australia | | | | | | Triglyceride (mg/dl at week 6)
| | | | | | | Arm 1 mean=148.67
| | | | | | | Arm 2 and Arm 3 (combined) mean=109.15
| | | | | | | Mean difference=-39.52 (-68.98, -10.06)
| | | | | | | Reported testing: Article reports significant EPA effect (p<0.05) and DHA effect (p<0.05) without adjusting baseline value by using the Bonferroni method.
| | | | | | | | HDL (mg/dl at week 6)
| | | | | | | Arm 1 mean=41.31
| | | | | | | Arm 2 and Arm 3 (combined) mean=43.33
| | | | | | | Mean difference=2.02 (-4.44, 8.48)
| | | | | | | Reported testing: Article reports no significant EPA effect (p>0.05) and DHA effect (p>0.05) without adjusting baseline value by using the Bonferroni method.
| | | | | | | LDL (mg/dl at week 6)
| | | | | | | Arm 1 mean=106.95
| | | | | | | Arm 2 and Arm 3 (combined) mean=107.45
| | | | | | | Mean difference=0.50 (-13.80, 14.79)
| | | | | | | Reported testing: Article reports no significant EPA effect (p>0.05) and DHA effect (p>0.05) without adjusting baseline value by using the Bonferroni method.
| | | | | | | Fasting blood glucose (mg/dl at week 6)
| | | | | | | Arm 1 mean=136.04
| | | | | | | Arm 2 and Arm 3 (combined) mean=155.85
| | | | | | | Mean difference=19.81 (2.25, 37.37)
| | | | | | | Reported testing: Article reports significant EPA effect (p=0.002) and DHA effect (p=0.002) after adjustment for baseline value by using the Bonferroni method.
| | | | | | | HbA1c (% at week 6)
| | | | | | | Arm 1 mean=7.04
| | | | | | | Arm 2 and Arm 3 (combined) mean=7.27
| | | | | | | Mean difference=0.23 (-0.28, 0.75)
| | | | | | | Reported testing: Article reports no significant EPA effect (p>0.05) and DHA effect (p>0.05) after adjustment for baseline value by using the Bonferroni method.

Evidence Table C.2 Evidence table of clinical effect of omega-3 fatty acids in inflammatory bowel disease

First Author, Year | Study Characteristics | Study Design Duration | Eligibility Criteria | Concurrent Disease Condition Medication | Arm | Interventions Dosage/Duration | Outcomes Results | Quality Applicability Funding Source
Almallah YZ, 1998^44^ | Sample size: 18 | Design: RCT | Inclusion: | Covariates: Sulphasalazine or mesalazine (SASP)/Rectal steroids | 1 | Sunflower oil 15 ml/d × 6 mo | Clinical score (change at month 6): | Quality:
| Age (mean/range): NA / 29–72 | Duration: 6 mo | Biopsy-proven ulcerative colitis/Distal disease | | 2 | Fish oil 15 ml/d × 6 mo | Arm 1= -2 | Jadad: 2
| Race: NA | | Exclusion: | | | | Arm 2 = -5 | Concealment of allocation: Yes
| % male: 50 | | Steroid treatment/Pregnancy/ Immune disorder | | | | Meta-anlysis: Not done; too few studies to pool. | Applicability: IB
| # sites: NA | | | | | | Reported testing: Testing between arms not reported. | Funding source: Hospital
| Location: UK | | | | | | Sigmoidoscopic score (change at month 6):
| | | | | | | Arm 1= -5
| | | | | | | Arm 2 = -9
| | | | | | | Meta-anlysis: Not done; too few studies to pool. Reported testing: Significant (p = 0.013) effect for fish oil (Arm 2) relative to sunflower oil (Arm 1) using Mann-Whitney U test.
| | | | | | | Histological score (change at month 6):
| | | | | | | Arm 1= -2
| | | | | | | Arm 2 = -4
| | | | | | | Meta-anlysis: Not done; too few studies to pool. Reported testing: Significant (p = 0.016) effect for fish oil (Arm 2) relative to sunflower oil (Arm 1) using Mann-Whitney U test.
| | | | | | | Induced remission(rate at month 6):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2 = 100%
| | | | | | | Meta-anlysis: Not done; too few studies to pool. Reported testing: Testing between arms not reported.
| | | | | | | Relapse: NA
| | | | | | | Immunosupressive requirement (# of patients at month 6, prednisolone enemata/oral corticosteroids):
| | | | | | | Arm 1 = 4/3
| | | | | | | Arm 2 = 2/0
| | | | | | | Meta-anlysis: Not done; too few studies to pool. Reported testing: Testing between arms not reported.
Aslan A, 1992^46^ | Sample size: 11 | Design: RXT | Inclusion: | Covariates: Sulphasalazine or mesalazine (SASP)/Rectal steroids | 1 | Oleic, palmitic, and linoleic acids 15 cap/d × 3 mo | Clinical score (change at month 3): | Quality:
| Age (mean/range): 63 / 31–74 | Duration: 3 mo | Mild to moderate IBD with min 10 cm/Biopsy-proven ulcerative colitis | | 2 | Max EPA (fish oil) 15 cap/d × 3 mo | Arm 1= point estimate before cross-over not reported | Jadad: 5
| Race: NR | X-over: month 3 | Exclusion: NR | | | | Arm 2 = point estimate before cross-over not reported | Concealment of allocation: NR
| % male: 100 | Run-in: None | | | | | Meta-anlysis: Not done; too few studies to pool. Reported testing: Significant (p < 0.05) effect for fish oil (Arm 2) relative to oleic, palmitic, and linoleic acids (Arm 1) using paired univariate Student's t test. | Applicability: IIIB
| # sites: 1 | Wash-out: 2 mo | | | | | Sigmoidoscopic score: NA | Funding source: NR
| Location: US | | | | | | Histological score (change at month 3):
| | | | | | | Arm 1= point estimate before cross-over not reported
| | | | | | | Arm 2 = point estimate before cross-over not reported
| | | | | | | Meta-anlysis: Not done; too few studies to pool. Reported testing: No significant difference between groups using paired univariate Student's t test.
| | | | | | | Induced remission: NA
| | | | | | | Relapse: NA
| | | | | | | Immunosupressive requirement: NA
Belluzzi A, 1996^54^ | Sample size: 78 | Design: RCT | Inclusion: | Covariates: Previous surgery | 1 | Miglyol 812 15 g/d × 12 mo | Clinical score: NA | Quality:
| Age (mean/range): NA / 18–67 | Duration: 12 mo | Remission of Crohn's disease/Elevated serum markers of inflammation | | 2 | Fish oil, enteric coated 15 g/d × 12 mo | Sigmoidoscopic score: NA | Jadad: 5
| Race: NA | | Exclusion: | | | | Histological score: NA | Concealment of allocation: NA
| % male: 50 | | Steroid treatment/Previous cytotoxic or immunosuppressive drug treatment/Pregnancy/lactating/Age between 18 and 75 years old/ Previous bowel resection of more than 1 m/ Previous sulphasalazine or mesalazine treatment | | | | Induced remission: NA | Applicability: IB
| # sites: NA | | | | | | Relapse (# of relapse at month 12) | Funding source: Industry
| Location: Italy | | | | | | Arm 1 =27
| | | | | | | Arm 2 =11
| | | | | | | risk ratio=0.41 (0.24, 0.70)
| | | | | | | Reported testing: Article reports significant difference (p<0.001) between Arm 1 and Arm 2.
| | | | | | | Immunosupressive requirement: NA
Greenfield SM, 1993^42^ | Sample size: 43 | Design: RCT | Inclusion: Ulcerative colitis, Disease > 1 year/Clinically stable/Prednisone or prednisolone treatment < 10 mg/day | Covariates: Sulphasalazine or mesalazine treatment (SASP)/Rectal steroids | 1 | Olive oil Variable dose × 6 mo | Clinical score: NA | Quality:
| Age (mean/range): 54 / NA | Duration: 9 mo | Exclusion: NA | | 2 | Max EPA (fish oil) Variable dose × 6 mo | Sigmoidoscopic score (change at month 9): | Jadad: 2
| Race: NA | | | | 3 | Super evening primrose oil (Borage and evening primrose oils) Variable dose × 6 mo | Arm 1= point estimate not reported | Concealment of allocation: NA
| % male: 70 | | | | | | Arm 2 = point estimate not reported | Applicability: IB
| # sites: NA | | | | | | Arm 3 = point estimate not reported | Funding source: NR
| Location: UK | | | | | | Meta-anlysis: Not done; too few studies to pool.
| | | | | | | Reported testing: No significant difference between groups using Mann-Whitney U test.
| | | | | | | Histological score(change at month 9):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Arm 3 = point estimate not reported
| | | | | | | Meta-anlysis: Not done; too few studies to pool.
| | | | | | | Reported testing: No significant difference between groups using Mann-Whitney U test
| | | | | | | Induced remission: NA
| | | | | | | Relapse(rate at month 9):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Arm 3 = point estimate not reported
| | | | | | | Meta-anlysis: This study was excluded from the meta-analysis of relapse because data was not reported separately by arm/group. The data was reported as number of patients in remission at entry.
| | | | | | | Reported testing: No significant difference between groups using Mann-Whitney U test
| | | | | | | Immunosuppressive requirement: NA
Hawthorne A, 1992^95^ | Sample size: 96 | Design: RCT | Inclusion: | Covariates: Sulphasalazine or mesalazine treatment (SASP) | 1 | Olive oil 20 ml/d × 12 mo | Clinical score: NA | Quality:
| Age (mean/range): 47 / 17–77 | Duration: 14 mo | Biopsy-proven ulcerative colitis/ two or more relapses in the previous 3 years | | 2 | Hi EPA (Fish oil) 20 ml/d × 12 mo | Sigmoidoscopic score: NA | Jadad: 3
| Race: NA | | Exclusion: | | | | Histological score: NA | Concealment of allocation: Yes
| % male: 55 | | Prednisolone > 20 mg/Likely to require surgery or deteriorating | | | | Induced remission (rate at month 12): | Applicability: IIIB
| # sites: 2 | | | | | | Arm 1= 63% | Funding source: Industry and Private, non-industry
| Location: UK | | | | | | Arm 2 = 54%
| | | | | | | Meta-anlysis: Not done; too few studies to pool. Reported testing: No significant effect (p = 0.44) for fish oil (Arm 2) relative to olive oil (Arm 1) using log rank analysis and Kaplan Meier method. [I think it's just Kaplan Meier]
| | | | | | | Relapse(rate at month 12):
| | | | | | | Arm 1= 48%
| | | | | | | Arm 2 = 42%
| | | | | | | Meta-anlysis: This study was excluded from the meta-analysis of relapse because the population was the same as another study that was included in the MA.^41^
| | | | | | | Reported testing: No significant effect (p = 0.54) for fish oil (Arm 2) relative to olive oil (Arm 1) using log rank analysis and Kaplan Meier method. I think it's just Kaplan Meier]
| | | | | | | Immunosuppressive requirement:
| | | | | | | (median prednisolone dose, mg at month 1, month 2)
| | | | | | | Arm 1: 6/5
| | | | | | | Arm 2: 1/0
| | | | | | | Meta-anlysis: Not done; too few studies to pool. Reported testing: Testing between arms not reported.
Hawthorne A^41^ | Sample size: 96 | Design: RCT | Inclusion: | Covariates: Sulphasalazine or mesalazine treatment (SASP) | 1 | Olive oil 20 ml/d × 12 mo | Clinical score: NA | Quality:
| Age (mean/range): 47 / 17–77 | Duration: 12 mo | Biopsy-proven ulcerative colitis / two or more relapses in the previous 3 years | | 2 | Hi EPA (Fish oil) 20 ml/d × 12 mo | Sigmoidoscopic score: NA | Jadad: 3
| Race: NA | | Exclusion: | | | | Histological score: NA | Concealment of allocation: Yes
| % male: 55 | | Prednisolone > 20 mg/Likely to require surgery or deteriorating | | | | Induced remission(rate at month 12): | Applicability: IIIB
| # sites: 2 | | | | | | Arm 1: 70% | Funding source: Industry and Private, non-industry
| Location: UK | | | | | | Arm 2: 61%
| | | | | | | Meta-anlysis: Not done; too few studies to pool.
| | | | | | | Reported testing: Testing between arms not reported.
| | | | | | | Relapse (# of relapse at month 12)
| | | | | | | Arm 1 =11
| | | | | | | Arm 2 =15
| | | | | | | risk ratio=1.32 (0.71, 2.46)
| | | | | | | Reported testing: Article reports no significant difference between Arm 1 and Arm 2 by survival analysis.
| | | | | | | Immunosuppressive requirement: NA
Loeschke K, 1996^39^ | Sample size: 64 | Design: RCT | Inclusion: | Covariates: 5-ASA/Sulphasalazine or mesalazine treatment (SASP) | 1 | Corn oil 6 ml/d × 24 mo | Clinical score(change from graph data at month 24): | Quality:
| Age (mean/range): 40 / NA | Duration: 24 mo | Biopsy-proven ulcerative colitis/ At least 1 relapse in the last 2 years/Gomes clinical score (IBD) below 8 | | 2 | Fish oil 5 g/d × 24 mo | Arm 1: +0.7 | Jadad: 5
| Race: NA | | Exclusion: Steroid treatment/Pregnancy/Cytotoxic or immunosuppressive drug treatment/Questionable adherence | | | | Arm 2: + 0.2 | Concealment of allocation: NA
| % male: 52 | | | | | | Meta-anlysis: Not done; too few studies to pool. | Applicability: IB
| # sites: 2 | | | | | | Reported testing: No significant difference between groups using two-way analysis of variance. | Funding source: Industry
| Location: Germany | | | | | | Sigmoidoscopic score: NA
| | | | | | | Histological score (at month 24):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2= point estimate not reported
| | | | | | | Meta-anlysis: Not done; too few studies to pool.
| | | | | | | Reported testing: No significant difference between groups using Mann-Whiney U test.
| | | | | | | Induced remission: NA
| | | | | | | Relapse (# of relapse at month 24)
| | | | | | | Arm 1 =18
| | | | | | | Arm 2 =18
| | | | | | | risk ratio=1.06 (0.69, 1.64)
| | | | | | | Reported testing: Article reports no significant difference between Arm 1 and Arm 2 by chi-square test.
| | | | | | | Immunosuppressive requirement: NA
Lorenz R, 1989^52^ | Sample size: 39 | Design: RXT | Inclusion: | Covariates: Sulphasalazine or mesalazine treatment (SASP)/Flagyl | 1 | Olive oil 11 ml/d × 3 mo | Clinical score(change from graph data at month 3): | Quality:
| Age (mean/range): 37 / 21–71 | Duration: 7 mo | Biopsy-proven Crohn's disease or ulcerative colitis | | 2 | Max EPA (fish oil) 11 ml/d × 3 mo | Arm 1= -12 Crohn's Disease Activity Index | Jadad: 5
| Race: NA | X-over: month 3 | Exclusion: Pregnancy/Pending surgery, abscesses or severe bleeding/Questionable adherence/Prednisone>8 mg/day/Inactive disease | | | | -2 Ulcerative Colitis Activity Index | Concealment of allocation: Yes
| % male: 41 | Run-in: None | | | | | Arm 2 = -3 Crohn's Disease Activity Index | Applicability: IB
| # sites: 1 | Wash-out: 1 mo | | | | | -2 Ulcerative Colitis Activity Index | Funding source: Unclear
| Location: Germany | | | | | | Meta-anlysis: Not done; too few studies to pool.
| | | | | | | Reported testing: No significant difference between groups using…
| | | | | | | Sigmoidoscopic score (change at month 3):
| | | | | | | Arm 1= point estimate before cross-over not reported
| | | | | | | Arm 2 = point estimate before cross-over not reported
| | | | | | | Meta-anlysis: Not done; too few studies to pool.
| | | | | | | Reported testing: Significant (p < 0.05) effect for fish oil (Arm 2) relative to olive oil (Arm 1) using…
| | | | | | | Histological score: NA
| | | | | | | Induced remission: NA
| | | | | | | Relapse: NA
| | | | | | | Immunosuppressive requirement: NA
Lorenz-Meyer H, 1996^55^ | Sample size: 204 | Design: RCT | Inclusion: Biopsy-proven Crohn's disease/Active disease/Steroid treatment | Covariates: Fistula | 1 | Corn oil 6 g/d × 12 mo | Clinical score: NA | Quality:
| Age (mean/range): 31 / 17–65 | Duration: 12 mo | Exclusion: | | 2 | Low-carbohydate diet Dosage NA × 12 mo | Sigmoidoscopic score: NA | Jadad: 3
| Race: NA | | Questionable adherence/Pregnancy/Cytotoxic or immunosuppressive drug treatment/NSAID treatment/Sulphasalazine or mesalazine treatment/Total parenteral nutrition (TPN)/Short bowel syndrome/Steatorrhea | | 3 | Fish oil 6 g/d × 12 mo | Histological score: NA | Concealment of allocation: NA
| % male: 33 | | | | | | Induced remission: NA | Applicability: IB
| # sites: 23 | | | | | | Relapse (# of relapse at month 12) | Funding source: NA
| Location: Germany | | | | | | Arm 1 =36
| | | | | | | Arm 3 =40
| | | | | | | risk ratio=1.03 (0.77, 1.39)
| | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 3.
| | | | | | | Immunosuppressive requirement: NA
Mantzaris GJ, 1996^40^ | Sample size: 50 | Design: RCT | Inclusion: | Covariates: Sulphasalazine or mesalazine treatment (SASP) | 1 | Olive oil 20 ml/d × 12 mo | Clinical score: NA | Quality:
| Age (mean/range): 36 / 17–65 | Duration: 12 mo | Remission of biopsy-proven ulcerative colitis/Mesalazine treatment | | 2 | Max EPA (fish oil) 20 ml/d × 12 mo | Sigmoidoscopic score: NA | Jadad: 2
| Race: NA | | Exclusion: NA | | | | Histological score: NA | Concealment of allocation: NA
| % male: 48 | | | | | | Induced remission: NA | Applicability: IB
| # sites: NA | | | | | | Relapse (# of relapse at month 12) | Comments: This study is included in the meta-analysis of relapse
| Location: Greece | | | | | | Arm 1 =5 | Funding source: NA
| | | | | | | Arm 2 =6
| | | | | | | risk ratio=0.98 (0.36, 2.70)
| | | | | | | Reported testing: Article reports no significant difference (p>0.1) between Arm 1 and Arm 2 by chi-square test.
| | | | | | | Immunosuppressive requirement: NA
Middleton SJ, 2002^43^ | Sample size: 63 | Design: RCT | Inclusion: Age between 18 and 70 years old/Biopsy-proven ulcerative colitis in remission | Covariates: Smoking/Sulphasalazine or mesalazine treatment (SASP)/5-ASA | 1 | Sunflower oil 6 cap/d × 12 mo | Clinical score: NA | Quality:
| Age (mean/range): 42 / 18–66 | Duration: 12 mo | Exclusion: Serious liver disease/Malignant disease/Pregnancy/lactating/Antiplatelet or anticoagulating treatment/Epilepsy/Lithium or phenothiazine/Serious renal disease | | 2 | GLA+ EPA+DHA 6 cap/d × 12 mo | Sigmoidoscopic score (at month 12): | Jadad: 3
| Race: NA | | | | | | Arm 1= point estimate not reported | Concealment of allocation: NR
| % male: 50 | | | | | | Arm 2 = point estimate not reported | Applicability: IB
| # sites: 1 | | | | | | Meta-anlysis: Not done; too few studies to pool. | Funding source: NR
| Location: UK | | | | | | Reported testing: No significant difference between groups using proportional Cox hazard regression.
| | | | | | | Histological score: NA
| | | | | | | Induced remission: NA
| | | | | | | Relapse (rate at month 12, extrapolated from graph):
| | | | | | | Arm 1= 38%
| | | | | | | Arm 2 = 55%
| | | | | | | Meta-anlysis: Not included in MA; point estimates not reported.
| | | | | | | Reported testing: No significant difference between groups using proportional Cox hazard regression.
| | | | | | | Immunosuppressive requirement: NA
Stenson WF, 1992^53^ | Sample size: 24 | Design: RXT | Inclusion: Ulcerative colitis Active disease | Covariates: Rectal steroids/Sulphasalazine or mesalazine treatment (SASP) | 1 | Vegetable oil 18 cap/d × 4 mo | Clinical score (change at month 4): | Quality:
| Age (mean/range): 42 / 25–62 | Duration: 9 mo | Exclusion: NA | | 2 | Max EPA (fish oil) 18 cap/d × 4 mo | Arm 1= point estimate before cross-over not reported | Jadad: 2
| Race: NA | X-over: month 4 | | | | | Arm 2 = point estimate before cross-over not reported | Concealment of allocation: NA
| % male: 56 | Run-in: None | | | | | Meta-anlysis: Not done; too few studies to pool. | Applicability: NA
| # sites: 4 | Wash-out: 1 mo | | | | | Reported testing: Significant (P < 0.14) effect for fish oil (Arm 2) relative to vegetable oil (Arm 1) using rank-sign test. | Funding source: Government and Private, non-industry
| Location: US | | | | | | Sigmoidoscopic score (change at month 4):
| | | | | | | Arm 1= point estimate before cross-over not reported
| | | | | | | Arm 2 = point estimate before cross-over not reported
| | | | | | | Meta-anlysis: Not done; too few studies to pool.
| | | | | | | Reported testing: Testing between arms not reported.
| | | | | | | Histological score(change at month 4):
| | | | | | | Arm 1= point estimate before cross-over not reported
| | | | | | | Arm 2 = point estimate before cross-over not reported
| | | | | | | Meta-anlysis: Not done; too few studies to pool.
| | | | | | | Reported testing: Testing between arms not reported.
| | | | | | | Induced remission: NA
| | | | | | | Relapse: NA
| | | | | | | Immunosuppressive requirement (mean prednisolone dose 8 in mg at month 4)
| | | | | | | Arm 1: 12.9
| | | | | | | Arm 2: 6.1
| | | | | | | Meta-anlysis: Not done; too few studies to pool.
| | | | | | | Reported testing: Testing between arms not reported.
Varghese TJ, 2000^94^ | Sample size: 51 | Design: RCT | Inclusion: Ulcerative colitis and extensive disease | Covariates: NA | 1 | Sunflower oil Dosage NA × 12 mo | Clinical score (change at month 6): | Quality:
| Age (mean/range): NA / NA | Duration: 6 mo | Exclusion: Cytotoxic or immunosuppressive drug treatment | | 2 | Omega-3 EFAs 6 mg/d × 6 mo | Arm 1= point estimate not reported | Jadad: 2
| Race: NA | | | | | | Arm 2 = point estimate not reported | Concealment of allocation: NA
| % male: 99 | | | | | | Meta-anlysis: Not done; too few studies to pool. | Applicability: NA
| # sites: NA | | | | | | Reported testing: Significant (p = 0.001) effect for Omega-3 EFAs (Arm 2) relative to sunflower oil (Arm 1). | Funding source: NA
| Location: UK | | | | | | Sigmoidoscopic score (change at month 6):
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-anlysis: Not done; too few studies to pool.
| | | | | | | Reported testing: Significant (p = 0.054) effect for Omega-3 EFAs (Arm 2) relative to sunflower oil (Arm 1).
| | | | | | | Histological score: NA
| | | | | | | Induced remission: NA
| | | | | | | Relapse: NA
| | | | | | | Immunosuppressive requirement: NA

Evidence table C.3 Evidence table of clinical effect of omega-3 fatty acids in rheumatoid arthritis

First Author, Year | Study Characteristics | Study Design Duration | Eligibility Criteria | Concurrent Disease Condition Medication | Arm | Interventions Dosage/Duration | Outcomes Results | Quality Applicability) Funding Source
Adam O, 2003^26^ | Sample size: NA | Design: RXT | Inclusion: | Covariates: Diet | 1 | Western diet Corn oil capsules1 g/10 kg body weight/day × 3 mo | Pain (cm on VAS at month 3) | Quality:
| Age (mean/range): 57/NA | Duration: 8mo | >= 6 tender joints/>=3 swollen joints/ AND one or both: morning stiffness >=30 min/ elevated ESR or CRP | | 2 | Placebo/control Modified lacto-vegetarian diet Corn oil capsules 1g/10 kg body weight/day × 3 mo | Arms 1, 2, 3, 4 = point estimate not reported | Jadad: 3
| Race: NA | X-over: month 5 | Exclusion: Prednisone > 10 mg/d/GI disorders/Alcohol use/Metabolic disease/Known allergies | | 3 | Western diet Menhaden oil 1g/10 kg body weight/day × 3 mo | Meta-analysis: Not included, point estimates not reported. | Concealment of allocation: NR
| % male: 7 | Run-in: None | | | 4 | Modified lacto-vegetarian diet Menhaden oil 1g/10 kg body weight/day × 3 mo | Reported testing: Testing between placebo (arms 1 and 2) and fish oil (arms 3 and 4) not reported. | Applicability: IIB
| # sites: NA | Wash-out: 2 mo | | | | | Swollen joints (number at month 3): | Funding source: Government
| Location: Germany | | | | | | Arms 1, 2, 3, 4 = point estimate not reported
| | | | | | | Meta-analysis: Not included, point estimates not reported.
| | | | | | | Reported testing: Testing between placebo (arms 1 and 2) and fish oil (arms 3 and 4) not reported.
| | | | | | | Acute phase reactant: NA
| | | | | | | Patient global assessment (at month 3):
| | | | | | | Arms 1, 2, 3, 4 = point estimate not reported
| | | | | | | Meta-analysis: Not included, point estimates not reported.
| | | | | | | Reported testing: Testing between placebo (arms 1 and 2) and fish oil (arms 3 and 4) not reported.
| | | | | | | Radiographic damage: NA
| | | | | | | NSAID consumption (at month 3):
| | | | | | | Arms 1, 2, 3, 4 = point estimate not reported
| | | | | | | Meta-analysis: Not performed, too few studies to pool.
| | | | | | | Reported testing: Testing between placebo (arms 1 and 2) and fish oil (arms 3 and 4) not reported.
| | | | | | | Steroid consumption (at month 3):
| | | | | | | Arms 1, 2, 3, 4 = point estimate not reported
| | | | | | | Meta-analysis: Not performed, too few studies to pool.
| | | | | | | Reported testing: Testing between placebo (arms 1 and 2) and fish oil (arms 3 and 4) not reported.
| | | | | | | DMARD consumption: NA
Alpigiani M, 1996^27^ | Sample size: 32 | Design: | Inclusion: | Covariates: NA | 1 | Diet | Pain: NA | Quality:
| Age (mean/range): 14 / NA | Duration: 6 mo | Juvenile chronic arthritis/Age Apr-13 | | 2 | Cod-liver oil (Eskisol) 5 g/d × 6 mo | Swollen joints: NA | Jadad: 1
| Race: NA | | Exclusion: | | | | Acute phase reactant: (change at month 6, CRP, mg%): | Concealment of allocation: NR
| % male: 44 | | NA | | | | Arm 1: -0.05 | Applicability: IIB
| # sites: 1 | | | | | | Arm 2: -0.28 | Funding source: NA
| Location: Italy | | | | | | Meta-analysis: Not included; point estimates not reported.
| | | | | | | Reported testing: Significant (p=.009) difference between arms by ANOVA.
| | | | | | | Patient global assessment: NA
| | | | | | | Radiographic damage: NA
| | | | | | | NSAID consumption: NA
| | | | | | | Steroid consumption: NA
| | | | | | | DMARD consumption: NA
Belch JF, 1988^28^ | Sample size: 49 | Design: RCT | Inclusion: | Covariates: Evening primrose oil | 1 | Placebo: Liquid paraffin capsules 12/d × 12 months | Pain (cm on VAS at month 12) | Quality:
| Age (mean/range): 49 / 28–74 | Duration: 15 mo | NSAIDs use/No DMARDs | | 2 | Fish oil (240 mg EPA) plus evening primrose oil (540 mg GLA) daily × 12 mo | Arms 1, 2, 3 = point estimate not reported | Jadad: 4
| Race: NA | | Exclusion: | | 3 | Evening primrose oil (540 mg GLA) daily × 12 mo | Meta-analysis: Not included, point estimates not reported. | Concealment of allocation: NR
| % male: 12 | | NA | | | | Reported testing: No difference between groups using Mann-Whitney U test. | Applicability: IIB
| # sites: NA | | | | | | Swollen joints (number at month 3): | Comments: Meta-analysis not performed because of insufficient statistics; study only reported data in graph.
| Location: UK | | | | | | Arms 1, 2, 3 = point estimate not reported | Funding source: Private, non-industry
| | | | | | | Meta-analysis: Not included, point estimates not reported.
| | | | | | | Reported testing: No difference between groups using Mann-Whitney U test.
| | | | | | | Acute phase reactant: (CRP and ESR at month 12)
| | | | | | | Arms 1, 2, 3 = point estimate not reported
| | | | | | | Meta-analysis: Not included, point estimates not reported.
| | | | | | | Reported testing: No difference in CRP or ESR between groups using Mann-Whitney U test.
| | | | | | | Patient global assessment: NA
| | | | | | | Radiographic damage: NA
| | | | | | | NSAID consumption (at month 15):
| | | | | | | Arm 1: Reduced in 33% of subjects
| | | | | | | Arm 2: Reduced in 80% of subjects
| | | | | | | Arm 3: Reduced in 73% of subjects
| | | | | | | Meta-analysis: Not performed, too few studies to pool.
| | | | | | | Reported testing: Testing between groups not reported.
| | | | | | | Steroid consumption: NA
| | | | | | | DMARD consumption: NA
Cleland LG, 1988^16^ | Sample size: 60 | Design: RCT | Inclusion: NA | Covariates: SAIDs/DMARDs | 1 | Olive oil 18 g/d × 3 mo | Pain (Analogue pain scale at month 3) | Quality:
| Age (mean/range): 51 / 22–74 | Duration: 3 mo | Exclusion: NA | | 2 | Max EPA (fish oil) 18 g/d × 3 mo | Arm 1 =7.1 | Jadad: 3
| Race: NA | | | | | | Arm 2 =7 | Concealment of allocation: NR
| % male: 30 | | | | | | effect size=-0.02(-0.60, 0.56) | Applicability: IB
| # sites: NA | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2. | Funding source: Government; Private, non-industry; Hospital
| Location: Australia | | | | | | Swollen joints (# of swollen joint at month 3)
| | | | | | | Arm 1 =3.5
| | | | | | | Arm 2 =3.6
| | | | | | | effect size=0.04(-0.54, 0.62)
| | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2.
| | | | | | | Acute phase reactant: (ESR at month 12)
| | | | | | | Arms 1, 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included, point estimates not reported.
| | | | | | | Reported testing: No significant change within group by Student's t test; testing between groups not reported.
| | | | | | | Patient global assessment: (at month 12)
| | | | | | | Arms 1, 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included, point estimates not reported.
| | | | | | | Reported testing: No significant change within group; testing between groups not reported.
| | | | | | | Radiographic damage: NA
| | | | | | | NSAID consumption NA
| | | | | | | Steroid consumption: NA
| | | | | | | DMARD consumption: NA
Geusens P, 1994^17^ | Sample size: 90 | Design: RCT | Inclusion: | Covariates: NSAIDs/DMARDs | 1 | Olive oil capsules 6 g/d × 12 mo | Pain (0–4 scale at month 3) | Quality:
| Age (mean/range): 57 / NA | Duration: 12 mo | Active disease | | 2 | Fish oil 3 g × 12 mo plus olive oil 3 g/d × 12 mo | Arm 1 =1.97 | Jadad: 3
| Race: NA | | Exclusion: | | 3 | Fish oil 6 g/d × 12 mo | Arm 2 and Arm 3 (combined) =1.89 | Concealment of allocation: NR
| % male: 22 | | NA | | | | effect size=-0.04(-0.57, 0.50) | Applicability: IB
| # sites: NA | | | | | | Reported testing: Article reports no significant differences (p>0.05) of the changes between Arm 2 or Arm 3 and Arm 1. | Funding source: ND
| Location: Belgium | | | | | | Swollen joint:s NA
| | | | | | | Acute phase reactant: NA
| | | | | | | Radiographic damage: NA
| | | | | | | NSAID consumption: consumption of NSAIDs and DMARDs combined reported, see below.
| | | | | | | Steroid consumption: NA
| | | | | | | DMARD consumption: consumption of NSAIDs and DMARDs combined reported, see below.
| | | | | | | Patient global assessment (0–10cm visual analog scale at month 3)
| | | | | | | Arm 1 =5.68
| | | | | | | Arm 2 and Arm 3 (combined) =4.53
| | | | | | | effect size=-1.38(-1.97, -0.79)
| | | | | | | Reported testing: Article reports significant differences (p<0.01) of the changes between Arm 3 and Arm1 by Mann-Whitney test.
| | | | | | | NSAID and/or DMARD consumption: (% with dose reduction at month 12)
| | | | | | | Arm 1 = 15
| | | | | | | Arm 2 = 29
| | | | | | | Arm 3 = 47
| | | | | | | Meta-analysis: Not done, too few studies to pool.
| | | | | | | Reported testing: Significant (p<.05) difference between arms 3 (high dose fish oil) and arm 1 (placebo) using chi-square test.
Hansen G, 1996^29^ | Sample size: 109 | Design: RCT | Inclusion: | Covariates: NSAIDs | 1 | Normal diet | Pain: (change on VAS at month 6) | Quality:
| Age (mean/range): 57 / NA | Duration: 6.0 mo | Increased morning stiffness/Increased sed rate/>=3 swollen joints | | 2 | Fish 114 g for 6 mo | Arm 1 = 0.2 | Jadad: 1
| Race: NA | | Exclusion: | | | | Arm 2 = -0.2 | Concealment of allocation: NR
| % male: 26 | | Underweight/Severe disorders | | | | Meta-analysis: Not included, point estimates not reported.
| # sites: NA | | | | | | Reported testing: Significant (p=0.01) difference between arms using Wilcoxons unpaired rank test. | Applicability: IB
| Location: Denmark | | | | | | Swollen joints: (change on 1–3 scale at month 6) | Funding source: ND
| | | | | | | Arm 1 = -1
| | | | | | | Arm 2 = -3
| | | | | | | Meta-analysis: Not included, point estimates not reported.
| | | | | | | Reported testing: Significant (p=0.01) difference between arms using Wilcoxons unpaired rank test.
| | | | | | | Acute phase reactant: (change, ESR, mm/hr at month 6)
| | | | | | | Arm 1 = 0
| | | | | | | Arm 2 = 1
| | | | | | | Meta-analysis: Not included, point estimates not reported.
| | | | | | | Reported testing: No significant difference between arms using Wilcoxons unpaired rank test.
| | | | | | | Patient global assessment: NA
| | | | | | | Radiographic damage: (Change, Larsen score at month 6)
| | | | | | | Arm 1 = 4
| | | | | | | Arm 2 = 3
| | | | | | | Meta-analysis: Not included, point estimates not reported.
| | | | | | | Reported testing: No significant difference between arms using Wilcoxons unpaired rank test.
| | | | | | | NSAID consumption:
| | | | | | | Arm 1 = point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not performed, too few studies to pool.
| | | | | | | Reported testing: Testing between groups not reported.
| | | | | | | Steroid consumption: NA
| | | | | | | DMARD consumption: NA
Kjeldsen-KraghJ,1992^30^ | Samplesize: 79 | Design: RCT | Inclusion: | Covariates: Naproxen | 1 | Corn oil 7g/d × 16 weeks Naproxen 750 mg/d × 10 weeks then reduction to 0 mg/d by week 13 continued through week 16. | Pain: (VAS at week 16) | Quality:
| Age (mean/range): 57 / 23–73 | Duration: 4.0 mo | >=6 tender joints/>=3 swollen joints/Increased sed rate/Increased morning stiffness/Prednisone or prednisolone = 10 mg/Functional class/Stable medication | | 2 | K-85 (fish oil) 750 mg for 16 wk Naproxen 750 mg/d × 16 weeks | Arms 1, 2, 3: point estimates not reported. | Jadad: 3
| Race: NA | | Exclusion: | | 3 | K-85 (fish oil) 750 mg for 16 wk Naproxen 750 mg/d × 10 weeks then reduction to 0mg/d by week 13 continued through week 16. | Meta-analysis: Not included, point estimates not reported. | Concealment of allocation: NR
| % male: 24 | | NA | | | | Reported testing: Testing between groups not reported. | Applicability: IB
| # sites: 7 | | | | | | Swollen joints: (number at month 16) | Funding source: Private, non-industry
| Location: Russia | | | | | | Arms 1, 2, 3: point estimates not reported.
| | | | | | | Meta-analysis: Not included, point estimates not reported.
| | | | | | | Reported testing: Testing between groups not reported.
| | | | | | | Acute phase reactant: NA
| | | | | | | Patient global assessment: (at week 16)
| | | | | | | Arms 1, 2, 3: point estimates not reported.
| | | | | | | Meta-analysis: Not included, point estimates not reported.
| | | | | | | Reported testing: Testing between groups not reported.
| | | | | | | Radiographic damage: NA
| | | | | | | NSAID consumption: NA
| | | | | | | Steroid consumption: NA
| | | | | | | DMARD consumption: NA
Kremer J, 1990^19^ | Sample size: 64 | Design: RCT | Inclusion: | Covariates: NSAIDs/DMARDs | 1 | Olive oil capsules 9/d × 24 weeks | Pain (0–4 five point scale at week 12) | Quality:
| Age (mean/range): 58 / 22–81 | Duration: 9 mo | >=6 tender joints/Increased sed rate/Increased morning stiffness/Stable medication/>=3 swollen joints | | 2 | Fish oil capsules × 24 weeks (27 mg/kg/d EPA, 18 mg/kg/d DHA) | Arm 1 =1.60 | Jadad: 2
| Race: NA | | Exclusion: | | 3 | Fish oilcapsules × 24 weeks (54 mg/kg/d EPA, 36 mg/kg/d DHA) | Arm 2 and Arm3 (combined) =1.51 | Concealment of allocation: NR
| % male: 33 | | NA | | | | effect size=-0.04(-0.69, 0.61) | Applicability: IB
| # sites: 1 | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2 and Arm 3. | Funding source: NA
| Location: US | | | | | | Swollen joints (# of swollen joint at week 12)
| | | | | | | Arm 1 =13.50
| | | | | | | Arm 2 and Arm3 (combined) =10.96
| | | | | | | effect size=-0.63(-1.30, 0.03)
| | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2 and Arm 3.
| | | | | | | Acute phase reactant: (ESR at week 24 and at week 36)
| | | | | | | Arms 1,2,3 = point estimates not reported.
| | | | | | | Meta-analysis: Not included, point estimates not reported.
| | | | | | | Reported testing: No significant difference in any arm using Student's t-test; testing between groups not reported.
| | | | | | | Patient global assessment (0–4 five point scale at week 12)
| | | | | | | Arm 1 =1.8
| | | | | | | Arm 2 and Arm3 (combined) =1.69
| | | | | | | effect size=-0.13(-0.78, 0.52)
| | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2 and Arm 3.
| | | | | | | Radiographic damage: NA
| | | | | | | NSAID consumption: NA
| | | | | | | Steroid consumption: NA
| | | | | | | DMARD consumption: NA
Kremer J, 1995^31^ | Sample size: 66 | Design: RCT | Inclusion: | Covariates: DMARDs/NSAIDs | 1 | Corn oil, 9 capsules/d × 26 or 30 wk. Diclofenac, 75 mg BID × first 18 or 22 wk | Pain: (0–4 scale, mean change at week 18 or 22) | Quality:
| Age (mean/range): 58 / NA | Duration: 6.5 mo | >=6 tender joints/>=3 swollen joints/Increased morning stiffness/Increased sed rate | | 2 | Menhaden oil (130 mg/kg/d of omega-3) × 26 or 30 wk, then corn oil until week 48. Diclofenac, 75 mg BID × first 18 or 22 wk | Arm 1=point estimate not reported | Jadad: 2
| Race: NA | | Exclusion: | | | | Arm 2 = point estimate not reported | Concealment of allocation: NR
| % male: 45 | | NA | | | | Meta-analysis: Not included because point estimates not reported. | Applicability: IB
| # sites: 3 | | | | | | Reported testing: Not reported for this outcome. | Funding source: NR
| Location: US | | | | | | Tender joints: (number, change at week 18 or 22)
| | | | | | | Arm 1=point estimate not reported
| | | | | | | Arm 2 = -5.3
| | | | | | | Meta-analysis: Not included because point estimate not reported for control group.
| | | | | | | Reported testing: Testing between groups not reported.
| | | | | | | Swollen joints: (number at week 18 or 22)
| | | | | | | Arm 1=point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included because point estimates not reported.
| | | | | | | Reported testing: Not reported for this outcome.
| | | | | | | Acute phase reactant: NA
| | | | | | | Patient global assessment: (mean change at week 18 or 22)
| | | | | | | Arm 1=point estimate not reported
| | | | | | | Arm 2 = -0.38
| | | | | | | Meta-analysis: Not included because point estimate not reported for control group.
| | | | | | | Reported testing: Testing between groups not reported.
| | | | | | | Radiographic damage: NA
| | | | | | | NSAID consumption: Defined in study protocol
| | | | | | | Steroid consumption: NA
| | | | | | | DMARD consumption: NA
Kremer J, 1985^18^ | Sample size: 52 | Design: RCT | Inclusion: | Covariates: NSAIDs/DMARDs | 1 | Parafin placebo capsules 10/day × 12 weeks Diet with polyunsaturated fat: saturated fat ratio=1:4. | Pain (1–5 five point scale at week 12) | Quality:
| Age (mean/range): 56 / NA | Duration: 3 mo | Increased sed rate/>=6 tender joints/>=3 swollen joints/Increased morning stiffness | | 2 | Max EPA (fish oil) capsules 10/d × 12 wk Diet with polyunsaturated fat: saturated fat ratio=1.4:1. | Arm 1 =2.8 | Jadad: 4
| Race: NA | | Exclusion: | | | | Arm 2 =2.5 | Concealment of allocation: NR
| % male: 32 | | Reliable adherence | | | | effect size=-0.13(-0.78, 0.51) | Applicability: IB
| # sites: NA | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2. | Funding source: NA
| Location: US | | | | | | Swollen joints (# of swollen joint at week 12)
| | | | | | | Arm 1 =13.5
| | | | | | | Arm 2 =13.4
| | | | | | | effect size=-0.02(-0.66, 0.63)
| | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2.
| | | | | | | Acute phase reactant
| | | | | | | Arm 1 =34.9
| | | | | | | Arm 2 =24.2
| | | | | | | effect size=-0.44(-1.10, 0.21)
| | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2.
| | | | | | | Patient global assessment (1–5 five point scale at week 12)
| | | | | | | Arm 1 =2.9
| | | | | | | Arm 2 =2.7
| | | | | | | effect size=-0.24(-0.89, 0.41)
| | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2.
| | | | | | | Radiographic damage: NA
| | | | | | | NSAID consumption: NA
| | | | | | | Steroid consumption: NA
| | | | | | | DMARD consumption: NA
Lau CS, 1995^38^ | Sample size: 45 | Design: RCT | Inclusion: | Covariates: NSAIDs | 1 | Air-filled placebo capsules 10/day × 6 mo | Pain: (at month 6) | Quality:
| Age (mean/range): NA / 27–69 | Duration: 6 mo | NSAIDs use/Clinically stable/No DMARDs | | 2 | Max EPA (fish oil) 10/day × 6 mo | Arm 1= point estimate not reported | Jadad: 2
| Race: NA | | Exclusion: | | | | Arm 2 = point estimate not reported | Concealment of allocation: NR
| % male: 29 | | NA | | | | Meta-analysis: Not included; point estimates not reported. | Applicability: IB
| # sites: 1 | | | | | | Reported testing: No statistically significant change within or between groups by ANOVA. | Funding source: ND
| Location: UK | | | | | | Swollen joints: (at month 6)
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included; point estimates not reported.
| | | | | | | Reported testing: No statistically significant change within or between groups by ANOVA.
| | | | | | | Acute phase reactant: (ESR at month 6)
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included; point estimates not reported.
| | | | | | | Reported testing: No statistically significant change within or between groups by ANOVA.
| | | | | | | Patient global assessment: NA
| | | | | | | Radiographic damage: NA
| | | | | | | NSAID consumption: NA
| | | | | | | Steroid consumption: NA
| | | | | | | DMARD consumption: NA
Lau CS, 1993^32^ | Sample size: 64 | Design: RCT | Inclusion: | Covariates: NSAIDs | 1 | Air-filled placebo capsules 10/day × 12 mo | Pain: (VAS at month 6) | Quality:
| Age (mean/range): 51 / 26–73 | Duration: 15 mo | NSAIDs use/Clinically stable/No DMARDs | | 2 | Max EPA (fish oil) capsules 10/day × 12 mo | Arm 1= point estimate not reported | Jadad: 3
| Race: NA | | Exclusion: | | | | Arm 2 = point estimate not reported | Concealment of allocation: NR
| % male: 30 | | NA | | | | Meta-analysis: Not included; point estimates not reported. | Applicability: IIB
| # sites: 1 | | | | | | Reported testing: No statistically significant change between groups by Wilcoxon rank sum test. | Funding source: Industry
| Location: Scotland | | | | | | Swollen joints: NA
| | | | | | | Acute phase reactant: (ESR at month 6)
| | | | | | | Arm 1= point estimate not reported
| | | | | | | Arm 2 = point estimate not reported
| | | | | | | Meta-analysis: Not included; point estimates not reported.
| | | | | | | Reported testing: No statistically significant change within or between groups by ANOVA.
| | | | | | | Patient global assessment: NA
| | | | | | | Radiographic damage: NA
| | | | | | | NSAID consumption: (% requiring at month 15)
| | | | | | | Arm 1 = 86
| | | | | | | Arm 2 = 45
| | | | | | | Meta-analysis: Not performed, too few studies to pool.
| | | | | | | Reported testing: No statistically significant change within or between groups by ANOVA.
| | | | | | | Steroid consumption: NA
| | | | | | | DMARD consumption: NA
Magaro M, 1988^21^ | Sample size: 20 | Design: RCT | Inclusion: | Covariates: NSAIDs | 1 | Usual diet | Patient assess pain (cm at day 45) | Quality:
| Age (mean/range): NA / 25–45 | Duration: 1.5 mo | Increased sed rate/>= 6 tender joints/>= 3 swollen joints/Increased morning stiffness/NSAIDs use/No DMARDs | | 2 | Max EPA (fish oil) 9 g/d × 45 days Usual diet | Arm 1 =4.20 | Jadad: 1
| Race: NA | | Exclusion: | | | | Arm 2 =4.80 | Concealment of allocation: NR
| % male: NA | | Diabetes/Obesity | | | | effect size=0.41 (-0.48, 1.29) | Applicability: IIB
| # sites: NA | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2. | Funding source: ND
| Location: Italy | | | | | | Swollen joints: NA
| | | | | | | Acute phase reactant (mm/1^st^ hour at day 45)
| | | | | | | Arm 1 =66.00
| | | | | | | Arm 2 =59.50
| | | | | | | effect size=-0.16 (-1.04, 0.72)
| | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2.
| | | | | | | Patient global assessment: NA
| | | | | | | Radiographic damage: NA
| | | | | | | NSAID consumption: NA
| | | | | | | Steroid consumption: NA
| | | | | | | DMARD consumption: NA
Magalish T, 2002^20^ | Sample size: 112 | Design: CCT | Inclusion: | Covariates: Duration of diabetes | 1 | Phonopheresis with hydrocortisone cream q/d × 10 d | Pain: (unspecified measure at day 10) | Quality:
| Age (mean/range): NA / 17–77 | Duration: 10 d | Age | | 2 | Phonopheresis with omega-3 fatty acids q/d 10 d | Arm 1 = 0.7 | Jadad: 0
| Race: NA | | Exclusion: | | | | Arm 2 = 0.6 | Concealment of allocation: NR
| % male: 26 | | NA | | | | Meta-analysis: Not included; measure not defined. | Applicability: IIB
| # sites: 2 | | | | | | Reported testing: Testing between groups not reported | Funding source: NR
| Location: Russia | | | | | | Swollen joints (# of swollen joint at month 0.3)
| | | | | | | Arm 1 =0.7
| | | | | | | Arm 2 =0.6
| | | | | | | effect size=-0.02(-0.66, 0.63)
| | | | | | | Reported testing: Unable to translate.
| | | | | | | Acute phase reactant: NA
| | | | | | | Patient global assessment: NA
| | | | | | | Radiographic damage: NA
| | | | | | | NSAID consumption: NA
| | | | | | | Steroid consumption: NA
| | | | | | | DMARD consumption: NA
Nielsen G, 1992^22^ | Sample size: 57 | Design: RCT | Inclusion: | Covariates: NSAIDs/DMARDs | 1 | Control capsules (n-6 fatty acids) 6/day × 12 weeks | Pain (Visual pain score at week 12) | Quality:
| Age (mean/range): NA / 33–78 | Duration: 3.0 mo | Increased sed rate/>= 6 tender joints/>= 3 swollen joints/Increased morning stiffness | | 2 | Pikasol (fish oil) capsules 6/d × 12 weeks | Arm 1 =136 | Jadad: 4
| Race: NA | | Exclusion: | | | | Arm 2 =104 | Concealment of allocation: NR
| % male: NA | | No current change in meds | | | | effect size=-0.85 (-1.42, -0.27) | Applicability: NR
| # sites: 3 | | | | | | Reported testing: Article reports significant differences (p=0.002) between Arm 1 and Arm 2. | Comments: Meta-analysis performed on patient assessment of pain, acute phase reactant, and swollen joints.
| Location: Denmark | | | | | | Swollen joints (0–2 three point index scale at wee 12) | Funding source: Private, non-industry
| | | | | | | Arm 1 =8
| | | | | | | Arm 2 =8
| | | | | | | effect size=0.00 (-0.55, 0.55)
| | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2.
| | | | | | | Acute phase reactant (mm/hour at week 12)
| | | | | | | Arm 1 =33
| | | | | | | Arm 2 =34
| | | | | | | effect size=0.06 (-0.49, 0.61)
| | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2.
| | | | | | | Patient global assessment: NA
| | | | | | | Radiographic damage: NA
| | | | | | | NSAID consumption: (at week 12)
| | | | | | | Arms 1, 2 = point estimate not reported
| | | | | | | Meta-analysis: Not performed, too few studies to pool.
| | | | | | | Reported testing: No difference within group, testing between groups not reported.
| | | | | | | Steroid consumption: (at week 12)
| | | | | | | Arms 1, 2 = point estimate not reported
| | | | | | | Meta-analysis: Not performed, too few studies to pool.
| | | | | | | Reported testing: No difference within group, testing between groups not reported.
| | | | | | | DMARD consumption(at week 12)
| | | | | | | Arms 1, 2 = point estimate not reported
| | | | | | | Meta-analysis: Not performed, too few studies to pool.
| | | | | | | Reported testing: No difference within group, testing between groups not reported.
Nordstrom D, 1995^23^ | Sample size: 22 | Design: RCT | Inclusion: | Covariates: NSAIDs/DMARDs | 1 | Safflower oil 30 g/day × 3 mo | Pain (Visual analogue scale at month 3) | Quality:
| Age (mean/range): 52 / 34–72 | Duration: 3 mo | NA | | 2 | Flaxseed oil 30 g/day × 3 mo | Arm 1 =4.60 | Jadad: 3
| Race: NA | | Exclusion: | | | | Arm 2 =4.00 | Concealment of allocation: NR
| % male: NA | | NA | | | | effect size=-0.21 (-1.04, 0.63) | Applicability: NR
| # sites: 1 | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2. | Funding source: Government; Private, non-industry
| Location: Finland | | | | | | Swollen Joints (Kaarela'sjoint score index at month 3)
| | | | | | | Arm 1 =9.50
| | | | | | | Arm 2 =9.10
| | | | | | | effect size=-0.06 (-0.90, 0.77)
| | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2.
| | | | | | | Acute phase reactant (mm/hour at month 3)
| | | | | | | Arm 1 =32.50
| | | | | | | Arm 2 =35.70
| | | | | | | effect size=0.13 (-0.71, 0.96)
| | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2.
| | | | | | | Patient global assessment (five-scale at month 3)
| | | | | | | Arm 1 =2.70
| | | | | | | Arm 2 =2.90
| | | | | | | effect size=0.26 (-0.58, 1.10)
| | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2.
| | | | | | | Radiographic damage: NA
| | | | | | | NSAID consumption: NA
| | | | | | | Steroid consumption: NA
| | | | | | | DMARD consumption: NA
Skoldstam L, 1992^25^ | Sample size: 46 | Design: RCT | Inclusion: | Covariates: NSAIDs/DMARDs | 1 | Control oil (maize, olive and peppermint oil) capsules 10 g/day × 6 mo | Pain (0–3 VAS at month 3) | Quality:
| Age (mean/range): 57 / 28–73 | Duration: 6 mo | Clinically stable/Stable medication/Increased sed rate/Increased morning stiffness/>= 6 tender joints/>= 3 swollen joints | | 2 | Max EPA (fish oil) 10 g/day × 6 mo | Arm 1 mean=1.28 | Jadad: 3
| Race: NA | | Exclusion: | | | | Arm 2 mean=136 | Concealment of allocation: NR
| % male: 26 | | NA | | | | effect size=0.11 (-0.49, 0.71) | Applicability: IB
| # sites: NA | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2. | Funding source: Government
| Location: Sweden | | | | | | Swollen joints: NA
| | | | | | | Acute phase reactant (mm/hour at month 3)
| | | | | | | Arm 1 =39
| | | | | | | Arm 2 =40
| | | | | | | effect size=0.04 (-0.55, 0.64)
| | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2.
| | | | | | | Patient global assessment (0–3 scale at month 3)
| | | | | | | Arm 1 =1.11
| | | | | | | Arm 2 =1.20
| | | | | | | effect size=0.04 (-0.56, 0.63)
| | | | | | | Reported testing: Article did not report statistical results comparing Arm 1 and Arm 2.
| | | | | | | Radiographic damage: NA
| | | | | | | NSAID consumption: NA
| | | | | | | Steroid consumption: NA
| | | | | | | DMARD consumption: NA
Tulleken J, 1990^24^ | Sample size: 28 | Design: RCT | Inclusion: | Covariates: NSAIDs/DMARDs | 1 | Coconut oil capsules 4 TID × 3 mo | Pain (10 cm VAS at month 3) | Quality:
| Age (mean/range): 55 / 29–68 | Duration: 3 mo | Stable medication | | 2 | Fish oil capsules 4 TID (6 g/day) × 3 mo | Arm 1 =3.8 | Jadad: 4
| Race: NA | | Exclusion: | | | | Arm 2 =2.4 | Concealment of allocation: Yes
| % male: 11 | | NA | | | | effect size=-0.72 (-1.50, 0.06) | Applicability: IIB
| # sites: NA | | | | | | Reported testing: Article reports no significant differences (p>0.05) between Arm 1 and Arm 2. | Comments: Meta-analysis performed on patient assessment of pain, swollen joints, and acute phase reactant.
| Location: Italy | | | | | | Swollen joints ((# of swollen joint at month 3) | Funding source: Private, non-industry
| | | | | | | Arm 1 =4
| | | | | | | Arm 2 =3
| | | | | | | effect size=-0.26(-1.02, 0.50)
| | | | | | | Reported testing: Article reports no significant differences (p>0.05) between Arm 1 and Arm 2.
| | | | | | | Acute phase reactant (mm/hour at month 3)
| | | | | | | Arm 1 =53
| | | | | | | Arm 2 =21
| | | | | | | effect size=-1.82 (-2.71, -0.92)
| | | | | | | Reported testing: Article reports no significant differences (p>0.05) between Arm 1 and Arm 2.
| | | | | | | Patient global assessment: NA
| | | | | | | Radiographic damage: NA
| | | | | | | NSAID consumption: NA
| | | | | | | Steroid consumption: NA
| | | | | | | DMARD consumption: NA
Tulleken J, 1988^34^ | Sample size: NA | Design: RXT | Inclusion: | Covariates: NSAIDs/DMARDs | 1 | Coconut oil capsules 12/day × 3 mo | Pain: NA | Quality:
| Age (mean/range): NA / NA | Duration: 24 | Active RA | | 2 | Fish oil capsules 12/day × 3 mo | Swollen joints: (at month 3) | Jadad: 2
| Race: NA | X-over: week 13 | Exclusion: | | | | Arms 1, 2 = point estimates not reported | Concealment of allocation: NR
| % male: NA | Run-in: NR | NR | | | | Meta-analysis: Not included; point estimates not reported. | Applicability: NR
| # sites: NA | Wash-out: NR | | | | | Reported testing: Significant difference between arms favoring fish oil, test not stated. | Funding source: ND
| Location: Netherlands | | | | | | Acute phase reactant: (CRP, mg/dl, at month 3)
| | | | | | | Arms 1, 2 = point estimates not reported before cross-over
| | | | | | | Meta-analysis: Not included; point estimates not reported.
| | | | | | | Reported testing: No significant difference between arms , test not stated.
| | | | | | | Patient global assessment: NA
| | | | | | | Radiographic damage: NA
| | | | | | | NSAID consumption: NA
| | | | | | | Steroid consumption: NA
| | | | | | | DMARD consumption: NA
van der Tempel H, 1990^33^ | Sample size: NA | Design: RXT | Inclusion: | Covariates: NSAIDs/DMARDs | 1 | Coconut oil capsules 12/day × 12 wk | Pain:(VAS, cm at week 12) | Quality:
| Age (mean/range): 53 / NA | Duration: 36 wk | NR | | 2 | Fish oil capsules 12/day × 12 wk | Arms 1, 2 = point estimates not reported. | Jadad: 4
| Race: NA | X-over: week 13 | Exclusion: | | | | Meta-analysis: Not included; point estimates not reported before cross-over. | Concealment of allocation: NR
| % male: 44 | Run-in: 12 wk | NR | | | | Reported testing: No significant differences between arms using t-test. | Applicability: IB
| # sites: NA | Wash-out: None | | | | | Swollen joints: (at week 12) | Comments: Meta-analysis not performed because data was not reported by arm separately.
| Location: Netherlands | | | | | | Arms 1, 2 = point estimates not reported. | Funding source: Private, non-industry
| | | | | | | Meta-analysis: Not included; point estimates not reported before cross-over.
| | | | | | | Reported testing: Significant differences between favoring fish oil using t-test.
| | | | | | | Acute phase reactant: (CRP, mg/dl, at month 3)
| | | | | | | Arms 1, 2 = point estimates not reported before cross-over
| | | | | | | Meta-analysis: Not included; point estimates not reported.
| | | | | | | Reported testing: No significant differences between arms using t-test.
| | | | | | | Patient global assessment: NA
| | | | | | | Radiographic damage: NA
| | | | | | | NSAID consumption: NA
| | | | | | | Steroid consumption: NA
| | | | | | | DMARD consumption: NA
Volker D, 2000^35^ | Sample size: 50 | Design: RCT | Inclusion: | Covariates: NSAIDs/DMARDs | 1 | Corn (50%)/olive oil (50%) soft gel capsules 40 mg/kg body weight/day × 15 wk | Pain: (percent change at week 15) | Quality:
| Age (mean/range): 57 / NA | Duration: 15 wk | Stable medication/Active disease/Diet<10g n-6 fatty acids | | 2 | Pikasol (fish oil) capsules 40 mg/kg body weight/day × 15 wk | Arm 1 = -8.6 | Jadad: 3
| Race: NA | | Exclusion: | | | | Arm 2 = -10.0 | Concealment of allocation: NR
| % male: NA | | NA | | | | Meta-analysis: Not included; data reported as percent change. | Applicability: NR
| # sites: NA | | | | | | Reported testing: No significant differnce between goups by MANOVA. | Funding source: Industry, private non-industry
| Location: Australia | | | | | | Swollen joints: (percent change at week 15)
| | | | | | | Arm 1 = -16.6
| | | | | | | Arm 2 = -36.7
| | | | | | | Meta-analysis: Not included; data reported as percent change.
| | | | | | | Reported testing: No significant differnce between goups by MANOVA.
| | | | | | | Acute phase reactant: (ESR, percent change at week 15)
| | | | | | | Arm 1 = -31.9
| | | | | | | Arm 2 = -6.2
| | | | | | | Meta-analysis: Not included; data reported as percent change.
| | | | | | | Reported testing: No significant differnce between goups by MANOVA.
| | | | | | | Patient global assessment: NA
| | | | | | | Radiographic damage: NA
| | | | | | | NSAID consumption: NA
| | | | | | | Steroid consumption: NA
| | | | | | | DMARD consumption: NA

Evidence table C.4 Evidence table of clinical effect of omega-3 fatty acids in renal disease

First Author, Year | Study Characteristics | | Study Design Duration | Eligibility Criteria | Covariates | Arm | Interventions Dosage/Duration | Outcomes Results | Quality Applicability Funding Sources
Bennett WM, 1989^100^ | Sample size: | 37 | Design: RCT | Inclusion | Covariates: Renal/Proteinuria/Nephrotic Renal impairment: scr > 0.12 mm/l | 1 | No treatment × 24 mo | Serum creatinine (change mmol/l at month 24): | Quality:
| Age (mean/range) | 39 / NA | Duration: 24 mo | Biopsy-proven Ig A nephropathy | | 2 | Max EPA (fish oil) 10 g/d × 24 mo | Arm 1= Subjects with baseline > 0.12 mmol/l = 0.22; Subjects with baseline <0.12 mmol/l, but with active disease = 0.01 | Jadad: 2
| Race | NA | | Exclusion: | | | | Arm 2 = Subjects with baseline >0.12 mmol/l = 0.19; Subjects with baseline <0.12 mmol/l, but with active disease = 0.07 ± .06 | Concealment of allocation: NA
| % male : | 57 | | Baseline serum creatinine>0.40 mmol/l or = 0.12 mmol/l without active disease | | | | Meta-anlysis: Not done; too few studies to pool. | Applicability: IIB
| # sites: | NA | | | | | | Reported testing: Testing between arms not reported. | Funding source: NA
| Location: | Australia | | | | | | Creatinine clearance (change ml/min at month 24):
| | | | | | | | Arm 1= -21
| | | | | | | | Arm 2 = -23
| | | | | | | | Meta-anlysis: Not done; too few studies to pool.
| | | | | | | | Reported testing: Testing between arms not reported.
| | | | | | | | ESRD (rate at month 24):
| | | | | | | | Arm 1= 10%
| | | | | | | | Arm 2 = 12%
| | | | | | | | Meta-anlysis: Not done; too few studies to pool.
| | | | | | | | Reported testing: Testing between arms not reported.
| | | | | | | | Graft thrombosis: NA
| | | | | | | | Mortality: NA
| | | | | | | | Immunosuppressive requirement: NA
Clark WFP, 1993^99^ | Sample size: | 21 | Design: RXT | Inclusion: | Covariates: NSAIDs/DMARDs | 1 | Olive oil 15 cap/d × 12 mo | Serum creatinine (μmol/L at month 12): | Quality:
| Age (mean/range) | 39 / 22–66 | Duration: 13 mo | Lupus nephritis | | 2 | Max EPA (fish oil) 15 cap/d × 12 mo | Arm 1= point estimate before cross-over not reported | Jadad: 3
| Race: | NA | X-over: month 5 | Exclusion: NA | | | | Arm 2 = point estimate before cross-over not reported | Concealment of allocation: NA
| % male: | 19 | Run-in: None | | | | | Meta-analysis: Not done; too few studies to pool. | Applicability: IIIB
| # sites: | NA | Wash-out: 3 mo | | | | | Reported testing: No significant (p = 0.60) effect for fish oil (Arm 2) relative to olive oil (Arm 1). | Funding source: Private, non industry
| Location: | Canada | | | | | | Creatinine clearance (ml/min/1.73 m^2^ at at month 12):
| | | | | | | | Arm 1= 78
| | | | | | | | Arm 2 = 75
| | | | | | | | Meta-anlysis: Not done; too few studies to pool.
| | | | | | | | Reported testing: No significant difference between groups.
| | | | | | | | ESRD: NA
| | | | | | | | Graft thrombosis: NA
| | | | | | | | Mortality: NA
| | | | | | | | Immunosuppressive requirement: NA
De Fijter CW, 1995^103^ | Sample size: | NA | Design: RXT | Inclusion: | Covariates: Hypertension | 1 | Corn oil 3 g/d × 5 mo | Serum creatinine: NA | Quality:
| Age (mean/range) | NA / NA | Duration: 27 mo | Dialysis/Start of erythropoietin/ | | 2 | EPA-B (fish oil) 3 g/d × 5 mo | Creatinine clearance: NA | Jadad: 3
| Race: | NA | X-over: month 12 | Exclusion: NA | | | | ESRD: NA | Concealment of allocation: NA
| % male: | NA | Run-in: None | | | | | Graft thrombosis (rate at month 5): | Applicability: NA
| # sites: | NA | Wash-out: 3 mo | | | | | Arm 1= 0% | Funding source: NA
| Location: | Netherlands | | | | | | Arm 2 = 0%
| | | | | | | | Meta-analysis: Not done; too few studies to pool.
| | | | | | | | Reported testing: Testing between arms not reported.
| | | | | | | | Mortality: NA
| | | | | | | | Immunosuppressive requirement: NA
Donadio JV, 1994^98^ | Sample size: | 106 | Design: RCT | Inclusion: Biopsy-proven Ig A nephropathy /Proteinuria/Serum creatinine increased by 25%/Creatinine <3.0 mg/dl/Expected survival of 2 or more years | Covariates: Renal/Proteinuria/Nephrotic | 1 | Olive oil 12 g/d × 24 mo | Serum creatinine (Annual median change mg/dl at month 24): | Quality:
| Age (mean/range): | 37 / NA | Duration: 60 mo | Exclusion: SLE/ Chronic liver disease/Pregnancy/lactating/ Antiglomerular basement membrane glomerulonephritis | | 2 | Max EPA (fish oil) 12 g/d × 12 mo Menhaden oil (fish oil) 12 g/d × 12 mo | Arm 1= 0.14 | Jadad: 4
| Race: | Caucasian | | | | | | Arm 2 = 0.03 | Concealment of allocation: NR
| % male: | 74 | | | | | | Meta-anlysis: Not done; too few studies to pool. | Applicability: IIB
| # sites: | 21 | | | | | | Reported testing: Significant (P = 0.001) effect for fish oil (Arm 2) relative to olive oil (Arm 1) using rank-sum test. | Funding source: Hospital and Industry
| Location: | US | | | | | | Creatinine clearance (Annual median change ml/min/1.73 m^2^ at at month 24):
| | | | | | | | Arm 1= -7.1
| | | | | | | | Arm 2 = -0.3
| | | | | | | | Meta-anlysis: Not done; too few studies to pool.
| | | | | | | | Reported testing: Significant (P = 0.009) effect for fish oil (Arm 2) relative to olive oil (Arm 1) using rank-sum test.
| | | | | | | | ESRD (rate at month 60):
| | | | | | | | Arm 1= 28%
| | | | | | | | Arm 2 = 7%
| | | | | | | | Meta-anlysis: Not done; too few studies to pool.
| | | | | | | | Reported testing: Significant effect for fish oil (Arm 2) relative to olive oil (Arm 1) using rank-sum test and Kaplan-Meier analysis.
| | | | | | | | Graft thrombosis: NA
| | | | | | | | Mortality(rate at month 60):
| | | | | | | | Arm 1= 1%
| | | | | | | | Arm 2 = 2%
| | | | | | | | Meta-anlysis: Meta-analysis not performed on renal studies due to insufficient statistics.
| | | | | | | | Reported testing: No significant effect for fish oil (Arm 2) relative to olive oil (Arm 1) using rank-sum test and Kaplan-Meier analysis.
| | | | | | | | Immunosuppressive requirement: NA
Donadio JV, 2001^104^ | Sample size: | 73 | Design: RCT | Inclusion: | Covariates: Previous meds tx/ Hypertension | 1 | Omacor 4 g/d × 24 mo | Serum creatinine (annual median change, mg/dl at month 60): | Quality:
| Age (mean/range): | 46 / NA | Duration: 60 mo | Biopsy-proven Ig A nephropathy/Age/Serum creatinine 1.5–4.9 mg/dl | | 2 | Omacor 8 g/d × 24 mo | Arm 1= 0.08 | Jadad: 2
| Race: | Caucasian | | Exclusion: | | | | Arm 2 = 0.10 | Concealment of allocation: NA
| % male: | 83 | | NA | | | | Meta-anlysis: Not done; too few studies to pool. | Applicability: IIB
| # sites: | 14 | | | | | | Reported testing: No significant (P = 0.51) effect for high dose Omacor (Arm 2) relative to low dose Omacor(Arm 1) using rank-sum test. | Funding source: Hospital and Industry
| Location: | US | | | | | | Creatinine clearance: NA
| | | | | | | | ESRD ((rate at month 36):
| | | | | | | | Arm 1= 27%
| | | | | | | | Arm 2 = 24%
| | | | | | | | Meta-anlysis: Not done; too few studies to pool.
| | | | | | | | Reported testing: No significant (P = 0.56) effect for high dose Omacor (Arm 2) relative to low dose Omacor(Arm 1) using rank-sum test.
| | | | | | | | Graft thrombosis: NA
| | | | | | | | Mortality (rate at month 36):
| | | | | | | | Arm 1= 0%
| | | | | | | | Arm 2 = 0%
| | | | | | | | Meta-anlysis: Not done; too few studies to pool.
| | | | | | | | Reported testing: No significant effect for high dose Omacor (Arm 2) relative to low dose Omacor(Arm 1) using rank-sum test.
| | | | | | | | Immunosuppressive requirement: NA
Gentile MG, 1993^106^ | Sample size: | NA | Design: RXT | Inclusion: | Covariates: soy diet | 1 | Soy diet alone Dosage NA × 2 mo | Serum creatinine (mg/dl at month 2): | Quality:
| Age (mean/range): | 45 / 15–60 | Duration: 9 mo | Biopsy-proven glomerular disease/Proteinuria/ Hyperlipidemia | | 2 | Soy diet Dosage NA × 2 mo Fish oil 5 g/d × 2 mo | Arm 1= point estimate before cross-over not reported | Jadad: 2
| Race: | NA | X-over: month 4 | Exclusion: | | | | Arm 2 = point estimate before cross-over not reported | Concealment of allocation: NA
| % male: | 45 | Run-in: 2 mo | Steroid treatment/Cytotoxic treatment/NSAID treatment/Lipid lowering drug treatment | | | | Meta-anlysis: Not done; too few studies to pool. | Applicability: IB
| # sites: | 1 | Wash-out: None | | | | | Reported testing: Testing between arms not reported | Funding source: Government
| Location | Italy | | | | | | Creatinine clearance(ml/min atb month 2):
| | | | | | | | Arm 1= point estimate before cross-over not reported
| | | | | | | | Arm 2 = point estimate before cross-over not reported
| | | | | | | | Meta-anlysis: Not done; too few studies to pool.
| | | | | | | | Reported testing: Testing between arms not reported.
| | | | | | | | ESRD: NA
| | | | | | | | Graft thrombosis: NA
| | | | | | | | Mortality: NA
| | | | | | | | Immunosuppressive requirement: NA
Pettersson EE, 1994^101^ | Sample size: | 34 | Design: RCT | Inclusion : | Covariates: Proteinuria/nephrotic | 1 | Corn oil 6g/d × 6 mo | Serum creatinine(change μmol/l at month 6): | Quality:
| Age (mean/range): | 41 / 22–68 | Duration: 6 mo | Biopsy-proven Ig A nephropathy /Proteinuria | | 2 | K-85 (fish oil) 6g/d × 6 mo | Arm 1= 1 | Jadad: 4
| Race: | NA | | Exclusion: | | | | Arm 2 = 8 | Concealment of allocation: NA
| % male: | 78 | | SLE/Steroid treatment /Cytotoxic or immunosuppressive drug treatment/NSAID treatment /Diabetes/Malignant disease/Heart failure/Rapidly progressive renal insufficiency/Uncontrolled hypertension | | | | Meta-anlysis: Not done; too few studies to pool. | Applicability: IIB
| # sites: | NA | | | | | | Reported testing: Testing between arms not reported. | Funding source: NA
| Location: | Sweden | | | | | | Creatinine clearance (change ml/min at month 6):
| | | | | | | | Arm 1= 0
| | | | | | | | Arm 2 = 12
| | | | | | | | Meta-anlysis: Not done; too few studies to pool.
| | | | | | | | Reported testing: Testing between arms not reported
| | | | | | | | ESRD: NA
| | | | | | | | Graft thrombosis: NA
| | | | | | | | Mortality: NA
| | | | | | | | Immunosuppressive requirement: NA
Schmitz PG, 2002^102^ | Sample size: | 24 | Design: RCT | Inclusion: | Covariates: Hyperlipidemia/Hypertension/Diabetes/Venous output resistance | 1 | Corn oil 4g/d × 12 mo | Serum creatinine: NA | Quality:
| Age (mean/range): | 53/NA | Duration: 12 mo | Initiation of hemodialysis with PTFE graft/Hemodialysis with new placement of PTFE graft | | 2 | Fish oil 4g/d × 12 mo | Creatinine clearance: NA | Jadad: 4
| Race: | Black | | Exclusion: | | | | ESRD:NA | Concealment of allocation: NA
| % male: | 46 | | Pregnancy/lactating/Surgical revision of graft/History of GI bleeding/Chronic anticoagulation treatment/ Malignant hypertension/Terminal of life-threatening diseases | | | | Graft thrombosis(rate at 12 mo): | Applicability: IIB
| # sites: | 1 | | | | | | Arm 1= 75% | Funding source: Private, non-industry and Government
| Location: | US | | | | | | Arm 2 = 25%
| | | | | | | | Meta-analysis: Not done; too few studies to pool.
| | | | | | | | Reported testing: Testing between arms not reported.
| | | | | | | | Patency (rate at 12 mo):
| | | | | | | | Arm 1= 15%
| | | | | | | | Arm 2 = 76%
| | | | | | | | Meta-analysis: Not done; too few studies to pool.
| | | | | | | | Reported testing: Significant (p < .03) effect for fish oil (Arm 2) relative to corn oil (Arm 1) using Mantel-Cox test.
| | | | | | | | Mortality : NA
| | | | | | | | Immunosuppressive requirement: NA

Evidence Table C.5 Evidence table of clinical effects of omega-3 fatty acids in systemic lupus erythematosus

First Author, Year | Study Characteristics | | Study design Duration | Eligibility Criteria | Concurrent Disease Condition Medication | Arm | Interventions Dosage/Duration | Outcomes Results | Quality Applicability Funding Source
Clark WF, 1993^99^ | Sample size: | 26 | Design: RXT | Inclusion: Lupus nephritis | Covariates: NSAIDs/DMARDs | 1 | Olive oil capsules 15/d × 12 mo | Disease activity: (SLEDAI score at month 12) | Quality:
| Age (mean/range): | 39 / 22–66 | Duration: 24 mo | Exclusion: NA | | 2 | Max EPA (fish oil) 15/d × 12 mo | Arm 1= point estimate not reported | Jadad: 3
| Race: | NA | X-over: month 13 | | | | | Arm 2 = point estimate not reported | Concealment of allocation: NA
| % male: | 19 | Run-in: None | | | | | Meta-analysis: Not done; too few studies to pool. | Applicability: IIIB
| # sites: | NA | Wash-out: 10 wk | | | | | Reported testing: No change in SLEDAI scores for either arm, statistical test used and comparison between arms for this outcome not explicitly stated. | Funding source: Private, non-industry
| Location: | Canada | | | | | | Disease activity: (anti-ds-DNA Ab level at month 12)
| | | | | | | | Arm 1= point estimate not reported
| | | | | | | | Arm 2 = point estimate not reported
| | | | | | | | Meta-analysis: Not done; too few studies to pool.
| | | | | | | | Reported testing: No treatment (p=0.71), time (p=0.25), order (p=0.35) or carry-over effect (p=0.92); statistical test used not stated.
| | | | | | | | Damage: NA
| | | | | | | | Patient perception: NA
Walton AJ, 1991^107^ | Sample size: | 27 | Design: RXT | Inclusion: Established SLE | Covariates: NA | 1 | Olive oil 20g/d × 12 wk | Disease Activity: (Unspecified individualized responses defined a priori and based on change in clinical and laboratory parameters at month 6) | Quality:
| Age (mean/range): | NA / 21–68 | Duration: 34 wk | | | 2 | Max EPA (fish oil) 20g/d × 12 wk | Arm 1: 4/17 useful/ideal status | Jadad: 3
| | | | | | | | 13/17 static/worse status
| Race: | NA | X-over: week 22 | | | | | Arm 2: 14/17 useful/ideal status | Concealment of allocation: Yes
| | | | | | | | 3/17 static/worse status
| % male: | 7 | Run-in: 2 wk | | | | | Meta-analysis: Not done; too few studies to pool. | Applicability: IIB
| # sites: | 1 | Wash-out: 8 wk | | | | | Reported testing: Testing between groups not reported. | Funding source: government; private, non-industry
| Location: | UK | | | | | | Damage: NA
| | | | | | | | Patient perception: NA
Westberg G, 1990^108^ | Sample size: | 20 | Design: RXT | Inclusion: Stable medication | Covariates: DMARDs, steroid use | 1 | Placebo/control Dosage/duration not collected | Disease activity: (Author's own instrument, at 6 mo) | Quality:
| Age (mean/range): | 44 / 31–64 | Duration: 21 mo | Exclusion: Inactive disease | | 2 | Max EPA (fish oil) Variable dose for 6 mo | Arm 1= point estimates not reported. | Jadad: 5
| Race: | NA | X-over: month 12 | | | | | Arm 2 = point estimates not reported. | Concealment of allocation Yes
| % male: | 12 | Run-in: 3 mo | | | | | Meta-analysis: Not done; too few studies to pool. | Applicability: IIB
| # sites: | 2 | Wash-out: 3 mo | | | | | Reported testing: No significant difference between groups using Student's t-test. | Funding source: NA
| Location: | Australia | | | | | | Disease activity: (anti-DNA Ab level at month 6)
| | | | | | | | Arm 1= point estimate not reported
| | | | | | | | Arm 2 = point estimate not reported
| | | | | | | | Meta-analysis: Not done; too few studies to pool.
| | | | | | | | Reported testing No significant difference between groups using Student's t-test.
| | | | | | | | Damage: NA
| | | | | | | | Patient Perception: NA

Evidence table C.6 Evidence table of clinical effect of omega-3 fatty acids in bone mineral density/osteoporosis

First Author, Year | Study Characteristics | | Study Design Duration | Eligibility Criteria | Concurrent Disease Condition Medication | Arm | Interventions Dosage/Duration | Outcomes Results | Quality Applicability Funding Source
Bassey EJ, 2000^109^ | Sample size: | 64 | Design: RCT | Inclusion: Age/Pre-menopausal | Covariates: | 1 | Calcium 1g/d × 12 mo | Bone mineral density: (change at month 12, g/cm^2^) | Quality:
Study A | Age (mean/range): | 35 / 25–40 | Duration: 12 mo | Exclusion: Health problems/BMI>36, <18/BMD outside 2SD of norms/Confounding drug therapy/Pregnancy/Lactating/ Dietary supplements/Irregular menses | Weight/Age/Dietary Calcium | 2 | Efacal (Ca, Primrose oil, Fish oil) | Arm 1= 0.011 | Jadad: 2
| Race: | NA | | | | | Ca 1 g/d × 12 mo | Arm 2 = 0.008 | Concealment of allocation: Yes
| % male: | 0 | | | | | Evening prim rose oil | Meta-analysis: Not done; too few studies to pool. | Applicability: IA
| # sites: | 1 | | | | | 4 g/d × 12 mo | Reported testing: Significant (p<.001) difference between groups using paired Student's t-test | Funding source:Industry
| Location: | UK | | | | | Fish oil | Fractures: NA
| | | | | | | 440 g/d × 12 mo
Bassey EJ, 2000^109^ | Sample Size: | 57 | Design: RCT | Inclusion: Age/Postmenopausal | Covariates: | 1 | Calcium 1g/d × 12 mo | Bone mineral density: (change at month 12, g/cm^2^) | Quality:
Study B | Age (mean/range): | 57/50–65 | Duration: 12 mo | Exclusion: Health problems/ BMI >36, <18/BMD outside 2SD of norms/Confounding drug therapy/Dietary supplements/ within 1 yr of menopause/Hormone levels outside of normal postmenopausal range/hormone replacement therapy | Weight/Age/Dietary Calcium | 2 | Efacal (Ca, Primrose oil, Fish oil) | Arm 1= -0.013 | Jadad: 2
| race: | NA | | | | | Ca 1 g/d × 12 mo | Arm 2 = -0.008 | Concealment of allocation: Yes
| % male: | 0 | | | | | Evening primrose oil | Meta-analysis: Not done; too few studies to pool. | Applicability: IA
| # sites: | 1 | | | | | 4 g/d × 12 mo | Reported testing: Significant (p<.001) difference between groups using paired Student's t-test. | Funding source: Industry
| Location: | UK | | | | | Fish oil | Fractures: NA
| | | | | | | 440 g/d × 12 mo
Kruger MC, 1998^110^ | Sample size: | 66 starting | Design: RCT | Inclusion: Osteoporosis confirmation by BMD | Covariates: | 1 | Coconut oil 6 g/d × 18 mo | Bone mineral density: (lumbar spine, g/cm^2^ at month 18) | Quality:
| Age (mean/range): | 80 / NA | Duration: 18 mo | Exclusion: Metabolic bone disease/ Diabetes/Renal failure | Weight/Age | 2 | Fish oil 6 g/d × 18 mo | Arm 1= 0.979 | Jadad: 2
| Race: | NA | | | | 2 | EPA 2g × 12 mo plus | Arm 2 = 1.053 | Concealment of allocation: NA
| % male: | 0 | | | | | HMGCoA reductace inhibitor | Meta-analysis: Not done; too few studies to pool. | Applicability: IIIB
| # sites: | NA | | | | | | Reported testing: Testing between groups not reported | Funding source: Industry
| Location: | South Africa | | | | | | Bone mineral density: (femoral neck, g/cm^2^ at month 18)
| | | | | | | | Arm 1= 0.709
| | | | | | | | Arm 2 = 0.774
| | | | | | | | Meta-analysis: Not done; too few studies to pool.
| | | | | | | | Reported testing: Testing between groups not reported
| | | | | | | | Fractures: (cumulative number at month 18)
| | | | | | | | Arm 1= 0
| | | | | | | | Arm 2 = 0
| | | | | | | | Meta-analysis: Not done; too few studies to pool.
| | | | | | | | Reported testing: Testing between groups not reported.
Terano T, 2001^111^ | Sample size: | 33 | Design: RCT | Inclusion: Hyperlipidemia | Covariates: | 1 | HMGCoA reductase inhibitor | Bone mineral density: (speed of sound, %, at month 12) | Quality:
| Age (mean/range): | 58 / NA | Duration: 12 mo | Exclusion: NA | Hyperlipidemia/Age/Weight | | | Arm 1= 98.6 | Jadad: 1
| Race: | NA | | | | | | Arm 2 = 99.3 | Concealment of allocation: NR
| % male: | 0 | | | | | | Meta-analysis: Not done; too few studies to pool. | Applicability: Not described
| # sites: | NA | | | | | | Reported testing: Testing between groups not reported | Funding source: NR
| Location: | Japan | | | | | | Bone mineral density: (transmission index, %, at month 12)
| | | | | | | | Arm 1= 99.4
| | | | | | | | Arm 2 = 101
| | | | | | | | Meta-analysis: Not done; too few studies to pool.
| | | | | | | | Reported testing: Testing between groups not reported
| | | | | | | | Bone mineral density: (osteosono assessment index, %, at month 12)
| | | | | | | | Arm 1= 99.4
| | | | | | | | Arm 2 = 99.3
| | | | | | | | Meta-analysis: Not done; too few studies to pool.
| | | | | | | | Reported testing: Testing between groups not reported.
| | | | | | | | Fractures: NA
Tsuchida K, 1999^112^ | Sample size: | 995 | Design: Cohort | Inclusion: | Covariates: | 1 | Fish -0–1 portions/week | Bone mineral density: | Quality
| Age (mean/range): | 45 / 40–49 | Duration: NA | Age | Weight/Age/Dietary Calcium/Menstrual cycle | 2 | Fish 2–5 portions/week | There was no association between fish intake and BMD of the 2^nd^ metacarpal bone. | Jadad: NA
| Race: | Asian | | Exclusion: | | 3 | Fish 6–7 portions/week | Soybean intake was associated with a significant (p=.03 by ANOVA) gradient in BMD of 2^nd^ metacarpal independent of age, height, weight and weekly calcium intake. Those with 2 or more portions were significantly higher than 0–1 portions. | Concealment of allocation: NA
| % male: | 0 | | Medical treatment/Ovalectomy | | 4 | Soybean 0–1 portions/week | Fractures: NA | Applicability: IA
| # sites: | 18 | | | | 5 | Soybean 2–5 portions/week | | Funding source: NR
| Location: | Japan | | | | 6 | Soybean 6–7 portions/week