# Appendix B. Coding/Data Abstraction Forms

## B.2 Literature Screener Form

## B.3 Quality review form