# Appendix A. Methodologic Approach

## A.1 Preliminary Research Questions

Table A.1.1 Preliminary research questions

General Questions: Questions posed for all three participating EPCs, for years 1 and 2.
1. What is the evidence that variable clinical effects may reflect differences in:; - Serving size (fish vs. dietary supplement);; - Source (fish, food, plant) vs. dietary supplement (fish oil, plant oil);; - Specific type(s) of omega-3 fatty acids (docosahexaenoic acid (DHA), eicosapentaenoic acid (EPA), docosapentaenoic acid (DPA), and alpha-linolenic acid (ALA), fish, fish oil), or the ratio of omega-6/omega-3 fatty acids used;; - Manufacturer (different purity, presence of other potentially active agents)?; 2. What is the evidence for adverse events, side effects, or counter-indications associated with omega-3 fatty acids (DHA, EPA, DPA, ALA, fish oil, fish)?; 3. What is the evidence that omega-3 fatty acids are associated with adverse events in specific subpopulations such as diabetics?; 4. What are the mean and median intakes of DHA, EPA, DPA, ALA, fish, fish oil, omega-6, omega-6/omega-3 ratio in the US population?; 5. What is the evidence that omega-3 fatty acids influence overall energy balance?; 6. What is the evidence that accurate interpretation of the results of clinical studies is dependent on knowing the absolute fatty acid content of the baseline data, the relative fatty acid content of the baseline diet, or the tissue ratios of fatty acids (omega-6/omega-3) during the investigative period?
DISEASE-SPECIFIC QUESTIONS: questions posed to the SCEPC for Year 1 of the project:
Immune-Mediated Diseases
1. What is the evidence that in adults or children with type I diabetes, omega-3 fatty acids increase insulin sensitivity?; 2. What is the evidence that in adults or children with rheumatoid arthritis, omega-3 fatty acids decrease pain or the number of swollen joints?; 3. What is the evidence that omega-3 fatty acids help maintain bone mineral status?; 4. What is the evidence that in adults or children with inflammatory bowel disease (ulcerative colitis and Chrohn's disease), omega-3 fatty acids lower leukotriene B4 or prostaglandin E2 levels?; 5. What is the evidence that in adults or children with systemic lupus erythematosis, omega-3 fatty acids prolong longevity?
Gastrointestinal/Renal
1. What is the evidence for the efficacy of omega-3 fatty acids in treatment of Crohn's disease, ulcerative colitis, renal inflammation, and glomerulosclerosis?; 2. What is the evidence for the efficacy of omega-3 fatty acids in treatment of the hypertriglyceridemia of type II diabetes, insulin resistance, or the metabolic syndrome?; 3. What is the evidence that omega-3 fatty acids influence the regulation of gene expression in the progression/prevention of obesity, and intestinal and liver diseases?

## A.2 Technical Expert Panel

The members of our technical expert panels are listed in Table A.2.1. We conducted our TEP meetings via teleconference. We held a conference call with the rheumatoid arthritis, systemic lupus erythematosis, and bone density TEP on February 7, 2003; the renal/diabetes TEP on February 12, 2003; and the gastrointestinal TEP on February 12, 2003. Dr. Rosaly Correa-de-Araujo, the Task Order Officer, and Jacqueline Besteman, Director of the Evidence-Based Practice Center Program, represented AHRQ on these calls; Dr. Anne Thurn, Director of the Evidence-Based Review Program, represented ODS; and Dr. Paul Shekelle, Director of the SCEPC, Dr. Catherine MacLean, the Task Order Director, and Rena Hasenfeld, the Project Manager, represented the SCEPC. The key comments and recommendations of each TEP are summarized in Table A.2.2. The TEP continued to advise the SCEPC throughout the project via mail, fax, e-mail, and phone calls.

Table A.2.1 Technical expert panel members

Rheumatoid Arthritis, Systemic Lupus Erythematosis, and Bone Density TEP
Name | Area of Expertise | Institution
Judith Ashley, PhD, MSPH, RD | Omega-3 Fatty Acids | University of Nevada School of Medicine
William S. Harris, PhD | Omega-3 Fatty Acids | University of Missouri-Kansas City School of Medicine
Robert P. Heaney, MD | Bone | Creighton University
David A. Isenberg, MD | SLE | University College London Medical School
Joel Kremer, MD | Rheumatoid Arthritis | The Center for Rheumatology
Bruce A. Watkins, PhD | Omega-3 Fatty Acids | Purdue University
Josiah F. Wedgwood, MD, PhD | Rheumatoid Arthritis | National Institute of Allergy and Infectious Diseases
Renal Disease and Diabetes TEP
Name | Area of Expertise | Institution
Judith Ashley, PhD, MSPH, RD | Omega-3 Fatty Acids | University of Nevada School of Medicine
Mayer B. Davidson, MD | Diabetes | Charles R. Drew University of Medicine and Science
James V. Donadio, MD | Renal Diseases | Mayo Medical School
William S. Harris, PhD | Omega-3 Fatty Acids | University of Missouri-Kansas City School of Medicine
Michael D. Jensen, MD | Diabetes | Mayo Medical School
William F. Keane, MD | Renal Diseases | Merck and Co., Inc.
Catherine Meyers, MD | Renal Diseases | NIDDK, Division of Kidney, Urologic & Hematologic Diseases
Gastrointestinal Diseases TEP
Name | Area of Expertise | Institution
Judith Ashley, PhD, MSPH, RD | Omega-3 Fatty Acids | University of Nevada School of Medicine
Andrea Belluzzi, MD | Irritable Bowel Disease | S Orsola Hospital, Bologna, Italy
Frank Hamilton, MD | Irritable Bowel Disease | NIDDK, Division of Digestive Diseases & Nutrition
William S. Harris, PhD | Omega-3 Fatty Acids | University of Missouri-Kansas City School of Medicine
Stephen James, MD | Inflammatory Bowel Disease | NIDDK, Division of Digestive Diseases & Nutrition
Michael Ken May, PhD | Inflammatory Bowel Disease | NIDDK, Division of Digestive Diseases & Nutrition
William F. Stenson, MD | Inflammatory Bowel Disease | Washington University

Table A.2.2 Key TEP comments and recommendations

Rheumatoid Arthritis, Systemic Lupus Erythematosis, and Bone Density TEP
1. What is the evidence that in adults or children with rheumatoid arthritis, omega-3 fatty acids decrease pain or the number of swollen joints?
• Restrict the search to randomized control trials.
• Include children with juvenile rheumatoid arthritis for now.
• If possible, the outcome measures should include: disease activity, damage, and patient perception (i.e. patient global assessment).
2. What is the evidence that omega-3 fatty acids help maintain bone mineral status?
• Include both randomized controlled trials and observational studies.
• The populations of interest are older women and women with osteoporosis.
• Outcomes for randomized controlled trials will likely be measures of bone density and biologic markers.
• Outcomes for observational studies are more likely to include fracture rates.
• There is a need to adjust for ethnicity in the analyses because bone shape may affect the • rate of fractures.
• In studies that report t-scores, there is a need to note the standard used to compute the t-score; WHO and NHANES are two different standards that may be used.
3. What is the evidence that in adults or children with systemic lupus erythematosus, omega-3 fatty acids prolong longevity?
• Restrict the study to randomized controlled trials.
• Longevity is not the correct outcome to assess.
• Recommended outcomes for assessment include disease activity, damage, and • patient perception (i.e. patient global assessment).
General Comments
• Note reported side effects of omega-3 fatty acids when reviewing the literature.
Renal Disease and Diabetes TEP
1. What is the evidence for the efficacy of omega-3 fatty acids in treatment of hypertriglyceridemia of type II diabetes, insulin resistance, or the metabolic syndrome?
• The question should be re-worded in the following way: What is the evidence in adults or children for the efficacy of omega-3 fatty acids in treatment of hyperlipedemia in a) type II diabetes, or b) insulin resistance/the metabolic syndrome?
• Do not to limit the review to hypertriglyceridemia; collect data on other lipids, as well.
• The question pertains specifically to the effect of omega-3 fatty acids on lipids in two different clinical syndromes: type II DM and the insulin resistance/metabolic syndrome.
• The question pertains to both adults and children.
2. What is the evidence that in adults or children with type I diabetes, omega-3 fatty acids increase insulin sensitivity?
• Since insulin resistance is not a feature of type I diabetes, the questions should be re-worded in the following way: What is the evidence in adults and children for an effect of omega-3 fatty acids on insulin sensitivity in a) type II diabetes, or b) the metabolic syndrome?
3. What is the evidence for the efficacy of omega-3 fatty acids in treatment of renal inflammation and glomerulosclerosis?
• There was no consensus on how “renal inflammation” and “glomerulosclerosis” should be defined.
• There was no consensus about whether to assess the effect of omega-3 fatty acids on the progression of renal disease.
• Randomized controlled trials should be examined to determine whether sufficient evidence exists to assess the effect of omega-3 fatty acids on renal inflammation and/or the progression of renal acute or chronic renal insufficiency.
• The question may be re-worded after the literature review has been completed.
Gastrointestinal Diseases TEP
1. What is the evidence for the efficacy of omega-3 fatty acids in treatment of Crohn's disease and ulcerative colitis?
• There are so few studies on the efficacy of omega-3 fatty acids in treating inflammatory bowel disease that it may be necessary to do a qualitative rather than a quantitative review of the literature.
• Efficacy is not uniformly defined in IBD. However, a recent NIH conference addressed defining efficacy in Crohn's disease.
• There are many potential confounders/effect modifiers for IBD, especially for Crohn's disease, including disease characteristics (severity, presence or absence of fistulas in Crohn's), medication use, and population characteristics.
2. What is the evidence that in adults or children with inflammatory bowel disease (ulcerative colitis and Crohn's disease), omega-3 fatty acids lower leukotriene B4 or prostaglandin E2 levels?
• A review of the effect of omega-3 fatty acids on leukotriene B4 or prostaglandin E2 should not be included in the report since neither is a measure of prevention or efficacy in IBD.
• There are no studies of the effects of omega-3 fatty acids on IBD in children.
General Comments
• Take note of the omega-3 preparation.
• Abstract and report side effects.

## A.3 Search Strategies

Table 3.1 Core search strategy

1. exp fatty acids, omega-3/; 2. fatty acids, essential/; 3. Dietary Fats, Unsaturated/; 4. linolenic acids/; 5. exp fish oils/; 6. (n 3 fatty acid$ or omega 3).tw.; 7. docosahexa?noic.tw,hw,rw.; 8. eicosapenta?noic.tw,hw,rw.; 9. alpha linolenic.tw,hw,rw.; 10. (linolenate or cervonic or timnodonic).tw,hw,rw.; 11. menhaden oil$.tw,hw,rw.; 12. (mediterranean adj diet$).tw.; 13. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.; 14. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.; 15. (fish adj2 oil$).tw.; 16. (cod liver oil$ or marine oil$ or marine fat$).tw.; 17. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.; 18. (fish consumption or fish intake or (fish adj2 diet$)).tw.; 19. diet$ fatty acid$.tw.; 20. or/1–19; 21. dietary fats/; 22. (randomized controlled trial or clinical trial or controlled clinical trial or evaluation studies or multicenter study).pt.; 23. random$.tw.; 24. exp clinical trials/ or evaluation studies/; 25. follow-up studies/ or prospective studies/; 26. or/22–25; 27. 21 and 26; 28. (Ropufa or MaxEPA or Omacor or Efamed or ResQ or Epagis or Almarin or Coromega).tw.; 29. (omega 3 or n 3).mp.; 30. (polyunsaturated fat$ or pufa or dha or epa or long chain or longchain or lc$).mp.; 31. 29 and 30; 32. 20 or 27 or 28 or 31

Table 3.2 Literature searches by disease category

Diabetes
1. exp fatty acids, omega-3/; 2. fatty acids, essential/; 3. Dietary Fats, Unsaturated/; 4. linolenic acids/; 5. exp fish oils/; 6. (n 3 fatty acid$ or omega 3).tw.; 7. docosahexa?noic.tw,hw,rw.; 8. eicosapenta?noic.tw,hw,rw.; 9. alpha linolenic.tw,hw,rw.; 10. (linolenate or cervonic or timnodonic).tw,hw,rw.; 11. menhaden oil$.tw,hw,rw.; 12. (mediterranean adj diet$).tw.; 13. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.; 14. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.; 15. (fish adj2 oil$).tw.; 16. (cod liver oil$ or marine oil$ or marine fat$).tw.; 17. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.; 18. (fish consumption or fish intake or (fish adj2 diet$)).tw.; 19. diet$ fatty acid$.tw.; 20. or/1–19; 21. dietary fats/; 22. (randomized controlled trial or clinical trial or controlled clinical trial or evaluation studies or multicenter study).pt.; 23. random$.tw.; 24. exp clinical trials/ or evaluation studies/; 25. follow-up studies/ or prospective studies/; 26. or/22–25; 27. 21 and 26; 28. (Ropufa or MaxEPA or Omacor or Efamed or ResQ or Epagis or Almarin or Coromega).tw.; 29. (omega 3 or n 3).mp.; 30. (polyunsaturated fat$ or pufa or dha or epa or long chain or longchain or lc$).mp.; 31. 29 and 30; 32. 20 or 27 or 28 or 31; 33. hyperinsulin?emia.tw.; 34. hyperinsulinemia/; 35. exp diabetes mellitus/; 36. diabetes.tw.; 37. insulin.tw.; 38. metabolic syndrome$.tw.; 39. exp insulin resistance/; 40. or/33–39; 41. 32 and 40; 42. 41 and human/
Inflammatory Bowel Disease and Renal Disease
1. exp fatty acids, omega-3/; 2. fatty acids, essential/; 3. Dietary Fats, Unsaturated/; 4. linolenic acids/; 5. exp fish oils/; 6. (n 3 fatty acid$ or omega 3).tw.; 7. docosahexa?noic.tw,hw,rw.; 8. eicosapenta?noic.tw,hw,rw.; 9. alpha linolenic.tw,hw,rw.; 10. (linolenate or cervonic or timnodonic).tw,hw,rw.; 11. menhaden oil$.tw,hw,rw.; 12. (mediterranean adj diet$).tw.; 13. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.; 14. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.; 15. (fish adj2 oil$).tw.; 16. (cod liver oil$ or marine oil$ or marine fat$).tw.; 17. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.; 18. (fish consumption or fish intake or (fish adj2 diet$)).tw.; 19. diet$ fatty acid$.tw.; 20. or/1–19; 21. dietary fats/; 22. (randomized controlled trial or clinical trial or controlled clinical trial or evaluation studies or multicenter study).pt.; 23. random$.tw; 24. exp clinical trials/ or evaluation studies/; 25. follow-up studies/ or prospective studies/; 26. or/22–25; 27. 21 and 26; 28. (Ropufa or MaxEPA or Omacor or Efamed or ResQ or Epagis or Almarin or Coromega).tw.; 29. (omega 3 or n 3).mp.; 30. (polyunsaturated fat$ or pufa or dha or epa or long chain or longchain or lc$).mp.; 31. 29 and 30; 32. 20 or 27 or 28 or 31; 33. exp inflammatory bowel diseases/; 34. inflammatory bowel.tw.; 35. (hemorrhagic proctocolitis or ulcerative proctocolitis).tw.; 36. (hemorrhagic rectocolitis or ulcerative rectocolitis).tw.; 37. (ileocolitis or ileitis or enteritis or crohn$ or pancolitis or proctitis or colitis).tw.; 38. exp nephritis/; 39. ((renal or kidney) and inflammation).tw.; 40. (glomerulo$ or nephritis or nephropath$).tw.; 41. or/33–40; 42. 32 and 41; 43. 42 and human/
Rheumatoid Arthritis
1. exp fatty acids, omega-3/; 2. fatty acids, essential/; 3. Dietary Fats, Unsaturated/; 4. linolenic acids/; 5. exp fish oils/; 6. (n 3 fatty acid$ or omega 3).tw; 7. docosahexa?noic.tw,hw,rw.; 8. eicosapenta?noic.tw,hw,rw.; 9. alpha linolenic.tw,hw,rw.; 10. (linolenate or cervonic or timnodonic).tw,hw,rw.; 11. menhaden oil$.tw,hw,rw.; 12. (mediterranean adj diet$).tw.; 13. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.; 14. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.; 15. (fish adj2 oil$).tw.; 16. (cod liver oil$ or marine oil$ or marine fat$).tw.; 17. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.; 18. (fish consumption or fish intake or (fish adj2 diet$)).tw.; 19. diet$ fatty acid$.tw.; 20. or/1–19; 21. dietary fats/; 22. (randomized controlled trial or clinical trial or controlled clinical trial or evaluation studies or multicenter study).pt.; 23. random$.tw.; 24. exp clinical trials/ or evaluation studies/; 25. follow-up studies/ or prospective studies/; 26. or/22–25; 27. 21 and 26; 28. (Ropufa or MaxEPA or Omacor or Efamed or ResQ or Epagis or Almarin or Coromega).tw.; 29. (omega 3 or n 3).mp; 30. (polyunsaturated fat$ or pufa or dha or epa or long chain or longchain or lc$).mp; 31. 29 and 30; 32. 20 or 27 or 28 or 31; 33. exp arthritis, rheumatoid/; 34. (rheumat$ adj2 arthritis).tw.; 35. stills diseas$.tw.; 36. caplans syndrome$.tw; 37. feltys syndrome$.tw; 38. rheumatoid nodule$.tw.; 39. sjogrens syndrome$.tw.; 40. ankylosing spondylitis.tw; 41. rheumat$.tw; 42. or/33–41; 43. 32 and 42; 44. limit 43 to human
Systemic Lupus Erythematosus
1. exp fatty acids, omega-3/; 2. fatty acids, essential/; 3. Dietary Fats, Unsaturated/; 4. linolenic acids/; 5. exp fish oils/; 6. (n 3 fatty acid$ or omega 3).tw.; 7. docosahexa?noic.tw,hw,rw.; 8. eicosapenta?noic.tw,hw,rw.; 9. alpha linolenic.tw,hw,rw.; 10. (linolenate or cervonic or timnodonic).tw,hw,rw.; 11. menhaden oil$.tw,hw,rw.; 12. (mediterranean adj diet$).tw.; 13. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.; 14. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.; 15. (fish adj2 oil$).tw.; 16. (cod liver oil$ or marine oil$ or marine fat$).tw.; 17. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.; 18. (fish consumption or fish intake or (fish adj2 diet$)).tw.; 19. diet$ fatty acid$.tw.; 20. or/1–19; 21. dietary fats/; 22. (randomized controlled trial or clinical trial or controlled clinical trial or evaluation studies or multicenter study).pt.; 23. random$.tw.; 24. exp clinical trials/ or evaluation studies/; 25. follow-up studies/ or prospective studies/; 26. or/22–25; 27. 21 and 26; 28. (Ropufa or MaxEPA or Omacor or Efamed or ResQ or Epagis or Almarin or Coromega).tw.; 29. (omega 3 or n 3).mp.; 30. (polyunsaturated fat$ or pufa or dha or epa or long chain or longchain or lc$).mp.; 31. 29 and 30; 32. 20 or 27 or 28 or 31; 33. exp Lupus Erythematosus, Systemic/; 34. (lupus glomerulonephritis or lupus nephritis).tw.; 35. (libman-sacks or lupus erythematosus disseminatus or systemic lupus erythematosus).tw.; 36. (lupus vasculitis or lupus meningoencephalitis or central nervous system systemic lupus).tw.; 37. or/33–36; 38. 32 and 37; 39. limit 38 to human
Bone Density/Osteoporosis
1. exp fatty acids, omega-3/; 2. fatty acids, essential/; 3. Dietary Fats, Unsaturated/; 4. linolenic acids/; 5. exp fish oils/; 6. (n 3 fatty acid$ or omega 3).tw.; 7. docosahexa?noic.tw,hw,rw.; 8. eicosapenta?noic.tw,hw,rw.; 9. alpha linolenic.tw,hw,rw.; 10. (linolenate or cervonic or timnodonic).tw,hw,rw.; 11. menhaden oil$.tw,hw,rw.; 12. (mediterranean adj diet$).tw.; 13. ((flax or flaxseed or flax seed or linseed or rape seed or rapeseed or canola or soy or soybean or walnut or mustard seed) adj2 oil$).tw.; 14. (walnut$ or butternut$ or soybean$ or pumpkin seed$).tw.; 15. (fish adj2 oil$).tw.; 16. (cod liver oil$ or marine oil$ or marine fat$).tw.; 17. (salmon or mackerel or herring or tuna or halibut or seal or seaweed or anchov$).tw.; 18. (fish consumption or fish intake or (fish adj2 diet$)).tw.; 19. diet$ fatty acid$.tw.; 20. or/1–19; 21. dietary fats/; 22. (randomized controlled trial or clinical trial or controlled clinical trial or evaluation studies or multicenter study).pt.; 23. random$.tw.; 24. exp clinical trials/ or evaluation studies/; 25. follow-up studies/ or prospective studies/; 26. or/22–25; 27. 21 and 26; 28. (Ropufa or MaxEPA or Omacor or Efamed or ResQ or Epagis or Almarin or Coromega).tw.; 29. (omega 3 or n 3).mp.; 30. (polyunsaturated fat$ or pufa or dha or epa or long chain or longchain or lc$).mp.; 31. 29 and 30; 32. 20 or 27 or 28 or 31; 33. bone density/; 34. (bone mineral or bone densit$ or bone mass).tw.; 35. exp Bone Demineralization, Pathologic/; 36. Bone Demineral$.tw.; 37. exp Bone Resorption/; 38. (bone loss$ or bone resportion).tw.; 39. exp Densitometry/; 40. or/33–39; 41. 32 and 40; 42. limit 41 to human

Table 3.3 Industry experts that were contacted for data about efficacy of omega-3 fatty acids

Name | Affiliation
Ian Newton | Roche Vitamins
Herb Wool, PhD | BASF Corporation
Annette Dickinson | Council for Responsible Nutrition

## Figure A.3.1 Letter sent to industry experts

[image]

## A.4 Inclusion/Exclusion Criteria

Table A.4.1 Inclusion/Exclusion Criteria at Screening Stage.*

Assessed the effect of omega-3 fatty acids on arthritis (including rheumatoid arthritis and juvenile rheumatoid arthritis), bone mineral metabolism, diabetes, IBD, lupus, or renal disease
Presented research on human subjects
Reported the results of randomized or controlled clinical trials or cohort/case control studies;† we accepted observational studies for bone mineral status only.
For cross-over studies, reported outcomes for each arm before the cross-over at the end of the first phase of treatment‡

* Language was not a barrier to inclusion;

† We defined a randomized controlled trial (RCT) as one in which the participants were assigned to one of two (or more) study groups using a process of random allocation (e.g., random number generation, coin flips); we defined a controlled clinical trial (CCT) as one in which participants were either: (1) assigned to one of two (or more) study groups using a quasi-random allocation method (e.g., alternation, date of birth, patient identifier), or (2) possibly assigned to one of two (or more) study groups using a process of random or quasi-random allocation;

‡ We did not use data from the end of the study period in studies with a cross-over design because as a result of this design, the treatment and placebo groups from these studies are not comparable to the treatment and placebo groups of the non-cross-over randomized controlled trials with which they would be pooled in a meta-analysis. For example, one half of the placebo group in a cross-over trial will have been exposed to treatment with omega-3 fatty acids prior to placebo and hence the measured effect could be biased by earlier treatment with Omega-3 fatty acids.

## A.5 Evidence Grading System

Table A.5.1 Summary Score for Methodologic Quality

Summary Score | Jadad Score | Concealment of Allocation
A | 5 | Performed
B | 5 | Not performed, or Not reported
| 3 or 4 | Performed, Not performed, or Not reported
| 0,1, or 2 | Performed
C | 0, 1, or 2 | Not performed or not reported

Even though a study may focus on a specific target population, limited study size, eligibility criteria and patient recruitment process may result in a narrow population sample that is of limited applicability, even to the target population. To capture this parameter, we categorize studies into the applicability scale described in Table A.5.1.

Table A.5.2 Applicability ratings

Applicability | | Health state
I | Sample is representative of the U.S. population. | A General population. Typical healthy people similar to Americans without known cardiovascular diseases.
II | Sample is representative of a relevant sub-group of the target population, but not the entire population. For example, a study that is restricted to women or a fish oil study in Japan where the background diet is very different from that of the US would fall into this category. | B Diseased population. Subjects with any of the following: inflammatory bowel disease, rheumatoid arthritis, renal disease, systemic lupus erythematosus or osteoporosis.
III | Sample is representative of a narrow subgroup of subjects only, and not well applicable to other subgroups. For example, a study of oldest old men or a study of a population on highly controlled diet.

## Figure A.5.1 Jadad score of methodologic quality.*

[image]

* Jadad A, Moore A, Carrol D, et al. Assessing the quality of reports of randomized clinical trials: Is blinding necessary? Control Clin Trials. 1996;17:1–12.

Table A.6.1 Peer Reviewers

Peer Reviewer | Area of Expertise | Affiliation
Richard Glassock, MD | nephrology | UCLA
David Heber, MD | nutrition | UCLA
Ted Kraegen, PhD | diabetes, nutrition | Garvan Research Institute, Sydney
Kenneth Saag, MD, MPH | osteoporosis, SLE | University of Alabama
Walter Willett, MD | epidemiology, nutrition | Harvard University
Robert Zurier, MD | rheumatoid arthritis, omega-3 fatty acids | University of Massachusetts Medical School