# Evidence Tables

* Calculated by review team

A.a Actinobacillus actinomycetemcomitans

ANCOVA Analysis of Covariance

ANOVA Analysis of Variance

API Approximal plague index

Appts. appointments

BANA. Benxoyl-DL-Arginine-Naphthylamide test

B.f.. Bacteroides forsythus

B.g.. Bacteroids gingivalis

bid Two times daily

B1 Bleeding

BL Bone Loss

BOP/SBI Bleeding on Probing

C Control Group

C.r.. Campylobacter rectus

CAG Chronic Atrophia Gastritis

CAL Clinical Attachment Level/Loss

CDI Cell-directed Inhibitors

CHX Chlorhexidine

CIS Simplified Calculus Index

CPITN. Community Periodontal Index of Treatment Needs

Diff Difference

E.c.. Eikenella corrodens

EDTA Ethylenediaminetetracetic Acid

GCF Gingival Crevicular Fluid

GI Gingival Index or Gingivitis Index

GLM General Linear Models

Grad. Graduate Grp Group

HCI Hydrochloride

Ind. Index

JP Juvenile Periodontitis

LAP Localized Aggressive Peridontitis

LoA Level of Attachment

max. Maximum

Mg. Milligram

MGI. Modified Gingival Index

min. Minute

mm Millimeter

mg/ml. Milligrams per milliliter

MMP-8 Metalloproteinas-8

Mo Month

NA. Not Applicable, measure not part of study

ng/ml. nanogram per milliliter

NR Not reported

NS Not significant

P Probability

PAL Probing Attachment Level

PBI Papilla Bleeding Index

PD Probing Depth

PDI Peridontal Disease Index

P.g. Porphyromonas gingivalis

P.i. Prevotella intermedia

PlI Plaque Index

PD Probing Depth Pocket

Pts Patients

quad. Quadrant

RCT Randomized Controlled Trial

Rmg. Remaining

RP Root Planing

SBI Sulcus Bleeding Index

SD Standard Deviation

SDD Subantimicrobial Dose Doxycycline

se Standard Error

sig. significance

SL Stomelysin

SRP Scaling and Root Planing

T Treatment Group

TC Triclosan

T.d. Treponema denticola

TET Tetracyline

tid Three times daily

TIMP Tissue Inhibitor of Metalloproteinases

Txt Treatment

wk. Week

w/w. Weight percent

x. Per

Yr Year

Evidence Table 1a. Effectiveness of Systemic Tetracycline as an Adjunct to Scaling and Root Planing to Treat Chronic Periodontitis

Study Description | Study Design Characteristics | Disease Characteristics | Examiner Characteristics | Description of Scaling and Root Planing | Eligible Study Groups and How Defined: | Study Group Characteristics | Compliance Monitoring | Baseline Measures | Time Interval(s) | Outcomes Assessed | Adverse Effects | Study Group Attrition and Reasons | Type of Analysis | Outcomes Accessed
| | | | | | | | | | | | | | (N of Pts) | | Attachment Level mm [image] (SD) | Probing Depth mm [image] (SD) | Spirochetes [image]% (SD) | Comments
Haffajee et al., 1995 ^46^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NR | Before SRP | 6 times (at baseline and 2, 4, 6, 8, and 10 months) | Clinical Measurement: | NR | NR | Type of analysis reported: | Baseline: | | | | | Only baseline values presented in table. Change score mostly presented in bar graphs. Text presents change scores for PD, but not the associated SDs.
Study Period: | RCT | Active disease, no rapidly progressing periodontal disease | 1 | Scaling and root planing by quadrant, approximate 10 day intervals, repeated during course of study every 3 months for 1 yr | 24 subjects, 6 sites per tooth | Mean All: 48 ± 12 | | | | BOP/SBI | | | Mann-Whitney and Kruskal-Wallis, change by site, averaged for individual, then averaged for group | T: | 13 | 3.6 (1.1) | 3.8 (0.5) | NA | Quality Score:
43 weeks (10 months) | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent on SRP: | T: 13 subjects | Mean T: 44 ± 15 | | | | PD | | | | C: | 11 | 3.5 (1.2) | 3.6 (0.5) | NA | 62; 46
Study/Treatment Site: | Random | All excluding third molars | NA | NR | C: 11 subjects | Mean C: 48 ± 11 | | | | CAL | | | | Final: 43 weeks (10 months)
Hospital Dental Clinic | Blinding: | Widman flap: | Assigned to Subjects: | | Dose, Mode, Schedule: | Gender: | | | | GI | | | | T: | 13 | NR | NR | NA
Location: | Examiners and patients blind | Yes, at active sites and where PD > 4mm | Same examiner throughout study | | All rinsed with 0.12% chlorhexidine for 30 days | All: 57% Male | | | | Radiographic Techniques: | | | | C: | 11 | NR | NR | NA
USA | Placebo: | | | | T: SRP plus 250 mg tetracycline 3×day for 30 days | T: 62% Male | | | | NR | | | | Change: | | [underlined: Gain] | [underlined: Reduction]
Patients Selected: | Yes | | | | C: SRP plus placebo (250 mg sucrose) 3×day for 30 days | C: 55% Male | | | | Microbiological Methods: | | | | T: | | 0.49 (NR) | 0.75 (NR) | NA
Originally 98 patients aged 14–71 with evidence of prior attachment loss, at least 20 teeth and at least 4 pockets >4 mm and 4 sites of LOA >3mm, no localized JP. From this pool, subjects exhibiting LOA >2.5 mm at ≥ 1 sites anytime during 6 months observation period were admitted to study | Split-mouth: | | | | | Race/Ethnicity: | | | | DNA probes and colony lifts for 14 taxa in 29 of 40 subjects | | | | C: | | NR | 0.46 (NR) | NA
| No | | | | | NR | | | | Subject Self Report: | | | | Test: | | Mann Whitney Test | Mann Whitney Test
| | | | | | | | | | NR | | | | P value: | | NS | NS
Author and Year: | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NR | Before SRP | 5 exams (at baseline, 2, 10, 20, and 30 weeks) | Clinical Measurement: | NR | NR | Type of analysis reported: | Baseline: | | | | | The PD values and spirochetes were measured at each exam. The CAL values are change scores from baseline. Standard errors are shown rather than standard deviations.
Lindhe et al, 1983 ^44^ | RCT | Advanced periodontitis | NR | Meticulous scaling under anesthesia (half mouth) requiring 2–4 visits during course of week | 14 subjects | Range: 37–52 | | | | OHI | | | Full participants only | T: | 7 | 7.1 (0.4) | 7.5 (0.3 se) | 48 (3 se) | Quality Score:
Study Period: | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent on SRP: | T: 7 subjects | Gender Distribution: | | | | GI | | | | C: | 7 | 7.4 (0.5) | 7.7 (0.4 se) | 37 (10 se) | 70; 77
50 weeks | Random | Premolars and incisors | NR | NR | C: 7 subjects | Male: 6 | | | | BOP | | | | Final: 50 weeks
Site of Study: | Blinding: | Widman flap: | Assigned to Subjects: | | Dose, Mode, Schedule: | Female: 8 | | | | PD | | | | T: | 7 | NR | 4.4 (0.1 se) | 0 (0 se)
Dept of Periodontology, Univ of Gothenburg, Sweden | Examiners and patients blind | No | NR | | T: SRP plus 250 mg tetracycline 4×day for 2 weeks, then 250 mg 1×day for 48 weeks | Race/Ethnicity: | | | | CAL | | | | C: | 7 | NR | 5.4 (0.2 se) | 8 (8 se)
Location: | Placebo: | | | | C: SRP plus placebo | NR | | | | Radiographic Techniques: | | | | Change: | | [underlined: Gain]
Gothenburg, Sweden | Yes | | | | | | | | | NR | | | | T: | | 1.7 (0.3 se) | 3.1* (NR) | NR
Patients Selected: | Split-mouth: | | | | | | | | | Microbiological Methods: | | | | C: | | 1.4 (0.3 se) | 2.3* (NR) | NR
Referral patients with at least 20 teeth, and 4 pairs of diseased sites around contralateral premolars or incisors with ≥ 6 mm PD and ≥ 40% bone loss | Yes, for SRP | | | | | | | | | Subgingival plaque; % coccoids, rods, spirochetes | | | | Test: | | NR | NR
| No, for intervention | | | | | | | | | Subject Self Report: | | | | P value: | | NR | NR
| | | | | | | | | | NR
Author and Year: | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NR | Before SRP | 3 times (at baseline and weeks 8 and 25) | Clinical Measurement: | NR | NR | Type of analysis reported: | Baseline: | | | | | No statistical testing of change scores between groups. No data reported for CAL, text says “no detectable change occurred.”
Listgarten et al., 1978 ^43^ | RCT | Severe chronic periodontitis | NR | Series of weekly scalings requiring 2 to 4 appts for 2 selected quadrants | 12 subjects | Mean: 34 | | | | Gingival fluid flow | | | Full participants only | T: | 6 | NR | 7.2 (0.5 se) | 36.3 (5.2 se) | Quality Score:
Study Period: | Subject/Site Allocation: | Types of Teeth: | Trained: | 2 additional scalings at weeks 15 and 22; not described in terms of intensity | T: 6 subjects | Range: 27 – 42 | | | | GI | | | | C: | 6 | NR | 7.0 (0.6 se) | 34.8 (6.2 se) | 38; 31
25 weeks | Random | NR | NR | Time spent on SRP: | C: 6 subjects | Gender Distribution: | | | | PI | | | | Final: 25 weeks
Site of Study: | Blinding: | Widman flap: | Assigned to Subjects: | NR | Dose, Mode, Schedule: | Male: 7 | | | | PD | | | | T: | 6 | NR | 4.8 (0.3 se) | 6.5 (4.0 se)
Central Hospital | NR | NR | NR | | T: SRP plus 250mg tetracycline 4×day for 2 two-week periods, separated by 4 weeks | Female: 5 | | | | CAL | | | | C: | 6 | NR | 4.8 (0.9 se) | 6.3 (4.3 se)
Location: | Placebo: | | | | C: SRP only | Race/Ethnicity: | | | | Radiographic Techniques: | | | | Change:
Sweden | No | | | | | NR | | | | NR | | | | T: | | NR | 2.4* (NR) | NR
Patients Selected: | Split-mouth: | | | | | | | | | Microbiological Methods: | | | | C: | | NR | 2.2* (NR) | NR
Wait-listed patients for periodontal care, patients had at least 3 pairs of contralateral teeth with PD of ≥ 5 mm and 50% bone loss | Yes, for SRP | | | | | | | | | Microbial composition | | | | Test: | | | NR
| No, for intervention | | | | | | | | | Histological data | | | | P value: | | | NS
| | | | | | | | | | Electron microscopy data
| | | | | | | | | | Subject Self Report:
| | | | | | | | | | NR
Al-Joburi et al., 1989 ^45^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | Yes | Before SRP | 5 times (at baseline and weeks 2, 8, 12, and 24) | Clinical Measurement: | Yes, 1 subject excluded because of nausea | 17 subjects excluded from full study: intercurrent but unrelated illness during the study which required taking antibiotics other than study medication (1); lost to follow-up (3); failed to take medication as prescribed (6); developed severe diarrhea (1) | Type of analysis reported: | PD 1 to 3 mm: | | | | | The difference in the reduction in spirochetes between tetracycline group and SRP alone group was significant at 2 and 8 weeks
Study Period: | RCT | Advanced adult chronic periodontitis | 2 | Thorough scaling and root planing (intensive) completed in 2 visits, one week apart | 96 enrolled in full study | Mean: 46 ± 9 (full study) | | | | BOP/SBI | | | Full participants for these 2 study groups | Baseline: | | | | | % Spirochetes:
24 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | 79 completed full study | Gender: | | | | PlI | | | | T: | NR | 7.25 (0.46) | 3.00 (0.00) | NR | [underlined: Baseline] | [underlined: Final]
Study/Treatment Site: | Random | NR | NR | 6 hours | 2 sites per subject | NR | | | | PD | | | | C: | NR | 7.50 (0.84) | 3.00 (0.00) | NR | T: 26 (NR) | 7 (NR)
Several Universities | Blinding: | Widman flap: | Assigned to Subjects: | | 51 in relevant groups | Race/Ethnicity: | | | | CAL | | | | Final: 24 weeks | | | | | C: 30 (NR) | 11 (NR)
Location: | Examiners and patients blind | NR | Same examiner throughout study | | T: 27 completed | NR | | | | Radiographic Techniques: | | | | T: | 27 | 7.06 (0.55) | 2.88 (0.22) | NR | (P ≤ 0.05)
Canada | Placebo: | | | | C: 24 completed | | | | | NR | | | | C: | 24 | 7.80 (0.82) | 3.00 (0.16) | NR | Quality Score:
Patient Population: | Yes | | | | Dose, Mode, Schedule: | | | | | Microbiological Methods: | | | | Change: | | | | | 69; 62
Patients with ≥ 2 sites with PD of ≥ 7 mm, and at least 15 teeth | Split-mouth: | | | | T: SRP plus 250 mg tetracycline capsule 4×day for 14 days | | | | | Crevicular fluid microbiota Plaque microbiota | | | | T: | | 0.19 (NR) | 0.12 (NR)
| No | | | | C: SRP plus placebo capsule 4×day for 14 days | | | | | Subject Self Report: | | | | C: | | -0.30 (NR) | 0.00 (NR)
| | | | | | | | | | NR | | | | Test:
| | | | | | | | | | | | | | P value:
| | | | | | | | | | | | | | PD 4 to 5 mm:
| | | | | | | | | | | | | | Baseline:
| | | | | | | | | | | | | | T: | | 9.06 (0.26) | 5.21 (0.08)
| | | | | | | | | | | | | | C: | | 9.11 (0.22) | 5.25 (0.08)
| | | | | | | | | | | | | | Final: 24 weeks
| | | | | | | | | | | | | | T: | | 8.00 (0.27) | 3.54 (0.14)
| | | | | | | | | | | | | | C: | | 8.09 (0.21) | 3.53 (0.12)
| | | | | | | | | | | | | | Change:
| | | | | | | | | | | | | | T: | | 1.06 (NR) | 1.67 (NR)
| | | | | | | | | | | | | | C: | | 1.02 (NR) | 1.72 (NR)
| | | | | | | | | | | | | | Test: | | t-test | t-test
| | | | | | | | | | | | | | P value: | | NS | NS
| | | | | | | | | | | | | | PD ≥ 7 mm:
| | | | | | | | | | | | | | Baseline:
| | | | | | | | | | | | | | T: | | 10.58 (0.25) | 7.40 (0.11)
| | | | | | | | | | | | | | C: | | 10.75 (0.29) | 7.60 (0.12)
| | | | | | | | | | | | | | Final: 24 weeks
| | | | | | | | | | | | | | T: | | 8.79 (0.26) | 4.36 (0.21)
| | | | | | | | | | | | | | C: | | 9.21 (0.34) | 4.75 (0.24)
| | | | | | | | | | | | | | Change:
| | | | | | | | | | | | | | T: | | 1.99 (NR) | 3.04 (NR)
| | | | | | | | | | | | | | C: | | 1.54 (NR) | 2.85 (NR)
| | | | | | | | | | | | | | Test: | | t-test | t-test
| | | | | | | | | | | | | | P value: | | NS | NS
Ramberg et al., 2001 ^47^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NR | Before SRP | 4 times (at baseline and years 1, 3, 5, and 13) | Clinical Measurement: | NR | Died (3), moved (18), withdrew from txt group (5) | Type of analysis reported: | Baseline: | | | | | The mean individual PD value which was decreased between baseline and Year 1 had significantly increased between 5 and 12 years
Study Period: | Prospective clinical trial | Advanced periodontitis | 2 | 4 to 6 sessions of non-surgical periodontal therapy under local anesthesia, during 3 week treatment interval. | 89 subjects | Mean: | | | | BOP | | | Full participants only | T: | 35 | NR | 4.2 (0.8) | NA | No sig difference in any measures reported for 3, 5, and 12 years
13 years (52 weeks of data reported) | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | T: 28 subjects | T: 41.2 | | | | PlI | | | | C: | 80 | NR | 3.9 (0.9) | NA | Quality Score:
Study/Treatment Site: | No mention of how subjects were assigned to groups; age; and gender matched control | All teeth | NR | 60 to 90 minutes | C: 61 subjects | C: 42.1 | | | | PD all teeth, six sites/tooth | | | | Final: 52 weeks | | | | | 31; 23
Department of Peridontology | Blinding: | Widman flap: | Assigned to Subjects: | | Dose, Mode, Schedule: | Range: | | | | CAL | | | | T: | 28 | NR | NR | NA
Location: | NR | NR | NR | | T: SRP plus 250 mg tetracycline tablet 4×day for 3 weeks and 0.2% chlorhexidine rinse 2×day | T: 24–60 | | | | Number of teeth | | | | C: | 61 | NR | NR | NA
Helsingborg, Sweden | Placebo: | | | | C: SRP and 0.2% chlorhexidine rinse 2×day | C: 23–66 | | | | Radiographic Techniques: | | | | Change: 52 weeks | | [underlined: Gain] | [underlined: Reduction]
Patient Population: | Yes | | | | | Gender: | | | | Bone Loss/Regeneration | | | | T: | | 0.47 (0.6) | 1.0 (0.8) | NA
Adults referred to the clinic, with ≥ 16 teeth (2 must be molars) | Split-mouth: | | | | | T: | | | | Microbiological Methods: | | | | C: | | 0.16 (0.5) | 0.7 (0.7) | NA
| No | | | | | Male: 16 | | | | NR | | | | Test: | | t-test | t-test
| | | | | | Female: 19 | | | | Subject Self Report: | | | | P value: | | < 0.001 | NS
| | | | | | C: | | | | NR
| | | | | | Male: 38
| | | | | | Female: 42
| | | | | | Race/Ethnicity:
| | | | | | NR

Evidence Table 1b. Effectiveness of Local Tetracycline as an Adjunct to Scaling and Root Planing to Treat Chronic Periodontitis

Study Description | Study Design Characteristics | Disease Characteristics | Examiner Characteristics | Description of Scaling and Root Planing | Eligible Study Groups and How Defined: | Study Group Characteristics | Compliance Monitoring | Baseline Measures | Assessment Time Interval(s) | Outcomes Assessed | Adverse Effects | Study Group Attrition and Reasons | Type of Analysis | Outcomes Accessed
| | | | | | | | | | | | | | (N of Pts) | | Attachment Level mm [image] (SD) | Probing Depth mm [image] (SD) | Spirochetes [image]% (SD) | Comments
Darhous et al., 1995 ^50^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 3 times (at baseline and weeks 6 and 8) | Clinical Measurement: | NR | NR | Type of analysis reported: | Baseline: | | | | | Tetracycline irrigation gave less bacterial counts than the control group right after irrigation, however, after 2 weeks the bacterial counts increased again and were insignificantly different in the 2 groups
Study Period: | Non-RCT | Moderate | NR | NR; modified Widman flap for all sites | 7 subjects, 2 sites (quadrants) per subject | Range: 35 to 65 | | | | PlI | | | Full participants only | T: | 7 | 6.54 (0.18) | 5.54 (0.67) | NA | Quality Score:
8 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | T: 7 subjects | Gender: | | | | PD | | | | C: | 7 | 6.53 (0.16) | 5.73 (0.24) | NA | 31; 31
Study/Treatment Site: | Unknown | NR | NR | NR | C: 7 subjects | NR | | | | CAL | | | | Final: 8 weeks
Graduate Program University Clinic | Blinding: | Widman flap: | Assigned to Subjects: | | Dose, Mode, Schedule: | Race/Ethnicity: | | | | GI | | | | T: | 7 | 3.45 (0.25) | 1.82 (0.69) | NA
Location: | NR | Always on all patients | NR | | T: SRP plus irrigation with 100 mg/ml tetracycline HCl for 5 minutes | NR | | | | Gingival fluid flow | | | | C: | 7 | 5.24 (0.21) | 3.05 (0.24) | NA
Cairo, Egypt | Placebo: | | | | C: SRP only | | | | | Radiographic Techniques: | | | | Change:
Patient Population: | No | | | | | | | | | NR | | | | T: | | 3.09 (0.35) | 3.72 (0.40) | NA
Adult patients with 4 to 7 mm PD | Split-mouth: | | | | | | | | | Microbiological Methods: | | | | C: | | 1.29 (0.31) | 2.68 (0.24) | NA
| Yes | | | | | | | | | Plaque microbiota | | | | Test: | | NR | NR
| | | | | | | | | | Subject Self Report: | | | | P value: | | NR | NR
| | | | | | | | | | NR
Drisko et al., 1995 ^49^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | Yes | Before SRP | 6 times (at baseline and months 1, 3, 6, 9, and 12) | Clinical Measurement: | Yes, 12 adverse events: | Poor compliance or unrelated illness (4); oral candidiasis (1); periodontal abscess 6 months after treatment (1) | Type of analysis reported: | Baseline: | | | | | There were no clinically significant differences in probing depth nor in clinical attachment level in the 2 groups of subjects at any of the examination intervals
Study Period: | RCT | NR | 3 (1 at each center) | Scaling and root planing under local anesthesia. Scaling could also occur after 10 days at fiber removal visit | 122 (116 completed) | Mean: 45.1 | | | | BOP/SBI | severe gingival redness, tongue pigmentation, glossitis, periodontal abscess, lympha-denopathy, oral candidiasis | | Full participants only | T: | | NR | 4.94 (NR) | NA | Quality Score:
52 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | T: 116 sites | Range: 25 to 73 | | | | PlI | | | | C: | | NR | 4.96 (NR) | NA | 62; 62
Study/Treatment Site: | Random | NR | Calibration (gold standard) | 5 minutes on each tooth | C: 116 sites | Gender: | | | | PD | | | | Final: 52 weeks
Dental Center and 2 universities | Blinding: | Widman flap: | Assigned to Subjects: | | Dose, Mode, Schedule: | Male: 68 | | | | CAL | | | | T: | 116 | NR | NR | NA
Location: | Examiners blind | NR | Same examiner throughout study | | T: SRP plus 17 mg tetracycline HCl fiber, removed at 10 days | Female: 54 | | | | Radiographic Techniques: | | | | C: | 116 | NR | NR | NA
Eastman Dental Center; | Placebo: | | | | C: SRP only | Race/Ethnicity: | | | | NR | | | | Change:
Minneapolis, MN | No | | | | | NR | | | | Microbiological Methods: | | | | T: | | NR | NR | NA
University of MN | Split-mouth: | | | | | | | | | NR | | | | C: | | NR | NR | NA
Kanas City, MO | Yes | | | | | | | | | Subject Self Report: | | | | Test: | | NR | NR
University of Missouri-Kansas | | | | | | | | | | Subject Satisfaction | | | | P value: | | NS | NS
USA
Patient Population:
Adult patients with 1–2 teeth with ≥ 5 mm PD and BOP. 46% were new to perio therapy, 54% were maintenance patients Approximately equal distribution between 3 centers
Friesen et al., 2002 ^58^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 4 times (at baseline and months 1, 3, and 6) | Clinical Measurement: | Bitter taste | Lost to follow-up (3), removed due to antibiotic use (1) | Type of analysis reported: | T1 (Single Strip): | | | | | Single and multiple fiber treatments resulted in a statistically significant reduction in probing depths (P = 0.333) compared to the scaling and untreated group, but the groups were not tested individually (one by one).
Study Period: | RCT | NR | NR | Local anesthesia | 28 subjects enrolled | Mean: 43.6 | | | | BOP/SBI | | | Intent to treat | Baseline: | | | | | Quality Score:
26 weeks (6 months) | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | 24 completed | Range: 26 to 69 | | | | PlI | | | | T: | 24 | NR | 6.26 (0.95) | NA | 46; 38
Study/Treatment Site: | Random site within subject | Both | Standardization | Minimum of 5 minutes per tooth | 3 sites/subject | Gender: | | | | PD | | | | C: | 24 | NR | 6.60 (1.10) | NA
Graduate Program University Clinic | Blinding: | Widman flap: | Assigned to Subjects: | | T1: 24 sites | Male: 13 | | | | CAL | | | | Final: 26 weeks
Location: | Examiners blind | NR | NR | | T2: 24 sites | Female: 15 | | | | GI | | | | T: | 24 | NR | NR | NA
USA | Placebo: | | | | C: 24 sites | Race/Ethnicity: | | | | Radiographic Techniques: | | | | C: | 24 | NR | NR | NA
Patient Population: | No | | | | Dose, Mode, Schedule: | NR | | | | NR | | | | Change: | | Gain | Reduction
Adult patients with 4 non-adjacent teeth with 6–10 mm PD and BOP | Split-mouth: | | | | T1: SRP plus single 13.5mg tetracycline strip inserted in pocket for 7 to 10 days | | | | | Microbiological Methods: | | | | T: | 24 | 0.31 (0.92) | 1.41 (NR) | NA
| Yes | | | | T2: SRP plus multiple 13.5mg tetracycline strips for 7 to 10 days | | | | | NR | | | | C: | 24 | - 0.13 (0.71) | 0.98 (NR) | NA
| | | | | C: SRP only | | | | | Subject Self Report: | | | | Test: | | ANOVA | ANOVA
| | | | | | | | | | NR | | | | P value: | | NS | NR
| | | | | | | | | | | | | | T2 (Multiple Strip):
| | | | | | | | | | | | | | Baseline:
| | | | | | | | | | | | | | T: | 24 | NR | 6.58 (1.23) | NA
| | | | | | | | | | | | | | C: | 24 | NR | 6.60 (1.10) | NA
| | | | | | | | | | | | | | Final: 26 weeks
| | | | | | | | | | | | | | T: | 24 | NR | NR | NA
| | | | | | | | | | | | | | C: | 24 | NR | NR | NA
| | | | | | | | | | | | | | Change: | | Gain | Reduction
| | | | | | | | | | | | | | T: | | 0.35 (0.68) | 1.85 (NR) | NA
| | | | | | | | | | | | | | C: | | -0.13 (0.71) | 0.98 (NR) | NA
| | | | | | | | | | | | | | Test: | | ANOVA | ANOVA
| | | | | | | | | | | | | | P value: | | NS | NR
Author and Year: | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Mean Age: | NA | Before SRP | 6 times (at baseline and months 1, 3, 6, 9, and 12) | Clinical Measurement: | NR | NR | Type of analysis reported: | Baseline: | | | | | CAL reported differently in 2 tables. Difference not clear. PD reported only in highly summarized version, not included here.
Goodson et al., 1985 ^48^ | RCT | Currently active | 1 | Scaling on day of fiber placement and again on day of fiber removal (day 10) | 10 subjects | NR | | | | PD | | | All who completed treatment | T: | NR | NR | NR | NA | Quality Score:
Study Period: | Subject/Site Allocation | Types of Teeth: | Trained: | Time spent on SRP: | 4 quadrants/subject | Gender Distribution: | | | | CAL | | | | C: | NR | NR | NR | NA | 38; 31
52 weeks | Random | NR, all in quadrant? | NA | Minimum of 45 min/quad | T: 9 teeth (96 sites) | Male: NR | | | | Radiographic Techniques: | | | | Final: 52 weeks
Site of Study: | Blinding: | Widman flap: | Assigned to Subjects: | | C: 9 teeth (91 sites) | Female: NR | | | | NR | | | | T: | 96 sites | NR | NR | NA
NR | Examiner blind | No | Same examiner throughout the study | | Dose, Mode, Schedule: | Race/Ethnicity: | | | | Microbiological Methods: | | | | C: | 91 sites | NR | NR | NA
Location: | Placebo: | | | | T: SRP plus 25% tetracycline fibers for 10 days | NR | | | | NR | | | | Change: n=9 | | [underlined: Gain for initial PD of > 3 mm]
NR (US authors) | No | | | | C: SRP only at baseline and day 10 | | | | | Subject Self Report: | | | | T: | | 1.19 (0.14 se) | NR | NA
Patients Selected: | Split-mouth: | | | | | | | | | NR | | | | C: | | 0.85 (0.15 se) | NR | NA
Patients with currently active periodontal disease and attachment loss of ≥ 2 mm at ≥ 1 sites | Yes | | | | | | | | | | | | | Test: | | ANOVA
| | | | | | | | | | | | | | P value: | | NS
| | | | | | | | | | | | | | Change: n=7 | | [underlined: Gain for initial PD of > 6 mm]
| | | | | | | | | | | | | | T: | | 2.04 (0.32 se) | NR | NA
| | | | | | | | | | | | | | C: | | 1.71 (0.45 se) | NR | NA
| | | | | | | | | | | | | | Test: | | ANOVA
| | | | | | | | | | | | | | P value: | | NS
Jeong et al., 1994 ^33^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Unclear | 5 times (at baseline and weeks 2, 4, 8, and 12) | Clinical Measurement: | NR | NR | Type of analysis reported: | T1 (Tetracycline)
Study Period: | RCT | Moderate | 1 | Thorough root planing at baseline, previous receipt of supragingival scaling | 16 subjects | Mean: NR | | | | SBI | | | Full participants only | Baseline:
12 weeks | Subject/Site allocation: | Types of Teeth: | Trained: | Time spent: | T1: 16 teeth | Range: 28 to 58 | | | | PlI | | | | T: | 16 | 5.06 (0.95) | 4.94 (0.77) | 8.7 (9.9)
Study/Treatment Site: | Random (quadrant within subject) | Single-rooted teeth | NA | 5 minutes each tooth | T2: 16 teeth | Gender: | | | | Tooth Mobility | | | | C: | 16 | 5.07 (1.03) | 4.67 (0.62) | 7.2 (9.9)
NR | Blinding: | Widman flap: | Assigned to Subjects: | | C: 16 teeth | Male: 6 | | | | CAL | | | | Final: 12 weeks
Location: | NR | NR | Same examiner throughout study | | Dose, Mode, Schedule: | Female: 10 | | | | PD | | | | T: | 16 | 3.31 (1.01) | 3.00 (0.73) | 1.7 (5.7)
NR | Placebo: | | | | T1: SRP plus 5% tetracycline HCI gel, 1 application | Race/Ethnicity: | | | | Radiographic Techniques: | | | | C: | 16 | 3.46 (0.74) | 3.00 (0.65) | 2.4 (5.0)
Patient Population: | No | | | | T2: SRP plus 5% tetracycline HCI plus citric acid in gel, 1 application | NR | | | | NR | | | | Change:
Adult patients with 1 tooth in each quadrant with 4–6 mm PD | Split-mouth: | | | | C: SRP only | | | | | Microbiological Methods: | | | | T: | | 1.75* (NR) | 1.94* (NR) | 7.0* (NR)
| Yes | | | | | | | | | Plaque microbiota (% motile rods and spirochetes) | | | | C: | | 1.61* (NR) | 1.67* (NR) | 4.8* (NR)
| | | | | | | | | | Subject Self Report: | | | | Test: | | NR | NR | NR
| | | | | | | | | | NR | | | | P value: | | NS | NS | NR
| | | | | | | | | | | | | | T2 (Tetracycline and Citric Acid) | | | | | Significant decrease in probing depth was noted after 12 weeks in tetracycline and citric acid group compared to the other groups
| | | | | | | | | | | | | | Baseline: | | | | | No difference between groups for CAL change
| | | | | | | | | | | | | | T: | 16 | 5.27 (0.73) | 5.07 (0.7) | 10.7 (13.4) | Quality Score:
| | | | | | | | | | | | | | C: | 16 | 5.07 (1.03) | 4.67 (0.62) | 7.2 (9.9) | 38; 46
| | | | | | | | | | | | | | Final: 12 weeks
| | | | | | | | | | | | | | T: | 16 | 2.93 (0.96) | 2.47 (0.74) | 4.0 (8.5)
| | | | | | | | | | | | | | C: | 16 | 3.46 (0.74) | 3.0 (0.65) | 2.4 (5.0)
| | | | | | | | | | | | | | Change:
| | | | | | | | | | | | | | T: | | 2.34* (NR) | 2.60* (NR) | 6.7* (NR)
| | | | | | | | | | | | | | C: | | 1.61* (NR) | 1.67* (NR) | 4.8* (NR)
| | | | | | | | | | | | | | Test: | | NR | NR | NR
| | | | | | | | | | | | | | P value: | | NS | < 0.05NR | NR
Kinane and Radvar 1999 ^53^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 4 times (at baseline, 6 weeks and months 3 and 6) | Clinical Measurement: | Yes, found none | 1 subject dropped from control, reason not given | Type of analysis reported: | Baseline: | | | | | The probing depth reduction at all time points was significantly greater in the SRP plus tetracycline fiber group than the SRP alone group (P < 0.01)
Study Period: | RCT | Severe, persistent pockets not responding to SRP | 1 | SRP under local anesthesia | 39 subjects, | Mean: 45 ± 6.4 | | | | BOP/SBI | | | All with any follow-up | T: | 19 | NR | 5.402 (0.141 se) | NA | This is a follow-up study
26 weeks (6 months) | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | 4 sites/subject | Gender: | | | | PlI | | | Analysis adjusted: | C: | 20 | NR | 5.480 (0.175 se) | NA | Quality Score:
Study/Treatment Site: | Random | NR | NA | NR | T: 19 subjects | Male: 29 | | | | PD | | | GLM, baseline value as continuous covariate | Final: 26 weeks | | | | | 54; 62
Dental Hospital, Dental Clinic | Blinding: | Widman flap: | Assigned to Subjects: | | C: 20 subjects | Female: 50 | | | | CAL | | | | T: | 19 | NR | NR | NA
Location: | Examiner blind | NR | Same examiner throughout study | | Dose, Mode, Schedule: | Race/Ethnicity: | | | | GI | | | | C: | 20 | NR | NR | NA
Glasgow, Scotland | Placebo: | | | | T: SRP plus 25% tetracycline fibers, removed after 10 days | NR | | | | Supperation | | | | Change: | | [underlined: Gain] | [underlined: Reduction]
Patient Population: | No | | | | C: SRP only | | | | | Radiographic Techniques: | | | | T: | | 0.687 (0.138 se) | 1.38 (0.166 se) | NA
Patients with persistent pockets that did not respond to SRP with ≥ 4 pockets with ≤5 mm PD and BOP | Split-mouth: | | | | | | | | | NR | | | | C: | | 0.537 (0.143 se) | 0.711 (0.188 se) | NA
| No | | | | | | | | | Microbiological Methods: | | | | Test: | | GLM | GLM
| | | | | | | | | | NR | | | | P value: | | NS | = 0.008
| | | | | | | | | | Subject Self Report:
| | | | | | | | | | NR
Lie et al., 1998 ^34^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | NR | 3 times (at baseline and months 3 and 6) | Clinical Measurement: | NR | NR | Type of analysis reported: | Defect Sites | | | | | There were no significant differences between the effects following topical application of the tetracycline ointment. Scaling and root planing alone appeared as effective as the drug augmented regiment
Study Period: | RCT | Moderate to severe | 1 | Sonic instrument and curets, 2 sessions, 1 week apart | 18 subjects | Range: 36 to 77 | | | | BOP/SBI | | | Full participants only | Baseline: | | | | | P.g. was significantly reduced in the treatment group.
26 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | T: 18 sites | Gender: | | | | PD | | | | T: | 18 sites | 13.8 (2.5) | 5.2 (1.5) | NA | Quality Score:
Study/Treatment Site: | Random | Single-rooted | NA | NR | C: 18 sites | NR | | | | CAL | | | | C: | 18 sites | 13.4 (1.8) | 5.1 (1.2) | NA | 62; 62
University of Bergen, Department of Peridontology | Blinding: | Widman flap: | Assigned to Patients: | | Dose, Mode, Schedule: | Race/Ethnicity: | | | | Radiographic Techniques: | | | | Final: 26 weeks
Location: | Examiner and patients blind | NR | Same examiner throughout study | | T: SRP plus application of 3% tetracycline ointment after each SRP session, 1 week apart | NR | | | | NR | | | | T: | 18 sites | 12.6 (2.0) | 3.5 (1.6) | NA
Bergen, Norway | Placebo: | | | | C: SRP only | | | | | Microbiological Methods: | | | | C: | 18 sites | 13.2 (1.5) | 4.0 (1.4) | NA
Patient Population: | No | | | | | | | | | NR | | | | Change:
Patients with untreated PD ≥ 5 mm and BOP | Split-mouth: | | | | | | | | | Patient Self Report: | | | | T: | | 1.2* (NR) | 1.7* (NR) | NA
| Yes | | | | | | | | | NR | | | | C: | | 0.2* (NR) | 1.1* (NR) | NA
| | | | | | | | | | | | | | Test: | | ANOVA | ANOVA
| | | | | | | | | | | | | | P value: | | NS | NS
| | | | | | | | | | | | | | [underlined: Nondefect Sites]
| | | | | | | | | | | | | | Baseline:
| | | | | | | | | | | | | | T: | | 13.1 (2.3) | 3.1 (0.6)
| | | | | | | | | | | | | | C: | | 12.8 (1.6) | 3.2 (1.1)
| | | | | | | | | | | | | | Final: 26 weeks
| | | | | | | | | | | | | | T: | | 12.5 (1.3) | 2.7 (0.9)
| | | | | | | | | | | | | | C: | | 12.4 (1.5) | 2.5 (0.9)
| | | | | | | | | | | | | | Change:
| | | | | | | | | | | | | | T: | | 0.6* (NR) | 0.4* (NR)
| | | | | | | | | | | | | | C: | | 0.4* (NR) | 0.7* (NR)
| | | | | | | | | | | | | | Test: | | NR | NR
| | | | | | | | | | | | | | P value: | | NS | NS
Author and Year: | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 4 times (at baseline, and weeks 8, 16, and 24) | Clinical Measurement: | NR | NR | Type of analysis reported: | Tetracycline vs Saline | | | | | Quality Score:
MacAlpine et al., 1985 ^31^ | Clinical trial | Generalized chronic periodontitis | 1 | Supra and subgingival instrumentation under local anesthesia | 11 subjects | Range: 25–67 | | | | BOP | | | All who completed treatment | Baseline: | | | | | 38; 38
Study Period: | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent on SRP: | 4 or 8 sites per subject | Gender Distribution: | | | | Plaque | | | | T: | 16 | NR | 7.5 (0.5) | 36 (NR)
24 weeks | Assignment method not reported | Single root | NA | NR | T: 16 sites | Males: 2 | | | | PD | | | | C: | 16 | NR | 7.4 (0.6) | 39 (NR)
Site of Study: | Blinding: | Widman flap: | Assigned to Subjects: | | C: 16 sites | Females: 9 | | | | CAL | | | | Final: 24 weeks
NR | NR | No | Same examiner throughout study | | Dose, Mode, Schedule: | Race/Ethnicity: | | | | Radiographic Techniques: | | | | T: | 16 | NR | 4.6 (1.3) | 1 (NR)
Location: | Placebo: | | | | T: SRP plus subgingival irrigation with tetracycline solution 50mg/ml every 2 weeks for 22 weeks | NR | | | | NR | | | | C: | 16 | NR | 4.9 (1.8) | 4 (NR)
NR (Swedish and US authors) | Yes | | | | C: SRP plus saline irrigation, every 2 weeks for 22 weeks | | | | | Microbiological Methods: | | | | Change: | | [underlined: Gain] | [underlined: Reduction]
Patients Selected: | Split-mouth: | | | | | | | | | Plaque microbiota (% spirochetes) | | | | T: | | 1.1 (1.4) | 2.9 (NR)
Patients with ≥ 6 mm PD demonstrated by loss of attachment BOP and subgingival calculus | Yes | | | | | | | | | Subject Self Report: | | | | C: | | 0.8 (1.4) | 2.5 (NR)
| | | | | | | | | | NR | | | | Test: | | NR | NR
| | | | | | | | | | | | | | P value: | | NS | NR
Minabe et al., 1991 ^52^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 4 times (at baseline and weeks 4, 6, and 8) | Clinical Measurement: | NR | NR | Type of analysis Reported: | Baseline: | | | | | No sig difference between treatments at any test period for PD or CAL or spirochetes.
Study Period: | RCT | Generalized periodontitis | NR | Single episode of supra- and ultrasonic subgingival root planing performed under local anesthesia | 16 subjects provided | Mean: 46 | | | | BOP | | | Full participants only | T: | 10 | 7.4 (2.22) | 6.60 (1.71) | 16.65 (14.1) | Only reported PD and CAL for 4 weeks, (graphic presentation shows little difference from 8 weeks):
8 weeks | Subject/Site allocation: | Types of Teeth: | Trained: | Time spent: | 46 total teeth, randomly allocated to 4 groups, only two groups included here | Range: NR | | | | PlI | | | | C: | 8 | 7.81 (2.33) | 6.03 (1.13) | 10.55 (9.96) | CAL:
Study/Treatment Site: | Random | Teeth bifurcated (molars) with furcation involvement | NR | NR | T: 10 sites | Gender: | | | | PD | | | | Final: 8 weeks | | | | | T: 5.4 (1.85)
Hospital dental clinic | Blinding: | Widman flap: | Assigned to Subjects: | | C: 8 sites | Male: 8 | | | | CAL | | | | T: | 10 | NR | NR | 2.39 (3.4) | C: 7.0 (1.36)
Location: | NR | NR | NR | | Dose, Mode, Schedule: | Female: 8 | | | | GI | | | | C: | 8 | NR | NR | 3.93 (5.89) | PD :
Yokosuka, Kanagawa, Japan | Placebo: | | | | T: SRP plus tetracycline-immobilized cross-linked collagen film administered at 1 week intervals at 4 times | Race/Ethnicity: | | | | Radiographic Techniques: | | | | Change: | | | | | T: 3.8 (0.79)
Patient Population: | No | | | | C: SRP only | NR | | | | NR | | | | T: | | NR | 2.7 (NR) | NR | C: 4.25 (0.71)
Adults attending hospital dental clinic | Split-mouth: | | | | | | | | | Microbiological Methods: | | | | C: | | NR | 2.0 (NR) | NR | Quality Score:
| Yes | | | | | | | | | Density of micro-organisms in periodontal pocket | | | | Test: | | Mann Whitney U | Mann Whitney U | Mann Whitney U | 23 ; 23
| | | | | | | | | | Subject Self Report: | | | | P value: | | NS | NS | NS
| | | | | | | | | | NR
Newman et al., 1994 ^57^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | Yes | After SRP | 4 times (at baseline and months 1, 3, and 6) | Clinical Measurement: | NR | Moved or could not complete the study due to unrelated illness (6); undated tooth fracture (1); data recording errors (1) | Type of analysis reported: | Baseline: | | | | | Fiber therapy significantly enhanced the effectiveness of SRP
Study Period: | Randomized in blocks of 4 such that 2 subjects within the block received control treatment in site with lower teeth and experimental treatment in the site with the higher tooth number | Localized recurrent periodontitis in maintenance patients | 7 | Full mouth ultrasonic scaling and root planing in accepted mechanical procedure for treating periodontitis | 113 subjects started | Mean: 51.0 | | | | BOP/SBI | | | All with any follow-up | T: | NR | 7.77 (2.17) | 6.46 (1.01) | NA | Quality Score:
26 weeks (6 months) | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | 105 completed | Gender: | | | | PD | | | | C: | NR | 7.55 (2.19) | 6.31 (1.20) | NA | 69; 69
Study/Treatment Site: | Random | Molars, pre-molars, cuspids, incisors | Calibration (gold standard) | NR | 2 teeth/subject | Male: 56 | | | | CAL | | | | Final: (26 weeks)
7 private dental practices | Blinding: | Widman flap: | Assigned to Subjects: | | T: 105 sites | Female: 49 | | | | Recession | | | | T: | 105 (sites) | NR | NR | NA
Location: | Examiners blind | NR | Same examiner throughout study | | C: 105 sites | Race/Ethnicity: | | | | Oral soft tissue | | | | C: | 105 (sites) | NR | NR | NA
USA | Placebo: | | | | Dose, Mode, Schedule: | NR | | | | Radiographic Techniques: | | | | Change: | | [underlined: Gain] | [underlined: Reduction]
Patient Population: | No | | | | T: SRP plus 12.1 cm of tetracycline HCl fiber applied for 10 days | | | | | NR | | | | T: | | 1.56 (0.145 se) | 1.81 (0.121 se) | NA
Periodontal maintenance patients receiving regular supportive periodontal therapy. | Split-mouth: | | | | C: SRP only | | | | | Microbiological Methods: | | | | C: | | 1.08 (0.145 se) | 1.08 (0.121 se) | NA
Pts had sites in 2 quadrants with 5–8 mm PD and BOP | Yes | | | | | | | | | Plaque microbiota | | | | Test: | | ANCOVA | ANCOVA
| | | | | | | | | | Subject Self Report: | | | | P value: | | < 0.05 | < 0.01
| | | | | | | | | | NR
Nylund and Egelberg, 1990 ^51^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Mean Age: | NA | Before SRP | 7 times (at baseline, and months 1, 2, 3, 6, 9, and 12) | Clinical Measurement: | NR | NR | Type of analysis reported: | Baseline: | | | | | All data reported in graphs. No significant differences found between treatment and control for any subgroup (by baseline PD or furcation grade) at any time point
Study Period: | Clinical trial | Generalized periodontitis | 1 | Single episode of crown and root debridement under local anesthesia using sonic, ultrasonic and various had instruments | 20 subjects | NR | | | | PD | | | All who completed treatment; t-tests on site data for subgroups of sites by baseline PD and furcation grade | T: | 65 teeth | NR | NR | NA | Quality Score:
52 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent on SRP: | T: 20 subjects (65 teeth) | Gender Distribution: | | | | CAL | | | | C: | 58 teeth | NR | NR | NA | 15; 23
Site of Study: | NR | Molars with furcation involvement | NR | 6–9 minutes/tooth | C: 20 subjects (58 teeth) | NR | | | | Plaque | | | | Final:
NR | Blinding: | Widman flap: | Assigned to Subjects: | | Dose, Mode, Schedule: | Race/Ethnicity: | | | | BOP | | | | T: | NR | NR | NR | NA
Location: | Examiner not blinded | No | Same examiner throughout study | | T: SRP plus irrigation with 50mg/ml tetracycline solution once every two weeks for 3 months | NR | | | | Radiographic Techniques: | | | | C: | NR | NR | NR | NA
NR | Placebo: | | | | C: SRP plus irrigation with saline once every two weeks for 3 months | | | | | NR | | | | Change:
Patients Selected: | Yes | | | | | | | | | Microbiological Methods: | | | | T: | | NR | NR | NA
Patients with loss of attachment, BOP, subgingival calculus, and 2+ molars with furcation involvement. No perio treatment for 3 years | Split-mouth: | | | | | | | | | NR | | | | C: | | NR | NR | NA
| Yes | | | | | | | | | Subject Self Report: | | | | Test: | | NR | NR
| | | | | | | | | | NR | | | | P value: | | NS | NS
Shiloah and Patters, 1994 ^54^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 3 times (at baseline, week 1 and month 1) | Clinical Measurement: | NR | NR | Type of analysis reported: | Baseline: | | | | | Data presented by figures only (bar charts) PD reduced 1–2mm, and CAL gained approx 1 mm in control and treatment groups.
Study Period: | RCT | Moderate to severe chronic adult periodontitis | 1 | SRP of entire dentition performed with ultrasonic scaler and Gracey curettes under local anesthesia | 7 subjects (1 or 2 teeth per subject) | Mean: 49.5 | | | | PlI | | | Full participants only | T: | | NR | NR | NA | Microbial outcomes:
4 weeks (1 month) | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | T: 12 sites | Range: 33 to 65 | | | | GI | | | | C: | | NR | NR | NA | Not sig for P.g., A.a.
Study/Treatment Site: | Random sites within subjects | Both | Calibration (Gold standard) | 4 to 7 hours per subject over several visits | C: 12 sites | Gender: | | | | PD | | | | Final: 4 weeks | | | | | Numbers of bacteria by type per site were also reduced in control and treatment groups, with no sig differences between groups.
Graduate Program University Clinic | Blinding: | Widman flap: | Assigned to Subjects: | | Dose, Mode, Schedule: | Male: 2 | | | | CAL | | | | T: | 12 sites | NR | NR | NA | Quality Score:
Location: | Examiner blind | NR | Same examiner throughout study | | T: SRP plus 5% aqueous tetracycline, 2 cc irrigation/site, 1 application | Female: 5 | | | | Gingival Fluid Flow | | | | C: | 12 sites | NR | NR | NA | 54; 54
USA | Placebo: | | | | C: SRP plus saline irrigation | Race/Ethnicity: | | | | Radiographic Techniques: | | | | Change:
Patient Population: | Yes | | | | | NR | | | | NR | | | | T: | | NR | NR | NA
Adults with ≥ 5 non-adjacent sites with ≥ 5 mm PD and attachment loss | Split-mouth: | | | | | | | | | Microbiological Methods: | | | | C: | | NR | NR | NA
| Yes | | | | | | | | | Bacterial DNA probes for A.a., P.g., and P.i. | | | | Test: | | ANOVA | ANOVA
| | | | | | | | | | Subject Self Report: | | | | P value: | | NS | NS
| | | | | | | | | | NR
Tonetti et al., 1998 ^35^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | Yes | Before SRP | 3 times (at baseline and months 3 and 6) | Clinical Measurement: | 7 subjects exhibited adverse events consisting of periodontal abscesses | Root fracture (1), abcess developed at experimental sites (3) | Type of analysis reported: | Baseline: | | | | | Test treatment resulted in a 0.5 mm greater reduction of PD than the control at 3 months, the improvement was highly significant but its duration did not extend until the 6 months evaluation. No differences were observed in terms of changes in CAL
Study Period: | RCT | NR | 6, 1 per center | Using sonic and hand instruments | 127 subjects enrolled | Mean: 49.7 (± 9.2) | | | | BOP/SBI | | | Full participants only | T: | 66 | 8.0 (2.0) | 6.3 (1.6) | NA | Quality Score:
26 weeks (6 months) | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | 123 completed | Gender: | | | | PD | | | | C: | 61 | 8.1 (2.3) | 5.8 (1.7) | NA | 69; 69
Study/Treatment Site: | Random | Molars with furcation involvement | Standardization | Minimum of 3 minutes | T: 63 subjects | Male: 69 | | | | CAL | | | | Final: 26 weeks (6 months)
Multicenter, 6 Private Periodontal Practices | Blinding: | Widman flap: | Assigned to Subjects: | | C: 60 subjects | Female: 56 | | | | Radiographic Techniques: | | | | T: | 63 | 7.1 (0.13 se) | 5.0 (1.5) | NA
Location: | Examiners blind | NR | Same examiner throughout the study | | Dose, Mode, Schedule: | Race/Ethnicity: | | | | NR | | | | C: | 60 | 7.1 (0.14 se) | 4.9 (1.4) | NA
Italy | Placebo: | | | | T: SRP plus tetracycline fibers containing 25% w/w tetracycline HCl crystals dispersed into a copolymer of ethylene and vinyl-acetate fiber in place for 10 ± 3 days | NR | | | | Microbiological Methods: | | | | Change: | | [underlined: Gain] | [underlined: Reduction]
Patient Population: | No | | | | C: SRP only | | | | | Plaque microbiota | | | | T: | | 0.9* (NR) | 1.3* (NR) | NA
Patients participating in regular periodontal supportive periodontal care programs, and presenting with at least 1 mandibular Class II furcation with persistent BOP, in maintenance care | Split-mouth: | | | | | | | | | Subject Self Report: | | | | C: | | 1.0* (NR) | 0.9* (NR) | NA
| No | | | | | | | | | NR | | | | Test: | | ANOVA | ANOVA
| | | | | | | | | | | | | | P value: | | NS | NS
Trombelli et al., 1996 ^55^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 3 times (at baseline, and days 30 and 60) | Clinical Measurement: | NR | NR | Type of analysis reported: | T1 (Irrigation with Tetracycline): | | | | | For PD, the 2 treatments differed from SRP alone (P = 0.011).
Study Period: | RCT | Adult advanced periodontitis | NR | Supragingival and subgingival ultrasonic scaling | 12 subjects with 63 sites | Mean: 41.8 | | | | BOP | | | NR | Baseline: | | | | | For CAL, there is no significant difference btw treatment groups and control (P = 0.121)
8 weeks (60 days) | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | T1: 20 sites | Range: 27 to 63 | | | | PlI | | | | T: | (20 sites) | 6.3 (1.9 se) | 5.8 (0.9 se) | NA | Quality Score:
Study/Treatment Site: | Random | Single-rooted teeth | NR | NR | T2: 24 sites | Gender: | | | | PD | | | | C: | (19 sites) | 6.3 (1.2 se) | 6.1 (1.3 se) | NA | 38; 46
Department of Periodontology, University of Ferrara, School of Dentistry | Blinding: | Widman flap: | Assigned to Subjects: | | C: 19 sites | Male: 4 | | | | CAL | | | | Final: 8 weeks
Location: | Examiners blind | NR | NR | | Dose, Mode, Schedule: | Female: 8 | | | | GI | | | | T: | | 4.7 (1.7 se) | 3.6 (1.9 se) | NA
Ferrara, Italy | Placebo: | | | | T1: SRP plus irrigation with 100 mg/ml tetracycline solution, 15 ml delivered subgingivally, 1 application for 4 minutes | Race/Ethnicity: | | | | Recession depth | | | | C: | | 4.9 (1.9 se) | 4.3 (1.9 se) | NA
Patient Population: | No | | | | T2: SRP plus vinyl acetate fibers with 25% tetracycline HCl by weight positioned in pockets and packed with blunt instrument. Removed after 10 days | NR | | | | O'Leary Plaque Control Record | | | | Change:
Adults referred for treatment with at least 3 non-molar teeth in same arch, sites having ≥ 5 mm PD | Split-mouth: | | | | C: SRP only | | | | | Radiographic Techniques: | | | | T: | | 1.8* (NR) | 2.2* (NR) | NA
| Yes | | | | | | | | | NR | | | | C: | | 1.4* (NR) | 1.8* (NR) | NA
| | | | | | | | | | Microbiological Methods: | | | | Test: | | ANOVA | ANOVA
| | | | | | | | | | NR | | | | P value: | | NS | NS
| | | | | | | | | | Subject Self Report: | | | | [underlined: T2 (Tetracycline Fibers):]
| | | | | | | | | | NR | | | | Baseline:
| | | | | | | | | | | | | | T: | (24 sites) | 7.3 (1.8 se) | 6.1 (1.1 se) | NA
| | | | | | | | | | | | | | C: | (19 sites) | 6.3 (1.2 se) | 6.1 (1.3 se) | NA
| | | | | | | | | | | | | | Final: 8 weeks
| | | | | | | | | | | | | | T: | | 5.5 (2.4 se) | 3.8 (1.4 se) | NA
| | | | | | | | | | | | | | C: | | 4.9 (1.9 se) | 4.3 (1.9 se) | NA
| | | | | | | | | | | | | | Change:
| | | | | | | | | | | | | | T: | | 1.6* (NR) | 2.3* (NR) | NA
| | | | | | | | | | | | | | C: | | 1.4* (NR) | 1.8* (NR) | NA
| | | | | | | | | | | | | | Test: | | ANOVA | ANOVA
| | | | | | | | | | | | | | P value: | | NS | NS
Unsal et al., 1994 ^59^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NR | Before SRP | 2 times (at baseline and at week 12) | Clinical Measurement: | None were reported | NR | Type of analysis reported: | Baseline: | | | | | For both PD and CAL, the control experienced NS better outcomes than the tetracycline group.
Study Period: | RCT | Moderate to advanced periodontitis | NR | All subjects received hand and ultrasonic scaling and root planing; selected sites were mechanically debrided with hand instruments | 22 subjects invited | Mean: 42 | | | | Bleeding index | | | Intent to treat. | T: | 7 (99 teeth) | 3.10 (1.21) | 4.25 (0.85) | NA | Quality Score:
12 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | 15 subjects in relevant 2 groups | Range: 30 to 57 | | | | PlI | | | | C: | 8 (110 teeth) | 3.66 (1.22) | 5.14 (1.45) | NA | 38; 46
Study/Treatment Site: | Random | NR | NR | NR | T: 7 (99 sites) | Gender: | | | | PD | | | | Final: 12 weeks
Department of Peridontology, Faculty of Dentistry | Blinding: | Widman flap: | Assigned to Subjects: | | C: 8 (110 teeth) | Male: 10 | | | | CAL | | | | T: | 7 | 2.29 (0.96) | 2.85 (0.55) | NA
Location: | NR | NR | NR | | Dose, Mode, Schedule: | Female: 12 | | | | GI/GI-S | | | | C: | 8 | 2.62 (1.24) | 3.31 (0.73) | NA
University of Ankara, Turkey | Placebo: | | | | T: SRP plus 40% tetracycline HCI (w/w) in white petroleum, single application of paste | Race/Ethnicity: | | | | Position of gingival margin | | | | Change:
Patient Population: | No | | | | C: SRP only | NR | | | | Radiographic Techniques: | | | | T: | | 0.81 (0.69) | 1.40 (0.32) | NA
Adult patients referred to clinic for treatment of periodontal disease, with ≥ 3 teeth in each quadrant with 2 sites having periodontal disease | Split-mouth: | | | | | | | | | NR | | | | C: | | 1.04 (0.16) | 1.83 (0.54) | NA
≥ 4 mm, BOP, and radiographic evidence bone loss | No | | | | | | | | | Microbiological Methods: | | | | Test: | | ANOVA | ANOVA
| | | | | | | | | | NR | | | | P value: | | NS | NS
| | | | | | | | | | Subject Self Report:
| | | | | | | | | | NR
Yalcin et al., 1999 ^56^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 4 times (at baseline and weeks 1, 3, and 7) | Clinical Measurement: | Oral candidiasis (1); severe gingival redness on quadrants treated with fibers (2) | NR | Type of analysis reported: | Baseline: | | | | | Tetracycline fiber treatment as adjunct to SRP is effective in regard to probing depth and bleeding on probing
Study Period: | RCT | Moderate to advanced periodontitis never treated | 1 examiner performed clinical measurements | NR | 17 subjects | Range: 25 to 52 | | | | BOP/SBI | | | All with any follow-up | T: | 210 (sites) CAL | 5.12 (2.53) | 4.71 (2.34) | NA | Quality Score:
7 weeks | Subject/Site Allocation: | Types of Teeth: | 1 examiner did SRP | Time spent: | T: 221 sites | Gender: | | | | PlI | | | | | 221 (sites) PD | | | | 62; 69
Study/Treatment Site: | Random | Both single and multi-root teeth | 1 examiner placed fibers | NR | C: 191 sites | Male: 9 | | | | PD | | | | C: | 179 (sites) CAL | 5.25 (2.59) | 4.55 (2.37) | NA
Health Department Clinic | Blinding: | Widman flap: | Trained: | | Dose, Mode, Schedule: | Female: 8 | | | | CAL | | | | | 191 (sites) PD
Location: | Examiners blind | NR | NR | | T: SRP plus slow-release tetracycline fibers placed subgingivally for 10 days | Race/Ethnicity: | | | | GI | | | | Final: 7 weeks
Istanbul, Turkey | Placebo: | | Assigned to Subjects: | | C: SRP only | NR | | | | Oral soft tissue examined to assess adverse effects | | | | T: | NR | NR | NR | NA
Patient Population: | No | | NR | | | | | | | Radiographic Techniques: | | | | C: | NR | NR | NR | NA
Patients with ≥ 2 sites in each of 4 quadrants with pocket depths of ≥ 5 mm | Split-mouth: | | | | | | | | | NR | | | | Change: | | [underlined: Gain] | [underlined: Reduction]
| Yes | | | | | | | | | Microbiological Methods: | | | | T: | | 0.95 (0.132 se) | 1.45 (0.14 se) | NA
| | | | | | | | | | NR | | | | C: | | 0.75 (0.158 se) | 1.04 (.0148 se) | NA
| | | | | | | | | | Subject Self Report: | | | | Test: | | ANCOVA | ANCOVA
| | | | | | | | | | NR | | | | P value: | | NS | = 0.047

Evidence Table 2a. Effectiveness of Systemic Minocycline as an Adjunct to Scaling and Root Planing to Treat Chronic Periodontitis

Study Description | Study Design Characteristics | Disease Characteristics | Examiner Characteristics | Description of Scaling and Root Planing | Eligible Study Groups and How Defined: | Study Group Characteristics | Compliance Monitoring | Baseline Measures | Assessment Time Interval(s) | Outcomes Assessed | Adverse Effects | Study Group Attrition and Reasons | Type of Analysis | Outcomes Accessed
| | | | | | | | | | | | | | (N of Pts) | | Attachment Level mm [image] (SD) | Probing Depth mm [image] (SD) | Spirochetes [image]% (SD) | Comments
Atilla et al., 1996 ^62^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 2 times (at baseline and 8 weeks) | Clinical Measurement: | NR | NR | Type of analysis reported: | T1: PD 4 to 5 mm | | | | | Systemic minocycline therapy might be useful as an adjunct to non-surgical therapy in the presence of deep pockets, especially for reinfected cases
Study Period: | Parallel non-randomized clinical trial | Moderate to severe periodontitis | NR | Non-surgical periodontal SRP | 21 subjects | Mean: 44 ± 5.87 | | | | BOP/SBI | | | Full participants only | Baseline: | | | | | Quality Score:
8 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | T1: 5 subjects (PD 4–5mm) | Range: 37 to 52 | | | | PD | | | | T: | 5 | NA | 3.11 (0.32) | NA | 31; 38
Study/Treatment Site: | Patients with PD ≥ 4 to 5 mm in one group, patients with PD ≥ 6 mm in another group | NR | NR | 2 or more appointments | T2: 5 subjects (PD ≥ 6 mm) | Gender: | | | | Level of neutral proteasse activity | | | | C: | 6 | NA | 3.26 (0.47) | NA
NR | Blinding: | Widman flap: | Assigned to Subjects: | | C1: 6 subjects (PD 4–5 mm) | Male: 12 | | | | Counting of epithelial cells in saliva | | | | Final: 6 weeks
Location: | NR | NR | Clinical measurements were determined by the same periodontist | | C2: 5 subjects (PD ≥ 6 mm) | Female: 9 | | | | Number of sites with PD of 4 to 5 mm or ≥ 6mm | | | | T: | 5 | NA | 1.67 (0.52) | NA
Turkey | Placebo: | | | | Dose, Mode, Schedule: | Race/Ethnicity: | | | | Radiographic Techniques: | | | | C: | 6 | NA | 1.76 (0.52) | NA
Patient Population: | No | | | | T1 and 2: SRP plus 100 mg minocycline 1×day for 14 days | NR | | | | NR | | | | Change:
Adult patients with minimum of 20 natural teeth and PD ≥ 4 mm | Split-mouth: | | | | C1 and 2: SRP only | | | | | Microbiological Methods: | | | | T: | | NA | 1.44* (NR) | NA
| No | | | | | | | | | NR | | | | C: | | NA | 1.50* (NR) | NA
| | | | | | | | | | Subject Self Report: | | | | Test: | | | NR
| | | | | | | | | | NR | | | | P value: | | | NS
| | | | | | | | | | | | | | T2: PD ≥ 6 mm
| | | | | | | | | | | | | | Baseline:
| | | | | | | | | | | | | | T: | 5 | NA | 4.17 (0.34) | NA
| | | | | | | | | | | | | | C: | 5 | NA | 4.19 (0.30) | NA
| | | | | | | | | | | | | | Final: 6 weeks
| | | | | | | | | | | | | | T: | 5 | NA | 1.94 (0.42) | NA
| | | | | | | | | | | | | | C: | 5 | NA | 2.45 (0.59) | NA
| | | | | | | | | | | | | | Change:
| | | | | | | | | | | | | | T: | | NA | 2.23* (NR) | NA
| | | | | | | | | | | | | | C: | | NA | 1.74* (NR) | NA
| | | | | | | | | | | | | | Test: | | | NR
| | | | | | | | | | | | | | P value: | | | NS
Author and Year: | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NR | Before SRP | 6 times (at baseline, and days 7, 14, 35, 49, and 70 ) | Clinical Measurement: | Vertigo in 2 subjects in treatment group, though not severe enough to affect walking | NR | Type of analysis reported: | Baseline: | | | | | No PD data reported for baseline or final exam. Results stated as “no significant changes in any study group during the experimental period”
Ciancio, et al., 1982 ^61^ | RCT | Moderate to severe periodontitis | 1 | Mechanical debridement by hand performed by 2 dental hygienists to mimic common practice | 26 subjects | Range 35–65 | | | | PD | | | Intent to treat | T: | 13 | NA | NR | 29 (NR) | The treatment resulted in a marked and long-lasting decrease in the proportion of spirochetes
Study Period: | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent on SRP: | T: 13 subjects | Gender Distribution: | | | | GI | | | | C: | 13 | NA | NR | 25 (NR) | Quality Score:
10 weeks | Random | Ramfjord teeth (molars, premolars, incisors) | NR | 45–60 min on average for 2 quadrants | C: 13 subjects | NR | | | | PI | | | | Final: 10 weeks | | | | | 62; 69
Site of Study: | Blinding: | Widman flap: | Assigned to Subjects: | | Dose, Mode, Schedule: | Race/Ethnicity: | | | | Radiographic Techniques: | | | | T: | 13 | NA | NR | 12 (NR)
Dept of Periodontology and Periodontal Disease Clinical Research Center, State University of New York at Buffalo | Examiner and subjects blind | No | Same examiner throughout study | | T: SRP plus 200 mg minocycline 1×day for 7days | NR | | | | NR | | | | C: | 13 | NA | NR | 15 (NR)
Location: | Placebo: | | | | C: SRP plus placebo | | | | | Microbiological Methods: | | | | Change:
Buffalo, NY | Yes | | | | | | | | | Plaque microbiota: % spirochetes, coccoid cells, non-motile rods, filaments and motile rods, gram stain, colonial and cellular morphology | | | | T: | | NA | NR | 17* (NR)
Patients Selected: | Split-mouth: | | | | | | | | | Subject Self Report: | | | | C: | | NA | NR | 10* (NR)
Adults with PD ≥ 5 mm and a gingival inflammatory index of ≥ 1 | Yes | | | | | | | | | NR | | | | Test: | | | NR | NR
| | | | | | | | | | | | | | P value: | | | NS | NR

Evidence Table 2b. Effectiveness of Local Minocycline as an Adjunct to Scaling and Root Planing to Treat Chronic Periodontitis

Study Description | Study Design Characteristics | Disease Characteristics | Examiner Characteristics | Description of Scaling and Root Planing | Eligible Study Groups and How Defined: | Study Group Characteristics | Compliance Monitoring | Baseline Measures | Assessment Time Interval(s) | Outcomes Assessed | Adverse Effects | Study Group Attrition and Reasons | Type of Analysis | Outcomes Accessed
| | | | | | | | | | | | | | (N of Pts) | | Attachment Level mm [image] (SD) | Probing Depth mm [image] (SD) | Spirochetes [image]% (SD) | Comments
Author and Year: | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 3 times (at baseline, and weeks 6 and 12) | Clinical Measurement: | Root sensitivity | 2 pairs lost: systemic antibiotics (1); inability to keep appointments (1) | Type of analysis reported: | Baseline: | | | | | Quality Score:
Graca et al., 1997 ^32^ | RCT | Moderate to advanced periodontitis | 1 | 2–6 teeth per patient were planed under local anesthesia using hand and ultrasonic instruments | 30 subjects enrolled | Range: 25 to 50 | | | | PlI | | | Full participants only | T: | 13 | 6.86 (1.04) | 5.93 (0.48) | NA | 69; 69
Study Period: | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent on SRP: | 26 completed, 2 to 6 teeth per subject | Gender Distribution: | | | | BOP | | | Matched pairs | C: | 13 | 6.83 (0.73) | 5.74 (0.35) | NA
12 weeks | Paired according to smoking, gender, age. If more than 6 teeth met criteria (PD ≥ 5–10 mm) then selection was random | NR | NR | NR | T: 13 subjects | Males: 6 | | | | CAL | | | | Final: 12 weeks
Site of Study: | Blinding: | Widman flap: | Assigned to Subjects: | | C: 13 subjects | Females: 20 | | | | PD | | | | T: | 13 | 4.91 (0.72) | 3.29 (0.49) | NA
United Medical and Dental Schools of Guy's and St. Thomas' Hospitals | Examiner and patients blind | NR | Same examiner throughout study | | Dose, Mode, Schedule: | Race/Ethnicity: | | | | Radiographic Techniques: | | | | C: | 13 | 5.27 (0.76) | 3.44 (0.47) | NA
Location: | Placebo: | | | | T: SRP plus 2% minocycline gel applied at baseline, and weeks 2 and 4 | White: 16 | | | | NR | | | | Change:
London, England | Yes | | | | C: SRP plus placebo gel | | | | | Microbiological Methods: | | | | T: | | 1.95* (NR) | 2.64* (NR) | NA
Patients Selected: | Split-mouth: | | | | | | | | | NR | | | | C: | | 1.56* (NR) | 2.30* (NR) | NA
Adults with 2 pockets 5–10 mm on separate teeth with attachment loss > 4 mm and radiographic evidence of bone loss and BOP | NR | | | | | | | | | Subject Self Report: | | | | Test: | | ANCOVA | ANCOVA
| | | | | | | | | | NR | | | | P value: | | <0.05 | NS
Author and Year: | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Mean Age: | NR | Before SRP | 3 times (at baseline, and months 3 and 6 | Clinical Measurement: | No adverse events were reported by completers | NR | Type of analysis reported: | Baseline: | | | | | Statistically significant differences in pocket depths were found between groups over the six months of the study but the P value was not reported
Henderson et al., 2002 ^67^ | RCT | Moderate to advanced chronic periodontitis | NR | Single episode of full mouth ultrasonic and hand instrumentation under local anesthetic | 15 subjects | Mean: 46.3 | | | | PD | | | Full participants only | T: | | NR | 6.7 (1.0) | NA | Quality Score:
Study Period: | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent on SRP: | One of 2 teeth per subject received treatment, adjacent tooth or opposite side (remote) served as controls, remotes used for control in this report | Range: 35 to 69 | | | | CAL | | | | C: | | NR | 7.1 (1.0) | NA | 54; 54
26 weeks (6 months) | Random | NR | NR | 90 minutes | T: 15 subjects | Gender Distribution: | | | | BOP | | | | Final: 26 weeks (6 months)
Site of Study: | Blinding: | Widman flap: | Assigned to Patients: | | C: 15 subjects | Male: 7 | | | | PlI | | | | T: | | NR | 4.3 (1.4) | NA
Department of Oral Rehabilitation, School of Dentistry, University of Otago | Examiners blind | NR | NR | | Dose, Mode, Schedule: | Female: 8 | | | | BI | | | | C: | | NR | 5.2 (1.2) | NA
Location: | Placebo: | | | | T: SRP plus a single application of 1 mg minocycline | Race/Ethnicity: | | | | Soft tissue appearance | | | | Change:
New Zealand | No | | | | C: SRP only | NR | | | | Radiographic Techniques: | | | | T: | | 2.1 (1.5) | 2.5 (1.4) | NA
Patients Selected: | Split-mouth: | | | | | | | | | NR | | | | C: | | 1.3 (1.3) | 1.8 (1.7) | NA
Adult patients with ≥ 2 pairs of adjacent 6–9 mm pockets and ≥ 3 mm loss of attachment, located in adjacent teeth in an interproximal space, on opposite sides of the mouth | Yes | | | | | | | | | Microbiological Methods: | | | | Test: | | NR | NR
| | | | | | | | | | NR | | | | P value: | | 0.04 | ≤ 0.05
| | | | | | | | | | Patient Self Report:
| | | | | | | | | | NR
Author and Year: | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Mean Age: | NA | Before SRP | 4 times (at baseline, and months 1, 3 and 6) | Clinical Measurement: | No untoward reactions were observed | No reasons given, but 9 were lost | Type of analysis reported: | Baseline: | | | | | Presented actual data for baseline but not for final. Instead just showed figures (bar graphs) which depicted the amount of change. Can not interpolate data from records.
Jones et al., 1994 ^64^ | RCT | Moderate to advanced periodontitis | NR | NR | 26 subjects enrolled | NR | | | CAL also recorded at month 5 | CAL | | | Full participants only | T: | | 10.93 (1.5) | 6.12 (0.63) | NA | Quality Score:
Study Period: | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent on SRP: | 17 completed | Gender Distribution: | | | | PD | | | Sites averaged across each subject and then averaged across subjects to create group mean | C: | | 10.77 (1.22) | 5.56 (0.95) | NA | 46; 46
26 weeks (6 months) | Random assignment to 4 groups | 3^rd^ molars and abutment teeth excluded | NR | NR | T: 11 subjects | NR | | | | PlI | | | Any site with ≥ 2 mm attachment loss was eliminated from analysis | Final: 26 weeks
Site of Study: | All sites ≥ 5 mm in the most diseased quadrant received treatment, other quadrants not treated | Widman flap: | Assigned to Subjects: | | C: 6 subjects | Race/Ethnicity: | | | | GI | | | | T: | 11 | NR | NR | NA
University of Texas Health Science Center | Blinding: | NR | NR | | Dose, Mode, Schedule: | NR | | | | BOP | | | | C: | 6 | NR | NR | NA
Location: | Examiners and patients blind | | | | T: SRP plus microencapsulated minocycline HCL powder in a biodegradable controlled-release system, injected into ≥ 5 mm pockets, 1 application | | | | | Radiographic Techniques: | | | | Change:
San Antonio, Texas, USA | Placebo: | | | | C: SRP plus saline subgingival irrigation for 30 seconds | | | | | NR | | | | T: | | NR | NR | NA
Patients Selected: | Yes | | | | | | | | | Microbiological Methods: | | | | C: | | NR | NR | NA
Adults with at least 2 sites on different teeth in 1 quadrant with PD > 7 mm and presence of P.g., P.i. or A.a. microbial species. | Split-mouth: | | | | | | | | | Anaerobic cultures (A.a., P.g., P.i., E.c., C.r.) | | | | Test: | | Duncans Multiple Range Test | Duncans Multiple Range Test
| No | | | | | | | | | DNA probe | | | | P value: | | NS | NS
| | | | | | | | | | Monoclonal antibodies
| | | | | | | | | | Subject Self Report:
| | | | | | | | | | NR
Author and Year: | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NR | Before SRP | 3 times (at baseline, 6 weeks, and 6 months) | Clinical Measurement: | Examined for adverse signs but none reported | Control: reason not given (1); | Type of analysis reported: | Baseline: | | | | | This is a follow-up study
Kinane and Radvar 1999 ^53^ | Parallel RCT | Chronic periodontitis with persistent pockets | 1 | Scaling and root planing under local anesthesia | 41 subjects | Mean: 45 (± 6.4) | | | | PD | | Treatment group: reason not given (1) | Full participants only | T: | 21 | NR | 5.58 (0.15 se) | NA | Quality Score:
Study Period: | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent on SRP: | T: 21 subjects | Gender Distribution: | | | | BOP/SBI | | | Analysis adjusted: GLM, baseline as continuous covariate | C: | 20 | NR | 5.48 (0.18 se) | NA | 54; 62
26 weeks (6 months) | Random | Sites with furcation lesions excluded | NR | NR | C: 20 subjects | Males: 50 | | | | PlI | | | | Final: 26 weeks
Site of Study: | Blinding: | Widman flap: | Assigned to Subjects: | | Dose, Mode, Schedule: | Females: 29 | | | | CAL | | | | T: | 21 | NR | NR | NA
Peridontal Department of the Glasgow Dental Hospital | Examiner blind | NR | Same examiner throughout study | | T: SRP plus 2% minocycline gel at baseline and weeks 2 and 4 | Race/Ethnicity: | | | | MGI | | | | C: | 20 | NR | NR | NA
Location: | Placebo: | | | | C: SRP only | NR | | | | Supperation | | | | Change: | | [underlined: Gain] | [underlined: Reduction]
Glasgow, Scotland | No | | | | | | | | | Radiographic Techniques: | | | | T: | | 0.57 (0.11 se) | 1.10 (0.16 se) | NA
Patients Selected: | Split-mouth: | | | | | | | | | NR | | | | C: | | 0.54 (0.14 se) | 0.71 (0.19 se) | NA
Patients with pockets that did not respond to SRP; at least 4 pockets > 5 mm and BOP that did not respond to SRP | No | | | | | | | | | Microbiological Methods: | | | | Test: | | GLM | GLM
| | | | | | | | | | NR | | | | P value: | | NS | NS
| | | | | | | | | | Subject Self Report:
| | | | | | | | | | NR
Author and Year: | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Mean Age: | NR | Before SRP | 4 times (at baseline, 1, 3 and 6 months) | Clinical Measurement: | Treatment group: black hairy tongue and abscesses at study sites unrelated to study drug (1), rhinitis (1); 1 subject in control group reported myalgia and granulomatous lesion | 7 sites in 2 subjects in treatment group not evaluable due to insufficient baseline PD | Type of analysis reported: | Baseline: | | | | | Substantially greater reductions in PD and CAL gains at each post treatment point versus control
Van Dyke et al, 2002 ^68^ | RCT | Moderate to severe peridontitis | NR | NR | 50 subjects recruited for full study (2 teeth per subject per treatment group) | NR | | | | PD | | | Intent to treat | T: | | 11.01 (NR) | 6.86 (NR) | N/A | Difference between treatments in sites with ≥ 5 mm and < 6 mm PD were highly significant (P < 0.01) at time points
Study Period: | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent on SRP: | 22 completed | Gender Distribution: | | | | CAL | | | | C: | | 11.11 (NR) | 6.53 (NR) | N/A | For sites with PD > 6 mm no statistical significant differences between treatment groups
26 weeks (6 months) | Random | No third molars | NR | NR | T: 12 subjects (77 sites) | Male: NR | | | | BI | | | | Final: 26 weeks (6 months) | | | | | Quality Score:
Site of Study: | Blinding: | Widman flap: | Assigned to Patients: | | C: 10 subjects (53 sites) | Female: NR | | | | PI | | | | T: | 12 | NR | NR | N/A | 46; 46
NR | Examiners and patients blind | NR | NR | | Dose, Mode, Schedule: | Race/Ethnicity: | | | | GI | | | | C: | 10 | NR | NR | N/A
Location: | Placebo: | | | | T: SRP plus 1 mg microencapsulated minocycline | NR | | | | Radiographic Techniques: | | | | Change:
NR | No | | | | C: SRP and saline | | | | | NR | | | | T: | | 1.02 (0.26 se) | 1.94 (0.21 se) | N/A
Patients Selected: | Split-mouth: | | | | | | | | | Microbiological Methods: | | | | C: | | 0.54 (0.18 se) | 1.66 (0.20 se) | N/A
Adult patients with ≥ 2 teeth having 1 site with PD ≥ 6 mm and prostaglandin E_2_ levels > 66.2 nt/ml in gingival crevicular fluid | No | | | | | | | | | NR | | | | Test: | | NR | NR
| | | | | | | | | | Patient Self Report: | | | | P value: | | NS | NS
| | | | | | | | | | NR
Author and Year: | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 5 times (at baseline, and weeks 2, 4, 6, and 12) | Clinical Measurement: | T: 17% gingival abcesses, diarrhea, gingival edema, echymosis, upset stomach | 22 subjects not included because of: lack of baseline data (4); failed to return (14); lost to follow-up (3); antibiotic use (1) | Type of analysis reported: | PD ≥ 5 m | | | | | Difference in PAL 0.8 mm in each group, not significant, P = 0.58
van Steenberghe et al., 1993 ^63^ | RCT | Moderate to severe chronic periodontitis | I at each site | SRP using hand instruments were performed at all surfaces of tested teeth | 103 subjects enrolled | Mean: 48.7 | | | | BOP | C: 12% gingival abcesses, mouth ulceration and pain | | Full participants only | Baseline: | | | | | Microbial outcomes assessed: No data, but stated significant changes in P.g., A.a., and P.I. at weeks 6 and 12
Study Period: | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent on SRP: | 81 subjects completed | Gender Distribution: | | | | PlI | | | | T: | | NR | 5.9 (NR) | NA | Reduction in bacterial counts were associated with an improvement in clinical parameters
12 weeks | Random | NR | Yes, experienced thorough discussion prior and during trial minimized diffs in clinical procedures | Max 3 minutes/tooth and 15/quad | T: 42 subjects | Males: 41 | | | | GI | | | | C: | | NR | 5.9 (NR) | NA | Quality Score:
Site of Study: | Blinding: | Widman flap: | Assigned to Subjects: | | C: 39 subjects | Females: 62 | | | | GCF | | | | Final: 12 weeks | | | | | 69; 77
4 Universities | Examiners and patients blind | NR | Same examiner throughout study | | Dose, Mode, Schedule: | Race/Ethnicity: | | | | PD | | | | T: | 42 (897 sites) | NR | 4.2 (NR) | NA
Location: | Placebo: | | | | T: SRP plus 2% minocycline ointment applied at baseline, and weeks 2, 4, and 6 | NR | | | | CAL | | | | C: | 39 (745 sites) | NR | 4.5 (NR) | NA
Belgium | Yes | | | | C: SRP plus placebo at baseline, and weeks 2, 4, and 6 | | | | | Radiographic Techniques: | | | | Change:
Patients Selected: | Split-mouth: | | | | | | | | | NR | | | | T: | | 0.8 (NR) | 1.7 (NR) | NA
Adults with at least 1 PD with ≥ 5 mm and attachment loss ≥ 3 mm in at least 1 site per quadrant; and radiographic evidence of alveoler bone loss | No | | | | | | | | | Microbiological Methods: | | | | C: | | 0.8 (NR) | 1.4 (NR) | NA
| | | | | | | | | | DNA Probe assay | | | | Test: | | t-test | t-test
| | | | | | | | | | Subject Self Report: | | | | P value: | | NS | = 0.0018
| | | | | | | | | | NR | | | | [underlined: PD ≥ 7 mm]
| | | | | | | | | | | | | | Baseline:
| | | | | | | | | | | | | | T: | | NR | 7.5 (NR) | NA
| | | | | | | | | | | | | | C: | | NR | 7.8 (NR) | NA
| | | | | | | | | | | | | | Final: 12 weeks
| | | | | | | | | | | | | | T: | 28 (151 sites) | NR | 4.4 (NR) | NA
| | | | | | | | | | | | | | C: | 24 (140 (sites) | NR | 5.7 (NR) | NA
| | | | | | | | | | | | | | Change:
| | | | | | | | | | | | | | T: | | 1.3 (NR) | 3.1 (NR) | NA
| | | | | | | | | | | | | | C: | | 0.9 (NR) | 2.1 (NR) | NA
| | | | | | | | | | | | | | Test: | | t-test | t-test
| | | | | | | | | | | | | | P value: | | NS | =0.0001
Author and Year: | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NR | Before SRP | 7 times (at baseline, and months 1, 3, 6, 9, 12, and 15) | Clinical Measurement: | T: 11 | 6 treatment and 5 control subjects excluded because they did not have a valid baseline evaluation, invalid post-baseline visits, improper randomizations, plus other reasons not listed for 2 subjects | Type of analysis reported: | PD ≥ 5 mm | | | | | Microbial outcomes assessed:
van Steenberghe et al., 1999 ^65^ | RCT | Moderate to severe chronic periodontitis | 1/center (6 centers) | Both supra and subgingival hand scaling under local anesthesia (if necessary); repeated at 6 and 12 months. | 104 subjects enrolled | Enrollees: | | | Additional microbiological sampling at week 2. | BOP | C: 14 | | Full participants only | Baseline: | | | | | Statistically significant greater reductions in P.g., T.d., and C.r. from baseline. For P.i. and A.a. the changes were not significant. F.n. and E.c. changes were not significant.
Study Period: | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent on SRP: | 93 completed | Mean: 46 | | | | PlI | Minor clinical adverse reactions (e.g., redness) | | | T: | 46 | NR | 6.5 (NR) | NA | Quality Score:
65 weeks (15 months) | Random | NR | Yes | Maximum 15 min/quad | T: 46 subjects | Range: 34 to 64 | | | | PD | 3 in of treatment group reported abcesses | | | C: | 47 | NR | 6.3 (NR) | NA | 85; 92
Site of Study: | Blinding: | Widman flap: | Assigned to Subjects: | | C: 47subjects | Gender Distribution: | | | | CAL | | | | Final: 65 weeks
6 university centers | Examiners and patients blind | NR | NR | | Dose, Mode, Schedule: | Males: 50% | | | | GI | | | | T: (PD) | (1241 sites) | NR | 4.6 (NR) | NA
Location: | Placebo: | | | | T: SRP plus 2% minocycline ointment applied at baseline, 2 wks, 1, 3, 6, 9, and 12 months | Males: 43 | | | | BI | | | | C: (PD) | (1275 sites) | NR | 5.1 (NR) | NA
Belgium, Sweden, The Netherlands, United Kingdom | Yes | | | | C: SRP plus placebo applied at baseline, 2 wks, 3, 6, 9, and 12 months | Females: 50 | | | | Radiographic Techniques: | | | | Change: | | [underlined: Gain]
Patients Selected: | Split-mouth: | | | | | Race/Ethnicity: | | | | Full mouth intra-oral radiography | | | | T: (CAL) | 45 (1.231 sites) | 0.9 (NR) | 1.9 (NR) | NA
Patients with ≥ 1 approximal PD of > 5 mm attachment loss of ≥ 3 mm, and radiographic evidence of alveolar bone loss in at least 1 site per quadrant | No | | | | | NR | | | | Microbiological Methods: | | | | C: (CAL) | 45 (1.275 sites) | 0.5 (NR) | 1.2 (NR) | NA
| | | | | | | | | | DNA/RNA Probe | | | | Test: | | t-test | t-test
| | | | | | | | | | (P.i. and microbiological) | | | | P value: | | 0.0001 | 0.0001
| | | | | | | | | | Subject Self Report: | | | | [underlined: PD ≥ 7 mm]
| | | | | | | | | | NR | | | | Baseline:
| | | | | | | | | | | | | | T: | | NR | 8.1 (NR) | NA
| | | | | | | | | | | | | | C: | | NR | 7.7 (NR) | NA
| | | | | | | | | | | | | | Final: 65 weeks
| | | | | | | | | | | | | | T: | 36 (334 sites) | NR | 5.3 (NR) | NA
| | | | | | | | | | | | | | C: | 35 (284 sites) | NR | 6.0 (NR) | NA
| | | | | | | | | | | | | | Change: | | [underlined: Gain]
| | | | | | | | | | | | | | T: | | 1.4 (NR) | 2.8 (NR) | NA
| | | | | | | | | | | | | | C: | | 1.0 (NR) | 1.7 (NR) | NA
| | | | | | | | | | | | | | Test: | | t-test | t-test
| | | | | | | | | | | | | | P value: | | 0.0001 | 0.0001
Author and Year: | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 5 times (at baseline, 1, 3, 6, and 9 months) | Clinical Measurement: | T: 68% | NR | Type of analysis reported: | Baseline: | | | | | CAL: Changes not reported for any group
Williams et al., 2001 ^66^ | RCT | Moderate to advanced periodontitis | 1 per site | Full mouth, local anesthesia if needed | 498 subjects enrolled | Mean: | | | | PD | C: 72% | | Intent to treat | T: | | 5.39 (1.43) | 5.8 (0.4) | NA | Change for PD ≥ 6 mm:
Study Period: | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent on SRP: | 467 completed | T: 49.1 | | | | CAL | Most common: headache, dental infection, increased periodontitis, tooth sensitivity, tooth caries, dental pain, gingivitis, stomatitis | | (All sites with PD ≥ 5 mm at baseline were included) | C: | | 5.38 (1.38) | 5.9 (0.5) | NA | T: 1.46 (0.09 se)
39 weeks (9 months) | Random but stratified for smoking and study center | NR | Trained and calibrated | No limit on time | T: 249/237 subjects | C: 47.2 | | | | BOP | | | | Final: 39 weeks | | | | | C: 1.05 (0.10 se)
Site of Study: | Blinding: | Widman flap: | Assigned to Subjects: | | C: 249/230 subjects | Range: 27–79 | | | | Radiographic Techniques: | | | | T: | 237 | NR | NR | NA | P ≤ 0.01
18 centers at Universities | Examiners and patients blind | NR | Same examiner throughout study | | Dose, Mode, Schedule: | Gender Distribution: | | | | NR | | | | C: | 230 | NR | NR | NA | Change for PD ≥ 7 mm:
Location: | Placebo: | | | | T: SRP plus 1 mg of 2% minocycline microspheres in 3 mg of polymer applied in all sites with pockets ≥ 5 mm at baseline and months 3 and 6 | Male: 54.8% | | | | Microbiological Methods: | | | | Change: | | | [underlined: Reduction] | | T: 1.99 (0.31 se)
USA | Yes | | | | C: SRP plus 3 mg of placebo polymer | Race/Ethnicity: | | | | NR | | | | T: | | NR | 1.32 (0.04 se) | NA | C: 0.98 (0.29 se)
Patients Selected: | Split-mouth: | | | | | White: 76% | | | | Subject Self Report: | | | | C: | | NR | 1.00 (0.04 se) | NA | P = 0.06
Adult patients with at least 4 teeth with 6–9 mm PD with BOP | No | | | | | | | | | NR | | | | Test: | | | ANCOVA/GLM | | Quality Score:
| | | | | | | | | | | | | | P value: | | | < 0.001 | | 92; 92

Evidence Table 3a. Effectiveness of Systemic Metronidazole as an Adjunct to Scaling and Root Planing to Treat Chronic Periodontitis

Study Description | Study Design Characteristics | Disease Characteristics | Examiner Characteristics | Description of Scaling and Root Planing | Eligible Study Groups and How Defined: | Study Group Characteristics | Compliance Monitoring | Baseline Measures | Assessment Time Interval(s) | Outcomes Assessed | Adverse Effects | Study Group Attrition and Reasons | Type of Analysis | Outcomes Accessed
| | | | | | | | | | | | | | (N of Pts) | | Attachment Level mm [image] (SD) | Probing Depth mm [image] (SD) | Spirochetes [image]% (SD) | Comments
Joyston-Bechal et al., 1986 ^71^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NR | NR | 2 times (at baseline and 156 weeks) | Clinical Measurement: | NR | NR | Type of analysis reported: | Baseline: | | | | | There were no significant differences between test and control groups in mean PD. However, when T and C were subdivided into severity groups, the shallower pockets differed by treatment group (P = 0.027) but the deeper did not (P = 0.89). These results are different from the original 22 week study where deeper pockets benefited more from metronidazole.
Study Period: | RCT | Moderate, severe | NR | Scaling and oral hygiene | 28 subjects of the original 45 subjects in earlier study | NR | | | | BOP/SBI | | | All who completed follow-up | T: | 15 | NA | 3.61 (NR) | NA | Quality Score:
156 weeks (3 years) | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | T: 15 subjects | Gender: | | | | PlI | | | | C: | 13 | NA | 3.61 (NR) | NA | 38; 31
Study/Treatment Site: | Random | Teeth 16, 21, 24, 36, 41, and 44 | NR | NR | C: 13 subjects | NR | | | | PD | | | | Final: 156 weeks
Hospital dental clinic | Blinding: | Widman flap: | Assigned to Subjects: | | Dose, Mode, Schedule: | Race/Ethnicity: | | | | Gingival bleeding | | | | T: | 15 | NA | 2.58 (NR) | NA
Location: | Examiners and patients blind | NR | NR | | T: SRP plus 1% chlorhexidine gel for the first 10 weeks; at the end of 2 weeks, they began 200 mg metronidazole, 1 that evening and 3×day for 5 days; repeated 4 weeks later; SRP as needed at 4 week intervals until week 10. Over the next 3 years, SRP given 2×year as needed | NR | | | | Calculus | | | | C: | 13 | NA | 2.99 (NR) | NA
London, England | Placebo: | | | | C: SRP with placebo; 1 tablet that evening and 3×day for 5 days; repeated 4 weeks later; SRP as needed at 4 week intervals until week 10. Over the next 3 years, got SRP 2×year as needed | | | | | Radiographic Techniques: | | | | Change: | | | [underlined: Reduction]
Patient Population: | Yes | | | | | | | | | NR | | | | T: | 15 | NA | 1.03 (NR) | NA
Patients from a previous study invited for follow-up study 3 years later | Split-mouth: | | | | | | | | | Microbiolgical Methods: | | | | C: | 13 | NA | 0.62 (NR) | NA
| No | | | | | | | | | NR | | | | Test: | | | t-test
| | | | | | | | | | Subject self Report: | | | | P value: | | | 0.214
| | | | | | | | | | NR
Loesche et al., 1984 ^69^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | All subjects reported that they used the entire supply of medication | NR | 4 times (at baseline and weeks 2, 15, and 30) | Clinical Measurement: | Metallic taste | Unknown number of subjects that did not return for clinical examinations of PD and CAL | Type of analysis reported: | | | | | | Microbial Outcomes:
Study Period: | RCT | Moderate to advanced periodontitis, multiple sites with bone loss and infection | 1 | Mechanical debridement (meticulous root surface debridement) | 14 subjects | NR | | | | PD | | | Full participants only, though the bacteriological analysis used all available data | Baseline: | | | | | [underlined: P.g.]
30 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | T: 7 subjects | Gender: | | | | CAL | | | | T: | NR | 5.4 (NR) | 5.2 (NR) | 37.8 (NR) | [underlined: Baseline:] | [underlined: Final:]
Study/Treatment Site: | Random | Both | NA | NR | C: 7 subjects | NR | | | | Radiographic Techniques: | | | | C: | NR | 5.0 (NR) | 6.2 (NR) | 31.7 (NR) | T: 5.9 | T: 0.9
University of Michigan, School of Dentistry | Blinding: | Widman flap: | Assigned to Subjects: | | Dose, Mode, Schedule: | Race/Ethnicity: | | | | NR | | | | | | | | | C: 5.8 | C: 2.0
Location: | Examiner and patients blind | NR | Same examiner throughout study | | T: SRP plus 250 mg metronidazole 3×day for 7 days starting at first session of root scaling | NR | | | | Microbiological Methods: | | | | Final: 15 to 30 weeks
Ann Arbor, MI | Placebo: | | | | C: SRP and placebo tablets 3×day for 7 days | | | | | Bacteriological sampling, anaerobic count of agar colonies dark field microscopy | | | | T: | NR | NR | NR | 19.6 (NR) | The treatment group had significant and sustained reduction of certain anaerobic organisms, such as B.g. and large spirochetes
Patient Population: | Yes | | | | | | | | | Subject Self Report: | | | | C: | NR | NR | NR | 31.2 (NR) | Quality Score:
Patients with multiple sites of periodontal bone loss, BOP, and an anaerobic periodontal infection assigned to groups depending on initial severity of condition | Split-mouth: | | | | | | | | | NR | | | | [underlined: PD 4 to 6 mm or 4–6 mm Attachment Loss:] | | | | | 46; 46
| No | | | | | | | | | | | | | Change: | | [underlined: Gain] | [underlined: Reduction]
| | | | | | | | | | | | | | T: | NR | 0.38 | 1.19 (NR) | NR
| | | | | | | | | | | | | | C: | NR | 0.28 | 1.05 (NR) | NR
| | | | | | | | | | | | | | Test: | | t-test | t-test
| | | | | | | | | | | | | | P value: | | NS | NS
| | | | | | | | | | | | | | [underlined: PD 6+ mm:]
| | | | | | | | | | | | | | Change: | | [underlined: Gain] | [underlined: Reduction]
| | | | | | | | | | | | | | T: | NR | 1.42 (NR) | 3.19 (NR) | NR
| | | | | | | | | | | | | | C: | NR | 0.23 (NR) | 1.55 (NR) | NR
| | | | | | | | | | | | | | Test: | | t-test | t-test
| | | | | | | | | | | | | | P value: | | 0.05 | 0.03
Loesche et al., 1991 ^73^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | All subjects reported taking the medication as instructed except for 1 who stopped taking meds after 4 days because of a “leg cramp” | Before SRP | 4 times (at baseline, weeks 4 to 6, and 2 annual visits) | Clinical Measurement: | No complaints about medication | Of the original 50, losses were due to pts not returning for treatment, moved from community, or refused treatment (no numbers reported) | Type of analysis reported: | | | | | | Microbial Outcomes:
Study Period: | RCT | Advanced periodontitis | 15 graduate students provided treatment, clinician did pre and post exam | Rigorous debridement of the root surfaces of teeth that had 3 mm of probing depth and occlusal adjustment of the teeth if necessary | 50 subjects started | T: 47.9 ± 9.2 | | | | BOP/SBI | | | All who completed follow-up | Baseline: | | | | | [underlined: Baseline:] | [underlined: Final:]
52 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | 39 completed | C: 48.3 ± 11.5 | | | | PD | | | | T: | 18 | NR | NR | 52.6 (4.1) | [underlined: P.g.] | [underlined: P.g.]
Study/Treatment Site: | Random | Disto lingual sites not included | Used standard procedures | 3 to 8 clinic visits | T: 18 subjects | Gender: | | | | CAL | | | | C: | 21 | NR | NR | 59.1 (2.5) | T: 0.5 (0.2) | T: 0.5 (0.5)
Graduate Periodontal University Clinic | Blinding: | Widman flap: | Assigned to Subjects: | | C: 21 subjects | Males: 20 (T: 9; C: 11) | | | | Root topography | | | | | | | | | C: 3.0 (2.1) | C: 0.2 (0.1)
Location: | Examiners and patients blind | NR | Same examiner at each treatment planning assessment | | Dose, Mode, Schedule: | Females: 19 (T: 9, C: 10) | | | | Nature of bony defect | | | | Final: 52 weeks
USA | Placebo: | | | | T: SRP plus 250 mg metronidazole tablets 3×day for 1 week | Race/Ethnicity: | | | | Adequacy of access for thorough root instrumentation | | | | T: | 18 | NR | NR | NR | [underlined: A.a.] | [underlined: A.a.]
Patient Population: | Yes | | | | C: SRP plus placebo tablets for 1 week | NR | | | | Radiographic Techniques: | | | | C: | 21 | NR | NR | NR | T: < 0.01 | T: < 0.01
Adult patients with deep pocketing and radiographic evidence bone loss about one or more teeth per jaw quadrant, spirochete infection in 2 quadrants | Split-mouth: | | | | | | | | | Bone Loss/Regeneration | | | | [underlined: PD 4–6 mm (23 – 74 sites)] | | | | | C: < 0.01 | C: < 0.01
| No | | | | | | | | | Microbiological Methods: | | | | Change: | | [underlined: Gain] | [underlined: Reduction] | | Metronidazole had a significant effect on the site specific reduction of spirochetes. 90% of sites in the treatment group and 64% in control had decrease in the percentage of spirochetes (P< 0.05)
| | | | | | | | | | Plaque microbiota, total anaerobic count, dark field microscopy | | | | T: | 17 | 0.40 (NR) | 0.75 (NR) | NR | No significant differences between the treatment groups were observed for CAL or PD.
| | | | | | | | | | | | | | C: | 19 | 0.27 (NR) | 0.81 (NR) | NR | Quality Score:
| | | | | | | | | | | | | | Test: | | ANOVA | ANOVA | | 54; 46
| | | | | | | | | | | | | | P value: | | NS | NS
| | | | | | | | | | | | | | [underlined: PD 7+ mm (1–47 sites)]
| | | | | | | | | | | | | | Change:
| | | | | | | | | | | | | | T: | 17 | 0.86 (NR) | 1.91 (NR) | NR
| | | | | | | | | | | | | | C: | 19 | 0.54 (NR) | 1.50 (NR) | NR
| | | | | | | | | | | | | | Test: | | ANOVA | ANOVA
| | | | | | | | | | | | | | P value: | | NS | NS
Loesche et al., 1992 ^74^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | All subjects reported taking the medication as instructed | Before SRP | 5 times (at baseline, 4–6 weeks, then annually for 2 years) | Clinical Measurement: | Metallic taste | Non-return for treatments; moved from community, or deceased | Type of analysis reported: | PD ≤ 3 mm (39–121 sites) per subject | | | | | Microbial Outcomes:
Study Period: | RCT | Advanced adult periodontitis | NR | Rigorous debridement of root surfaces of teeth that had 3 mm or more PD and occlusal adjustment of teeth if necessary by 2 grad students | 33 subjects completed | NR | | | | BOP/SBI | | | Full participants only (with exception of 1 subject who completed the bacteriological analysis but wouldn't return for clinical exam) | Baseline: | | | | | Baseline: | Final
104 weeks (2 years) | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | T: 15 subjects | Gender: | | | | PD | | | | T: | | NR | NR | NA | P.g. | P.g.
Study/Treatment Site: | Random | NR | NR | NR | C: 18 subjects | Males: 17 | | | | CAL | | | | C: | | NR | NR | NA | T: 0.1 (0.2) | T: < 0.1 (0.1)
Graduate Periodontal Clinic | Blinding: | Widman flap: | Assigned to Subjects: | | Dose, Mode, Schedule: | Females: 16 | | | | Root topography | | | | Final: 104 weeks | | | | | C: 0.4 (1.4) | C: < 0.1 (0.1)
Location: | Examiners and patients blind | NR | Same examiner for each treatment planning session; examiner not involved in evaluation of data | | T: SRP plus 250 mg metronidazole 3×day for 1 week after SRP | Race/Ethnicity: | | | | Nature of bony defect | | | | T: | | NR | NR | NA | A.a. | A.a.
NR | Placebo: | | | | C: SRP with placebo (3×day for 1 week) | NR | | | | Adequacy of access for thorough root instrumentation | | | | C: | | NR | NR | NA | T: < 0.1 (0.1) | T: < 0.1 (0.1)
Patient Population: | Yes | | | | | | | | | Radiographic Techniques: | | | | Change: | | Gain | Reduction | | C: 0.3 (1.1) | C: < 0.1 (0.1)
Adult patients with deep pocketing and bone loss about 1 or more teeth per jaw quadrant (at least 4 such teeth per patient) with 20% + spirochetes | Split-mouth: | | | | | | | | | Bone Loss/Regeneration | | | | T: | | 0.04 (NR) | 0.05 (NR) | NA | The clinical improvements in the metronidazole group were associated with significantly lower proportions of spirochetes. These findings indicate that systemic metronidazole, when given after the root surface debridement is completed, leads to additional treatment benefits including a reduced need for surgery.
| No | | | | | | | | | Microbiological Methods: | | | | C: | | -0.33 (NR) | 0.20 (NR) | NA | At 4–6 weeks, treatment group had highly significant (P < 0.01) reduction in PD and gain in attachment levels in relation to controls in PD 4–6 mm and ≥ 7 mm.
| | | | | | | | | | Anaerobic count of agar colonies | | | | Test: | | ANOVA | ANOVA | | Quality Score:
| | | | | | | | | | Subject Self Report: | | | | P value: | | 0.07 | 0.08 | | 46; 38
| | | | | | | | | | NR | | | | PD4–6 mm (16–69 sites) per subject | | | | | Spirochetes ([image]%):
| | | | | | | | | | | | | | Baseline: | | | | | Baseline | Final
| | | | | | | | | | | | | | T: | | NR | NR | NA | T: 59.1 (18.0) | 22.9 (17.0)
| | | | | | | | | | | | | | C: | | NR | NR | NA | C: 60.0 (12.7) | 34.08 (20.3)
| | | | | | | | | | | | | | Final:104 weeks
| | | | | | | | | | | | | | T: | | NR | NR | NA
| | | | | | | | | | | | | | C: | | NR | NR | NA
| | | | | | | | | | | | | | Change: | | Gain | Reduction
| | | | | | | | | | | | | | T: | | 0.79 (NR) | 1.22 (NR) | NA
| | | | | | | | | | | | | | C: | | 0.32 (NR) | 0.75 (NR) | NA
| | | | | | | | | | | | | | Test: | | ANOVA | ANOVA
| | | | | | | | | | | | | | P value: | | < 0.01 | < 0.01
| | | | | | | | | | | | | | PD ≥ 7 mm (1–51 sites) per subject
| | | | | | | | | | | | | | Baseline:
| | | | | | | | | | | | | | T: | | NR | NR | NA
| | | | | | | | | | | | | | C: | | NR | NR | NA
| | | | | | | | | | | | | | Final:104 weeks
| | | | | | | | | | | | | | T: | | NR | NR | NA
| | | | | | | | | | | | | | C: | | NR | NR | NA
| | | | | | | | | | | | | | Change: | | Gain
| | | | | | | | | | | | | | T: | | 1.69 (NR) | 2.83 (NR) | NA
| | | | | | | | | | | | | | C: | | 1.03 (NR) | 1.78 (NR) | NA
| | | | | | | | | | | | | | Test: | | ANOVA | ANOVA
| | | | | | | | | | | | | | P value: | | 0.06 | < 0.01
Noyan et al., 1997 ^75^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NR | Before SRP | 2 times (at baseline and 6 weeks) | Clinical Measurement: | NR | NR | Type of analysis reported: | Baseline: | | | | | Quality Score:
Study Period: | RCT | NR | 2 | Mechanical subgingival debridement at selected sites in 2 quadrants, repeated 7 days later. | 10 subjects | Range: 35 to 51 | | | | PlI | | | All who completed follow-up | T: | 5 | 9.61 (NR) | 5.53 (NR) | NA | 31; 23
6 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | T: 5 subjects | Gender: | | | | PD | | | | C: | 5 | 9.56 (NR) | 5.19 (NR) | NA
Study/Treatment Site: | Random | NR | NR | NR | C: 5 subjects | Male: 3 | | | | CAL | | | | Final: 6 weeks
NR | Blinding: | Widman flap: | Assigned to Subjects: | | Dose, Mode, Schedule: | Female: 7 | | | | GI | | | | T: | 5 | 8.61 (NR) | 3.62 (NR) | NA
Location: | NR | NR | NR | | T: SRP plus 250 mg 1×day metronidazole for 7 days and second SRP after 1 week | Race/Ethnicity: | | | | Radiographic Techniques: | | | | C: | 5 | 8.97 (NR) | 3.88 (NR) | NA
Turkey | Placebo: | | | | C: SRP at baseline and second SRP at week 1 | NR | | | | NR | | | | Change:
Patient Population: | No | | | | | | | | | Microbiological Methods: | | | | T: | | 1.00 (NR) | 1.91 (NR) | NA
Adults with at least 1 approximal site per quadrant with PD ≥ 5 mm | Split-mouth: | | | | | | | | | Subgingival samples, agar colonies, anaerobic counts | | | | C: | | 0.59 (NR) | 1.31 (NR) | NA
| Yes | | | | | | | | | Subject Self Report: | | | | Test: | | Krustal Wallis, ANOVA | Krustal Wallis, ANOVA
| | | | | | | | | | NR | | | | P value: | | 0.001 | 0.001
Palmer et al., 1998 ^76^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NR | Before SRP | 4 times (at baseline and weeks 8 and 24) | Clinical Measurement: | NR | Failed to attend 2^nd^ appointment or reevaluation (6) (not reported as to which treatment group these subjects were assigned to) | Type of analysis reported: | Baseline: | | | | | Probing depth presented graphically, no statistical significance found between groups for PD, CAL, or spirochetes
Study Period: | RCT | Moderate to advanced adult periodontitis | NR | Subgingival scaling by ultrasonic instrumentation under local anesthesia of all affected teeth | 58 subjects | Mean: | | | | BOP/SBI | | | Full participants only | T: | | NR | NR | 47.1 (10.1) | Quality Score:
24 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | T: 31 subjects | T: 44.7 (6.2) | | | | PlI | | | Only sites with baseline PD ≥ 4–6 mm were evaluated | C: | | NR | NR | 47.2 (13.0) | 46; 46
Study/Treatment Site: | Random | NR | NR | 2 appointments, 90 minutes per appointment, 1 week apart, 2 contralateral quadrants done at each appointment | C: 27 subjects | C: 50.5 (6.1) | | | | PD | | | | Final: 26 weeks (6 months)
Hospital Dental Clinic, United Medical and Dental Schools of Guy's and St. Thomas Hospitals | Blinding: | Widman flap: | Assigned to Subjects: | | Dose, Mode, Schedule: | Range: 35 to 65 | | | | CAL | | | | T: | | NR | NR | 25.8 (10.3)
Location: | Examiners blind | NR | Same examiner throughout study | | T: SRP plus 200 mg metronidazole 3×day for 7 days | Gender: | | | | Radiographic Techniques: | | | | C: | | NR | NR | 25.6 (10.9)
London, UK | Placebo: | | | | C: SRP only | Male: 47 | | | | NR | | | | Change: | | [underlined: Gain]
Patient Population: | No | | | | | Female: 43 | | | | Microbiological Methods: | | | | T: | | 0.67 (0.67) | 1.62 (NR) | NR
Patients referred from dental practitioners, with PD of ≥ 5 mm and attachment loss ≥ 2 mm and bone loss ≥ 4 mm | Split-mouth: | | | | | Race/Ethnicity: | | | | Plaque microbiota, bacterial morphotype evaluated with dark field microscopy | | | | C: | | 0.51 (0.43) | 1.68 (NR) | NR
| No | | | | | NR | | | | Subject Self Report: | | | | Test: | | ANOVA | ANOVA | ANOVA
| | | | | | | | | | NR | | | | P value: | | NS | NS | NS
Author and Year: | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NR | Before SRP | 4 times (at baseline, and months 1, 3, and 6) | Clinical Measurement: | None | 66 recruited for full study; 4 were lost: | Type of analysis reported: | Baseline: | | | | | Presented as % of sites with low (0–3 mm) or high (≥ 6 mm), not in actual mm measurements or changes.
Rooney et al., 2002 ^70^ | RCT | Advanced chronic periodontal disease | 2 | Quadrant root planings under local anesthesia with ultrasonic scaler and Gracey curettes. SRP done by 2 experienced periodontists. | 31 subjects | Range: 20 to 45 | | | | PD | | lacked one month data (1); lacked 3 month data (1); had no 6 month data (3); no 3 and 6 month data (2); unable to determine which treatment groups the 4 were assigned to | Full participants only | T: | NR | NR | NR | NA | Differences in PD and CAL treatment effects were significantly greater in the treatment group than in the control.
Study Period: | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent on SRP: | T: 16 subjects | Gender Distribution: | | | | CAL | | | | C: | NR | NR | NR | NA | Microbiological data showed significant difference for treatment group versus control only at 1 month and not at months 3 and 6.
26 weeks | Random | All but 3^rd^ molars and severely malpositioned teeth | NR | 45 minutes for all teeth in quadrant; SRPs separated by maximum of 12 days, usually 7 days. | C: 15 subjects | NR | | | | BOP | | | | Final: 26 weeks | | | | | For PD ≥ 6 mm, at 24 weeks there was a significant PD change in favor of the treatment (P < 0.05) but a nonsignificant CAL change.
(6 months) | Blinding: | Widman flap: | Assigned to Patients: | | Dose, Mode, Schedule: | Race/Ethnicity: | | | | Presence of Suppuration | | | | T: | 16 | NR | NR | NA | Quality Score:
Site of Study: | Examiners and patients blind | NR | Same clinician provided treatment throughout study | | All received 0.2% chlorhexidine mouthrinse (10ml, 60s) 2×day until 1 week after non-surgical therapy | NR | | | | Plaque deposits | | | | C: | 15 | NR | NR | NA | 69; 54
Department of Perodontology, Bristol Dental School and Hospital | Placebo: | | | | T: SRP plus 200 mg metronidazole + placebo (calcium lactate tablets) 3×day for 7 days | | | | | Radiographic Techniques: | | | | Change:
Location: | Yes | | | | C: SRP plus placebo (lactose capsules and calcium lactate tablets) 3×day for 7 days | | | | | NR | | | | T: | | NR | NR | NA
UK | Split-mouth: | | | | | | | | | Microbiological Methods: | | | | C: | | NR | NR | NA
Patients Selected: | Yes, for microbiotic samples, 1 in each quadrant | | | | | | | | | Following incubation, anaerobic counts from agar plates for P.g., P.i., A..a., and others | | | | Test | | ANCOVA | ANCOVA
Patients <46 years old referred by practitioners who had failed to respond to non-surgical periodontal treatment with PD ≥ 6 mm and BOP. | | | | | | | | | | Patient Self Report: | | | | P-value | | ≤0.05 | ≤0.001
| | | | | | | | | | NR
Soder, Frithiof, et al., 1990 ^72^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | Checked by interviews and tablet count. 92 complied, 2 lost to follow up appts, 4 reduced their intake between 2 and 6 days | Before SRP | 3 times (at baseline and months 1 and 6) | Clinical Measurement: | Gastric discomfort (6); severe diarrhea (1); objected to taste of metronidazole (8) | Refused to take tablets (1); left Sweden and did not attend clinic (3); worked too far from clinic (1); lacked time (1) | Type of analysis reported: | Baseline: | | | | | The results show the supplementary effect of adjunctive metronidazole in non-surgical treatment of moderate and advanced periodontitis
Study Period: | RCT | Moderate to advanced recalcitrant to comprehensive non-surgical treatment | 4 (authors) | All received deep scaling | 98 subjects started | Range: 31–40 | | | | BOP/SBI | (T: 15, C: 9) | Not clear which treatment group each was assigned to | Full participants only | T: | | NA | 2.81 (0.61) | 6.69 (12.15) | The mean percentage of spirochetes as related to the total number of microorganisms counted did not differ significantly between groups
26 weeks (6 months) | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | 92 completed | Gender: | | | | PD | | | | C: | | NA | 2.75 (0.46) | 7.65 (10.46) | Quality Score:
Study/Treatment Site: | Random | NR | Calibration (gold standard) | NR | T: 46 sites | Male: 52 | | | | Furcation involvement | | | | Final: 26 weeks | | | | | 85; 85
NR | Blinding: | Widman flap: | Assigned to Subjects: | | C: 46 sites | Female: 46 | | | | Tooth morbidity | | | | T: | 46 sites | NA | 2.35 (0.61) | 4.35 (6.31)
Location: | Examiners and patients blind | NR | NR | | Dose, Mode, Schedule: | Race/Ethnicity: | | | | Gingival retraction | | | | C: | 46 sites (43 for spirochetes) | NA | 2.34 (0.43) | 7.86 (12.51)
Stockholm, Germany | Placebo: | | | | T: SRP plus 400 mg metronidazole tablets 3×day for 1 week | NR | | | | Presence of purulent exudates | | | | Change:
Patient Population: | Yes | | | | C: SRP plus placebo | | | | | PI | | | | T: | | NA | 0.46* (NR) | 2.34* (NR)
Young adult patients originally randomly selected from register of residents for Stockholm in 1985. This sample group is a subset with persistent pockets ≥ 5 mm in ≥ 3 teeth and radiographic marginal alveolar bone loss | Split-mouth: | | | | | | | | | Radiographic Techniques: Bone loss/regeneration | | | | C: | | NA | 0.41* (NR) | -0.21 (NR)
| No | | | | | | | | | Microbiological Methods: Crevicular fluid microbiota (samples from Ramfjord teeth) | | | | Test: | | | NR | t-test
| | | | | | | | | | Subject Self Report: | | | | P value: | | | NR | NS
| | | | | | | | | | Recording of remaining teeth, filled services, improvement of oral conditions, cervical sensitivity

Evidence Table 3b. Effectiveness of Local Metronidazole as an Adjunct to Scaling and Root Planing to Treat Chronic Periodontitis

Study Description | Study Design Characteristics | Disease Characteristics | Examiner Characteristics | Description of Scaling and Root Planing | Eligible Study Groups and How Defined: | Study Group Characteristics | Compliance Monitoring | Baseline Measures | Assessment Time Interval(s) | Outcomes Assessed | Adverse Effects | Study Group Attrition and Reasons | Type of Analysis | Outcomes Accessed
| | | | | | | | | | | | | | (N of Pts) | | Attachment Level mm [image] (SD) | Probing Depth mm [image] (SD) | Spirochetes [image]% (SD) | Comments
Author and Year: | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Mean Age: | NR | Before SRP | 2 times (at baseline and 90 days) | Clinical Measurement: | NR | 1 female subject withdrew from study before second examination | Type of analysis reported: | Baseline: | | | | | Treatment group had significantly more PD improvement than control (P < 0.03)
Al-Mubarak et al., 2000 ^80^ | RCT | Moderate to advanced signs of adult periodontitis | 1 | One session of SRP for all teeth with PD > 5 mm within the involved quadrant | 15 subjects started | Mean: 58.6 | | | | PD | | | Full participants only | T: | | NA | NR | NA | Quality Score:
Study Period: | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent on SRP: | 14 completed | Range: 41 to 79 | | | | Plaque Registration | | | | C: | | NA | NR | NA | 46; 46
13 weeks (90 days) | Random | No teeth with profound furcation involvement or advanced degree of mobility | Calibrated | One hour | T: 14 subjects | Gender Distribution: | | | | BOP | | | | Final: 13 weeks (90 days)
Site of Study: | Blinding: | Widman flap: | Assigned to Patients: | | C: 14 subjects | Male: 8 | | | | Radiographic Techniques: | | | | T: | | NA | NR | NA
NR | Examiner blind | NR | Same provider throughout study | | Dose, Mode, Schedule: | Female: 7 | | | | NR | | | | C: | | NA | NR | NA
Location: | Placebo: | | | | T: SRP plus 25% metronidazole gel applied on days 0 and 7 | Race/Ethnicity: | | | | Microbiological Methods: | | | | Change:
NR | No | | | | C: SRP only | NR | | | | NR | | | | T: | | NA | 2.2 (0.6) | NA
Patients Selected: | Split-mouth: | | | | | | | | | Patient Self Report: | | | | C: | | NA | 1.4 (0.8) | NA
Adult patients with at least 1 tooth in each quadrant with PD ≥ 5 mm | Yes | | | | | | | | | NR | | | | Test: | | | NR
| | | | | | | | | | | | | | P value: | | | < 0.03
Awartani et al., 1998 ^28^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NR | Before SRP | 5 times (at baseline and weeks 2, 4, 6, and 14) | Clinical Measurement: | None reported by subjects | 1 subject failed to show up for last examination | Type of analysis reported: | Baseline: | | | | | For the treatment of mild to moderate adult periodontitis subgingival scaling alone is as effective as the combination of scaling and antibiotic therapy
Study Period: | RCT | Mild to moderate periodontitis | 1 | Subgingival scaling performed under local anesthesia, moderate to heavy supragingival calculus removed by ultrasonic scaling; subgingival SRP as needed by Gracey curettes | 13 subjects (247 teeth) started | Mean: 37.3 | | | | BOP/SBI | | | All subjects who completed all follow-ups | T: | 360 sites: | NA | 4.61 (NR) | NA | Quality Score:
14 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | 12 subjects completed | Range: 28 to 57 | | | | PlI | | | | C: | 378 sites | NA | 4.65(NR) | NA | 54; 54
Study/Treatment Site: | Random to quadrants | NR | NA | 1 session per quadrant | T: 60 teeth (360 sites) | Gender: | | | | PD | | | | Final: 14 weeks
College of Dentistry, King Saud University | Blinding: | Widman flap: | Assigned to Subjects: | | C: 63 teeth (378 sites) | All Male | | | | GI | | | | T: | NR | NA | NR | NA
Location: | Examiners blind | NR | Same examiner throughout study | | Dose, Mode, Schedule: | Race/Ethnicity: | | | | Radiographic Techniques: | | | | C: | NR | NA | NR | NA
Saudi Arabia | Placebo: | | | | T: SRP plus 25% metronidazole gel applied once daily on days 0 and 7 | NR | | | | NR | | | | Change: | | | [underlined: Reduction]
Patient Population: | No | | | | C: SRP alone | | | | | Microbiological Methods: | | | | T: | | NA | 0.21 (NR) | NA
Patients with at least 1 tooth in each quadrant with PD ≥ 5 mm | Split-mouth: | | | | | | | | | NR | | | | C: | | NA | 0.33 (NR) | NA
| Yes | | | | | | | | | Subject Self Report: | | | | Test: | | | Tukey's and Scheffe's Multiple Range
| | | | | | | | | | NR | | | | P value: | | | NS
Aziz-Gandour and Newman, 1986 ^77^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | Yes with irrigation profiency checked at day 7 | Before SRP | 5 times (at baseline and days 7, 28, 56, and 84) | Clinical Measurement: | NR | 1 subject excluded from overall study excluded because of failure to attend all visits, but it is not clear which treatment group subject was assigned to | Type of analysis reported: | Baseline: | | | | | PD reductions reached a maximum at day 28 (last day of treatment) and were less at days 56 and 84.
Study Period: | RCT | Chronic periodontitis | NR | Supra and subgingival scaling, root planing and sub-contact area debridement and polishing | 16 subjects | T: | | | | SBI | | | Full participants only | T: | NR | NA | 5.3 (NR) | NA | There were sig diffs at all times between treatment and placebo, favoring metronidazole treatment for 84 days (P <0.01).
12 weeks (84 days) | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | T: 10 (210 sites) | Mean: 42 | | | | PlI | | | | C: | NR | NA | 4.6 (NR) | NA | PD final outcomes in graphic form only.
Study/Treatment Site: | Random | NR | Nr | NR | C: 6 (118 sites) | Range: 29 to 54 | | | | PD | | | | Final: 12 weeks | | | | | Quality Score:
Health Department Clinic | Blinding: | Widman flap: | Assigned to Subjects: | | Dose, Mode, Schedule: | C: | | | | GI | | | | T: | 10 (210 sites) | NA | NR | NA | 46; 46
Location: | Examiners and patients blind | NR | NR | | T: SRP plus irrigation with 0.05% metronidazole formulation for 28 days | Mean: 48 | | | | Gingival recession | | | | C: | 6 (118 sites) | NA | NR | NA
UK | Placebo: | | | | C: SRP plus irrigation with 0.1% quinine sulphate formulation for 28 days | Range: 43 to 55 | | | | Radiographic Techniques: | | | | Change:
Patient Population: | Yes | | | | | Gender: | | | | NR | | | | T: | | NA | NR | NA
Patients with approximal surface pockets ≥ 4 mm with bone reabsorption as seen on radiographs | Split-mouth: | | | | | T: | | | | Microbiological Methods: | | | | C: | | NA | NR | NA
| No | | | | | Male: 5 | | | | NR | | | | Test: | | | Chi Square
| | | | | | Female: 5 | | | | Subject Self Report: | | | | P value: | | | <0.01
| | | | | | C: | | | | NR
| | | | | | Male: 4
| | | | | | Female: 2
| | | | | | Race/Ethnicity
| | | | | | NR
Griffiths et al., 2000 ^79^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 5 times (at baseline and months 1, 3, 6, and 9) | Clinical Measurement: | NR | NR | Type of analysis reported: | Baseline: | | | | | Quality Score:
Study Period: | RCT | Chronic adult periodontitis | 2 (1 at each center) | Subgingival scaling of all quadrants. Supragingival scaling was provided if necessary to facilitate home care procedures | 88 subjects (average of 42 sites per subject) | Mean: 46 (clinic 1) | | | | BOP/SBI | | | Intent to treat | T: | 1,770 sites | 11.2 (1.6*) | 5.9 (0.6*) | NA | 62; 62
39 weeks (9 months) | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | 10 sites per quadrant | 47 (clinic 2) | | | | PD | | | | C: | 1,780 sites | 11.2 (1.6*) | 6.0 (0.5*) | NA
Study/Treatment Site: | Random | No third molars | Calibration (gold standard) | Supragingival scaling of not more than 20 minutes; subgingival debridement: 60 minutes per quadrant, 1 wk apart, ≤ 2 times | T: 1,770 sites | Range: 34 to 71 | | | | CAL | | | | Final: 36 weeks
Department of Periodontology, Eastman Dental Institute London | Blinding: | Widman flap: | Assigned to Subjects: | | C: 1,780 sites | Gender: | | | | Radiographic Techniques: | | | | T: | NR | NR | NR | NA
Royal Air Force Institute of Dental Health and Training at Haton, Bucks | Examiners blind | NR | Same examiner throughout study | | Dose, Mode, Schedule: | Male: 42 | | | | NR | | | | C: | NR | NR | NR | NA
Location: | Placebo: | | | | T: SRP plus 25% metronidazole gel applied 1×week for 3 weeks for each quadrant (1 week delay between quadrants) | Female: 46 | | | | Microbiological Methods: | | | | Change: | | [underlined: Gain] | [underlined: Reduction]
UK | No | | | | C: SRP alone | Race/Ethnicity: | | | | NR | | | | T: | | 0.8 (NR) | 1.5 (NR) | NA
Patient Population: | Split-mouth: | | | | | NR | | | | Subject Self Report: | | | | C: | | 0.4 (NR) | 1.0 (NR) | NA
Patients referred by general dental practitioners for treatment; at least 2 sites in each quadrant with PD ≥ 5 mm other than 3^rd^ molars | Yes | | | | | | | | | NR | | | | Test: | | paired t-test | paired t-test
| | | | | | | | | | | | | | P value: | | < 0.001 | < 0.001
Kinane and Radvar 1999 ^53^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 4 times (at baseline, 6 weeks and at months 3 and 6) | Clinical Measurement: | Yes, found none | 2 from treatment, 1 from control group, reasons not given | Type of analysis reported: | Baseline: | | | | | This is a follow-up study
Study Period: | RCT | Chronic periodontitis with previously unsuccessful mechanical therapy | 1 | SRP under local anesthesia | 39 subjects (4 sites per subject) | Mean: 45 ± 6.4 | | | | BOP/SBI | | | All with any follow-up | T: | | NR | 5.506 (0.152 se) | NA | Quality Score:
26 weeks (6 months) | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | T: 19 subjects | Range: NR | | | | PlI | | Analysis adjusted: GLM, baseline value as continuous covariate | Analysis adjusted: GLM, baseline value as continuous covariate | C: | | NR | 5.480 (0.175 se) | NA | 54; 62
Study/Treatment Site: | Random | NR | NR | NR | C: 20 subjects | Gender: (Full study) | | | | PD | | | | Final: 26 weeks
Hospital Dental Clinic | Blinding: | Widman flap: | Assigned to Subjects: | | Dose, Mode, Schedule: | Male: 29 | | | | CAL | | | | T: | 17 (75 sites) | NR | NR | NA
Location: | Examiner blind | NR | Same examiner throughout study | | T: SRP plus 25% metronidazole gel 2×day, repeated after 7 days | Female: 50 | | | | GI | | | | C: | 19 (79 sites) | NR | NR | NA
Glasgow, Scotland | Placebo: | | | | C: SRP only | Race/Ethnicity: | | | | Supperation | | | | Change: | | [underlined: Gain] | [underlined: Reduction]
Patient Population: | No | | | | | NR | | | | Radiographic Techniques: | | | | T: | | 0.541 (0.214) | 0.929 (0.196) | NA
Patients with persistent pockets that did not respond to SRP, with at least 4 non-adjacent teeth, with PD ≥ 5 mm and BOP | Split-mouth: | | | | | | | | | NR | | | | C: | | 0.537 (0.143) | 0.711 (0.188) | NA
| No | | | | | | | | | Microbiological Methods: | | | | Test: | | GLM | GLM
| | | | | | | | | | NR | | | | P value: | | 0.768 | NS
| | | | | | | | | | Subject Self Report:
| | | | | | | | | | NR
Lie et al., 1998 ^34^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 3 times (at baseline and months 3 and 6) | Clinical Measurement: | NR | None | Type of analysis reported: | Defect Sites: | | | | | Clinical and microbiological recordings were also performed on non-defect sites: the ANOVA revealed no differences for probing depth between treatment groups (P = 0.6247). The same findings apply to the attachment level measure (P = 0.3966). A.a. were rarely detected by the diagnostic handling. P.g. was significantly reduced in all treatment groups
Study Period: | RCT | Moderate to severe | 2 (1 operator; 1 examiner, blind) | Subgingival SRP with sonic instrument and curettes, two sessions, 1 week apart | 18 subjects | Range: 36 to 77 | | | | BOP/SBI | | | All subjects who completed all follow-ups | Baseline: | | | | | Quality Score:
26 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | T: 18 sites | Gender: | | | | PD | | | | T: | 18 (18 sites) | 13.2 (1.2) | 5.0 (1.1) | NA | 54; 62
Study/Treatment Site: | Random | Single-rooted | NR | NR | C: 18 sites | NR | | | | CAL | | | | C: | 18 (18 sites) | 13.4 (1.8) | 5.1 (1.2) | NA
Department of Periodontology, University of Bergen | Blinding: | Widman flap: | Assigned to Subjects: | | Dose, Mode, Schedule: | Race/Ethnicity: | | | | Radiographic Techniques: | | | | Final: 26 weeks
Location: | Examiner and patients blind | NR | 1 operator and 1 examiner assigned to all patients | | T: SRP plus application of 25% metronidazole sustained release gel after each SRP session, 1 week apart | NR | | | | NR | | | | T: | 18 (18 sites) | 12.3 (1.5) | 3.4 (1.0) | NA
Bergen, Norway | Placebo: | | | | C: Two SRP sessions, at baseline and week 1 | | | | | Microbiological Methods: | | | | C: | 18 (18 sites) | 13.2 (1.5) | 4.0 (1.4) | NA
Patient Population: | No | | | | | | | | | Use of commercial kit | | | | Change:
Patients referred for treatment, previously untreated, with PD ≥ 5 mm and BOP | Split-mouth: | | | | | | | | | Subject Self Report: | | | | T: | | 0.9* (NR) | 1.6* (NR) | NA
| Yes | | | | | | | | | NR | | | | C: | | 0.2* (NR) | 1.1* (NR) | NA
| | | | | | | | | | | | | | Test: | | ANOVA | ANOVA
| | | | | | | | | | | | | | P value: | | NS | NS
| | | | | | | | | | | | | | [underlined: NonDefect Sites]:
| | | | | | | | | | | | | | Baseline:
| | | | | | | | | | | | | | T:
| | | | | | | | | | | | | | C:
| | | | | | | | | | | | | | Final: 26 weeks
| | | | | | | | | | | | | | T:
| | | | | | | | | | | | | | C:
| | | | | | | | | | | | | | Change:
| | | | | | | | | | | | | | T:
| | | | | | | | | | | | | | C:
| | | | | | | | | | | | | | Test:
| | | | | | | | | | | | | | P value:
Moran et al., 1990 ^37^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 6 times (at baseline and weeks 1, 2, 4, 8, and 12) | Clinical Measurement: | NR | Failure to make all visits (4). Not clear which groups they were assigned to | Type of analysis reported: | Baseline: | | | | | Maximum reductions in microbiota counts were seen in treatment sites and sustained over 12 weeks.
Study Period: | RCT | Chronic periodontitis | 1 | Root planing by hand with local anesthesia using Gracey-type curettes | 69 subjects completed full study (101 pockets) | Mean: 47.6 | | | | BOP/SBI | | | Full participants only | T: | 15 pockets | 7.9 (2.0) | 6.6 (0.9) | NA | Quality Score:
13 weeks (3 months) | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | T: 15 pockets | Range: 37 to 58 | | | | PD | | | | C: | 18 pockets | 7.8 (1.9) | 6.9 (1.4) | NA | 62; 62
Study/Treatment Site: | Random | Anterior to molars | NR | 10 to 15 minutes per tooth | C: 18 pockets | Gender: | | | | CAL | | | | Final: 12 weeks
Health Department Clinic (Department of Peridontology, University of Wales | Blinding: | Widman flap: | Assigned to Subjects: | | Rmg subjects assigned to non-eligible treatments | Male: 28 | | | | Radiographic Techniques: | | | | T: | 15 pockets | 6.0 (2.3) | 3.2 (1.4) | NA
Location: | Examiners and patients blind | NR | Same examiner throughout study | | Dose, Mode, Schedule: | Female: 41 | | | | NR | | | | C: | 18 pockets | 6.2 (2.5) | 4.4 (2.2) | NA
Wales, UK | Placebo: | | | | T: SRP plus acrylic strips impregnated with metronidazole | Race/Ethnicity: | | | | Microbiological Methods: | | | | Change:
Patient Population: | No | | | | C: SRP only | NR | | | | Crevicular fluid microbiota (white blood cells count) | | | | T: | | 1.9* (NR) | 3.4* (NR) | NA
Adult patients referred by outside practitioners or other departments w/in the hospital, with pocketing ≥ 6 mm at several sites anterior to molars | Split-mouth: | | | | | | | | | Subject Self Report: | | | | C: | | 1.6* (NR) | 2.5* (NR) | NA
| No | | | | | | | | | NR | | | | Test: | | ANCOVA | ANCOVA
| | | | | | | | | | | | | | P value: | | NS | NS
Noyan et al., 1997 ^75^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 2 times (at baseline and 6 weeks) | Clinical Measurement: | NR | NR | Type of analysis reported: | Baseline: | | | | | Variations in the number of sites infected with the same microorganisms and the great dissimilarities in bacterial counts at initial exam did not allow for a statistical analysis for the evaluation of the effects of different treatment modalities on cultivated subgingival microbiota.
Study Period: | RCT | NR | 2 | Careful mechanical subgingival debridement at selected sites in 2 quadrants, repeated 7 days later in 3 quadrants | 10 subjects | Range: 35 to 51 | | | | PlI | | | All who completed follow-up | T: | 5 (5sites) | 8.79 (NR) | 5.57 (NR) | NA | Quality Score:
6 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | T: 5 subjects (5 sites) | Gender: | | | | PD | | | | C: | 5 (5sites) | 9.56 (NR) | 5.19 (NR) | NA | 23; 23
Study/Treatment Site: | Random | NR | NR | NR | C: 5 subjects (5 sites) | Male: 3 | | | | CAL | | | | Final: 6 weeks
NR | Blinding: | Widman flap: | Assigned to Subjects: | | Dose, Mode, Schedule: | Female: 7 | | | | GI | | | | T: | 5 (5 sites) | 7.54 (NR) | 3.48 (NR) | NA
Location: | NR | NR | NR | | T: SRP plus 25% metronidazole gel at day 0 and 7, SRP again at day 7 | Race/Ethnicity: | | | | Radiographic Techniques: | | | | C: | 5 (5 sites) | 8.97 (NR) | 3.88 (NR) | NA
Turkey | Placebo: | | | | C: SRP at baseline and week 1 | NR | | | | NR | | | | Change:
Patient Population: | No | | | | | | | | | Microbiological Methods: | | | | T: | | 1.25 (NR) | 2.09 (NR) | NA
Adult patients with 1 tooth/quadrant having at least 1 approximal site with PD ≥ 5 mm | Split-mouth: | | | | | | | | | Subgingival samples, agar colonies, anaerobic counts (A.a.) | | | | C: | | 0.59 (NR) | 1.31 (NR) | NA
| Yes | | | | | | | | | Subject Self Report: | | | | Test: | | Kruskal-Wallis | Kruskal-Wallis
| | | | | | | | | | NR | | | | | | ANOVA | ANOVA
| | | | | | | | | | | | | | P value: | | <0.01 | NS
Palmer et al., 1998 ^76^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NR | Before SRP | 3 times (at baseline, and weeks 8, and 24) | Clinical Measurement: | NR | Failed to attend 2^nd^ appointment or re-evaluation (6), not reported as to which treatment grp these subjects were assigned to | Type of analysis reported: | Baseline: | | | | | Probing depth presented graphically, no statistical significance found between groups for PD, CAL and spirochetes
Study Period: | RCT | Advanced adult periodontitis | NR | Subgingival scaling by ultrasonic instrumentation under local anesthesia of all affected teeth | 90 subjects referred for full study | Mean: | | | | BOP/SBI | | | Full participants only | T: | NR | NR | NR | 40.6 (14.6) | Quality Score:
24 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | 53 completed | T: 48.1 (7.3) | | | | PlI | | | Only sites with baseline probing depths ≥ 4 to 6 mm were evaluated | C: | NR | NR | NR | 47.2 (13.0) | 54; 46
Study/Treatment Site: | Random | NR | NR | 2 appointments, 90 minutes each, 1 week apart, 2 contralateral quadrants done at each appointment | T: 26 subjects | C: 50.5 (6.1) | | | | PD | | | | Final: 26 weeks (6 months)
Hospital Dental Clinic; United Medical and Dental Schools of the Guys and St. Thomas Hospitals | Blinding: | Widman flap: | Assigned to Subjects: | | C: 27 subjects | Range: 35 to 65 | | | | CAL | | | | T: | 26 | NR | NR | 23.5 (10.5)
Location: | Examiners blind | NR | Same examiner throughout study | | Dose, Mode, Schedule: | Gender: | | | | Radiographic Techniques: | | | | C: | 27 | NR | NR | 25.6 (10.9)
London, UK | Placebo: | | | | T: SRP plus application of 25% metronidazole gel, on all PD ≥ 4 mm sites; subgingival reapplication after 1 week in PD sites ≥ 4 mm | Male: 43 referred | | | | NR | | | | Change: | | [underlined: Gain] | [underlined: Reduction]
Patient Population: | No | | | | C: SRP only | Female: 47 referred | | | | Microbiological Methods: | | | | T: | | 0.47 (0.65) | 1.74 (NR) | NR
Patients referred from dental practitioners with PD of ≥ 5 mm with attachment loss ≥ 2 mm and bone loss ≥ 4 mm | Split-mouth: | | | | | Race/Ethnicity: | | | | Plaque microbiota; bacterial morphotype evaluated with dark field microscopy | | | | C: | | 0.51 (0.43) | 1.68 (NR) | NR
| No | | | | | NR | | | | Subject Self Report: | | | | Test: | | ANOVA | ANOVA | ANOVA
| | | | | | | | | | NR | | | | P value: | | NS | NS | NS
Riep et al., 1999 ^78^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 3 times (at baseline, day 21 and 3 months) | Clinical Measurement: | NR | Antibiotic treatment during course of study (1) | Type of analysis reported: | Baseline: | | | | | [underlined: Microbial Outcomes Assessed]:
Study Period: | RCT | Local recurrent periodontitis | 1 | SRP under local anesthesia | 30 subjects entered | Mean: 47 | | | | BOP/SBI | | | Full participants only | T: | 29 (58 sites) | NR | 6.8 (NR) | NA | P.g. was statistically significantly reduced in both groups from baseline, but not significantly between groups
13 weeks (3 months) | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | 29 completed | Gender: | | | | PlI | | | | C: | 29 (58 sites) | NR | 6.6 (NR) | NA | For P.i., the values decreased significantly, but only after SRP
Study/Treatment Site: | Random | Single root, teeth with furcation involvement were excluded | NA | NR | T: 58 sites | Male: 17 | | | | PD | | | | Final: 12 weeks | | | | | A.a. was not significantly different from either treatment
Department of Periodontology, Humbolt University | Blinding: | Widman flap: | Assigned to Subjects: | | C: 58 sites | Female: 12 | | | | CAL | | | | T: | 29 (58 sites) | NR | 5.1 (NR) | NA | Quality Score:
Location: | Examiners blind | NR | Same examiner throughout study, different person provided treatment | | Dose, Mode, Schedule: | Race/Ethnicity: | | | | Radiographic Techniques: | | | | C: | 29 (58 sites) | NR | 4.9 (NR) | NA | 46; 38
Berlin, Germany | Placebo: | | | | T: SRP plus 25% metronidazole gel applied 5× during 10 days | NR | | | | NR | | | | Change: | | [underlined: Gain] | [underlined: Reduction]
Patient Population: | No | | | | C: SRP only | | | | | Microbiological Methods: | | | | T: | | 1.31 (0.8) | 1.7 (NR) | NA
Maintenance patients scheduled for SRP with PD ≥ 6 mm in 2 non-adjacent sites in 2 different quadrants, and BOP in separate quadrants | Split-mouth: | | | | | | | | | Plaque microbiota (subgingival plaque samples); commercial kit analysis for P.g., P.i., A.a. | | | | C: | | 1.14 (0.8) | 1.7 (NR) | NA
| Yes | | | | | | | | | Subject Self Report: | | | | Test: | | Wilcoxen Signed-Ranks Test | Wilcoxen Signed-Ranks Test
| | | | | | | | | | NR | | | | P value: | | NS | NS
Stelzel and Florès-de-Jacoby, 2000 ^36^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | NR | 4 times (at baseline and days 91, 175, and 259) | Clinical Measurement: | No clinically relevant side effects noted | Irregular participation or other reasons unrelated to study (5) | Type of analysis reported: | Baseline: | | | | | Spirochetes and motil rods were combined in analysis and no significant difference was found in them between treatments.
Study Period: | RCT | Adult periodontitis | NR | Subgingival SRP | 64 subjects enrolled | Average: 47 | | | | BOP/SBI | | | Full participants only | T: | NR | 6.65 (1.13) | 6.00 (0.62) | NR | Quality Score:
37 weeks (9 months) | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | 59 completed | Range: 23 to 70 | | | | PD | | | | C: | NR | 6.69 (1.22) | 6.02 (0.62) | NR | 69; 62
Study/Treatment Site: | Random | NR | NR | NR | 21 with untreated periodontitis | Gender: | | | | CAL | | | | Final: 37 weeks
Health Department Clinic | Blinding: | Widman flap: | Assigned to Subjects: | | 10 had been pretreated | NR | | | | Radiographic Techniques: | | | | T: | 59 (522 teeth) | 5.64 (0.96) | 4.63 (0.75) | NR
Location: | Patient blind | NR | NR | | 28 were recall | Race/Ethnicity: | | | | NR | | | | C: | 59 (506 teeth) | 5.75 (1.03) | 4.83 (0.92) | NR
Helsinki, Germany | Placebo: | | | | T: 522 teeth (986 pockets) | NR | | | | Microbiological Methods: | | | | Change:
Patient Population: | No | | | | C: 506 teeth (945 pockets) | | | | | Plaque microbiota, dark field microscopy | | | | T: | | 1.01* (NR) | 1.37 (NR) | NR
Patients with ≥ 2 pockets with PD ≥ 5 mm and BOP in each quadrant | Split-mouth: | | | | Only 45 subjects were evaluated for microbiological samples | | | | | Subject Self Report: | | | | C: | | 0.94* (NR) | 1.19 (NR) | NR
| Yes | | | | Dose, Mode, Schedule: | | | | | NR | | | | Test: | | Wilcoxen | Wilcoxen
| | | | | T: SRP plus 25% metronidazole gel applied 2×day at day 0 and 7 | | | | | | | | | P value: | | NS | <0.05
| | | | | C: SRP only

* NR as to standard error or standard deviation.

Evidence Table 4. Effectiveness of Systemic Metronidazole and Amoxicillin as an Adjunct to Scaling and Root Planing to Treat Chronic Periodontitis

Study Description | Study Design Characteristics | Disease Characteristics | Examiner Characteristics | Description of Scaling and Root Planing | Eligible Study Groups and How Defined: | Study Group Characteristics | Compliance Monitoring | Baseline Measures | Time Interval(s) | Outcomes Assessed | Adverse Effects | Study Group Attrition and Reasons | Type of Analysis | Outcomes Accessed
| | | | | | | | | | | | | | (N of Pts) | | Attachment Level mm [image] (SD) | Probing Depth mm [image] (SD) | Spirochetes [image]% (SD) | Comments
Berglundh et al., 1998 ^81^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NR | NR | 4 times (at baseline and months 2, 12, and 24) | Clinical Measurement: | NR | NR | Type of analysis reported: | Baseline: | | | | | Microbial Outcomes:
Study Period: | RCT | Advanced periodontitis | NR | Non-surgical subgingival scaling and root planing under local anesthesia; SRP in 2 quadrants (mandible, maxilla) | 16 subjects | Range: 35 to 58 | | | | BOP/SBI | | | Full participants only | T: | 8 | NR | 4.8 (0.7) | NA | [underlined: P.g.:]
104 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | T: 8 subjects | Gender: | | | | PlI | | | | C: | 8 | NR | 4.5 (0.8) | NA | [underlined: Baseline] | [underlined: Final]
Study/Treatment Site: | Random | NR | NR | Required 3 to 5 sessions to complete | C: 8 subjects | Male: 6 | | | | PD | | | | Final: 104 weeks | | | | | T: 19.1 | T: 0.0
Department of Periodontology, Göteborg University | Blinding: | Widman flap: | Assigned to Subjects: | | Dose, Mode, Schedule: | Female: 10 | | | | CAL | | | | T: | 8 | 2.1 (0.4) | 2.7 (0.2) | NA | C: 9.8 | C: 1.8
Location: | NR | NR | NR | | T: SRP plus 250 mg metronidazole 3×day and 375 mg amoxicillin 2×day for 2 weeks | Race/Ethnicity: | | | | Tooth Loss (# of remaining teeth) | | | | C: | 8 | 1.5 (0.5) | 2.9 (0.6) | NA | [underlined: A.a.:]
Göteborg, Sweden | Placebo: | | | | C: SRP with placebo 3×day for 2 weeks | NR | | | | Radiographic Techniques: | | | | Change: | | | | | [underlined: Baseline] | [underlined: Final]
Patient Population: | Yes | | | | | | | | | Bone Loss Regeneration | | | | T: | | 1.1 (0.3) | 2.1* (NR) | NA | T: 0.1 | T: 0.0
Patients were referred to the clinic | Split-mouth: | | | | | | | | | Microbiological Methods: | | | | C: | | 0.8 (0.4) | 1.6* (NR) | NA | C: 0.5 | C: 0.1
| No | | | | | | | | | Plaque microbiota sampling (A.a., P.g., P.i.) | | | | Test: | | | NR | NR | Using the study treatment resulting in an improvement of the periodontal conditions and elimination of A.a. and P.g.
| | | | | | | | | | Subject Self Report: | | | | P value: | | | NR | NR | [underlined: P.i.:]
| | | | | | | | | | NR | | | | | | | | | [underlined: Baseline] | [underlined: Final]
| | | | | | | | | | | | | | | | | | | T: 0.1 | T: 0.0
| | | | | | | | | | | | | | | | | | | C: 0.5 | T: 0.1
| | | | | | | | | | | | | | | | | | | Quality Score:
| | | | | | | | | | | | | | | | | | | 46; 54
Flemmig et al., 1998 ^82^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | At day 10, remaining tablets of prescribed medication were counted | NR | 5 times (10 days, months 3, 6, 9, and 12) | Clinical Measurement: | Gastro-intestinal intolerance (4) (mainly diarrhea during or after taking prescribed medication) | Lost for gastro-intestinal intolerance (2); developed serious medical conditions not related to antibiotic therapy (2); concomitant dental therapy (1); relocation (3); inability to attend regular study appointments (2) | Type of analysis reported: | Baseline: | | | | | Data presented graphically. The highest CAL was found in sites with probing depths of ≥ 7 mm at baseline followed by sites 4–6 mm deep at baseline. There were no sig differences btw groups.
Study Period: | RCT | Untreated periodontitis | 1 | Supra and subgingival full mouth scaling under local anesthesia performed by dental students until no supragingival plaque or calculus visible and no pathological exposed and subgingival root surfaces felt hard and smooth | 48 subjects enrolled | Mean: 51.8 ± 11.0 | | | | PD | | | Full participants only | T: | 18 | NR | NR | NA | In subjects with A.a., a significantly higher incidence of CAL gain of 2 mm or more was achieved in treatment group over control (P < 0.05). The adverse was true for P.g. where there was a loss (P < 0.05).
52 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | 38 completed | Gender: | | | | CAL | | | Subject is the unit of analysis | C: | 20 | NR | NR | NA | Quality Score:
Study/Treatment Site: | Random | NR | Dental students | 2 hours per quadrant | T: 18 subjects | Male: 17 | | | | Radiographic Techniques: | | | | Final: 52 weeks | | | | | 38; 31
Department of Peridontology, Julius Maximilian University | Blinding: | Widman flap: | Assigned to Subjects: | | C: 20 subjects | Female: 21 | | | | NR | | | | T: | 18 | NR | NR | NA
Location: | Subject blind | NR | Same dentist throughout study | | Dose, Mode, Schedule: | Race/Ethnicity: | | | | Microbiological Methods: | | | | C: | 20 | NR | NR | NA
Wurzburg, Germany | Placebo: | | | | T: SRP plus 250 mg metronidazole 3×day and 375 mg amoxicillin 3×day plus 0.06% chlorhexidine subgingival irrigation 1×day, for 8 days | NR | | | | Plaque microbiota (A.a., P.g.) | | | | Change:
Patient Population: | No | | | | C: SRP and oral hygiene instructions | | | | | Swab samples (tongue, tonsils, and buccal mucosa) | | | | T: | | NR | NR | NA
Patients 30 yrs + with subgingival detection with A.a. and/or P.g. and ≥ 4 pockets with PD ≥ 6 mm | Split-mouth: | | | | | | | | | Polymerase Chain Reaction | | | | C: | | NR | NR | NA
| No | | | | | | | | | Subject Self Report: | | | | Test:
| | | | | | | | | | NR | | | | P value:
Author and Year: | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NR | Before SRP | 4 times (at baseline, and months 1, 3, and 6) | Clinical Measurement: | None | 66 recruited for full study; 4 were lost: | Type of analysis reported: | Baseline: | | | | | Presented as % of sites with low (0–3 mm) or high (≥ 6 mm), not in actual mm measurements or changes.
Rooney et al., 2002 ^70^ | RCT | Advanced chronic periodontal disease | 2 | Quadrant root planings under local anesthesia with ultrasonic scaler and Gracey curettes. SRP done by 2 experienced periodontists. | 30 subjects | Range: 20 to 45 | | | | PD | | lacked one month data (1); lacked 3 month data (1); had no 6 month data (3); no 3 and 6 month data (2); unable to determine which treatment groups the 4 were assigned to | Full participants only | T: | NR | NR | NR | NA | Differences in PD and CAL treatment effects were significantly greater in the treatment group than in the control.
Study Period: | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent on SRP: | T: 15 subjects | Gender Distribution: | | | | CAL | | | | C: | NR | NR | NR | NA | Microbiological data showed significant difference for treatment group versus control only at 1 month and not at months 3 and 6.
26 weeks | Random | All but 3^rd^ molars and severely malpositioned teeth | NR | 45 minutes for all teeth in quadrant; SRPs separated by maximum of 12 days, usually 7 days. | C: 15 subjects | NR | | | | BOP | | | | Final: 26 weeks | | | | | Quality Score:
(6 months) | Blinding: | Widman flap: | Assigned to Patients: | | Dose, Mode, Schedule: | Race/Ethnicity: | | | | Presence of Suppuration | | | | T: | 15 pts | NR | NR | NA | 69; 54
Site of Study: | Examiners and patients blind | NR | Same clinician provided treatment throughout study | | All received 0.2% chlorhexidine mouthrinse (10ml, 60s) 2×day until 1 week after non-surgical therapy | NR | | | | Plaque deposits | | | | C: | 15 pts | NR | NR | NA
Department of Perodontology, Bristol Dental School and Hospital | Placebo: | | | | T: SRP plus 250 mg amoxicillin + 200 mg metronidazole 3×day for 7 days | | | | | Radiographic Techniques: | | | | Change:
Location: | Yes | | | | C: SRP plus placebo (lactose capsules and calcium lactate tablets) 3×day for 7 days | | | | | NR | | | | T: | | NR | NR | NA
UK | Split-mouth: | | | | | | | | | Microbiological Methods: | | | | C: | | NR | NR | NA
Patients Selected: | Yes, for microbiotic samples, 1 in each quadrant | | | | | | | | | Following incubation, anaerobic counts from agar plates for P.g., P.i., A..a., and others | | | | Test | | ANCOVA | ANCOVA
Patients <46 years old referred by practitioners who had failed to respond to non-surgical periodontal treatment with PD ≥ 6 mm and BOP. | | | | | | | | | | Patient Self Report: | | | | P-value | | ≤0.05 | ≤0.001
| | | | | | | | | | NR
Author and Year: | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | Subjects were asked to return unused meds after 7 days. No tablets were returned, though 1 subject complained about missing 1 tablet. | Before SRP | 3 times (at baseline, 6 weeks and 3 months after medicine completion) | Clinical Measurement: | Face rash (T:1, C:1); gastro-intestinal intolerance (T: 9); rash on neck | Severe headache, severe diarrhea, refused tablets because of size, unwilling to avoid alcohol (T: 4); pregnant | Type of analysis reported: | Baseline: | | | | | Sites with P.g. had significantly greater PD reduction with treatment (1.52mm) placebo (1.1mm) and there was difference in the group that had no P.g.
Winkel et al., 2001 ^83^ | RCT | Generalized severe adult periodontitis | 1 at each clinic | Full mouth scaling and root planing, under local anesthetic, if requested. Approximately 6 weeks later, subjects were recalled and SRP was readministered to pockets with PD > 3 mm and BOP | 49 subjects completed | Mean: 42 | | | | PlI | (T: 1); nausea after alcohol | (C: 1) | Full participants only | T: | 23 | 7.7 (1.8) | 7.81 (0.9) | NA | The greatest PD reduction was found at sites with initial PD ≥ 7 mm (T: 3.2 mm, C: 2.5 mm). These sites had most pronounced CAL gains (T: 2.0 mm, C: 1.5 mm)
Study Period: | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent on SRP: | T: 23 subjects | T: 45 | | | | PD | (T: 1) | | | C: | 26 | 7.4 (1.1) | 8.1 (1.2) | NA | Quality Score:
12 weeks | Random | NR | NR | 3 to 6 sessions of 1 hour each over 6 week period | C: 26 subjects | C: 40 | | | | BI | | | | Final: 12 weeks | | | | | 85; 77
(3 months) | Blinding: | Widman flap: | Assigned to Subjects: | | Dose, Mode, Schedule: | Range: 28 to 63 | | | | CAL | | | | T: | 23 | 5.8 (1.5) | 4.6 (0.9) | NA
Site of Study: | Examiners and patients blind | NR | One examiner for all clinical and biological samples at each clinic and throughout study | | T: SRP plus 375 mg amoxicillin and 250 mg metronidazole tablets, 3×day for 7 days | Gender Distribution: | | | | Radiographic Techniques: | | | | C: | 26 | 5.1 (1.4) | 5.6 (1.3) | NA
Clinics for Periodontology | Placebo: | | | | C: SRP plus identical placebos, 3×day for 7 days | Male: T: 11 | | | | NR | | | | Change: | | [underlined: Gain] | [underlined: Reduction]
Location: | Yes | | | | | C: 10 | | | | Microbiological Methods: | | | | T: | | 2.3* (NR) | 3.2* (NR) | NA
Amsterdam and Utrecht, Netherlands | Split-mouth: | | | | | Female: T: 12 | | | | Plaque sampling (P.m., P.g., B.f., B.i.) | | | | C: | | 1.9* (NR) | 2.5* (NR) | NA
Patients Selected: | No | | | | | C: 16 | | | | Mowbell's et al., 1991, 1994 | | | | Test: | | Mann Whitney | Mann Whitney
Patients referred to clinic for PD treatment ≥ 1 sites in ≥ 3 quadrants with PD > 6 mm and CAL ≥ 3 mm plus BOP and radiographic evidence of bone loss | | | | | | Race/Ethnicity: | | | | Subject Self Report: | | | | P value: | | NS | <0.05
| | | | | | NR | | | | NR

Evidence Table 5. Effectiveness of Local Chlorhexidine Combinations as an Adjunct to Scaling and Root Planing to Treat Chronic Periodontitis

Study Description | Study Design Characteristics | Disease Characteristics | Examiner Characteristics | Description of Scaling and Root Planing | Eligible Study Groups and How Defined: | Study Group Characteristics | Compliance Monitoring | Baseline Measures | Time Interval(s) | Outcomes Assessed | Adverse Effects | Study Group Attrition and Reasons | Type of Analysis | Outcomes Accessed
| | | | | | | | | | | | | | (N of Pts) | | Attachment Level mm [image] (SD) | Probing Depth mm [image] (SD) | Spirochetes [image]% (SD) | Comments
Aziz-Gandour and Newman, 1986 ^77^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | Yes, with irrigation | Before SRP | 5 times (at baseline and days 7, 28, 56, and 84) | Clinical Measurement: | NR | 1 subject excluded from full study because of failure to attend all visits, but it is not clear which treatment group subject was assigned to | Type of analysis reported: | Baseline: | | | | | For chlorhexidine and control groups, there were significant differences in pocket depth only at day 56 visit.
Study Period: | RCT | Chronic peridontitis | NR | Supra and subgingival scaling, root planing and sub-contact area debridement and polishing | 12 subjects | Mean: | | | | SBI | | | Full participants only | T: | 6 (147 sites) | NA | 4.8 (NR) | NA | Clinically, the differences between groups was relatively small.
12 weeks (84 days) | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | T: 6 subjects (147 surfaces) | T: 43 | | | | PlI | | | | C: | 6 (118 sites) | NA | 4.6 (NR) | NA | Quality Score:
Study/Treatment Site: | Random | NR | NR | NR | C: 6 subjects (118 surfaces) | C: 48 | | | | PD | | | | Final: 12 weeks (84 days) | | | | | 54; 46
Health Department Clinic | Blinding: | Widman flap: | Assigned to Subjects: | | Dose, Mode, Schedule: | Range: | | | | GI | | | | T: | NR | NA | NR | NA
Location: | Examiners and patients blind | NR | NR | | T: SRP plus 0.2% chlorhexidine irrigation 1×day for 28 days | T: 32 to 53 | | | | Gingival recession | | | | C: | NR | NA | NR | NA
UK | Placebo: | | | | C: SRP plus 0.1% quinine sulphate irrigation | C: 43 to 55 | | | | Radiographic Techniques: | | | | Change:
Patient Population: | Yes | | | | | Gender: | | | | NR | | | | T: | | NA | NR | NA
Patients with approximal surface pockets and ≥ 4 mm bone reabsorption as seen on radiographs | Split-mouth: | | | | | Male: | | | | Microbiological Methods: | | | | C: | | NA | NR | NA
| No | | | | | T: 1 | | | | NR | | | | Test: | | | ChiSquare, Paired t-test
| | | | | | C: 2 | | | | Subject Self Report: | | | | P value: | | | NS
| | | | | | Female: | | | | NR
| | | | | | T: 5
| | | | | | C: 4
| | | | | | Race/Ethnicity:
| | | | | | NR
Azmak et al., 2002 ^93^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 4 times (at baseline and months 1, 3, and 6) | Clinical Measurement: | NR | Use of antibiotics (2) | Type of analysis reported: | Baseline: | | | | | Outcome data presented graphically.
Study Period: | RCT | Moderate to severe chronic periodontitis | NR | Under local anesthesia | 22 subjects enrolled | Range: 36 to 62 | | | GCF MMP measured at baseline, days 2 and 10, and months 1, 3, and 6 | BOP/SBI | | | Full participants only | T: | 20 sites | 8.83 (1.34) | 7.00 (0.69) | NA | Improvements were not statistically significant at 1, 3, and 6 months for PD and CAL.
26 weeks (6 months) | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | 20 completed | Gender: | | | | PlI | | | | C: | 20 sites | 8.72 (0.84) | 6.83 (0.86) | NA | Quality Score:
Study/Treatment Site: | Random | NR | NR | 5 minutes per tooth | 2 sites per mouth | Both | | | | PD | | | | Final: 26 weeks | | | | | 38; 31
Ege University | Blinding: | Widman flap: | Assigned to Subjects: | | T: 20 sites | Race/Ethnicity: | | | | CAL | | | | T: | 20 sites | NR | NR | NA
Location: | Examiners blind | NR | Same examiner throughout study | | C: 20 sites | NR | | | | GCI | | | | C: | 20 sites | NR | NR | NA
Izmir, Turkey | Placebo: | | | | Dose, Mode, Schedule: | | | | | GCF-MMP - 8 levels | | | | Change:
Patient Population: | No | | | | T: SRP plus 2.5 mg chlorhexidine chip in isolated pockets | | | | | Radiographic Techniques: | | | | T: | 20 sites | NR | NR | NA
Patients with 2 interproximal sites selected from anterior teeth with PD 6 to 8 mm and BOP, ≥ 4 sites with ≥ 4 mm attachment loss, and at least 2 teeth between selected sites | Split-mouth: | | | | C: SRP only | | | | | NR | | | | C: | 20 sites | NR | NR | NA
| Yes | | | | | | | | | Microbiological Methods: | | | | Test: | | Repeated Measures ANCOVA | Repeated Measures ANCOVA
| | | | | | | | | | NR | | | | P value: | | 0.574 | 0.138
| | | | | | | | | | Subject Self Report:
| | | | | | | | | | NR
Braatz et al., 1985 ^30^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | Yes, subjects were checked every 2 weeks for their ability to irrigate the experimental sites | Before SRP | 3 times (at baseline and weeks 12 and 24) | Clinical Measurement: | NR | NR | Type of analysis reported: | Baseline: | | | | | Chlorhexidine group and control group did not differ significantly in any of the studied parameters so treatment did not augment SRP
Study Period: | RCT | Generalized chronic periodontitis | 1 | Single episode of supra and subgingival instrumentation under local anesthesia | 14 subjects (2 to 25 sites per subject) | Range: 40 to 70 | | | | BOP/SBI | | | Full participants only | T: | 54 sites | NR | 7.6 (0.9) | 6.8% (9.0) | Quality Score:
24 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | T: 54 sites | Gender: | | | | PD | | | | C: | 52 sites | NR | 7.5 (0.7) | 9.2% (11.0) | 46; 38
Study/Treatment Site: | Random | Single-rooted | NA | NR | C: 52 sites | Male: 8 | | | | CAL | | | | Final: 24 weeks
NR | Blinding: | Widman flap: | Assigned to Subjects: | | Dose, Mode, Schedule: | Female: 6 | | | | Radiographic Techniques: | | | | T: | 54 sites | NR | 4.3 (1.4) | 0.8% (3.0)
Location: | NR | NR | Same examiner throughout study | | T: SRP plus irrigation with 0.2% chlorhexidine 1×day for 24 weeks on 1 side of maxillary and/or mandibular jaw | Race/Ethnicity: | | | | NR | | | | C: | 52 sites | NR | 4.5 (1.5) | 1.2% (4.1)
USA | Placebo: | | | | C: SRP only | NR | | | | Microbiological Methods: | | | | Change: | | [underlined: Gain]
Patient Population: | No | | | | | | | | | Spirochete analysis, dark field microscopy | | | | T: | 54 sites | 1.4 (1.4) | 3.3* (NR) | NR
Patients with at least 2 sites with PD ≥ 7 mm on single-rooted teeth with BOP | Split-mouth: | | | | | | | | | Subject Self Report: | | | | C: | 52 sites | 1.2 (1.1) | 3.0* (NR) | NR
| Yes | | | | | | | | | NR | | | | Test: | | ANOVA | ANOVA | ANOVA
| | | | | | | | | | | | | | P value: | | NS | NS | NS
Author and Year: | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NR | Before SRP | 4 times (at baseline and months 3, 6, and 9) | Clinical Measurement: | NR | Antibiotic use during test period (1) | Type of analysis reported: | Baseline: | | | | | SRP produced a significant reduction in microorganisms. The addition of the chlorhexidine chip did not augment the results.
Grisi et al., 2002 ^94^ | RCT | Chronic periodontitis | 1 | Full mouth supragingival scaling under anesthesia with Gracey curets | 20 subjects invited | Mean: 41.8 ± 5.6 | | | | PlI | | | Full participants only | T: | 10 (41 sites) | NR | 5.2 (0.6) | NA | Quality Score:
Study Period: | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent on SRP: | 19 subjects enrolled and completed | Range: 35 to 56 | | | | GR | | | | C: | 9 (39 sites) | NR | 5.2 (0.6) | NA | 46; 38
39 weeks (9 months) | Random | NR | NA | NR | T: 10 (41 sites) | Gender Distribution: | | | | PD | | | | Final: 39 weeks (9 months)
Site of Study: | Blinding: | Widman flap: | Assigned to Subjects: | | C: 9 (43 sites) | Male: 11 (T: 5, C: 3) | | | | BOP | | | | T: | 10 (41 sites) | NR | 3.0 (0.8) | NA
NR | Examiner blind | NR | NR | | Dose, Mode, Schedule: | Female: 9 (T: 5, C: 6) | | | | Suppuration | | | | C: | 9 (39 sites) | NR | 2.9 (0.6) | NA
Location: | Placebo: | | | | T: SRP plus chlorhexidine chip at baseline and at 3 and 6 months in all pockets ≥ 5 mm; chip position assessed at days 3 and 7 after placement | Race/Ethnicity: | | | | CAL | | | | Change: | | [underlined: Gain] | [underlined: Reduction]
Brazil | No | | | | C: SRP alone | NR | | | | PBS | | | | T: | 10 (41 sites) | 0.6 (0.7) | 2.2 (0.7) | NA
Patients Selected: | Split-mouth: | | | | Note: Full mouth supragingival prophylaxis 1×month for both treatment and control groups. | | | | | Radiographic Techniques: | | | | C: | 9 (39 sites) | 1.0 (0.4) | 2.4 (0.7) | NA
Patients with PD ≥ 5 mm in at least 4 sites and BOP | No | | | | | | | | | NR | | | | Test: | | Mann-Whitney | Mann-Whitney
| | | | | | | | | | Microbiological Methods: | | | | P value: | | 0.07 | NS
| | | | | | | | | | BANA Test; Microbes: B.f., T.d., P.g.
| | | | | | | | | | Subject Self Report:
| | | | | | | | | | NR
Heasman et al., 2001 ^92^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 4 times (at baseline and months 1, 3, and 6) | Clinical Measurement: | Only 1 subject reported any oral symptoms at any time during trial | Withdrew after 3 mos for non-treatment related reasons (2) | Type of analysis reported: | Baseline: | | | | | The results suggest that the chlorhexidine chip is beneficial for subjects on maintenance therapy although the benefit is not apparent until 6 months after placement
Study Period: | RCT | Moderate to advanced chronic periodontitis | 2 | At baseline, supragingival ultrasonic scaling and prophylaxis of all teeth. All target sites were root planed under local anesthesia | 26 subjects recruited | Mean: 42.6 | | | | BOP/SBI | | | Intent to treat | T: | 87 sites | 14.23 (0.19 se) | 6.64 (0.12 se) | NA | Quality Score:
26 weeks (6 months) | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | 24 completed | Range: 34 to 59 | | | | PlI | | | | C: | 165 sites | 14.14 (0.16 se) | 6.47 (0.11 se) | NA | 54; 54
Study/Treatment Site: | Random | Molars | Calibration (Gold standard) | Maximum of 5 minutes per tooth for supragingival scaling | T: 87 sites | Gender: | | | | PD | | | | Final: 26 weeks
Department of Periodontology of Newcastle Dental School and Hospital | Blinding: | Widman flap: | Assigned to Subjects: | | C: 165 sites | Male: 8 | | | | CAL | | | | T: | NR | NR | NR | NA
Location: | Examiners blind | NR | Same examiner throughout study. Clinician placed all periochips, always in the absence of examiner | | Dose, Mode, Schedule: | Female:18 | | | | Radiographic Techniques: | | | | C: | NR | NR | NR | NA
UK | Placebo: | | | | T: SRP plus 2.5 mg controlled release chlorhexidine chip inserted in pockets | Race/Ethnicity: | | | | NR | | | | Change: | | [underlined: Gain] | [underlined: Reduction]
Patient Population: | No | | | | C: SRP only | White: 100% | | | | Microbiological Methods: | | | | T: | NR | 0.43 (0.15 se) | 0.78 (0.12 se) | NA
Adults with ≥ 10 natural uncrowned teeth; ≥ 1 pocket per quadrant with PD ≥ 5 mm and persistent BOP | Split-mouth: | | | | | | | | | NR | | | | C: | NR | 0.15 (0.09 se) | 0.45 (0.13 se) | NA
| Yes (left side, right side) | | | | | | | | | Subject Self Report: | | | | Test: | | t-test | t-test
| | | | | | | | | | NR | | | | P value: | | 0.048 | 0.05
Jeffcoat et al., 1998 ^91^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 6 times (at baseline, day 7, week 6, and months 3, 6, and 9) | Clinical Measurement: | Higher in treatment group: | Concurrent medical/ dental treatment; illness; lack of follow-up | Type of analysis reported: | Baseline: | | | | | Quality Score:
Study Period: | RCT | Adult periodontitis | At least one at each center | All subjects received scaling and root planing | 447 subjects entered | Mean: 46.4 | | | | BOP/SBI | minor and transient toothache (including pain, tenderness, aching, throbbing, soreness, discomfort, or sensitivity) | | Intent to treat, analysis adjusted | T: | 225 | 5.27 (1.34 se) | 5.73 (0.59 se) | NA | 85; 93
39 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | 419 subjects completed | Range: 27 to 79 | | | | PlI | | | | C: | 222 | 5.14 (1.48 se) | 5.64 (0.55 se) | NA
(9 months) | Random | NR | Calibration (gold standard) | 1 hour for all teeth for removal of supragingival calculus and 1 hour for SRP | T: 211 sites | Gender: | | | | PD | | | | Final: 39 weeks (9 months)
Study/Treatment Site: | Blinding: | Widman flap: | Assigned to Subjects: | | C: 208 sites | Male: 207 | | | | CAL | | | | T: | | NR | NR | NA
10 centers at 10 different universities | Examiners and patients blind | NR | Same examiner throughout study | | Dose, Mode, Schedule: | Female: 240 | | | | GI | | | | C: | | NR | NR | NA
Location: | Placebo: | | | | T: SRP plus 2.5 mg controlled release chlorhexidine chips at baseline, 3 and 6 months if PD ≥ 5 mm | Race/Ethnicity: | | | | Staining examination | | | | Change: | | [underlined: Gain] | [underlined: Reduction]
USA | Yes | | | | C: SRP with placebo chip | NH White: 336 (75.2%) | | | | Radiographic Techniques: | | | | T: | 211 | 0.75 (0.06 se) | 0.95 (0.05 se) | NA
Patient Population: | Split-mouth: | | | | | NH Black: 85 (19%) | | | | NR | | | | C: | 208 | 0.55 (0.06 se) | 0.69 (0.05 se) | NA
Patients with ≥ 10 natural teeth and ≥ 4 teeth with PD of 5 to 8 mm and BOP | Yes | | | | | Hispanic: 8 (1.8%) | | | | Microbiological Methods: | | | | Test: | | NR | NR
| | | | | | Asian/Pacific Islander: 12 (2.7%) | | | | NR | | | | P value: | | 0.012 | 0.00056
| | | | | | Other: 6 (1.3%) | | | | Subject Self Report:
| | | | | | | | | | NR
Author and Year: | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 4 times (at baseline, and weeks 8, 16, and 24) | Clinical Measurement: | NR | NR | Type of analysis reported: | Baseline: | | | | | Quality Score:
MacAlpine 1985 ^31^ | Clinical trial | Generalized chronic periodontitis | 1 | Supra and subgingival instrumentation under local anesthesia until operator was confident that the tooth surfaces had been equately debrided | 11 subjects | Range: 25–67 | | | Spirochetes were assessed at baseline and weeks 7, 15, and 23 | BOP | | | All who completed treatment | T: | 16 sites | NR | 7.7 (0.9) | 32 (20) | 38; 38
Study Period: | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent on SRP: | 4 or 8 sites per subject | Gender Distribution: | | | | Plaque scores | | | | C: | 16 sites | NR | 7.4 (0.6) | 39 (21)
24 weeks | Assignment method not reported | Single root | NA | NR | T: 16 sites | Males: 2 | | | | PD | | | | Final: 24 weeks
Site of Study: | Blinding: | Widman flap: | Assigned to Subjects: | | C: 16 sites | Females: 9 | | | | CAL | | | | T: | 16 sites | NR | 4.2 (1.0) | 2 (3)
NR | NR | No | Same investigator throughout study | | Dose, Mode, Schedule: | Race/Ethnicity: | | | | Radiographic Techniques: | | | | C: | 16 sites | NR | 4.9 (1.8) | 4 (7)
Location: | Placebo: | | | | T: SRP plus subgingival irrigation with 2% chlorhexidine solution every 2 weeks for 24 weeks | NR | | | | NR | | | | Change: | | [underlined: Gain] | [underlined: Reduction]
NR (Swedish and US authors) | Yes | | | | C: SRP and saline irrigation, every 2 weeks for 24 weeks | | | | | Microbiological Methods: | | | | T: | | 1.7 (1.3) | 1.7 (1.3) | NR
Patients Selected: | Split-mouth: | | | | | | | | | Subgingival plaque samples (% spirochetes); dark field microscopy | | | | C: | | 0.8 (1.4) | 0.8 (1.4) | NR
Patients with PD ≥ 6 mm demonstrated by attachment loss, BOP, and subgingival calculus | Yes | | | | | | | | | Subject Self Report: | | | | Test: | | ANOVA | ANOVA
| | | | | | | | | | NR | | | | P value: | | NS | NS
Oosterwaal et al., 1991 ^89^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 4 times (at baseline and weeks 4, 12, and 36) | Clinical Measurement: | NR | NR | Type of analysis reported: | Baseline: | | | | | Data on clinical outcomes presented graphically.
Study Period: | RCT | Advanced periodontitis | 2 | Selected pockets got both hand and ultrasonic mechanical (Gracey curettes) debridement. | 10 subjects | Mean: 48 | | | | BOP/SBI | | | Full participants only | T: | 10 (10 sites) | NA | 7.6 (0.7) | NR | Effect of SRP and chlorhexidine gel did not differ from SRP and placebo gel.
36 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Other pockets got SRP 4 weeks later | T: 10 sites | Range: 33 to 62 | | | | PlI | | | | C: | 10 (10 sites) | NA | NR | NR | No differences among groups in PD or % spirochetes after 36 weeks.
Study/Treatment Site: | Random | Single-rooted | NR | Time spent: | C: 10 sites | Gender: | | | | PD | | | | Final: 36 weeks | | | | | Quality Score:
Department of Periodontology, University of Nijmegen | Blinding: | Widman flap: | Assigned to Subjects: | NR | Dose, Mode, Schedule: | Male: 4 | | | | Radiographic Techniques: | | | | T: | 10 (10 sites) | NA | 4.7 (1.0) | NR | 63; 54
Location: | Examiners and patients blind | NR | NR | | T: SRP plus 2% chlorhexidine gel, applied 3 times within 10 minutes after SRP | Female: 6 | | | | NR | | | | C: | 10 (10 sites) | NA | NR | NR
Netherlands | Placebo: | | | | C: SRP with placebo gel applied 3 times with syringe within 10 minutes after SRP | Race/Ethnicity: | | | | Microbiological Methods: | | | | Change:
Patient Population: | Yes | | | | | NR | | | | Subgingival microflora by microscopic and culture studies of plaque samples (% spirochetes, motile rods, non-motile rods) | | | | T: | | NA | NR | NR
Patients referred with 4 interdental pockets of 7 to 9 mm affecting single rooted teeth, BOP, alveolar bone and attachment loss | Split-mouth: | | | | | | | | | Subject Self Report: | | | | C: | | NA | NR | NR
| Yes | | | | | | | | | NR | | | | Test: | | | ANOVA | ANOVA
| | | | | | | | | | | | | | P value: | | | NS | NS
Author and Year: | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | Via questionnaire | Before SRP | 5 times (at baseline, at end of months 1, 2, 4, and 8) | Clinical Measurement: | Yes, subjects rated subjective outcomes (pain, swelling) | NR | Type of analysis reported: | Single-rooted | | | | | At each follow-up visit a statistically significant (P < 0.001) improvement at end of baseline was recorded for PD in both groups. The difference between the Treatment and Control groups were never statistically significant.
Quirynen et al., 2000 ^95^ | NR | Advanced chronic adult periodontitis | 1 | Under local anesthesia, using periodontal curettes, on all pockets within 24 hours. | 24 subjects in relevant | Range: 37 to 69 | | | | GI | | | Full participants only | Baseline: | | | | | All pockets showed a statistically significant gain in CAL over the entire experimental period. Differences between groups were small and insignificant
Study Period: | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent on SRP: | treatment groups | Gender Distribution: | | | | PI | | | | T: | 12 | NR | 6.2 (2.0) | NR | For initial PD ≥ 7 mm, the control group had a 0.3 greater gain in CAL for both single and multi-root teeth
35 weeks (8 months) | Unknown | Single and multi-rooted third molars excluded | NA | Completed during 2 sessions within 24 hours, starting with the lower jaw. | T: 12 subjects | Male: 20 | | | | PD | | | | C: | 12 | NR | 6.2 (1.8) | NR
Site of Study: | Blinding: | Widman flap: | Assigned to Subjects: | | C: 12 subjects | Female: 16 | | | | Gingival recession or over growth | | | | Final: 35 weeks (8 months)
Department of Peridontology of the University Hospital of Catholic University Leuven | NR | NR | Same examiner throughout study | | Dose, Mode, Schedule: | Race/Ethnicity: | | | | CAL | | | | T: | 12 | NR | 4.0 (1.0) | NR
Location: | Placebo: | | | | T: SRP plus 2× during first 24 hours: brush tongue with 1% chlorhexidine gel for 60 sec; rinse mouth 2× with 0.2% chlorhexidine solution for 1 min; spray tonsils 4×/tonsil with 0.2% chlorhexidine spray; subgingival irrigation of pockets 3× within 10 min with 1% chlorhexidine gel. All repeated a third time at day 8. At home for next 2 months: chlorhexidine rinse 2×day and tonsil spray | White: 100% | | | | BOP | | | | C: | 12 | NR | 3.9 (1.5) | NR
Belgium | No | | | | C: SRP alone | | | | | Radiographic Techniques: | | | | Change: | | Gain | Reduction
Patients Selected: | Split-mouth: | | | | | | | | | NR | | | | T: | | NR | 2.2 (1.8) | NR
Patients referred by general dental practitioner with at least 2 multi-rooted teeth and 3 single-rooted teeth in the 1^st^ quadrant and at least 6 sites with PD ≥ 7mm | No | | | | | | | | | Microbiological Methods: | | | | C: | | NR | 2.3 (1.3) | NR
| | | | | | | | | | Differential phase-contrast microscopy (coccoid cells, motile rods, spirochetes and others) | | | | Test: | | | Mann Whitney U
| | | | | | | | | | Subject Self Report: | | | | P value: | | | NS
| | | | | | | | | | Questionnaire | | | | Multi-rooted | | | | | Statistically significant differences in reduction of spirochetes at 8 months (data presented graphically)
| | | | | | | | | | | | | | Baseline: | | | | | Quality Score:
| | | | | | | | | | | | | | T: | 12 | NR | 6.4 (1.9) | NR | 54; 54
| | | | | | | | | | | | | | C: | 12 | NR | 6.6 (1.6) | NR
| | | | | | | | | | | | | | Final: 35 weeks (8 months)
| | | | | | | | | | | | | | T: | 12 | NR | 4.5 (1.4) | NR
| | | | | | | | | | | | | | C: | 12 | NR | 4.2 (1.3) | NR
| | | | | | | | | | | | | | Change: | | Gain | Reduction
| | | | | | | | | | | | | | T: | | NR | 1.9 (1.5) | NR
| | | | | | | | | | | | | | C: | | NR | 2.4 (1.3) | NR
| | | | | | | | | | | | | | Test: | | | Mann Whitney U
| | | | | | | | | | | | | | P value: | | | NS
Reynolds et al., 1992 ^88^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 3 times (at baseline and weeks 2 and 4) | Clinical Measurement: | NR | NR | Type of analysis reported: | Baseline: | | | | | Data in graphic form only.
Study Period: | RCT | Early to moderate adult periodontitis | NR | Entire dentition ultrasonically scaled and irrigated until all supra and subgingival calculus was removed | 60 subjects | Range: 28 to 58 | | | | PlI | | | NR | T: | NR | NA | NR | NR | PD changes were nonsignificantly greater in chlorhexidine 7–9 mm and 4–6 mm PD groups only.
4 weeks (28 days) | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | T: 30 subjects | Gender: | | | | PD | | | | C: | NR | NA | NR | NR | No significant changes in the % spirochetes.
Study/Treatment Site: | Random | NR | NR | 30 to 40 minutes for ultrasonic scaling per subject | C: 30 subjects | Male: 28 | | | | GI | | | | Final: 4 weeks | | | | | Quality Score:
Dental School, University of Maryland | Blinding: | Widman flap: | Assigned to Subjects: | | Dose, Mode, Schedule: | Female: 32 | | | | Radiographic Techniques: | | | | T: | NR | NA | NR | NR | 69; 69
Location: | Examiners and patients blind | NR | NR | | T: SRP plus 200 ml subgingival irrigation with 0.12% chlorhexidine (single episode) | Race/Ethnicity: | | | | NR | | | | C: | NR | NA | NR | NR
USA | Placebo: | | | | C: SRP with placebo, subgingival irrigation with sterile water (single episode) | NR | | | | Microbiological Methods: | | | | Change:
Patient Population: | Yes | | | | | | | | | Plaque microbiota on a subset of 15 subjects (spirochetes and mobile organisms) | | | | T: | NR | NA | NR | NR
New patients | Split-mouth: | | | | | | | | | Cell morphology | | | | C: | NR | NA | NR | NR
| No | | | | | | | | | Dark field microscopy | | | | Test:
| | | | | | | | | | Subject Self Report: | | | | P value:
| | | | | | | | | | NR
Shiloah and Patters 1994 ^54^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 3 times (at baseline, week 1, and month 1) | Clinical Measurement: | NR | NR | Type of analysis reported: | Baseline: | | | | | Data shown graphically.
Study Period: | RCT | Moderate to severe periodontitis | 1 | Thorough SRP of entire dentition performed with ultrasonic scaler and Gracey curets, under local anesthesia | 7 subjects, 1 or 2 teeth per subject | Mean: 47.8 | | | | PlI | | | Full participants only | T: | 12 sites | NR | NR | NA | Although PD decreased significantly (P = 0.0001) no significant difference among the treatment groups was noted (P = 0.67).
4 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | T: 12 sites | Range: 33 to 65 | | | | PD | | | | C: | 12 sites | NR | NR | NA | Attachment loss was reduced by an average 1 mm following therapy. Although CAL decreased significantly (P = 0.0001) no significant difference among treatment groups was noted (P = 0.06).
Study/Treatment Site: | Random sites within subjects | Single and multi-rooted | Standardization Calibration (Gold standard) | 4 to 7 hours per subject over several visits | C: 12 sites | Gender: | | | | CAL | | | | Final: 4 weeks | | | | | Treatment resulted in reduction of 3 target species of 67% at month 1
Graduate Program University Clinic | Blinding: | Widman flap: | Assigned to Subjects: | | Dose, Mode, Schedule: | Male: 2 | | | | GI | | | | T: | 12 sites | NR | NR | NA | Quality Score:
Location: | Examiner blind | NR | Same examiner throughout study | | T: SRP plus irrigation with 0.12% chlorhexidine solution, 2cc/site, 1 aplication | Female: 5 | | | | Gingival fluid flow | | | | C: | 12 sites | NR | NR | NA | 54; 54
USA | Placebo: | | | | C: SRP plus irrigation of pockets with 0.85%, saline, 2cc/site | Race/Ethnicity: | | | | Radiographic Techniques: | | | | Change:
Patient Population: | Yes | | | | | NR | | | | NR | | | | T: | 12 sites | NR | NR | NA
Volunteer adults with PD ≥ 5 mm in non-adjacent sites with ≥ 5 mm PD, attachment loss and presence of target organism | Split-mouth: | | | | | | | | | Microbiological Methods: | | | | C: | 12 sites | NR | NR | NA
| Yes | | | | | | | | | DNA/RNA probe for subgingival flora(A.a., P.g., P.i.) | | | | Test: | | ANOVA | ANOVA
| | | | | | | | | | Subject Self Report: | | | | P value: | | NS | NS
| | | | | | | | | | NR
Soskolne et al., 1997 ^90^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 4 times (at baseline, 1, 3, and 6 months) | Clinical Measurement: | NR | Antibiotic or anti-inflammatory drug use; loss to follow-up, or withdrawal of consent (24) | Type of analysis reported: | Baseline: | | | | | Results show that the treatment of periodontal pockets with chlorhexidine as an adjunct to SRP provides a significantly greater improvement
Study Period: | RCT | Moderate adult periodontitis | 3 (1 at each center) | Full mouth mechanical supra- and subgingival scaling | 118 eligible subjects at baseline | Mean: 47.5 | | | | BOP/SBI | | | All with any follow-up | T: | | NR | 5.99 (0.05 se) | NA | For initial PD ≥ 7 mm: Create CAL gain for treatment group of 0.65 mm, P < 0.001.
26 weeks (6 months) | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | 94 completed | Range: 30 to 65 | | | | PlI | | | | C: | | NR | 6.01 (0.05 se) | NA | Create PD reduction in treatment group of 0.22, P ≤ 0.0001
Study/Treatment Site: | Random to 2 quadrants of the upper jaw | NR | Calibration (gold standard) | ≤1 hour | T: 94 subjects (401 pockets) | Gender: | | | | PD | | | | Final: 26 weeks (6 months) | | | | | Quality Score:
Royal Air Force Base at Halton, UK; Newcastle, UK; Jerusalem, Israel | Blinding: | Widman flap: | Assigned to Subjects: | | C: 94 subjects (412 pockets) | Male: 60 | | | | CAL | | | | T: | 94 (401 pockets) | NR | NR | NA | 62; 54
Location: | Examiners and patients blind | NR | Same examiner throughout study | | Dose, Mode, Schedule: | Female: 58 | | | | GI | | | | C: | 94 (412 pockets) | NR | NR | NA
UK and Israel | Placebo: | | | | T: SRP plus 2.5 mg chlorhexidine chip inserted into each pocket of 5 to 8 mm in designated quadrant at baseline and 3 months if pocket was still 5 to 8mm | Race/Ethnicity: | | | | Staining index | | | | Change: | | [underlined: Gain] | [underlined: Reduction]
Patient Population: | No | | | | C: SRP only | NR | | | | Radiographic Techniques: | | | | T: | 94 (401 pockets) | 0.47 (0.062 se) | 1.16 (0.058 se) | NA
Patients with ≥ 1 PD 5 to 8 mm and BOP in each of 2 maxillary quadrants | Split-mouth: | | | | | | | | | NR | | | | C: | 94 (412 pockets) | 0.31 (0.06 se) | 0.70 (0.056 se) | NA
| Yes | | | | | | | | | Microbiological Methods: | | | | Test: | | MANOVA | MANOVA
| | | | | | | | | | NR | | | | P value: | | < 0.05 | ≤ 0.0001
| | | | | | | | | | Subject Self Report:
| | | | | | | | | | NR
Southard et al., 1989 ^86^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 5 times (at baseline and weeks 5, 7, 11, and 15) | Clinical Measurement: | NR | NR | Type of analysis reported: | Baseline: | | | | | No significant treatment effects
Study Period: | RCT | Moderate periodontitis | 2 | 2 assigned quadrants received SRP. Anesthesized by standard nerve blocks or local infiltration techniques. | 8 subjects | Range: 35 to 65 | | | | PlI | | | Full participants only | T: | 8 | 14.4 (NR) | 6.6 (NR) | NA | B.g. was significantly reduced only in treatment group vs control (P < 0.01) but did not extend to the 15^th^ week
15 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Areas were debrided by hand with a Gracey curette until the root was deemed smooth by tactile sensation with a periodontal probe | T: 16 sites | Gender: | | | | PD | | | | C: | 8 | 13.6 (NR) | 6.3 (NR) | NA | Quality Score:
Study/Treatment Site: | Randomized 4 quadrant design | Posterior | NR | Time spent: | C: 16 sites | Male: 4 | | | | CAL | | | | Final: 15 weeks | | | | | 54; 38
Department of Periodontics, School of Dentistry, University of Missouri | Blinding: | Widman flap: | Assigned to Subjects: | NR | Dose, Mode, Schedule: | Female: 4 | | | | GI | | | | T: | 8 | 12.7 (NR) | 4.2 (NR) | NA
Location: | Examiners and patients blind | NR | Same clinician performed all treatments, while a 2^nd^ examiner measured all clinical parameters | | T: SRP plus irrigation with 2% chlorhexidine at baseline and weeks 1, 2, and 3 on all teeth in quadrant | Race/Ethnicity: | | | | Bleeding tendency | | | | C: | 8 | 12.0 (NR) | 3.8 (NR) | NA
Kansas City, MO | Placebo: | | | | C: SRP only | NR | | | | Radiographic Techniques: | | | | Change: | | [underlined: Gain] | [underlined: Reduction]
Patient Population: | No | | | | | | | | | NR | | | | T: | | 1.7 (NR) | 2.4* (NR) | NA
Volunteer patients with at least 1 site with PD ≥ 6 mm and BOP in each quadrant | Split-mouth: | | | | | | | | | Microbiological Methods: | | | | C: | | 1.6 (NR) | 2.5* (NR) | NA
| Yes | | | | | | | | | B.g. plaque sample, fluorescent antibody reagent, fluorescent microscope | | | | Test: | | Newman Keuls | Newman Keuls
| | | | | | | | | | Subject Self Report: | | | | P value: | | NS | NS
| | | | | | | | | | NR
Taggart et al., 1990 ^87^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 4 times (at baseline and weeks 2, 6, and 10) | Clinical Measurement: | NR | NR | Type of analysis reported: | Baseline: | | | | | Chlorhexidine has a slight adjunctive effect in the reduction of pocket depth but not significant
Study Period: | NR | Moderate to advanced chronic periodontitis | NR | Instrumentation on test and control quadrants with an ultrasonic handpiece scaler, under local anesthesia, until the subgingival root surfaces were considered sufficiently smooth | 10 subjects | Range: 28 to 51 | | | | SBI | | | Full participants only | T: | 10 (10 sites) | NR | 3.5 (0.6) | 24.9 (12.4) | Quality Score:
10 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | 2 sites per subject | Gender: | | | | PlI | | | | C: | 10 (10 sites) | NR | 3.4 (0.5) | 23.3 (14) | 46; 46
Study/Treatment Site: | Random assigned to upper quadrants | Upper quadrants, no third molars or central incisors | NR | NR | T: 10 sites | Male: 3 | | | | PD | | | | Final: 10 weeks
Health Department Clinic (Department of Periodontology and Preventive Dentistry, United Medical and Dental schools of Guy's and St. Thomas' Hospitals | Blinding: | Widman flap: | Assigned to Subjects: | | C: 10 sites | Female: 7 | | | | CAL | | | | T: | NR | NR | 2.6 (0.3) | 9.6 (14.7)
Location: | NR | NR | NR | | Dose, Mode, Schedule: | Race/Ethnicity: | | | | Radiographic Techniques: | | | | C: | NR | NR | 2.6 (0.7) | 13.1 (15.3)
London, England | Placebo: | | | | T: SRP plus irrigation with 0.02% chlorhexidine once during scaling | NR | | | | NR | | | | Change: | | [underlined: Gain] | [underlined: Reduction]
Patient Population: | Yes | | | | C: SRP with placebo (irrigation with water once during scaling) | | | | | Microbiological Methods: | | | | T: | NR | 0.5 (1.1 se) | 0.9 (NR) | 15.3* (NR)
Patients with with chronic PD involving both sides of the jaw to a similar extent; at least 1 pair of pockets 4 to 6–7 mm (or above) in contra-lateral quadrants and radiographic evidence of bone loss | Split-mouth: | | | | | | | | | Plaque microbiota (cocci, spirochetes, motile rods and other rod forms), dark field microscopy | | | | C: | NR | 0.4 (1.0 se) | 0.8 (NR) | 16.2* (NR)
| Yes | | | | | | | | | Subject Self Report: | | | | Test: | | NR | ANOVA | ANOVA
| | | | | | | | | | NR | | | | P value: | | NS | NS | NS
Unsal et al., 1994 ^59^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | Yes | NR | 2 times (at baseline and week 12) | Clinical Measurement: | NR | NR | Type of analysis reported: | Baseline: | | | | | No statistically significant differences were found in the reduction of the probing depths or gains in attachment level between the treatment groups
Study Period: | RCT | Moderate to advanced adult periodontitis | NR | Mechanical debridement by hand with Gracey curettes and ultrasonic scaling and root planing in pockets > 4 mm | 22 subjects invited | Mean: 42 | | | | Bleeding index | | | Intent to treat | T: | 7 (99 sites) | 4.03 (1.50) | 4.90 (1.11) | NA | Quality Score:
12 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | 15 enrolled | Range: 30 to 57 | | | | PlI | | | | C: | 8 (110 sites) | 3.66 (1.22) | 5.14 (1.45) | NA | 46; 46
Study/Treatment Site: | Random | NR | NR | NR | T: 7 subjects (97 sites) | Gender: | | | | PD | | | | Final: 12 weeks
Department of Peridontology, Faculty of Dentistry | Blinding: | Widman flap: | Assigned to Subjects: | | C: 8 subjects (110 sites) | Male: 10 | | | | CAL | | | | T: | 7 | 3.33 (1.76) | 3.32 (1.01) | NA
Location: | NR | NR | NR | | Dose, Mode, Schedule: | Female: 12 | | | | GI | | | | C: | 8 | 2.62 (1.24) | 3.32 (0.73) | NA
University of Ankara, Turkey | Placebo: | | | | T: SRP plus 1% chlorhexidine gel applied once | Race/Ethnicity: | | | | Position of gingival margin | | | | Change:
Patient Population: | No | | | | C: SRP only | NR | | | | Radiographic Techniques: | | | | T: | | 1.04 (0.16) | 1.58 (0.96) | NA
Adult patients with at least 3 teeth in each quadrant having 2 sites with a PD of ≥ 4 mm and radiographic evidence of bone loss | Split-mouth: | | | | | | | | | NR | | | | C: | | 0.70 (1.09) | 1.83 (0.54) | NA
| No | | | | | | | | | Microbiological Methods: | | | | Test: | | ANOVA | ANOVA
| | | | | | | | | | NR | | | | P value: | | NS | NS
| | | | | | | | | | Subject Self Report:
| | | | | | | | | | NR
Watts and Newman, 1986 ^84^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 4 times (at baseline and days 28, 56, and 84) | Clinical Measurement: | No injuries or staining noted | NR | Type of analysis reported: | Baseline: | | | | | No significant added benefit with 0.02% chlorhexidine was apparent. Data presented graphically.
Study Period: | RCT | Chronic periodontitis | NR | Supra and subgingival scaling and root planing of the test sites, reduction of any overhanging restorations that were present and full mouth polishing using a rubber cup | 11 subjects | Mean: 39 | | | | SBI | | | Full participants only. | T: | 5 (128 sites) | NA | 6.1 (NR) | NA | Chi Square of PD reduction = 4.9
12 weeks (84 days) | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | 262 sites | Range: | | | | PlI | | | Sites less than 5 mm PD were eliminated prior to the next visit. | C: | 6 (134 sites) | NA | 5.9 (NR) | NA | Quality Score:
Study/Treatment Site: | Random | NR | NR | NR | T: 5 pockets (128 sites) | T: 26 to 49 | | | | PD | | | | Final: 12 weeks | | | | | 46; 46
Eastman Dental Hospital | Blinding: | Widman flap: | Assigned to Subjects: | | C: 6 pockets (134 sites) | C: 34 to 48 | | | | Radiographic Techniques: | | | | T: | NR | NA | NR | NA
Location: | Examiners and patients blind | NR | NR | | Dose, Mode, Schedule: | Gender: | | | | NR | | | | C: | NR | NA | NR | NA
UK | Placebo: | | | | T: SRP plus irrigation with 0.02% chlorhexidine 1×day for 28 days | Male: | | | | Microbiological Methods: | | | | Change:
Patient Population: | Yes | | | | C: SRP with 0.01% quinine sulphate (placebo) irrigation 1×day for 28 days | T: 3 | | | | NR | | | | T: | | NA | NR | NA
Adult patients referred for periodontal treatment with PD ≥ 5 mm and radiographic evidence of bone loss | Split-mouth: | | | | | C: 1 | | | | Subject Self Report: | | | | C: | | NA | NR | NA
| No | | | | | Female: | | | | Found the procedure pleasant | | | | Test: | | | Chi Square
| | | | | | T: 2 | | | | | | | | P value: | | | NS
| | | | | | C: 5
| | | | | | Race/Ethnicity:
| | | | | | NR
Wennström et al., 1987 ^85^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 3 times (at baseline and weeks 40 and 52) | Clinical Measurement: | NR | NR | Type of analysis reported: | Baseline: | | | | | Results are presented in terms of percentage of sites
Study Period: | RCT | Moderate to severe periodontal disease | 1 | Subgingival mechanical debridement of entire dentition at week 32 of study | 10 subjects | Mean: 43.1 | | | 52 week study, SRP and treatment at week 32 | BOP/SBI | | | Full participants only | T: | | NR | 6.7 (NR) | NA | Quality Score:
52 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | T: 28 sites | Range: 22 to 61 | | | | PlI | | | | C: | | NR | 6.9 (NR) | NA | 46; 46
Study/Treatment Site: | Random assignment of quadrants | NR | NA | 6 visits during 6 weeks | C: 24 sites | Gender: | | | | PD | | | | Final: 52 weeks
Graduate Program, Department of Periodontology, University Clinic | Blinding: | Widman flap: | Assigned to Subjects: | | Dose, Mode, Schedule: | NR | | | | CAL | | | | T: | | NR | 4.8 (NR) | NA
Location: | Examiners blind | NR | Same examiner throughout study | | All subjects received professional tooth cleaning every 4 weeks | Race/Ethnicity: | | | | GI | | | | C: | | NR | 5.1 (NR) | NA
Sweden | Placebo: | | | | T: SRP plus irrigation with 0.2% chlorhexidine 3×week | NR | | | | Radiographic Techniques: | | | | Change: | | [underlined: Gain] | [underlined: Reduction]
Patient Population: | Yes | | | | C: SRP plus irrigation with saline 3×week | | | | | Bone Loss/Regeneration | | | | T: | 28 sites | 0.6 (0.4) | 1.9* (NR) | NA
Patients with PD ≥ 6 mm and BOP selected from the waiting list | Split-mouth: | | | | | | | | | Microbiological Methods: | | | | C: | 24 sites | 0.7 (0.5) | 1.8* (NR) | NA
| Yes | | | | | | | | | Crevicular fluid microbiota | | | | Test: | | Paired t-test | NR
| | | | | | | | | | Subject Self Report: | | | | P value: | | NS | NR
| | | | | | | | | | NR

Evidence Table 6a. Effectiveness of Other Systemic Antibiotics as an Adjunct to Scaling and Root Planing to Treat Chronic Periodontitis

Study Description | Study Design Characteristics | Disease Characteristics | Examiner Characteristics | Description of Scaling and Root Planing | Eligible Study Groups and How Defined: | Study Group Characteristics | Compliance Monitoring | Baseline Measures | Assessment Time Interval(s) | Outcomes Assessed | Adverse Effects | Study Group Attrition and Reasons | Type of Analysis | Outcomes Accessed
| | | | | | | | | | | | | | (N of Pts) | | Attachment Level mm [image] (SD) | Probing Depth mm [image] (SD) | Spirochetes [image]% (SD) | Comments
Bain et al., 1994 ^97^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | Bottle check at 2 week visit for a count of unusued medication | Before SRP | 5 times (at baseline and weeks 2, 8, 12, 24) | Clinical Measurement: | Two subjects | Adverse events (4) | Type of analysis reported: | Baseline: | | | | | Attachment level measurements were consistently slightly lower in the drug group, this was only statistically significant at the 12 week interval
Study Period: | RCT | Advanced chronic peridontitis | 7 (1 per center) | Thorough scaling and root planing | 193 started | Mean: | | | | BOP/SBI | (1 from each group) terminated due to periodontal symptoms and 2 (both spiramycin subjects) due to emergent signs (gastro-intestinal upset, abdominal pain, diarrhea) | | Full participants only | T: | 93 | 10.72 (0.15 se) | 7.6 (0.08 se) | NA | (P=0.0146)
24 weeks (6 months) | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | 189 completed | T: 47.3 ± 1.0 | | | | PlI | | | | C: | 96 | 10.69 (0.16 se) | 7.53 (0.08 se) | NA | Quality Score:
Study/Treatment Site: | Random | NR | NR | 3 to 5 hours during the 2 weeks of drug therapy | T: 93 subjects | C: 48.5 ± 1.2 | | | | PD | | | | Final: 24 weeks | | | | | 85; 85
7 dental faculties at Canadian Universities | Blinding: | Widman flap: | Assigned to Subjects: | | C: 96 subjects | Gender: | | | | CAL | | | | T: | 93 | 8.85 (0.16 se) | 4.73 (0.11 se) | NA
Location: | Examiner and patients blind | NR | NR | | Dose, Mode, Schedule: | NR | | | | GCF | | | | C: | 96 | 9.11 (0.19 se) | 5.13 (0.14 se) | NA
Canada | Placebo: | | | | T: SRP plus 1,500,000 IU of spiramycin (“500” capsules), 2×day, for 14 days | Race/Ethnicity: | | | | Radiographic Techniques: | | | | Change:
Patient Popultion: | Yes | | | | C: SRP plus placebo 2×day for 14 days | NR | | | | NR | | | | T: | | 1.87* (NR) | 2.87* (NR) | NA
Patients ≥ 15 teeth and ≥ 2 sites in interproximal areas with PD ≥ 7 mm and a contacting adjacent tooth; radiographic evidence of bone loss | Spilt-mouth: | | | | | | | | | Microbiological Methods: | | | | C: | | 1.58* (NR) | 2.40* (NR) | NA
| No | | | | | | | | | Crevicular fluid microbiota | | | | Test: | | ANOVA | ANOVA
| | | | | | | | | | Subject Self Report: | | | | P value: | | NS | < 0.0075
| | | | | | | | | | NR
Haffajee et al., 1995 ^46^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NR | Before SRP | 6 times (at baseline and 2, 4, 6, 8, and 10 months) | Clinical Measurement: | NR | NR | Type of analysis reported: | Baseline: | | | | | Only baseline values presented in table. Change score mostly presented in bar graphs. Text presents change scores for PD, but not the associated SDs.
Study Period: | RCT | NR | 1 | Scaling and root planing by quadrant, approximate 10 day intervals, repeated during course of study every 3 months for 1 yr | 21 subjects, 6 sites per tooth | Mean All: 48 ± 12 | | | | BOP/SBI | | | Mann-Whitney and Kruskal-Wallis, change by site, averaged for individual, then averaged for group | T: | 13 | 4.2 (1.3) | 4.1 (0.8) | NA | Quality Score:
43 weeks (10 months) | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent on SRP: | T: 10 subjects | Mean T: 44 ± 15 | | | | PD | | | Subject is unit of analysis | C: | 11 | 3.5 (1.2) | 3.6 (0.5) | NA | 62; 46
Study/Treatment Site: | Random | All excluding third molars | NA | NR | C: 11 subjects | Mean C: 48 ± 11 | | | | CAL | | | | Final: 43 weeks (10 months)
Hospital Dental Clinic | Blinding: | Widman flap: | Assigned to Subjects: | | Dose, Mode, Schedule: | Gender: | | | | GI | | | | T: | 13 | NR | NR | NA
Location: | Examiners and patients blind | Yes, at active sites and where | Same examiner throughout study | | All rinsed with 0.12% chlorhexidine for 30 days | All: 57% Male | | | | Radiographic Techniques: | | | | C: | 11 | NR | NR | NA
USA | Placebo: | PD > 4mm | | | T: SRP plus 250 mg amoxicillin and 125 mg clavulanic acid 3×day for 30 days | T: 62% Male | | | | NR | | | | Change: | | [underlined: Gain] | [underlined: Reduction]
Patients Selected: | Yes | | | | C: SRP plus placebo (250 mg sucrose) 3×day for 30 days | C: 55% Male | | | | Microbiological Methods: | | | | T: | | 0.68 (NR) | 0.75 (NR) | NA
Originally 98 patients aged 14–71 with evidence of prior attachment loss, at least 20 teeth and at least 4 pockets >4 mm and 4 sites of LOA >3mm, no localized JP, no rapidly progressing PD. From this pool, subjects exhibiting LOA >2.5 mm at ≥ 1 sites anytime during 6 months observation period were admitted to study | Spilt-mouth: | | | | | Race/Ethnicity: | | | | DNA probes and colony lifts for 14 taxa in 29 of 40 subjects | | | | C: | | NR | 0.46 (NR) | NA
| No | | | | | NR | | | | Subject Self Report: | | | | Test: | | Mann Whitney Test | Mann Whitney Test
| | | | | | | | | | NR | | | | P value: | | < 0.01 | NS
Ng and Bissada, 1998 ^98^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: (For full study) | Compliance with drug intake was reinforced verbally at each appointment | Before SRP | 5 times (at baseline and weeks 3, 6, 12, and 24) | Clinical Measurement: | Adverse effects collected but none reported | None left study | Type of analysis reported: | Baseline: | | | | | Doxycycline resulted in a statistically significant, yet modest, clinical improvement over placebo
Study Period: | RCT | Generalized moderate adult periodontitis | 1 | Ultrasonic and hand SRP in 1 session, under local anesthesia, only half mouth received SRP | 16 subjects | Range: 32 to 72 | | | | PlI | | | Full participants only | T: | 8 | 7.8 (1.2) | 4.3 (0.9) | NA | Quality Score:
24 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | T: 8 subjects | Gender: (For full study) | | | | PD | | | | C: | 8 | 9.0 (1.9) | 4.3 (0.9) | NA | 62; 77
Study/Treatment Site: | Random | NR | NR | NR | C: 8 subjects | Male: 18 | | | | CAL | | | | Final: 24 weeks
NR | Blinding: | Widman flap: | Assigned to Subjects: | | Dose, Mode, Schedule: | Female: 14 | | | | GI | | | | T: | 8 | 7.4 (0.5) | 4.6 (0.4) | NA
Location: | Examiners blind | NR | Same examiner throughout study | | T: SRP plus 200 mg doxycycline first day then 100 mg 1×day for 6 weeks | Race/Ethnicity: | | | | Radiographic Techniques: | | | | C: | 8 | 9.9 (0.8) | 4.0 (0.6) | NA
USA | Placebo: | | | | C: SRP with placebo (capsules orally 1 daily) | NR | | | | Periapical radiographs using paralleling x-ray technique | | | | Change:
Patient Popultion: | Yes | | | | | | | | | Microbiological Methods: | | | | T: | | 0.4* (NR) | -0.3* (NR) | NA
Patients with generalized periodontitis and having at least 2 teeth with ≥ 5 mm probing depth | Spilt-mouth: | | | | | | | | | NR | | | | C: | | -0.9* (NR) | 0.3* (NR) | NA
| Yes | | | | | | | | | Subject Self Report: | | | | Test: | | ANOVA | ANOVA
| | | | | | | | | | NR | | | | P value: | | ≤ 0.05 | NS
Al-Joburi et al., 1989 ^45^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | Yes | Before SRP | 5 times (at baseline and weeks 2, 8, 12, and 24) | Clinical Measurement: | Yes, 1 subject excluded because of nausea | 17 subjects excluded: intercurrent but unrelated illness during the study which required taking antibiotics other than study medication (1); loss to follow-up (3); failed to take medication as prescribed (6); developed severe diarrhea (1) | Type of analysis reported: | PD 1 to 3 mm: | | | | | Despite intensive SRP, the additional use of an antibiotic resulted in a significantly greater reduction in spirochete level at the 2, 8 and 24 week visits
Study Period: | RCT | Advanced adult chronic | 2 (1 at each site) | Thorough scaling and root planing (intensive) completed in 2 visits, one week apart | 96 started full study | Mean: 46 ± 0.9 | | | | BOP/SBI | | | Full participants only | Baseline: | | | | | There were no significant intergroup differences in CAL or PD at 24 weeks
24 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | 52 completed relevant treatments | Gender: | | | | PlI | | | | T: | 28 | 7.29 (0.57) | 3.00 (0.00) | 28 (NR) | Quality Score:
Study/Treatment Site: | Random | NR | NR | 6 hours | 2 interproximal sites per subject | NR | | | | PD | | | | C: | 24 | 7.50 (0.84) | 3.00 (0.35) | 30 (NR) | 69; 69
Several Universities | Blinding: | Widman flap: | Assigned to Subjects: | | T: 28 subjects | Race/Ethnicity: | | | | CAL | | | | Final: 24 weeks
Location: | Examiners and patients blind | NR | Same examiner throughout study | | C: 24 subjects | NR | | | | Radiographic Techniques: | | | | T: | | 6.67 (0.67) | 2.58 (0.34) | 3 (NR)
Canada | Placebo: | | | | Dose, Mode, Schedule: | | | | | NR | | | | C: | | 7.80 (0.82) | 3:00 (0.16) | 11 (NR)
Patient Popultion: | Yes | | | | T: SRP plus 500 mg spiramycin 2×day for 14 days | | | | | Microbiological Methods: | | | | Change:
Patients at least 35 years old with at least ≥ 2 sites with probing depth ≥ 7 mm and at least 15 teeth | Spilt-mouth: | | | | C: SRP plus placebo, 1 capsule 2×day for 14 days | | | | | Crevicular fluid microbiota | | | | T: | | 0.62* (NR) | 0.42* (NR) | NR
| No | | | | | | | | | Plaque microbiota | | | | C: | | -0.30* (NR) | 0.00* (NR) | NR
| | | | | | | | | | Subject Self Report: | | | | Test: | | NR | NR | NR
| | | | | | | | | | NR | | | | P value: | | NS | NS | Sig
| | | | | | | | | | | | | | [underlined: PD 4 to 6 mm:]
| | | | | | | | | | | | | | Baseline:
| | | | | | | | | | | | | | T: | | 9.11 (0.27) | 5.26 (0.11)
| | | | | | | | | | | | | | C: | | 9.11 (0.22) | 5.25 (0.08)
| | | | | | | | | | | | | | Final:
| | | | | | | | | | | | | | T: | | 8.31 (0.30) | 3.94 (0.20)
| | | | | | | | | | | | | | C: | | 8.09 (0.21) | 3.53 (0.12)
| | | | | | | | | | | | | | Change:
| | | | | | | | | | | | | | T: | | 0.80* (NR) | 1.32* (NR)
| | | | | | | | | | | | | | C: | | 1.02* (NR) | 1.72* (NR)
| | | | | | | | | | | | | | Test: | | NR | NR
| | | | | | | | | | | | | | P value: | | NS | NS
| | | | | | | | | | | | | | [underlined: PD > 7 mm:]
| | | | | | | | | | | | | | Baseline:
| | | | | | | | | | | | | | T: | | 10.60 (0.27) | 7.49 (0.13)
| | | | | | | | | | | | | | C: | | 10.75 (0.29) | 7.60 (0.17)
| | | | | | | | | | | | | | Final:
| | | | | | | | | | | | | | T: | | 9.14 (0.26) | 4.92 (0.21)
| | | | | | | | | | | | | | C: | | 9.21 (0.34) | 4.75 (0.24)
| | | | | | | | | | | | | | Change:
| | | | | | | | | | | | | | T: | | 0.46* (NR) | 2.57* (NR)
| | | | | | | | | | | | | | C: | | 1.54* (NR) | 2.85* (NR)
| | | | | | | | | | | | | | Test: | | NR | NR
| | | | | | | | | | | | | | P value: | | NS | NS
Chin Quee et al., 1987 ^96^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NR | Before SRP | 8 times (at baseline, 14 days, and months 1, 2, 3, 4, 5, and 6) | Clinical Measurement: | Yes, only significant difference was 4 in treatment group had diarrhea in second week, did not mention others (by means of questionnaire) | Lost to follow-up (6) | Type of analysis reported: | Baseline: | | | | | The adjunctive use of this treatment resulted in a significant increase in attachment level as well as a significant decrease in the proportion of spirochetes, and both of these changes were sustained until the end of the study. Data presented graphically
Study Period: | RCT | Advanced periodontitis | 2 | Thorough SRP, 2 sessions of 3 hours each, one week apart | 56 subjects recruited (2 sites/person) | Mean: 4 | | | | PlI | | | Full participants only | T: | 26 | NR | NR | 40 (NR) | No significant intergroup differences at any time interval for PD
26 weeks (6 months) | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | 50 completed | T: 42 ± 1.41 | | | | GI | | | | C: | 24 | NR | NR | 45 (NR) | Quality Score:
Study/Treatment Site: | Random | NR | Standardization (practice on subjects before study began) | 6 hours | T: 26 subjects | C: 46 ± 1.33 | | | | PD | | | | Final: 26 weeks | | | | | 54; 54
NR | Blinding: | Widman flap: | Assigned to Subjects: | | C: 24 subjects | Gender: | | | | CAL | | | | T: | 26 | NR | NR | 3.0 (NR)
Location: | Examiners and patients blind | NR | Same examiner throughout study | | Dose, Mode, Schedule: | No sig difference between groups | | | | Radiographic Techniques: | | | | C: | 24 | NR | NR | 15.0 (NR)
NR | Placebo: | | | | T: SRP plus 3 tablets (750,000 IUs spiramycin and 125 mg metronidazole) 2×day for 14 days | Race/Ethnicity: | | | | NR | | | | Change:
Patient Popultion: | Yes | | | | C: SRP and placebo, 3 tablets 2×day for 14 days | No sig difference between groups | | | | Microbiological Methods: | | | | T: | | NR | NR | NR
Patients over 35 years old with ≥ 2 sites with PD ≥ 7mm and at least 15 teeth | Spilt-mouth: | | | | | | | | | Subgingival bacteria (cocoid cells, motile cells, spirochetes and other cells), dark field microscopy | | | | C: | | NR | NR | NR
| No | | | | | | | | | Subject Self Report: | | | | Test: | | ANOVA | ANOVA | ANOVA
| | | | | | | | | | NR | | | | P value: | | <0.05 | NS | <0.05
Rooney et al., 2002 ^70^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NR | Before SRP | 4 times (at baseline, and months 1, 3, and 6) | Clinical Measurement: | None | 66 recruited for full study; 4 were lost: | Type of analysis reported: | Baseline: | | | | | Presented as % of sites with low (0–3 mm) or high (≥ 6 mm), not in actual mm measurements or changes.
Study Period: | RCT | Advanced chronic periodontal disease | 2 | Quadrant root planings under local anesthesia with ultrasonic scaler and Gracey curettes. SRP done by 2 experienced periodontists. | 31 subjects | Range: 20 to 45 | | | | PD | | lacked one month data (1); lacked 3 month data (1); had no 6 month data (3); no 3 and 6 month data (2); unable to determine which treatment groups the 4 were assigned to | Full participants only | T: | NR | NR | NR | NA | Differences in PD and CAL treatment effects were significantly greater in the treatment group than in the control.
26 weeks (6 months) | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent on SRP: | T: 16 subjects | Gender Distribution: | | | | CAL | | | | C: | NR | NR | NR | NA | Microbiological data showed significant difference for treatment group versus control only at 1 month and not at months 3 and 6.
Site of Study: | Random | All but 3^rd^ molars and severely malpositioned teeth | NR | 45 minutes for all teeth in quadrant; SRPs separated by maximum of 12 days, usually 7 days. | C: 15 subjects | NR | | | | BOP | | | | Final: 26 weeks | | | | | Quality Score:
Department of Perodontology, Bristol Dental School and Hospital | Blinding: | Widman flap: | Assigned to Patients: | | Dose, Mode, Schedule: | Race/Ethnicity: | | | | Presence of Suppuration | | | | T: | 16 | NR | NR | NA | 69; 54
Location: | Examiners and patients blind | NR | Same clinician provided treatment throughout study | | All received 0.2% chlorhexidine mouthrinse (10ml, 60s) 2×day until 1 week after non-surgical therapy | NR | | | | Plaque deposits | | | | C: | 15 | NR | NR | NA
UK | Placebo: | | | | T: SRP plus 250 mg amoxicillin+ placebo (calcium lactate tablets) 3×day for 7 days | | | | | Radiographic Techniques: | | | | Change:
Patients Selected: | Yes | | | | C: SRP plus placebo (lactose capsules and calcium lactate tablets) 3×day for 7 days | | | | | NR | | | | T: | | NR | NR | NA
Patients <46 years old referred by practitioners who had failed to respond to non-surgical periodontal treatment with PD ≥ 6 mm and BOP. | Spilt-mouth: | | | | | | | | | Microbiological Methods: | | | | C: | | NR | NR | NA
| Yes, for microbiotic samples, 1 in each quadrant | | | | | | | | | Following incubation, anaerobic counts from agar plates for P.g., P.i., A..a., and others | | | | Test | | ANCOVA | ANCOVA
| | | | | | | | | | Patient Self Report: | | | | P-value | | ≤ 0.05 | ≤ 0.001
| | | | | | | | | | NR
Smith et al., 2002 ^99^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NR | Before SRP | 7 times (at baseline and weeks 1, 2, 3, 6, 10, and 22) | Clinical Measurement: | None reported | tooth extraction (1), and failure to take medication (1) | Type of analysis reported: | PD ≥ 6 mm | | | | | Deep pockets (6mm) showed statistical significant difference
Study Period: | RCT | Periodontitis in adults | 1 | By hand by one hygienist, minor scaling and polishing at weeks 6, 10, and 22 | 44 subjects completed study | Mean: 42.68 | | | | BOP/SBI | | | Full participants only | Baseline: | | | | | (P < 0.05) starting at week 6
22 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | T: 23 subjects | Gender: | | | | PlI | | | | T: | 23 | NA | 6.76 (NR) | NA | Across all sites: Analysis of covariance test shows that the difference between 2 study groups is insignificant at baseline and it is significant
Study/Treatment Site: | Random | Rumfjord teeth: 16, 21, 24, 36, 41, and 44 | NA | NR | C: 21 subjects | Male: 21 | | | | PD | | | | C: | 21 | NA | 6.76 (NR) | NA | (P < 0.02) at week 22
The Royal London Hospital | Blinding: | Widman flap: | Assigned to Subjects: | | Dose, Mode, Schedule: | Female: 23 | | | | Calculus to bleeding Ind | | | | Final: 22 weeks
Location: | Examiners and patients blind | NR | Same examiner throughout study | | T: SRP plus 500 mg azithromycin 1×day for 3 days at week 2 | Race/Ethnicity: | | | | Radiographic Techniques: | | | | T: | | NA | 3.67 (NR) | NA
London, UK | Placebo: | | | | C: SRP with placebo | NR | | | | NR | | | | C: | | NA | 4.54 (NR) | NA
Patient Popultion: | Yes | | | | | | | | | Microbiological Methods: | | | | Change:
Adult patients referred to clinic with ≥ 2 sextants with CPITN scores of 4 and at least 20 remaining teeth | Spilt-mouth: | | | | | | | | | Crevicular fluid microbiota | | | | T: | | NA | 3.09* (NR) | NA
| No | | | | | | | | | Subject Self Report: | | | | C: | | NA | 2.22* (NR) | NA
| | | | | | | | | | NR | | | | Test: | | | ANCOVA
| | | | | | | | | | | | | | P value: | | | < 0.05
| | | | | | | | | | | | | | PD 4 – 5 mm | | | | | Moderate pockets (4–5mm) demonstrated significant difference between groups starting at week 6
| | | | | | | | | | | | | | Baseline:
| | | | | | | | | | | | | | T: | 23 | NA | 4.58 (NR) | NA
| | | | | | | | | | | | | | C: | 21 | NA | 4.58 (NR) | NA
| | | | | | | | | | | | | | Final: 22 weeks
| | | | | | | | | | | | | | T: | | NA | 2.79 (NR) | NA
| | | | | | | | | | | | | | C: | | NA | 3.31 (NR) | NA
| | | | | | | | | | | | | | Change:
| | | | | | | | | | | | | | T: | | NA | 1.79* (NR) | NA
| | | | | | | | | | | | | | C: | | NA | 1.27* (NR) | NA
| | | | | | | | | | | | | | Test: | | | ANCOVA
| | | | | | | | | | | | | | P value: | | | < 0.01
| | | | | | | | | | | | | | PD 1 – 3 mm | | | | | Shallow pockets (1–3mm) was statistically different between 2 study groups at week 6 only
| | | | | | | | | | | | | | Baseline: | | | | | Quality Score:
| | | | | | | | | | | | | | T: | 23 | NA | 2.35 (NR) | NA | 69; 54
| | | | | | | | | | | | | | C: | 21 | NA | 2.35 (NR) | NA
| | | | | | | | | | | | | | Final: 22 weeks
| | | | | | | | | | | | | | T: | | NA | 1.94 (NR) | NA
| | | | | | | | | | | | | | C: | | NA | 2.08 (NR) | NA
| | | | | | | | | | | | | | Change:
| | | | | | | | | | | | | | T: | | NA | 0.41* (NR) | NA
| | | | | | | | | | | | | | C: | | NA | 0.27* (NR) | NA
| | | | | | | | | | | | | | Test: | | | ANCOVA
| | | | | | | | | | | | | | P value: | | | NS

Evidence Table 6b. Effectiveness of Other Local Antibiotics as an Adjunct to Scaling and Root Planing to Treat Chronic Periodontitis

Study Description | Study Design Characteristics | Disease Characteristics | Examiner Characteristics | Description of Scaling and Root Planing | Eligible Study Groups and How Defined: | Study Group Characteristics | Compliance Monitoring | Baseline Measures | Assessment Time Interval(s) | Outcomes Assessed | Adverse Effects | Study Group Attrition and Reasons | Type of Analysis | Outcomes Accessed
| | | | | | | | | | | | | | (N of Pts) | | Attachment Level mm [image] (SD) | Probing Depth mm [image] (SD) | Spirochetes [image]% (SD) | Comments
Eickholz et al., 2002 ^101^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP, but PD measured after scaling | 3 times (at baseline and months 3 and 6) | Clinical Measurement: | Yes, “minor complications” | One singular inflammation 2 months after application of treatment gel | Type of analysis reported: | Baseline: | | | | | Adjunctive topical subgingival application of a biodegradable doxycycline gel provided more favorable CAL gain and PD reduction than SRP alone and placebo
Study Period: | RCT | Untreated or recurrent moderate to severe periodontitis | 6 | On all test teeth and the respective neighboring teeth by hand under local anesthesia | 111 started | Mean: 49 ± 9 | | | | BOP/SBI | | | Intent to treat | T: | NR | 9.15 (1.99 se) | 7.33 (1.55 se) | NA | Pairwise comparisons of PD at 6 months resulted in a 0.44 (1.67 se) greater reduction (P = 0.0066) in doxycycline group versus placebo. For CAL it was 0.37 (1.84 se) at 6 months in favor of doxycycline (P = 0.038)
26 weeks (6 months) | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | 108 completed | Range: 23 to 71 | | | | PlI | | | | C: | NR | 9.13 (2.17 se) | 7.33 (1.57 se) | NA | Quality Score:
Study/Treatment Site: | Random | Both, non-adjacent teeth | NR | 10 minutes per tooth | T: 108 sites | Gender: | | | | PD | | | | Final: 26 weeks | | | | | 92; 92
3 Graduate Program University Clinics and Centers | Blinding: | Widman flap: | Assigned to Subjects: | | C: 108 sites | Male: 42 | | | | CAL (vertical relative attachment level) | | | | T: | | NR | NR | NA
Location: | Examiners and patients blind | NR | One examiner for baseline; a different examiner for all of remaining assessment | | Dose, Mode, Schedule: | Female: 69 | | | | GI | | | | C: | | NR | NR | NA
Heidelberg and Frankfurt, Germany and Njmegen, Netherlands | Placebo: | | | | T: SRP plus 15% doxycycline gel, subgingival application | Race/Ethnicity: | | | | Radiographic Techniques: | | | | Change: | | [underlined: Gain] | [underlined: Reduction]
Patient Population: Patients over 23 years old, scheduled for periodontal treatment, with at least 3 single rooted teeth with PD of 5 mm and BOP of PD ≥ 6 mm | Yes | | | | C: SRP and placebo polymer gel | NR | | | | NR | | | | T: | | 2.0 (1.7 se) | -3.1 (1.2 se) | NA
| Split-mouth: | | | | | | | | | Microbiological Methods: | | | | C: | | 1.6 (2.2 se) | -2.7 (1.6 se) | NA
| Yes | | | | | | | | | Plaque microbiota tested (A.a., P.g., B.f., and T.d.) but results were reported separately | | | | Test: | | ANOVA | ANOVA
| | | | | | | | | | Subject Self Report: | | | | P value | | 0.057 | 0.002
| | | | | | | | | | NR
Kimura et al., 1991 ^100^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before | 4 times (at baseline and visits 0, 1, and 4) | Clinical Measurement: | Yes, none reported | Protocol violation consisting of the usage of other agents (3); deviated from the experimental schedule (1) | Type of analysis reported: | Baseline: | | | | | No statistical significant differences in microbiological results between groups.
Study Period: | NR | Severe chronic periodontitis | NR | Supragingival scaling followed by subgingival mechanical debridement consisting of root planing and scaling without local anesthesia | 31 subjects started | Mean: 43.9 | | | Microbiota sampling at days 0, 14, 21, and 42 | NR | | | Full participants only | T: | NR | NA | NA | 9.5 (10.4) | SRP was effective in and of itself.
6 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | 27 completed | Range: 29 to 53 | | | | Radiographic Techniques: | | | | C: | NR | NA | NA | 20.2 (11.7) | Quality Score:
Study/Treatment Site: | Random | Premolars on the first molar in each jaw quadrant | NR | NR | T: 27 sites | Gender: | | | | NR | | | | Final: 4 weeks | | | | | 38; 38
Department of Periodontology, Osaka University Faculty of Dentistry | Blinding: | Widman flap: | Assigned to Subjects: | | C: 27 sites | Male: 14 | | | | Microbiological Methods: | | | | T: | | NA | NA | 3.7 (6.1)
Location: | NR | NR | NR | | Dose, Mode, Schedule: | Female: 13 | | | | Plaque microbiota and anaerobic culture studies of spirochetes, motile rods, coccoid cells, using dark field microscopy | | | | C: | | NA | NA | 5.5 (7.3)
Osaka, Japan | Placebo: | | | | T: SRP plus controlled release ofloxacin inserts applied in 5+ mm pockets around test tooth and adjacent teeth weekly from days 0–35 | Race/Ethnicity: | | | | Subject Self Report: | | | | Change:
Patient Population: | Yes | | | | C: SRP plus placebo strips | NR | | | | NR | | | | T: | | NA | NA | NR
Patients with at least one site with deep PD ≥ 5 mm on the premolars and bone loss on radiography | Split-mouth: | | | | | | | | | | | | | C: | | NA | NA | NR
| NR | | | | | | | | | | | | | Test:
| | | | | | | | | | | | | | P value:

Evidence Table 7. Effectiveness of Other Antimicrobials as an Adjunct to Scaling and Root Planing to Treat Chronic Periodontitis

Study Description | Study Design Characteristics | Disease Characteristics | Examiner Characteristics | Description of Scaling and Root Planing | Eligible Study Groups and How Defined: | Study Group Characteristics | Compliance Monitoring | Baseline Measures | Assessment Time Interval(s) | Outcomes Assessed | Adverse Effects | Study Group Attrition and Reasons | Type of Analysis | Outcomes Accessed
| | | | | | | | | | | | | | (N of Pts) | | Attachment Level mm [image] (SD) | Probing Depth mm [image] (SD) | Spirochetes [image]% (SD) | Comments
Furuichi et al., 1997 ^102^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | NR | 4 times (at baseline and days 2, 7, and 14) | Clinical Measurement: | NR | NR | Type of analysis reported: | Baseline: | | | | | No significant differences were observed between the 2 groups regarding composition of the subgingival microbiota
Study Period: | RCT | Moderate periodontitis | 1 | Mechanical meticulous scaling and root planing performed until root surface was hard and smooth | 16 subjects | Mean: 49.2 | | | | BOP/SBI | | | Full participants only | T: | 32 sites | NA | 5.6 (0.89) | 46.3 (18.9) | Quality Score:
8 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Assigned quadrant was anaesthesized | T: 32 sites | Gender: | | | | PlI | | | | C: | 32 sites | NA | 5.8 (0.86) | 36.9 (14.0) | 77; 69
Study/Treatment Site: | Random | Single-rooted | NA | Time spent: | C: 32 sites | Male: 10 | | | | PD | | | | Final: 8 weeks
Specialist Clinic for Periodontitis, Göteborg University | Blinding: | Widman flap: | Assigned to Subjects: | NR | Dose, Mode, Schedule: | Female: 6 | | | | GI | | | | T: | | NA | 3.8 (0.81) | 12.5 (7.5)
Location: | Examiner and patients blind | NR | Same examiner throughout study | | T: SRP plus supragingival and subgingival 0.6% tricolsan gel and 0.3% tricolsan dentifrice 2×day for 2 weeks, repeated again after 1 week washout period | Race/Ethnicity: | | | | Radiographic Techniques: | | | | C: | | NA | 3.9 (0.72) | 13.7 (7.7)
Sweden | Placebo: | | | | C: SRP plus placebo gel and a dentifrice both without triclosan | NR | | | | NR | | | | Change: | | | [underlined: Reduction] | [underlined: Reduction]
Patient Population: | Yes | | | | | | | | | Microbiological Methods: | | | | T: | | NA | 1.8 (0.68) | 38.4 (17.4)
Patients referred to clinic with ≥ 2 sites, at single rooted teeth in each of 2 contralateral quadrants with PD ≥ 5 mm and BOP | Split-mouth: | | | | | | | | | Plaque microbiota (coccoid cells, non-motile rods, spirochetes and motile rods, filaments, and fusiforms) and dark field microscopy | | | | C: | | NA | 1.9 (0.69) | 21.6 (17.7)
| Yes | | | | | | | | | Subject Self Report: | | | | Test: | | | ANOVA | ANOVA
| | | | | | | | | | NR | | | | P value: | | | 0.589 | 0.371
Listgarten et al., 1989 ^103^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | Yes | Before SRP | 4 times (at 4 weeks prior to baseline, baseline, and weeks 4 and 8) | Clinical Measurement: | Yes, mucosal irritation | Never start (2); mucosal irritation associated with use of test rinse (2); medication taken during course of study (2); and failed to complete all examinations or failed to comply with protocol (10) | Type of analysis reported: | Baseline: | | | | | No between group differences reported.
Study Period: | RCT | Moderate to deep pockets | NR | Thorough subgingival scaling by hand of test sites | 56 subjects recruited | Mean: 49 | | | | PlI | | | Full participants only | T: | 20 | 6.65 (0.34 se) | 6.35 (0.25 se) | 35.45 (4.13 se) | Quality Score:
8 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | 40 completed | Range: 19 to 78 | | | | PD | | | | C: | 20 | 6.45 (0.36 se) | 6.20 (0.34 se) | 37.25 (4.30 se) | 69; 54
Study/Treatment Site: | Random | No furcation involvement | NR | NR | T: 20 subjects | Gender: | | | | CAL | | | | Final: 8 weeks
Clinics of the School of Dental Medicine | Blinding: | Widman flap: | Assigned to Subjects: | | C: 20 subjects | Male: 20 | | | | GI | | | | T: | 20 | 5.15 (0.44 se) | 4.30 (0.33 se) | 11.40 (3.48 se)
Location: | Examiner and provider blind | NR | NR | | Dose, Mode, Schedule: | Female: 20 | | | | Radiographic Techniques: | | | | C: | 20 | 5.20 (0.47 se) | 4.80 (0.42 se) | 16.80 (5.14 se)
USA | Placebo: | | | | T: SRP plus irrigation with 7% tetra potassium peroxydiphosphate solution applied subgingivally to each test site for a 5 second period twice a day for 8 weeks | Race/Ethnicity: | | | | NR | | | | Change:
Patient Population: | Yes | | | | C: SRP with placebo | NR | | | | Microbiological Methods: | | | | T: | | 1.50* (NR) | 2.05* (NR) | NR
Adult patients attending clinics with a pair of similar contralateral 5–10 mm pockets, not continuous with furcation involvement | Split-mouth: | | | | | | | | | Subgingival microbial samples (coccoid cells, motile rods, spirochetes, others), dark field microscopy | | | | C: | | 1.25* (NR) | 1.40* (NR) | NR
| Yes | | | | | | | | | Subject Self Report: | | | | Test: | | NR | NR
| | | | | | | | | | Compliance with protocol was checked by inspection of volume of residual rinse in irrigation at the 2^nd^ and 3^rd^ visit, and by questioning the subjects | | | | P value: | | NS | NS
Oosterwaal et al., 1991 ^89^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 4 times (at baseline and weeks 4, 12, and 36) | Clinical Measurement: | NR | NR | Type of analysis reported: | T1: Amine Fluoride: | | | | | Statistical analysis of the bacteriological and clinical examinations failed to demonstrate any significant differences between the groups
Study Period: | RCT | Advanced periodontitis | 2 | Mechanical debridement with Gracey curettes or ultrasonic instruments | 10 subjects | Mean: 48 | | | | BOP/SBI | | | Full participants only | Baseline: | | | | | SRP in pockets not in trial within 4 weeks of baseline.
36 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | T1: 10 sites | Range: 33 to 62 | | | | PlI | | | | T: | 10 | NA | NR | NA | Quality Score:
Study/Treatment Site: | Random | Single-rooted | NR | NR | T2: 10 sites | Gender: | | | | PD | | | | C: | 10 | NA | NR | NA | 62; 54
Program University Clinic, Department of Periodontology of Nijmegen | Blinding: | Widman flap: | Assigned to Subjects: | | C: 10 sites | Male: 4 | | | | Radiographic Techniques: | | | | Final: 36 weeks
Location: | Examiners and patients blind | NR | NR | | Dose, Mode, Schedule: | Female: 6 | | | | NR | | | | T: | 10 | NA | NR | NA
Netherlands | Placebo: | | | | T1: 1.25% amine fluoride gel (applied 3 times with syringe within 10 minutes after SRP) | Race/Ethnicity: | | | | Microbiological Methods: | | | | C: | 10 | NA | NR | NA
Patient Population: | Yes | | | | T2: 4% stannous fluoride gel 3× within 10 minutes | NR | | | | Subgingival plaque microbiota (anaerobic gram-positive bacteria), agar plates, dark field microscopy | | | | Change: | | | [underlined: Reduction]
Patients with ≥ 4 interdental pockets of 7 mm to 9 mm affecting single rooted teeth referred to clinic | Split-mouth: | | | | C: SRP with placebo gel (applied 3 times with syringe within 10 minutes after SRP) | | | | | Subject Self Report: | | | | T: | | NA | NR | NA
| Yes | | | | | | | | | NR | | | | C: | | NA | NR | NA
| | | | | | | | | | | | | | Test: | | | ANOVA
| | | | | | | | | | | | | | P value: | | | NS
| | | | | | | | | | | | | | [underlined: T2: Stannous Fluoride:]
| | | | | | | | | | | | | | Baseline:
| | | | | | | | | | | | | | T: | 10 | NA | NR | NA
| | | | | | | | | | | | | | C: | 10 | NA | NR | NA
| | | | | | | | | | | | | | Final: 36 weeks
| | | | | | | | | | | | | | T: | 10 | NA | NR | NA
| | | | | | | | | | | | | | C: | 10 | NA | NR | NA
| | | | | | | | | | | | | | Change: | | | [underlined: Reduction]
| | | | | | | | | | | | | | T: | | NA | NR | NA
| | | | | | | | | | | | | | C: | | NA | NR | NA
| | | | | | | | | | | | | | Test: | | | ANOVA
| | | | | | | | | | | | | | P value: | | | NS
Rosling et al., 2001 ^104^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NA | Before SRP | 14 times (complete re-examination at 12 months, years 3, 5, and 12; and yearly CAL) | Clinical Measurement: | NR | Withdrew for reasons unrelated to study (9); major systemic disease, moved and not appreciate treatment provided (24) | Type of analysis reported: | Baseline: | | | | | The mean PD decreased between baseline and 3 months but tended to increase in both groups during 12 months to 13 years
Study Period: | Non-RCT | Advanced destructive periodontitis | 3 | Non-surgical supra-and subgingival ultrasonic instrumentation under local anesthesia | 223 subjects enrolled | NR | | | | BOP | | | Full participants only | T: | 58 | NR | 3.9 (0.9) | NA | Quality Score:
676 weeks (13 years) | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | 150 completed | Gender: | | | | PD | | | | C: | 92 | NR | 3.7 (0.9) | NA | 31; 23
Study/Treatment Site: | Unknown | Single-rooted teeth - “non-molar teeth” | Calibration (Gold standard) | 1 hour for 4 to 6 sessions, then interval between sessions never exceeded 1 week | T: 75 enrolled, 58 completed | NR | | | | CAL | | | | Final: 676 weeks
Department of Periodontology | Blinding: | Wideman flap: | Assigned to Subjects: | | C: 148 enrolled, 92 completed | Race/Ethnicity: | | | | Number of teeth | | | | T: | | NR | 2.9 (0.5) | NA
Location: | NR | NR | NR | | Dose, Mode, Schedule: | NR | | | | Radiographic Techniques: | | | | C: | | NR | 3.3 (0.6) | NA
Helsingborg, Sweden | Placebo: | | | | T: SRP plus irrigation with ultrasound device using povidone-iodine solution | | | | | Bone Loss/Regeneration | | | | Change: | | [underlined: Gain]
Patient Population: | Yes | | | | C: SRP plus ultrasound device using tap water | | | | | Microbiological Methods: | | | | T: | | 0.28 (NR) | 1.0 *(NR) | NA
Patients referred for treatment with ≥ 8 non-molar teeth, and periodontal lesions with PD ≥ 6 mm at ≥ 2 teeth in each quadrant | Split-mouth: | | | | | | | | | NR | | | | C: | | 0.87 (NR) | 0.4* (NR) | NA
| No | | | | | | | | | Subject Self Report: | | | | Test: | | NR | NR
| | | | | | | | | | NR | | | | P value: | | NR | NR
Wennström et al., 1987 ^85^ | Design Type: | Severity: | Number: | SRP performed: | Subject/Site allocation: | Age: | NR | Before SRP | 3 times (at baseline and weeks 10 and 52) | Clinical Measurement: | NR | NR | Type of analysis reported: | Baseline: | | | | | In the comparison between the different treatment groups, the hydrogen peroxide group showed a smaller residual probing depth than the non-irrigated of the saline irrigated groups
Study Period: | RCT | Moderate to severe periodontal disease | 1 | Subgingival debridement of entire dentition | 10 subjects | Mean: 43.1 | | | 52 week study, SRP and treatment at week 32 | BOP/SBI | | | Full participants only | T: | 10 | NR | 7.1 (NR) | NA | Microbiological and radiological results presented in a different paper
52 weeks | Subject/Site Allocation: | Types of Teeth: | Trained: | Time spent: | T: 10 (28 sites) | Range: 22 to 61 | | | | PlI | | | | C: | 10 | NR | 6.9 (NR) | NA | Quality Score:
Study/Treatment Site: | Random | NR | Specially trained dental hygienists | 6 visits over about 6 weeks | C: 10 (24 sites) | Gender: | | | | PD | | | | Final: 52 weeks | | | | | 46; 46
Department of Periodontology School of Dentistry, University of Goteberg | Blinding: | Widman flap: | Assigned to Subjects: | | Dose, Mode, Schedule: | NR | | | | CAL | | | | T: | 10 | NR | 4.5 (NR) | NA
Location: | Examiner blind | NR | Same examiner throughout study | | All patients received professional tooth cleaning once every 4 weeks. | Race/Ethnicity: | | | | GI | | | | C: | 10 | NR | 5.1 (NR) | NA
Sweden | Placebo: | | | | T: SRP plus irrigation with 3% hydrogen peroxide for 2 minutes 3×week for 2 weeks intervals prior to baseline, then professional irrigation with hydrogen peroxide for 6 weeks | NR | | | | Radiographic Techniques: | | | | Change: | | [underlined: Gain] | [underlined: Reduction]
Patient Population: | Yes | | | | C: SRP plus irrigation with saline 3×week at same schedule as treatment group | | | | | Bone Loss/Regeneration | | | | T: | | 0.8 (0.8) | 2.6* (NR) | NA
Patients with 2–3 interproximal sites in each quadrant with PD ≥ 6 mm and BOP selected from waiting list | Split-mouth: | | | | | | | | | Microbiological Methods: | | | | C: | | 0.7 (0.5) | 1.8* (NR) | NA
| Yes | | | | | | | | | Crevicular fluid microbiota | | | | Test: | | t-test | t-test
| | | | | | | | | | Subject Self Report: | | | | P value: | | NS | < 0.05
| | | | | | | | | | NR