# Acknowledgments

This study was supported by Contract 290-97-0011 from the Agency of Healthcare Research and Quality (Task No. 6). We acknowledge the continuing support of Jacqueline Besteman, JD, MA, director of the AHRQ Evidence-based Practice Program, Ernestine Murray, RN, MAS, the AHRQ Task Order Officer for this project, and Isabel Garcia, DDS, MPH, the National Institute for Dental and Craniofacial Research representative.

We are deeply appreciative of the clinical and research assistance for this systematic review provided by James D. Bader, DDS, MPH, and Daniel A. Shugars, DDS, PhD, of the University of North Carolina at Chapel Hill School of Dentistry and Cecil G. Sheps Center for Health Services Research (Dr. Bader). Both were instrumental in advising on the key questions, designing literature search strategies, selecting critical outcomes, identifying consultants, reviewing titles and abstracts, and initially reviewing clinical articles (Dr. Bader, tetracycline; Dr. Shugars, minocycline). Dr. Bader in addition was extremely helpful with data abstraction and abstractor training and provided a thoughtful review of the draft evidence report. We are singularly indebted to Anne Jackman, MSW, of UNC’s Cecil G. Sheps Center for Health Services Research for her unwavering project management and research support. We thank our abstractors, Nancy Fan Lenfestey, MHA, of RTI and Laura Sterling, MD, and Gerald Gartlehner, MD, of the University of North Carolina at Chapel Hill. Finally, the investigators deeply appreciate the considerable support, commitment, and contributions from RTI staff Ghada Homsi, ME, Loraine Monroe, and Terri Kissiah.

In addition, we would like to extend our appreciation to the members of our Technical Expert Advisory Group (TEAG), who served as vital resources throughout our process. They are: Gary Armitage, DDS, Division of Periodontology, University of California at San Francisco School of Dentistry, San Francisco, Calif.; Jack Caton, DDS, Eastman Dental Center, Rochester, NY; Daniel Fine, DMD, Department of Oral Biology, University of Medicine and Dentistry of New Jersey, Newark, NJ; Sarah D. Grossi, DDS, MS, Department of Oral Biology, State University of New York at Buffalo, Buffalo, NY; Marjorie Jeffcoat, DDS, Department of Periodontology, University of Alabama-Birmingham, Birmingham, Ala.; and Anthony Neely, DDS, School of Dentistry, University of Detroit Mercy, Detroit, Mich.

We owe our thanks as well to our external peer reviewers, who provided constructive feedback and insightful suggestions for improvement of our report. Our peer reviewers included Drs. Armitage, Caton, Fine, and Neely from the TEAG, and Dr. Debora Matthews, DDS, Dipl. Periodontics, MSc, Division of Periodontics, Dalhousie University, Nova Scotia, Canada. Our Federal Reviewers included Dr. William Maas of the Centers for Disease Control and Prevention, David Atkins, MD, Chief Medical Officer at ARHQ and David Lewin, of the AHRQ editorial staff, and several other anonymous reviewers from NIDCR and AHRQ.