# Full Bibliography

Antibiotic gels for periodontal disease. Drug Ther Bull. 1994;32:43-44. [pmid: 7635031].
Consensus Report: Periodontal Diseases: Epidemiology and diagnosis. Ann Periodontol. 1996;1:216-222. [pmid: 9118258].
in adults: clinical results. J Clin Perio. 2002;29.
Review Manager (RevMan) [Computer Program] Version 4.2 for Windows. Oxford, England: The Cochrane Collaboration; 2002.
Aboul-Dahab O. A clinical evaluation of non-steroidal anti-inflammatory drugs (NSAIDS) as adjuncts in the management of periodontal disease. Egypt Dent J. 1993;39:511-518. [pmid: 9590980].
Addy M, Hassan H, Moran J, Wade W, Newcombe R. Use of antimicrobial containing acrylic strips in the treatment of chronic periodontal disease. A three month follow-up study. J Periodontol. 1988;59:557-564. [pmid: 3054047].
Ainamo A, Bergenholtz A, Hugoson A, Ainamo J. Location of the mucogingival junction 18 years after apically repositioned flap surgery. J Clin Periodontol. 1992;19:49-52. [pmid: 1732309].
Ainamo J, Lie T, Ellingsen BH, et al. Clinical responses to subgingival application of a metronidazole 25% gel compared to the effect of subgingival scaling in adult periodontitis. J Clin Periodontol. 1992;19:723-729. [pmid: 1447392].
Aitken S, Birek P, Kulkarni GV, Lee WL, McCulloch CA. Serial doxycycline and metronidazole in prevention of recurrent periodontitis in high-risk patients. J Periodontol. 1992;63:87-92. [pmid: 1552469].
Al-Joburi W, Chin Quee T, Lautar C, et al. Effects of adjunctive treatment of periodontitis with tetracycline and spiramycin. J Periodontol. 1989;60:533-539. [pmid: 2681673].
Al-Joburi W, Koulourides T. Effect of fluoride on in vitro root surface lesions. Caries Res. 1984;18:33-40. [pmid: 6360374].
Al-Mubarak SA, Karring T, Ho A. Clinical evaluation of subgingival application of metronidazole 25%, and adjunctive therapy. J Int Acad Periodontol. 2000;2:64-70. [pmid: 12666963].
Albandar JM, Brunelle JA, Kingman A. Destructive periodontal disease in adults 30 years of age and older in the United States, 1988-1994. J Periodontol. 1999;70:13-29. [pmid: 10052767].
Albandar JM, Kingman A. Gingival recession, gingival bleeding, and dental calculus in adults 30 years of age and older in the United States, 1988-1994. J Periodontol. 1999;70:30-43. [pmid: 10052768].
Aldridge JP, Lester V, Watts TL, Collins A, Viberti G, Wilson RF. Single-blind studies of the effects of improved periodontal health on metabolic control in type 1 diabetes mellitus. J Clin Periodontol. 1995;22:271-275. [pmid: 7622632].
Alexander DC, Martin JC, King PJ, Powell JR, Caves J, Cohen ME. Interleukin-1 beta, prostaglandin E2, and immunoglobulin G subclasses in gingival crevicular fluid in patients undergoing periodontal therapy. J Periodontol. 1996;67:755-762. [pmid: 8866314].
Ali RW, Lie T, Skaug N. Early effects of periodontal therapy on the detection frequency of four putative periodontal pathogens in adults. J Periodontol. 1992;63:540-547. [pmid: 1625154].
Alkan A, Aykac Y, Bostanci H. Does temporary splinting before non-surgical therapy eliminate scaling and root planing-induced trauma to the mobile teeth? J Oral Sci. 2001;43:249-254.
Anderson GB, Plotzke AE, Morrison EC, Caffesse RG. Effectiveness of an irrigating solution utilized during ultrasonic scaling. Quintessence Int. 1995;26:849-858. [pmid: 8596815].
Anonymous. Antibiotic gels for periodontal disease. Drug Ther Bull. 1994;32:43-44. [pmid: 7635031].
Anonymous. Modulation of the host response in periodontal therapy. J Periodontol. 2002;73:460-470. [pmid: 11990448].
Antczak-Bouckoms A, Joshipura K, Burdick E, Tulloch JF. Meta-analysis of surgical versus non-surgical methods of treatment for periodontal disease. J Clin Periodontol. 1993;20:259-268. [pmid: 8473536].
Antczak-Bouckoms AA, Weinstein MC. Cost-effectiveness analysis of periodontal disease control. J Dent Res. 1987;66:1630-1635. [pmid: 10872396].
Ashley RA. Clinical trials of a matrix metalloproteinase inhibitor in human periodontal disease. SDD Clinical Research Team. Ann N Y Acad Sci. 1999;878:335-346. [pmid: 10415739].
Asikainen S, Jousimies-Somer H, Kanervo A, Saxen L. The immediate efficacy of adjunctive doxycycline in treatment of localized juvenile periodontitis. Arch Oral Biol. 1990;35 Suppl:231S-234S. [pmid: 2088233].
Atici K, Yamalik N, Eratalay K, Etikan I. Analysis of gingival crevicular fluid intracytoplasmic enzyme activity in patients with adult periodontitis and rapidly progressive periodontitis. A longitudinal study model with periodontal treatment. J Periodontol. 1998;69:1155-1163. [pmid: 9802716].
Atilla G, Balcan M, Bicakci N, Kazandi A. The effect of non-surgical periodontal and adjunctive minocycline-HCL treatments on the activity of salivary proteases. J Periodontol. 1996;67:1-6. [pmid: 8676266].
Atilla G, Baylas H. Electron probe analysis of cementum surfaces. J Marmara Univ Dent Fac. 1996;2:510-514. [pmid: 9569806].
Attstrom R. [Clinical procedure for the prevention of periodontitis]. [German]. Deutsche Zahnarztliche Zeitschrift. 1982;37:545-551. [pmid: 6754346].
Aukhil I, Lopatin DE, Syed SA, Morrison EC, Kowalski CJ. The effects of periodontal therapy on serum antibody (IgG) levels to plaque microorganisms. J Clin Periodontol. 1988;15:544-550. [pmid: 3198782].
Avera JB, Camargo PM, Klokkevold PR, Kenney EB, Lekovic V. Guided tissue regeneration in Class II furcation involved maxillary molars: a controlled study of 8 split-mouth cases. J Periodontol. 1998;69:1020-1026. [pmid: 9776030].
Awartani FA, Zulqarnain BJ. Comparison of the clinical effects of subgingival application of metronidazole 25% gel and scaling in the treatment of adult periodontitis. Quintessence Int. 1998;29:41-48. [pmid: 9611474].
Axtelius B, Soderfeldt B, Edwardsson S, Attstrom R. Therapy-resistant periodontitis (I). Clinical and treatment characteristics. J Clin Periodontol. 1997;24:640-645. [pmid: 9378836].
Aziz-Gandour IA, Newman HN. The effects of a simplified oral hygiene regime plus supragingival irrigation with chlorhexidine or metronidazole on chronic inflammatory periodontal disease. J Clin Periodontol. 1986;13:228-236. [pmid: 3517075].
Azmak N, Atilla G, Luoto H, Sorsa T. The effect of subgingival controlled-release delivery of chlorhexidine chip on clinical parameters and matrix metalloproteinase-8 levels in gingival crevicular fluid. J Periodontol. 2002;73:608-615. [pmid: 12083533].
Babay N. Comparative SEM study on the effect of root conditioning with EDTA or tetracycline Hcl on periodontally involved root surfaces. Indian J Dent Res. 2000;11:53-57. [pmid: 11307429].
Babay N. The effect of EDTA on the attachment and growth of cultured human gingival fibroblasts in periodontitis-affected root surface. J Cont Dent Pract. 2001;2:13-23.
Bach G, Neckel C, Mall C, Krekeler G. Conventional versus laser-assisted therapy of periimplantitis: a five-year comparative study. Implant Dentist. 2000;9:247-251.
Bader HI, Boyd RL. Long-term monitoring of adult periodontitis patients in supportive periodontal therapy: correlation of gingival crevicular fluid proteases with probing attachment loss. J Clin Periodontol. 1999;26:99-105. [pmid: 10048643].
Bader JD, Bonito AJ, Shugars. Cardiovascular Effects on Epinephrine on Hypertensive Dental Patients. Rockville, Md: Evidence Report/Technology Assessment No. 48. AHRQ Publication No. 02-E006. Agency for Healthcare Research and Quality; 2002.
Bader JD, Shugars DA, Rozier G, et al. Diagnosis and Management of Dental Caries. Evidence Report/Technology Assessment No. 36 (prepared by Research Triangle Institute and University of North Carolina at Chapel Hill Evidence-based Practice Center under Contract No. 290-97-0011). AHRQ Publication No. 01-E056. Rockville, MD: Agency for Healthcare Research and Quality; 2001.
Badersten A, Nilveus R, Egelberg J. Effect of nonsurgical periodontal therapy. II. Severely advanced periodontitis. J Clin Periodontol. 1984;11:63-76. [pmid: 6363463].
Badersten A, Nilveus R, Egelberg J. Scores of plaque, bleeding, suppuration and probing depth to predict probing attachment loss. 5 years of observation following nonsurgical periodontal therapy. J Clin Periodontol. 1990;17:102-107. [pmid: 2406291].
Baehni P, Thilo B, Chapuis B, Pernet D. Effects of ultrasonic and sonic scalers on dental plaque microflora in vitro and in vivo. J Clin Periodontol. 1992;19:455-459. [pmid: 1430279].
Bain CA, Beagrie GS, Bourgoin J, et al. The effects of spiramycin and/or scaling on advanced periodontitis in humans. J Can Dent Assoc. 1994;60:209. , 212-217. [pmid: 8156459].
Bakdash MB, Wolff LF, Pihlstrom BL, Aeppli DM, Bandt CL. Salt and peroxide compared with conventional oral hygiene. III. Patient compliance and acceptance. J Periodontol. 1987;58:308-313. [pmid: 3035166].
Balk EM, Bonis PA, Moskowitz H, et al. Correlation of quality measures with estimates of treatment effect in meta-analyses of randomized controlled trials. JAMA. 2002;287:2973-82. [pmid: 12052127].
Balos K, Bal B, Eren K. The effects of various agents on root surfaces (a scanning electron microscopy study). Newsletter - Int Acad Periodontol. 1991;1:13-16.
Bardet P, Suvan J, Lang NP. Clinical effects of root instrumentation using conventional steel or non-tooth substance removing plastic curettes during supportive periodontal therapy (SPT). J Clin Periodontol. 1999;26:742-747. [pmid: 10589810].
Becherer CF. [Closed or open periodontitis treatment. A review of the literature]. Schweizer Monatsschrift Fur Zahnmedizin. 1994;104:1191-1201. [pmid: 7973551].
Becker W, Becker BE, Ochsenbein C, et al. A longitudinal study comparing scaling, osseous surgery and modified Widman procedures. Results after one year. J Periodontol. 1988;59:351-365. [pmid: 3292752].
Begg C, Cho M, Eastwood S, et al. Improving the quality of reporting of randomized controlled trials. The CONSORT statement. JAMA. 1996;276:637-639. [pmid: 8773637].
Beikler T, Karch H, Ehmke B, Klaiber B, Flemmig TF. Protective effect of serum antibodies against a 110-kilodalton protein of Actinobacillus actinomycetemcomitans following periodontal therapy. Oral Microbiol Immunol. 1999;14:281-287. [pmid: 10551154].
Ben Hatit Y, Blum R, Severin C, Maquin M, Jabro MH. The effects of a pulsed Nd:YAG laser on subgingival bacterial flora and on cementum: an in vivo study. J Clin Laser Med Surg. 1996;14:137-143. [pmid: 9484091].
Berglundh T, Krok L, Liljenberg B, Westfelt E, Serino G, Lindhe J. The use of metronidazole and amoxicillin in the treatment of advanced periodontal disease. A prospective, controlled clinical trial. J Clin Periodontol. 1998;25:354-362. [pmid: 9650870].
Beuchat M, Busslinger A, Schmidlin PR, Michel B, Lehmann B, Lutz F. Clinical comparison of the effectiveness of novel sonic instruments and curettes for periodontal debridement after 2 months. J Clin Periodontol. 2001;28:1145-1150. [pmid: 11737512].
Bhide VM, Smith L, Overall CM, Birek P, McCulloch CA. Use of a fluorogenic septapeptide matrix metalloproteinase assay to assess responses to periodontal treatment. J Periodontol. 2000;71:690-700. [pmid: 10872948].
Biagini G, Checchi L, Miccoli MC, Vasi V, Castaldini C. Root curettage and gingival repair in periodontitis. J Periodontol. 1988;59:124-129. [pmid: 3279178].
Bichara J, Greenwell H, Drisko C, et al. The effect of postsurgical naproxen and a bioabsorbable membrane on osseous healing in intrabony defects. J Periodontol. 1999;70:869-877. [pmid: 10476894].
Blomlof J. Root cementum appearance in healthy monkeys and periodontitis-prone patients after different etching modalities. J Clin Periodontol. 1996;23:12-18. [pmid: 8636451].
Blomlof J, Blomlof L, Lindskog S. Ultrasonic subgingival root planing and EDTA etching in a one-step procedure. Swed Dent J. 1997;21:213-219. [pmid: 9505333].
Blomlof JP, Blomlof LB, Lindskog SF. Smear layer formed by different root planing modalities and its removal by an ethylenediaminetetraacetic acid gel preparation. Int J Periodontics Restorative Dent. 1997;17:242-249. [pmid: 9497716].
Blomlof L, Bergman E, Forsgardh A, et al. A clinical study of root surface conditioning with an EDTA gel. I. Nonsurgical periodontal treatment. Int J Periodontics Restorative Dent. 2000;20:560-565. [pmid: 11203592].
Bollen CM, Mongardini C, Papaioannou W, Van Steenberghe D, Quirynen M. The effect of a one-stage full-mouth disinfection on different intra-oral niches. Clinical and microbiological observations. J Clin Periodontol. 1998;25:56-66. [pmid: 9477021].
Bollen CM, Vandekerckhove BN, Papaioannou W, Van Eldere J, Quirynen M. Full- versus partial-mouth disinfection in the treatment of periodontal infections. A pilot study: long-term microbiological observations. J Clin Periodontol. 1996;23:960-970. [pmid: 8915027].
Bonito AJ, Patton LL, Shugars DA, et al. Management of Dental Patients Who Are HIV-Positive. Rockville, Md.: Evidence Report/Technology Assessment No. 37. AHRQ Publication No. 01-E042. Agency for Healthcare Research and Quality; 2002.
Booth V, Ashley FP, Lehner T. Passive immunization with monoclonal antibodies against Porphyromonas gingivalis in patients with periodontitis. Infect Immun. 1996;64:422-427. [pmid: 8550186]. [pmcid: 173780].
Boutsi EA, Umeda M, Nagasawa T, Laosrisin N, Ishikawa I. Follow-up of two cases of Papillon-Lefevre syndrome and presentation of two new cases. Int J Periodontics Restorative Dent. 1997;17:334-347. [pmid: 9497724].
Braatz L, Garrett S, Claffey N, Egelberg J. Antimicrobial irrigation of deep pockets to supplement non-surgical periodontal therapy. II. Daily irrigation. J Clin Periodontol. 1985;12:630-638. [pmid: 3863836].
Bratthall G, Lindberg P, Havemose-Poulsen A, et al. Comparison of ready-to-use EMDOGAIN-gel and EMDOGAIN in patients with chronic adult periodontitis. J Clin Periodontol. 2001;28:923-929. [pmid: 11686810].
Brayer WK, Mellonig JT, Dunlap RM, Marinak KW, Carson RE. Scaling and root planing effectiveness: the effect of root surface access and operator experience. J Periodontol. 1989;60:67-72. [pmid: 2646421].
Briss PA, Zaza S, Pappaioanou M, et al. Developing an evidence-based Guide to Community Preventive Services--methods. The Task Force on Community Preventive Services. Am J Prev Med. 2000;18:35-43. [pmid: 10806978].
Brown JB, Rosenstein D, Mullooly J, O'Keeffe Rosetti M, Robinson S, Chiodo G. Impact of intensified dental care on outcomes in human immunodeficiency virus infection. AIDS Patient Care and STDs. 2002;16:479-486. [pmid: 12437859].
Brown LJ, Johns BA, Wall TP. The economics of periodontal diseases. Periodontol. 2000;29:223-234.
Buchmann R, Hasilik A, Heinecke A, Lange DE. PMN responses following use of 2 biodegradable GTR membranes. J Clin Periodontol. 2001;28:1050-1057. [pmid: 11686827].
Buduneli N, Vardar S, Atilla G, Sorsa T, Luoto H, Baylas H. Gingival crevicular fluid matrix metalloproteinase-8 levels following adjunctive use of meloxicam and initial phase of periodontal therapy. J Periodontol. 2002;73:103-109. [pmid: 11846190].
Burgett FG, Ramfjord SP, Nissle RR, Morrison EC, Charbeneau TD, Caffesse RG. A randomized trial of occlusal adjustment in the treatment of periodontitis patients. JClin Periodontol. 1992;19:381-387. [pmid: 1634627].
Caffesse RG, Kerry GJ, Chaves ES, et al. Clinical evaluation of the use of citric acid and autologous fibronectin in periodontal surgery. J Periodontol. 1988;59:565-569. [pmid: 3054048].
Caffesse RG, Quinones CR. Outcome studies of periodontal treatment modalities. Curr Opin Periodontol. 1993;:170-177.
Caffesse RG, Sweeney PL, Smith BA. Scaling and root planing with and without periodontal flap surgery. J Clin Periodontol. 1986;13:205-210. [pmid: 3517073].
Calongne KB, Aichelmann-Reidy ME, Yukna RA, Mayer ET. Clinical comparison of microporous biocompatible composite of PMMA, PHEMA and calcium hydroxide grafts and expanded polytetrafluoroethylene barrier membranes in human mandibular molar Class II furcations. A case series. J Periodontol. 2001;72:1451-1459. [pmid: 11699489].
Camargo PM, Lekovic V, Weinlaender M, et al. A controlled re-entry study on the effectiveness of bovine porous bone mineral used in combination with a collagen membrane of porcine origin in the treatment of intrabony defects in humans. J Clin Periodontol. 2000;27:889-896. [pmid: 11140555].
Camargo PM, Lekovic V, Weinlaender M, Vasilic N, Kenney EB, Madzarevic M. The effectiveness of enamel matrix proteins used in combination with bovine porous bone mineral in the treatment of intrabony defects in humans. J Clin Periodontol. 2001;28:1016-1022. [pmid: 11686822].
Carnevale G, Kaldahl WB. Osseous resective surgery. Periodontol. 2000;22:59-87.
Castellani R, Wolffe GN, Renggli HH. Pocket elimination surgery with simultaneous connective tissue graft. A case report with 3-year follow-up. J Clin Periodontol. 2001;28:365-371. [pmid: 11314894].
Caton JG. Evaluation of Periostat for patient management. Compend Contin Educ Dent. 1999;20:451-456. , 458-460, 462; quiz 463. [pmid: 10650360].
Caton JG, Ciancio SG, Blieden TM, et al. Subantimicrobial dose doxycycline as an adjunct to scaling and root planing: post-treatment effects. J Clin Periodontol. 2001;28:782-789. [pmid: 11442739].
Caton JG, Ciancio SG, Blieden TM, et al. Treatment with subantimicrobial dose doxycycline improves the efficacy of scaling and root planing in patients with adult periodontitis. J Periodontol. 2000;71:521-532. [pmid: 10807113].
Cattabriga M, Pedrazzoli V, Cattabriga A, Pannuti E, Trapani M, Verrocchi GC. Tetracycline fiber used alone or with scaling and root planing in periodontal maintenance patients: clinical results. Quintessence Int. 1996;27:395-400. [pmid: 8941833].
Cattabriga M, Rotundo R, Muzzi L, et al. Retrospective evaluation of the influence of the interleukin-1 genotype on radiographic bone levels in treated periodontal patients over 10 years. J Periodontol. 2001;72:767-773. [pmid: 11453239].
Cattabriga M, Tornese P, Paolantonio M, Angelini A. [Comparative evaluation of the clinical effects of root scaling with and without local anesthesia]. [Italian]. Stomatol Mediterr. 1987;7:297-305. [pmid: 3334287].
Chan YK, Needleman IG, Clifford LR. Comparison of four methods of assessing root surface debridement. J Periodontol. 2000;71:385-393. [pmid: 10776925].
Chapple IL, Walmsley AD, Saxby MS, Moscrop H. Effect of instrument power setting during ultrasonic scaling upon treatment outcome. J Periodontol. 1995;66:756-760. [pmid: 7500240].
Chaves ES, Jeffcoat MK, Ryerson CC, Snyder B. Persistent bacterial colonization of Porphyromonas gingivalis, Prevotella intermedia, and Actinobacillus actinomycetemcomitans in periodontitis and its association with alveolar bone loss after 6 months of therapy. J Clin Periodontol. 2000;27:897-903. [pmid: 11140556].
Chen HY, Cox SW, Eley BM. Cathepsin B, alpha2-macroglobulin and cystatin levels in gingival crevicular fluid from chronic periodontitis patients. J Clin Periodontol. 1998;25:34-41. [pmid: 9477018].
Chen HY, Cox SW, Eley BM, Mantyla P, Ronka H, Sorsa T. Matrix metalloproteinase-8 levels and elastase activities in gingival crevicular fluid from chronic adult periodontitis patients. J Clin Periodontol. 2000;27:366-369. [pmid: 10847542].
Chin Quee T, Al-Joburi W, Lautar-Lemay C, et al. Comparison of spiramycin and tetracycline used adjunctively in the treatment of advanced chronic periodontitis. J Antimicrob Chemother. 1988;22 Suppl B:171-177. [pmid: 3182440].
Chin Quee T, Chan E, Clark C, et al. The role of adjunctive Rodogyl therapy in the treatment of advanced periodontal disease. A longitudinal clinical and microbiologic study. J Periodontol. 1987;58:594-601. [pmid: 3309251].
Christgau M, Palitzsch KD, Schmalz G, Kreiner U, Frenzel S. Healing response to non-surgical periodontal therapy in patients with diabetes mellitus: clinical, microbiological, and immunologic results. J Clin Periodontol. 1998;25:112-124. [pmid: 9495610].
Christie P, Claffey N, Renvert S. The use of 0.2% chlorhexidine in the absence of a structured mechanical regimen of oral hygiene following the non-surgical treatment of periodontitis. J Clin Periodontol. 1998;25:15-23. [pmid: 9477015].
Chung RM, Grbic JT, Lamster IB. Interleukin-8 and beta-glucuronidase in gingival crevicular fluid. J Clin Periodontol. 1997;24:146-152. [pmid: 9083897].
Ciancio SG. Clinical experiences with tetracyclines in the treatment of periodontal diseases. Ann N Y Acad Sci. 1994;732:132-139. [pmid: 7978786].
Ciancio SG. Systemic medications: clinical significance in periodontics. J Clin Periodontol. 2002;29 Suppl 2:17-21. [pmid: 12087965].
Ciancio SG, Cobb CM, Leung M. Tissue concentration and localization of tetracycline following site-specific tetracycline fiber therapy. J Periodontol. 1992;63:849-853. [pmid: 1403593].
Ciancio SG, Slots J, Reynolds HS, Zambon JJ, McKenna JD. The effect of short-term administration of minocycline HCl on gingival inflammation and subgingival microflora. J Periodontol. 1982;53:557-561. [pmid: 6752371].
Claffey N, Egelberg J. Clinical characteristics of periodontal sites with probing attachment loss following initial periodontal treatment. J Clin Periodontol. 1994;21:670-679. [pmid: 7852611].
Claffey N, Kelly A, Bergquist J, Egelberg J. Patterns of attachment loss in advanced periodontitis patients monitored following initial periodontal treatment. J Clin Periodontol. 1996;23:523-531. [pmid: 8811471].
Claffey N, Loos B, Gantes B, Martin M, Egelberg J. Probing depth at re-evaluation following initial periodontal therapy to indicate the initial response to treatment. J Clin Periodontol. 1989;16:229-233. [pmid: 2654197].
Claffey N, Nylund K, Kiger R, Garrett S, Egelberg J. Diagnostic predictability of scores of plaque, bleeding, suppuration and probing depth for probing attachment loss. 3 1/2 years of observation following initial periodontal therapy. J Clin Periodontol. 1990;17:108-114. [pmid: 2406292].
Clancio SG. Clinical experiences with tetracyclines in the treatment of periodontal diseases. Ann N Y Acad Sci. 1994;732:132-139. [pmid: 7978786].
Clark SM. The influence of two ultrasonic tips on root surfaces--in vivo. Gen Dent. 1990;38:125-128. [pmid: 2132225].
Clarke M., Oxman A. D.; Cochrane Reviewer's Handbook 4.0. The Cochrane Collaboration; 1999;issue 1.
Clifford LR, Needleman IG, Chan YK. Comparison of periodontal pocket penetration by conventional and microultrasonic inserts. J Clin Periodontol. 1999;26:124-130. [pmid: 10048647].
Cobb CM. Clinical significance of non-surgical periodontal therapy: an evidence- based perspective of scaling and root planing. J Clin Periodontol. 2002;29 Suppl 2:6-16. [pmid: 12010523].
Cobb CM. Non-surgical pocket therapy: mechanical. Ann Periodontol. 1996;1:443-490. [pmid: 9118268].
Colombo AP, Eftimiadi C, Haffajee AD, Cugini MA, Socransky SS. Serum IgG2 level, Gm(23) allotype and FcgammaRIIa and FcgammaRIIIb receptors in refractory periodontal disease. J Clin Periodontol. 1998;25:465-474. [pmid: 9667480].
Colombo AP, Haffajee AD, Smith CM, Cugini MA, Socransky SS. Discrimination of refractory periodontitis subjects using clinical and laboratory parameters alone and in combination. J Clin Periodontol. 1999;26:569-576. [pmid: 10487306].
Colombo AP, Sakellari D, Haffajee AD, Tanner A, Cugini MA, Socransky SS. Serum antibodies reacting with subgingival species in refractory periodontitis subjects. J Clin Periodontol. 1998;25:596-604. [pmid: 9696261].
Conway TB, Beck FM, Walters JD. Gingival fluid ciprofloxacin levels at healthy and inflamed human periodontal sites. J Periodontol. 2000;71:1448-1452. [pmid: 11022774].
Cortellini P, Paolo G, Prato P, Tonetti MS. Long-term stability of clinical attachment following guided tissue regeneration and conventional therapy. J Clin Periodontol. 1996;23:106-111. [pmid: 8849846].
Cortellini P, Tonetti MS. Microsurgical approach to periodontal regeneration. Initial evaluation in a case cohort. J Periodontol. 2001;72:559-569. [pmid: 11338311].
Cox SW, Eley BM. Cathepsin B/L-, elastase-, tryptase-, trypsin- and dipeptidyl peptidase IV-like activities in gingival crevicular fluid. A comparison of levels before and after basic periodontal treatment of chronic periodontitis patients. J Clin Periodontol. 1992;19:333-339. [pmid: 1355496].
Cugini MA, Haffajee AD, Smith C, Kent RLJ, Socransky SS. The effect of scaling and root planing on the clinical and microbiological parameters of periodontal diseases: 12-month results. J Clin Periodontol. 2000;27:30-36. [pmid: 10674959].
D'Archivio D, Di Placido G, Tumini V, Del Giglio Matarazzo A, Tritapepe R, Paolantonio M. [A comparative evaluation of the efficacy of the excisional new attachment procedure (ENAP) relative to root planing in the etiological phase of periodontal therapy]. [Italian]. Minerva Stomatol. 1999;48:439-445. [pmid: 10726448].
Dahlen G, Rosling B. Identification of bacterial markers by culture technique in evaluation of periodontal therapy. Int Dent J. 1998;48:104-110. [pmid: 9779091].
Dahlen G, Wikstrom M, Renvert S. Treatment of periodontal disease based on microbiological diagnosis. A 5-year follow-up on individual patterns. J Periodontol. 1996;67:879-887. [pmid: 8884645].
Daly CG, Seymour GJ, Kieser JB, Corbet EF. Histological assessment of periodontally involved cementum. J Clin Periodontol. 1982;9:266-274. [pmid: 6178759].
Daneshmand N, Jorgensen MG, Nowzari H, Morrison JL, Slots J. Initial effect of controlled release chlorhexidine on subgingival microorganisms. J Periodontal Res. 2002;37:375-379. [pmid: 12366861].
Darhous MS, Aboul Dahab OM, Abdel Rahman R. A chairside microbiological evaluation using the BANA test after a single subgingival irrigation with 1.64% SnF2 solution combined with subgingival scaling. Egypt Dent J. 1995;41:1257-1262. [pmid: 9497666].
Darhous MS, Zahran F, Ragy N. Bacteriological and clinical assessment of tetracycline as root conditioning in adjunct to periodontal surgery. Egypt Dent J. 1995;41:1167-1178. [pmid: 9497653].
De Lissovoy G, Rentz AM, Dukes EM, et al. The cost-effectiveness of a new chlorhexidine delivery system in the treatment of adult periodontitis. J Am Dent Assoc. 1999;130:855-862. [pmid: 10377645].
De Soete M, Mongardini C, Peuwels M, et al. One-stage full-mouth disinfection. Long-term microbiological results analyzed by checkerboard DNA-DNA hybridization. J Periodontol. 2001;72:374-382. [pmid: 11327066].
De Vree H, Steenackers K, De Boever JA. Periodontal treatment of rapid progressive periodontitis in 2 siblings with Papillon-Lefevre syndrome: 15-year follow-up. J Clin Periodontol. 2000;27:354-360. [pmid: 10847540].
Demetriou N, Tsami-Pandi A, Parashis A. Compliance with supportive periodontal treatment in private periodontal practice. A 14-year retrospective study. J Periodontol. 1995;66:145-149. [pmid: 7730966].
Diallo AS, Sembene M, Diallo PD, Ngom M, Benoist H. [Clinical and bacteriologic response to irrigation with a chlorhexidine solution in the treatment of periodontal pockets]. [French]. Odonto-Stomatol Tropicale. 2000;23:19-23.
Dionne RA, Lepinski AM, Gordon SM, Jaber L, Brahim JS, Hargreaves KM. Analgesic effects of peripherally administered opioids in clinical models of acute and chronic inflammation. Clin Pharmacol Ther. 2001;70:66-73. [pmid: 11452246].
Doungudomdacha S, Rawlinson A, Walsh TF, Douglas CW. Effect of non-surgical periodontal treatment on clinical parameters and the numbers of Porphyromonas gingivalis, Prevotella intermedia and Actinobacillus actinomycetemcomitans at adult periodontitis sites. J Clin Periodontol. 2001;28:437-445. [pmid: 11350507].
Dowell P, al-Arrayed F, Adam S, Moran J. A comparative clinical study: the use of human type I collagen with and without the addition of metronidazole in the GTR method of treatment of periodontal disease. J Clin Periodontol. 1995;22:543-549. [pmid: 7560238].
Dragoo MR. A clinical evaluation of hand and ultrasonic instruments on subgingival debridement. 1. With unmodified and modified ultrasonic inserts. Int J Periodontics Restorative Dent. 1992;12:310-323. [pmid: 1428611].
Dragoo MR, Wheeler BG. Clinical evaluation of subgingival debridement with ultrasonic instruments used by trained and untrained operators. Gen Dent. 1996;44:234-237. [pmid: 8957817].
Drisko CH. The use of locally delivered doxycycline in the treatment of periodontitis. Clinical results. J Clin Periodontol. 1998;25:947-952. ; discussion 978-979. [pmid: 9839851].
Drisko CL. Scaling and root planing without overinstrumentation: hand versus power-driven scalers. Curr Opin Periodontol. 1993;78-88.
Drisko CL, Cobb CM, Killoy WJ, et al. Evaluation of periodontal treatments using controlled-release tetracycline fibers: clinical response. J Periodontol. 1995;66:692-699. [pmid: 7473012].
Dubrez B, Duroux P, Cimasoni G. Bone density of class II furcation lesions treated by guided tissue regeneration. A follow-up study by digital analysis of superimposable radiographs. J Clin Periodontol. 1996;23:882-888. [pmid: 8891942].
Duke SP, Garrett S. Equivalence in periodontal trials: a description for the clinician. J Periodontol. 1998;69:650-654. [pmid: 9660333].
Eckles TA, Reinhardt RA, Dyer JK, Tussing GJ, Szydlowski WM, DuBous LM. Intracrevicular application of tetracycline in white petrolatum for the treatment of periodontal disease. J Clin Periodontol. 1990;17:454-462. [pmid: 2201706].
Efeoglu E, Sandalli P. A 14-year follow-up study of localized juvenile periodontitis treated by scaling and root planing, systemic metronidazole, and subgingival curettage: a case report. Periodontal Clin Investig. 1996;18:6-12. [pmid: 9116471].
Ehmke B, Kress W, Karch H, Grimm T, Klaiber B, Flemmig TF. Interleukin-1 haplotype and periodontal disease progression following therapy. J Clin Periodontol. 1999;26:810-813. [pmid: 10599909].
Ehnevid H, Jansson L. Effects of proximal vertical destructions on periodontal status and healing in adjacent proximal sites with horizontal destruction. J Clin Periodontol. 1998;25:571-577. [pmid: 9696258].
Ehnevid H, Jansson LE. Effects of furcation involvements on periodontal status and healing in adjacent proximal sites. J Periodontol. 2001;72:871-876. [pmid: 11495134].
Ehnevid H, Jansson LE, Lindskog SF, Blomlof LB. Periodontal healing in relation to radiographic attachment and endodontic infection. J Periodontol. 1993;64:1199-1204. [pmid: 8106946].
Eickholz P, Kim TS, Burklin T, et al. Non-surgical periodontal therapy with adjunctive topical doxycycline: a double-blind randomized controlled multicenter study. J Clin Periodontol. 2002;29:108-117. [pmid: 11895538].
Eickholz P, Kim TS, Holle R, Hausmann E. Long-term results of guided tissue regeneration therapy with non-resorbable and bioabsorbable barriers. I. Class II furcations. J Periodontol. 2001;72:35-42. [pmid: 11210071].
Eickholz P, Kugel B, Pohl S, Naher H, Staehle HJ. Combined mechanical and antibiotic periodontal therapy in a case of Papillon-Lefevre syndrome. J Periodontol. 2001;72:542-549. [pmid: 11338309].
Elter JR, Lawrence HP, Offenbacher S, Beck JD. Meta-analysis of the effect of systemic metronidazole as an adjunct to scaling and root planing for adult periodontitis. J Periodontal Res. 1997;32:487-496. [pmid: 9379316].
Emingil G, Darcan S, Keskinoglu A, Kutukculer N, Atilla G. Localized aggressive periodontitis in a patient with type 1 diabetes mellitus: a case report. J Periodontol. 2001;72:1265-1270. [pmid: 11577961].
Engelmann U, Kleber M, Graber HG, Seddig M, Weigt D. [The effect of chlorhexidine (author's transl)]. Zahn Mund Kieferheilkd Zentralbl. 1981;69:248-259. [pmid: 6457471].
Engstrom H, Chamberlain D, Kiger R, Egelberg J. Radiographic evaluation of the effect of initial periodontal therapy on thickness of the maxillary sinus mucosa. J Periodontol. 1988;59:604-608. [pmid: 3054049].
Engstrom PE, Shi XQ, Tronje G, et al. The effect of hyaluronan on bone and soft tissue and immune response in wound healing. J Periodontol. 2001;72:1192-1200. [pmid: 11577951].
Eren KS, Gurgan CA, Bostanci HS. Evaluation of non-surgical periodontal treatment using 2 time intervals. J Periodontol. 2002;73:1015-1019. [pmid: 12296586].
Esposito V, Vaia E, Zarone F, Bozzini V. [Scanning electron microscopic examination of root surfaces after scaling and root planing]. [Italian]. Minerva Stomatol. 1988;37:151-157. [pmid: 3287128].
Feres M, Haffajee AD, Allard K, Som S, Goodson JM, Socransky SS. Antibiotic resistance of subgingival species during and after antibiotic therapy. J Clin Periodontol. 2002;29:724-735. [pmid: 12390569].
Feres M, Haffajee AD, Allard K, Som S, Socransky SS. Change in subgingival microbial profiles in adult periodontitis subjects receiving either systemically-administered amoxicillin or metronidazole. J Clin Periodontol. 2001;28:597-609. [pmid: 11422580].
Ferreira CE, Grossi SG, Novaes Junior AB, Dunford RG, Feres-Filho EJ. Effect of mechanical treatment on healing after third molar extraction. Int J Periodontics Restorative Dent. 1997;17:250-259. [pmid: 9497717].
Fine JB, Harper DS, Gordon JM, Hovliaras CA, Charles CH. Short-term microbiological and clinical effects of subgingival irrigation with an antimicrobial mouthrinse. J Periodontol. 1994;65:30-36. [pmid: 8133413].
Finkbeiner RL. The results of 1328 periodontal pockets treated with the argon laser: selective pocket thermolysis. J Clin Laser Med Surg. 1995;13:273-281. [pmid: 10155061].
Finkelman RD. Re: role of controlled drug delivery for periodontitis (position paper). The American Academy of Periodontology (2000;71:12-40). J Periodontol. 2000;71:1929-1933. [pmid: 11156051].
Flemmig TF, Epp B, Funkenhauser Z, et al. Adjunctive supragingival irrigation with acetylsalicylic acid in periodontal supportive therapy. J Clin Periodontol. 1995;22:427-433. [pmid: 7560220].
Flemmig TF, Milian E, Karch H, Klaiber B. Differential clinical treatment outcome after systemic metronidazole and amoxicillin in patients harboring Actinobacillus actinomycetemcomitans and/or Porphyromonas gingivalis. J Clin Periodontol. 1998;25:380-387. [pmid: 9650874].
Flemmig TF, Milian E, Kopp C, Karch H, Klaiber B. Differential effects of systemic metronidazole and amoxicillin on Actinobacillus actinomycetemcomitans and Porphyromonas gingivalis in intraoral habitats. [erratum appears in J Clin Periodontol 1998 May;25(5):437.]. J Clin Periodontol. 1998;25:1-10. [pmid: 9477013].
Flemmig TF, Rumetsch M, Klaiber B. Efficacy of systemically administered acetylsalicylic acid plus scaling on periodontal health and elastase-alpha 1-proteinase inhibitor in gingival crevicular fluid. J Clin Periodontol. 1996;23:153-159. [pmid: 8707972].
Flemming TF, Milian E, Kopp C, Karch H, Klaiber B. Differential effects of systemic metronidazole and amoxicillin on Actinobacillus actinomycetemcomitans and Porphyromonas gingivalis in intraoral habitats. [erratum appears in J Clin Periodontol 1998 May;25(5):437.]. J Clin Periodontol. 1998;25:1-10. [pmid: 9477013].
Forabosco A, Galetti R, Spinato S, Colao P, Casolari C. A comparative study of a surgical method and scaling and root planing using the Odontoson. J Clin Periodontol. 1996;23:611-614. [pmid: 8841891].
Forgas LB, Gound S. The effects of antiformin-citric acid chemical curettage on the microbial flora of the periodontal pocket. J Periodontol. 1987;58:153-158. [pmid: 3550035].
Fourmousis I, Tonetti MS, Mombelli A, Lehmann B, Lang NP, Bragger U. Evaluation of tetracycline fiber therapy with digital image analysis. J Clin Periodontol. 1998;25:737-745. [pmid: 9763329].
Fowler C, Garrett S, Crigger M, Egelberg J. Histologic probe position in treated and untreated human periodontal tissues. J Clin Periodontol. 1982;9:373-385. [pmid: 6754765].
Friesen LR, Williams KB, Krause LS, Killoy WJ. Controlled local delivery of tetracycline with polymer strips in the treatment of periodontitis. J Periodontol. 2002;73:13-19. [pmid: 11846194].
Friskopp J, Huledal G. Plasma levels of lidocaine and prilocaine after application of Oraqix, a new intrapocket anesthetic, in patients with advanced periodontitis. J Clin Periodontol. 2001;28:425-429. [pmid: 11350505].
Friskopp J, Nilsson M, Isacsson G. The anesthetic onset and duration of a new lidocaine/prilocaine gel intra-pocket anesthetic (Oraqix) for periodontal scaling/root planing. J Clin Periodontol. 2001;28:453-458. [pmid: 11350509].
Froum SJ, Weinberg MA, Tarnow D. Comparison of bioactive glass synthetic bone graft particles and open debridement in the treatment of human periodontal defects. A clinical study. J Periodontol. 1998;69:698-709. [pmid: 9660339].
Furuichi Y, Ramberg P, Krok L, Lindhe J. Short-term effects of triclosan on healing following subgingival scaling. J Clin Periodontol. 1997;24:777-782. [pmid: 9350563].
Galgut PN, Todd-Pokropek A. Recurrence of destructive periodontal disease after treatment. A long term study. Bulletin Du Groupement International Pour La Recherche Scientifique En Stomatologie Et Odontologie. 1993;36:15-21.
Galgut PN, Waite IM, Brookshaw JD, Kingston CP. A 4-year controlled clinical study into the use of a ceramic hydroxylapatite implant material for the treatment of periodontal bone defects. J Clin Periodontol. 1992;19:570-577. [pmid: 1332987].
Gallardo F, Plaza JC, De la Sotta R. Prevalence of Porphyromonas gingivalis, Prevotella intermedia and Actinobacillus actinomycetemcomitans in patients with rapidly progressive periodontitis. Medicina Oral. 2000;5:151-158. [pmid: 11507550].
Gamonal JA, Lopez NJ, Aranda W. Periodontal conditions and treatment needs, by CPITN, in the 35-44 and 65-74 year-old population in Santiago, Chile. Int Dent J. 1998;48:96-103. [pmid: 9779090].
Garrett MB, Yukna RA, Cassingham RJ, Zimny ML. Comparison of pocket epithelium removal by sulcular and internally beveled incisions with and without prescaling. Int J Periodontics Restorative Dent. 1986;6:56-66. [pmid: 3536777].
Garrett S. Local delivery of doxycycline for the treatment of periodontitis. Compend Contin Educ Dent. 1999;20:437-440. , 442, 444 passim; quiz 448. [pmid: 10650359].
Garrett S, Adams DF, Bogle G, et al. The effect of locally delivered controlled-release doxycycline or scaling and root planing on periodontal maintenance patients over 9 months. J Periodontol. 2000;71:22-30. [pmid: 10695935].
Garrett S, Johnson L, Drisko CH, et al. Two multi-center studies evaluating locally delivered doxycycline hyclate, placebo control, oral hygiene, and scaling and root planing in the treatment of periodontitis. J Periodontol. 1999;70:490-503. [pmid: 10368053].
Gellin RG, Miller MC, Javed T, Engler WO, Mishkin DJ. The effectiveness of the Titan-S sonic scaler versus curettes in the removal of subgingival calculus. A human surgical evaluation. J Periodontol. 1986;57:672-680. [pmid: 3550033].
Geng S, Cao C, Chen Z. [The effect of non-surgical periodontal and adjunctive minocycline-HCL treatments on collagenase activity]. [Chinese]. Chung-Hua Kou Chiang i Hsueh Tsa Chih Chinese J Stomatol. 2000;35:336-339.
Giedrys-Leeper E, Selipsky H, Williams BL. Effects of short-term administration of metronidazole on the subgingival microflora. J Clin Periodontol. 1985;12:797-814. [pmid: 3908494].
Glavind L, Attstrom R. Periodontal self-examination. A motivational tool in periodontics. J Clin Periodontol. 1979;6:238-251. [pmid: 393726].
Gmur R, Saxer UP, Guggenheim B. Effects of blunt scaling on periodontal status and subgingival microorganisms. A pilot study. Schweizer Monatsschrift Fur Zahnmedizin. 1994;104:430-439. [pmid: 8209214].
Goene RJ, Winkel EG, Abbas F, Rodenburg JP, van Winkelhoff AJ, de Graaff J. Microbiology in diagnosis and treatment of severe periodontitis. A report of four cases. J Periodontol. 1990;61:61-64. [pmid: 2179514].
Golub LM, McNamara TF, Ryan ME, et al. Adjunctive treatment with subantimicrobial doses of doxycycline: effects on gingival fluid collagenase activity and attachment loss in adult periodontitis. J Clin Periodontol. 2001;28:146-156. [pmid: 11168739].
Goodson JM. Antimicrobial strategies for treatment of periodontal diseases. Periodontol 2000. 1994;5:142-168. [pmid: 9673166].
Goodson JM, Cugini MA. Comparative response of mobile teeth following monolithic fiber therapy or scaling. Compendium - Supplement. 1988:S418-23.
Goodson JM, Cugini MA, Kent RL, et al. Multicenter evaluation of tetracycline fiber therapy: I. Experimental design, methods, and baseline data. J Periodontal Res. 1991;26:361-370. [pmid: 1831504].
Goodson JM, Hogan PE, Dunham SL. Clinical responses following periodontal treatment by local drug delivery. J Periodontol. 1985;56:81-87. [pmid: 3866055].
Goodson JM, Offenbacher S, Farr DH, Hogan PE. Periodontal disease treatment by local drug delivery. J Periodontol. 1985;56:265-272. [pmid: 3891959].
Gordon J, Walker C, Hovliaras C, Socransky S. Efficacy of clindamycin hydrochloride in refractory periodontitis: 24-month results. J Periodontol. 1990;61:686-691. [pmid: 2254835].
Gordon J, Walker C, Lamster I, et al. Efficacy of clindamycin hydrochloride in refractory periodontitis. 12-month results. J Periodontol. 1985;56:75-80. [pmid: 3908641].
Gotfredsen K, Karlsson U. A prospective 5-year study of fixed partial prostheses supported by implants with machined and TiO2-blasted surface. J Prosthodont. 2001;10:2-7. [pmid: 11406789].
Gottehrer NR, Donley T. A current protocol for nonsurgical periodontal therapy. Dent Today. 2001;20:76-81. [pmid: 11462346].
Graca MA, Watts TL, Wilson RF, Palmer RM. A randomized controlled trial of a 2% minocycline gel as an adjunct to non-surgical periodontal treatment, using a design with multiple matching criteria. J Clin Periodontol. 1997;24:249-253. [pmid: 9144047].
Grbic JT, Lamster IB, Celenti RS, Fine JB. Risk indicators for future clinical attachment loss in adult periodontitis. Patient variables. J Periodontol. 1991;62:322-329. [pmid: 2072245].
Greenstein G. Contemporary interpretation of probing depth assessments: diagnostic and therapeutic implications. A literature review. J Periodontol. 1997;68:1194-1205. [pmid: 9444595].
Greenstein G. Full-mouth therapy versus individual quadrant root planning: a critical commentary. J Periodontol. 2002;73:797-812. [pmid: 12146540].
Greenstein G. Periodontal diseases are curable. J Periodontol. 2002;73:950-953. [pmid: 12211506].
Greenstein G. Treating periodontal diseases with tetracycline-impregnated fibers: data and controversies. Compend Contin Educat Dent. 1995;16:448-455. ; quiz 456.
Greenstein G, Ciancio S. Re: Non-surgical treatment of patients with periodontitis. J Periodontol. 1997;68:1023-1028. [pmid: 9358372].
Greenstein G, Lamster I. Efficacy of periodontal therapy: statistical versus clinical significance. J Periodontol. 2000;71:657-662. [pmid: 10807133].
Greenstein G, Lamster I. Efficacy of subantimicrobial dosing with doxycycline. Point/counterpoint. J Am Dent Assoc. 2001;132:457-466. [pmid: 11315376].
Greenstein G, Polson A. The role of local drug delivery in the management of periodontal diseases: a comprehensive review. J Periodontol. 1998;69:507-520. [pmid: 9623893].
Greenwell H, Bakr A, Bissada N, Debanne S, Rowland D. The effect of Keyes' method of oral hygiene on the subgingival microflora compared to the effect of scaling and/or surgery. J Clin Periodontol. 1985;12:327-341. [pmid: 3889075].
Greenwell H, Bissada NF, Maybury JE, De Marco TJ. Clinical and microbiologic effectiveness of Keyes' method of oral hygiene on human periodontitis treated with and without surgery. J Am Dent Assoc. 1983;106:457-461. [pmid: 6343456].
Greenwell H, Bissada NF. Variations in subgingival microflora from healthy and intervention sites using probing depth and bacteriologic identification criteria. J Periodontol. 1984;55:391-397. [pmid: 6379140].
Greer N, Mosser G, Logan G, Halaas GW. A practical approach to evidence grading. Joint Commission J Qual Improv. 2000;26:700-712.
Gregg RH2, McCarthy D. Laser periodontal therapy: case reports. Dent Today. 2001;20:74-81. [pmid: 11665421].
Griffiths GS, Smart GJ, Bulman JS, Weiss G, Shrowder J, Newman HN. Comparison of clinical outcomes following treatment of chronic adult periodontitis with subgingival scaling or subgingival scaling plus metronidazole gel. J Clin Periodontol. 2000;27:910-917. [pmid: 11140558].
Grisi DC, Salvador SL, Figueiredo LC, Souza SL, Novaes AB, Grisi MF. Effect of a controlled-release chlorhexidine chip on clinical and microbiological parameters of periodontal syndrome. J Clin Periodontol. 2002;29:875-881. [pmid: 12445218].
Grossi SG, Skrepcinski FB, DeCaro T, et al. Treatment of periodontal disease in diabetics reduces glycated hemoglobin. J Periodontol. 1997;68:713-719. [pmid: 9287060].
Gunsolley JC, Califano JV, Koertge TE, Burmeister JA, Cooper LC, Schenkein HA. Longitudinal assessment of early onset periodontitis. J Periodontol. 1995;66:321-328. [pmid: 7623250].
Gunsolley JC, Yeung GM, Butler JH, Waldrop TC. Is loss of attachment due to root planning and scaling in sites with minimal probing depths a statistical or real occurrence?. J Periodontol. 2001;72:349-353. [pmid: 11327062].
Gunsolley JC, Zambon JJ, Mellott CA, Brooks CN, Kaugars CC. Maintenance therapy in young adults with severe generalized periodontitis. J Periodontol. 1994;65:274-279. [pmid: 8164122].
Guyatt GH, Haynes RB, Jaeschke RZ, et al. Users' Guides to the Medical Literature: XXV. Evidence-based medicine: principles for applying the Users' Guides to patient care. Evidence- Based Medicine Working Group. JAMA. 2000;284:1290-1296. [pmid: 10979117].
Haerian A, Adonogianaki E, Mooney J, Manos A, Kinane DF. Effects of treatment on gingival crevicular collagenase, stromelysin and tissue inhibitor of metalloproteinases and their ability to predict response to treatment. J Clin Periodontol. 1996;23:83-91. [pmid: 8849843].
Haffajee AD, Cugini MA, Dibart S, Smith C, Kent RLJ, Socransky SS. Clinical and microbiological features of subjects with adult periodontitis who responded poorly to scaling and root planing. J Clin Periodontol. 1997;24:767-776. [pmid: 9350562].
Haffajee AD, Dibart S, Kent RLJ, Socransky SS. Clinical and microbiological changes associated with the use of 4 adjunctive systemically administered agents in the treatment of periodontal infections. J Clin Periodontol. 1995;22:618-627. [pmid: 8583019].
Haffajee AD, Socransky SS. Microbial etiological agents of destructive periodontal diseases. Periodontol 2000. 1994;5:78-111. [pmid: 9673164].
Hagiwara S, Iida M, Ishikawa I. [Clinical and microbiological study concerning effects of scaling and root planing. 2. The effects of mechanical debridement until one year and of minocycline application topically]. [Japanese]. Kokubyo Gakkai Zasshi - the Journal of the Stomatological Society, Japan. 1993;60:301-312. [pmid: 8345248].
Hakkarainen K. Relative influence of scaling and root planing and occlusal adjustment on sulcular fluid flow. J Periodontol. 1986;57:681-684. [pmid: 3550034].
Hakkarainen K, Ainamo J. Longitudinal measurements of sulcular fluid flow after debridement of deep pockets. Proc Finn Dent Soc. 1982;78:20-25. [pmid: 7048300].
Hakkarainen K, Uitto VJ, Ainamo J. Collagenase activity and protein content of sulcular fluid after scaling and occlusal adjustment of teeth with deep periodontal pockets. J Periodontal Res. 1988;23:204-210. [pmid: 2841442].
Hammerle CH, Ingold HP, Lang NP. Evaluation of clinical and radiographic scoring methods before and after initial periodontal therapy. J Clin Periodontol. 1990;17:255-263. [pmid: 2189898].
Hanioka T, Tanaka M, Ojima M, Shizukuishi S, Folkers K. Effect of topical application of coenzyme Q10 on adult periodontitis. Mol Aspects Med. 1994;15:241-249.
Hanookai D, Nowzari H, Contreras A, Morrison JL, Slots J. Herpesviruses and periodontopathic bacteria in Trisomy 21 periodontitis. J Periodontol. 2000;71:376-384. [pmid: 10776924].
Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20:21-35. [pmid: 11306229].
Hayes C, Antczak-Bouckoms A, Burdick E. Quality assessment and meta-analysis of systemic tetracycline use in chronic adult periodontitis. J Clin Periodontol. 1992;19:164-168. [pmid: 1532607].
He L, Geng S, Cao C. [The efficacy of the chlorhexidine chip following scaling and root planing (SRP) and compared to SRP alone]. Zhonghua Kou Qiang Yi Xue Za Zhi. 2001;36:443-445. [pmid: 11930721].
He T, Hayashi J, Yamamoto M, Ishikawa I. Genotypic characterization of Actinobacillus actinomycetemcomitans isolated from periodontitis patients by arbitrarily primed polymerase chain reaction. J Periodontol. 1998;69:69-75. [pmid: 9527564].
Heasman PA, Heasman L, Stacey F, McCracken GI. Local delivery of chlorhexidine gluconate (PerioChip) in periodontal maintenance patients. J Clin Periodontol. 2001;28:90-95. [pmid: 11142674].
Heijl L, Dahlen G, Sundin Y, Wenander A, Goodson JM. A 4-quadrant comparative study of periodontal treatment using tetracycline-containing drug delivery fibers and scaling. J Clin Periodontol. 1991;18:111-116. [pmid: 2005224].
Heijl L, Heden G, Svardstrom G, Ostgren A. Enamel matrix derivative (EMDOGAIN) in the treatment of intrabony periodontal defects. J Clin Periodontol. 1997;24:705-714. [pmid: 9310876].
Hellden LB, Listgarten MA, Lindhe J. The effect of tetracycline and/or scaling on human periodontal disease. J Clin Periodontol. 1979;6:222-230. [pmid: 393725].
Hellstrom MK, Ramberg P, Krok L, Lindhe J. The effect of supragingival plaque control on the subgingival microflora in human periodontitis. J Clin Periodontol. 1996;23:934-940. [pmid: 8915022].
Hemmings KW, Griffiths GS, Bulman JS. Detection of neutral protease (Periocheck) and BANA hydrolase (Perioscan) compared with traditional clinical methods of diagnosis and monitoring of chronic inflammatory periodontal disease. J Clin Periodontol. 1997;24:110-114. [pmid: 9062857].
Henderson RJ, Boyens JV, Holborow DW, Pack AR. Scaling and root-planing treatment with adjunctive subgingival minocycline. A clinical pilot study over six months, of sites adjacent to and remote from the antibiotic application. J Int Acad Periodontol. 2002;4:77-87. [pmid: 12670086].
Henke CJ, Genco RJ, Killoy WJ, Miller DP, Evans CJ, Finkelman RD. An economic evaluation of a chlorhexidine chip for treating chronic periodontitis: the CHIP (chlorhexidine in periodontitis) study. J Am Dent Assoc. 2001;132:1557-1569. [pmid: 11806071].
Henke CJ, Villa KF, Aichelmann-Reidy ME, et al. An economic evaluation of a chlorhexidine chip for treating chronic periodontitis: the CHIP (chlorhexidine in periodontitis) study. J Am Dent Assoc. 2001;132:1557-1569. [pmid: 11806071].
Hermann JS, Rieder C, Rateitschak KH, Hefti AF. Sonic and ultrasonic scalers in a clinical comparison. A study in non-instructed patients with gingivitis or slight adult periodontitis. Schweizer Monatsschrift Fur Zahnmedizin. 1995;105:165-170. [pmid: 7878417].
Herrera D, Sanz M, Jepsen S, Needleman I, Roldan S. Review article: A systematic review on the effect of systemic antimicrobials as an adjunct to scaling and root planing in periodontitis patients. J Clin Periodontol. 2002;29:139.
Higashi T, Okamoto H. The effect of ultrasonic irrigation before and after citric acid treatment on collagen fibril exposure: an in vitro SEM study. J Periodontol. 1995;66:887-891. [pmid: 8537872].
Hill RW, Ramfjord SP, Morrison EC, et al. Four types of periodontal treatment compared over two years. J Periodontol. 1981;52:655-662. [pmid: 7028941].
Hinrichs JE, Jarzembinski C, Hardie N, Aeppli D. Intrasulcular laser Doppler readings before and after root planing. J Clin Periodontol. 1995;22:817-823. [pmid: 8550856].
Hinrichs JE, Wolff LF, Pihlstrom BL, Schaffer EM, Liljemark WF, Bandt CL. Effects of scaling and root planing on subgingival microbial proportions standardized in terms of their naturally occurring distribution. J Periodontol. 1985;56:187-194. [pmid: 3889269].
Hirsch A, Attal U, Chai E, Goultschin J, Boyan BD, Schwartz Z. Root coverage and pocket reduction as combined surgical procedures. J Periodontol. 2001;72:1572-1579. [pmid: 11759869].
Ho KY, Huang JS, Tsai CC. Bone regeneration in advanced periodontitis lesions after a single episode of root planing--case report with ten-years of follow-up. Kao-Hsiung i Hsueh Ko Hsueh Tsa Chih [Kaohsiung Journal of Medical Sciences]. 1998;14:186-191.
Hoffman HG, Garcia-Palacios A, Patterson DR, Jensen M, Furness T3, Ammons WFJ. The effectiveness of virtual reality for dental pain control: a case study. Cyberpsychol Behav. 2001;4:527-535. [pmid: 11708732].
Hoffman ID. Familial occurrence of juvenile periodontitis with varied treatment of one of the siblings with five-year follow-up. Case report. J Periodontol. 1983;54:44-49. [pmid: 6338205].
Holzhausen M, Rossa C, Marcantonio Jr E, Nassar PO, Spolidorio DMP, Spolidorio LC. Effect of selective cyclooxygenase-2 inhibition on the development of ligature-induced periodontitis in rats. J Periodontol. 2002;73:1030-1036. [pmid: 12296588].
Horiba N, Maekawa Y, Yamauchi Y, Ito M, Matsumoto T, Nakamura H. Complement activation by lipopolysaccharides purified from gram-negative bacteria isolated from infected root canals. Oral Surg Oral Med Oral Pathol. 1992;74:648-651. [pmid: 1437068].
Horibe M, Watanabe H, Ishikawa I. Effect of periodontal treatments on serum IgG antibody titers against periodontopathic bacteria. J Clin Periodontol. 1995;22:510-515. [pmid: 7560233].
Hosaka Y, Saito A, Nakagawa T, Seida K, Yamada S, Okuda K. Effect of initial therapy on dynamics of immunogloblin G levels to some periodontopathic bacteria in serum and gingival crevicular fluid. Bull Tokyo Dent Coll. 1994;35:207-216. [pmid: 8689734].
Hou GL, Tsai CC, Weisgold AS. Periodontal and prosthetic therapy in severely advanced periodontitis by the use of the crown sleeve coping telescope denture. A longitudinal case report. Australian Dent J. 1997;42:169-174. [pmid: 9241927].
Hou GL, Tsai CC, Weisgold AS. Ultrasonic scaling therapy in advanced periodontitis. IV. A long-term study over six years. Kao-Hsiung i Hsueh Ko Hsueh Tsa Chih [Kaohsiung Journal of Medical Sciences]. 1997;13:103-116.
Hou GL, Wu YM, Liou MD, Tsai CC. The efficacy of nonsurgical periodontal therapy by ultrasonic scaling and root planning. I. Clinical evaluation of probing pocket depth. Kao-Hsiung i Hsueh Ko Hsueh Tsa Chih [Kaohsiung J Med Sci]. 1987;3:723-733.
Howell TH, Ridker PM, Ajani UA, Hennekens CH, Christen WG. Periodontal disease and risk of subsequent cardiovascular disease in U.S. male physicians. J Am Coll Cardiol. 2001;37:445-450. [pmid: 11216961].
Hugoson A, Ravald N, Fornell J, Johard G, Teiwik A, Gottlow J. Treatment of class II furcation involvements in humans with bioresorbable and nonresorbable guided tissue regeneration barriers. A randomized multi-center study. J Periodontol. 1995;66:624-634. [pmid: 7562355].
Hujoel PP, Loesche WJ. Efficiency of split-mouth designs. J Clin Periodontol. 1990;17:722-728. [pmid: 2262586].
Hujoel PP, Powell LV, Kiyak HA. The effects of simple interventions on tooth mortality: findings in one trial and implications for future studies. J Dent Res. 1997;76:867-874. [pmid: 9126183].
Hung HC, Douglass CW. Meta-analysis of the effect of scaling and root planing, surgical treatment and antibiotic therapies on periodontal probing depth and attachment loss. J Clin Periodontol. 2002;29:975-986. [pmid: 12472990].
Imrey PB, Chilton NW, Pihlstrom BL, et al. Proposed guidelines for American Dental Association acceptance of products for professional, non-surgical treatment of adult periodontitis. Task Force on Design and Analysis in Dental and Oral Research. J Periodontal Res. 1994;29:348-360. [pmid: 7880252].
Isidor F, Attstrom R, Karring T. Regeneration of alveolar bone following surgical and non-surgical periodontal treatment. J Clin Periodontol. 1985;12:687-696. [pmid: 3863840].
Isidor F, Karring T, Attstrom R. The effect of root planing as compared to that of surgical treatment. J Clin Periodontol. 1984;11:669-681. [pmid: 6389611].
Istatkov V, Yordanov Y, Bakalov R, Zhivkov S. Analgesic effect in stomatology. (Clinical-experimental and clinical studies). MBI (Medico-Biologic Information). 1989;5:12-15.
Itic J, Serfaty R. Clinical effectiveness of subgingival irrigation with a pulsated jet irrigator versus syringe. [erratum appears in J Periodontol 1992 Jun;63(6):565.]. J Periodontol. 1992;63:174-181. [pmid: 1593412].
Izumi Y, Hiwatashi-Horinouchi K, Furuichi Y, Sueda T. Influence of different curette insertion depths on the outcome of non-surgical periodontal treatment. J Clin Periodontol. 1999;26:716-722. [pmid: 10589807].
Izumi Y, Taniguchi T, Maruyama Y, Sueda T. Effective periodontal treatment in a patient with type IIA von Willebrand's disease: report of a case. J Periodontol. 1999;70:548-553. [pmid: 10368060].
Jeffcoat M. Clinical significance: an introduction. J Clin Periodontol. 2002;29:5.
Jeffcoat M. What is clinical significance? J Clin Periodontol. 2002;29 Suppl 2:30-32.
Jeffcoat MK, Bray KS, Ciancio SG, et al. Adjunctive use of a subgingival controlled-release chlorhexidine chip reduces probing depth and improves attachment level compared with scaling and root planing alone. J Periodontol. 1998;69:989-997. [pmid: 9776027].
Jeffcoat MK, Geurs NC, Magnusson I, et al. Intrapocket anesthesia for scaling and root planing: results of a double-blind multicenter trial using lidocaine prilocaine dental gel. J Periodontol. 2001;72:895-900. [pmid: 11495138].
Jeffcoat MK, Page R, Reddy M, et al. Use of digital radiography to demonstrate the potential of naproxen as an adjunct in the treatment of rapidly progressive periodontitis. J Periodontal Res. 1991;26:415-421. [pmid: 1832454].
Jeffcoat MK, Palcanis KG, Weatherford TW, Reese M, Geurs NC, Flashner M. Use of a biodegradable chlorhexidine chip in the treatment of adult periodontitis: clinical and radiographic findings. J Periodontol. 2000;71:256-22. [pmid: 10711616].
Jeffcoat MK, Reddy MS, Moreland LW, Koopman WJ. Effects of nonsteroidal antiinflammatory drugs on bone loss in chronic inflammatory disease. Ann N Y Acad Sci. 1993;696:292-302. [pmid: 8109834].
Jenkins WM, Said SH, Radvar M, Kinane DF. Effect of subgingival scaling during supportive therapy. J Clin Periodontol. 2000;27:590-596. [pmid: 10959785].
Jeong SN, Han SB, Lee SW, Magnusson I. Effects of tetracycline-containing gel and a mixture of tetracycline and citric acid-containing gel on non-surgical periodontal therapy. J Periodontol. 1994;65:840-847. [pmid: 7990020].
Jervoe-Storm PM, Frentzen M. [Ultrasonic root cleansing with 0.1% chlorhexidine gluconate as a coolant]. [German]. Deutsche Zahnarztliche Zeitschrift. 1991;46:493-496. [pmid: 1817915].
Jin L, Wong KY, Leung WK, Corbet EF. Comparison of treatment response patterns following scaling and root planing in smokers and non-smokers with untreated adult periodontitis. J Clin Dent. 2000;11:35-41. [pmid: 11460281].
Johnson GK, Reinhardt RA, DuBois LM. Comparison of closed and fiber-optic-augmented sonic scaling performed by general dentists. Gen Dent. 1991;39:333-338. [pmid: 1812050].
Johnson LR, Stoller NH, Polson A, Harrold CQ, Ryder M, Garrett S. The effects of subgingival calculus on the clinical outcomes of locally- delivered controlled-release doxycycline compared to scaling and root planing. J Clin Periodontol. 2002;29:87-91. [pmid: 11895536].
Johnson V, Johnson BD, Sims TJ, et al. Effects of treatment on antibody titer to Porphyromonas gingivalis in gingival crevicular fluid of patients with rapidly progressive periodontitis. J Periodontol. 1993;64:559-565. [pmid: 8393109].
Jones AA, Kornman KS, Newbold DA, Manwell MA. Clinical and microbiological effects of controlled-release locally delivered minocycline in periodontitis. J Periodontol. 1994;65:1058-1066. [pmid: 7853130].
Joyston-Bechal S, Smales FC, Duckworth R. Effect of metronidazole on chronic periodontal disease in subjects using a topically applied chlorhexidine gel. J Clin Periodontol. 1984;11:53-62. [pmid: 6363462].
Joyston-Bechal S, Smales FC, Duckworth R. A follow-up study 3 years after metronidazole therapy for chronic periodontal disease. J Clin Periodontol. 1986;13:944-949. [pmid: 3540025].
Kaldahl WB, Kalkwarf KL, Patil KD, Dyer JK, Bates REJ. Evaluation of four modalities of periodontal therapy. Mean probing depth, probing attachment level and recession changes. J Periodontol. 1988;59:783-793. [pmid: 3066888].
Kaldahl WB, Kalkwarf KL, Patil KD, Molvar MP. Relationship of gingival bleeding, gingival suppuration, and supragingival plaque to attachment loss. J Periodontol. 1990;61:347-351. [pmid: 2195151].
Kaldahl WB, Kalkwarf KL, Patil KD, Molvar MP. Responses of four tooth and site groupings to periodontal therapy. J Periodontol. 1990;61:173-179. [pmid: 2181110].
Kaldahl WB, Kalkwarf KL, Patil KD, Molvar MP, Dyer JK. Long-term evaluation of periodontal therapy: I. Response to 4 therapeutic modalities. J Periodontol. 1996;67:93-102. [pmid: 8667142].
Kaldahl WB, Kalkwarf KL, Patil KD, Molvar MP, Dyer JK. Long-term evaluation of periodontal therapy: II. Incidence of sites breaking down. J Periodontol. 1996;67:103-108. [pmid: 8667129].
Kalkwarf KL, Kaldahl WB, Patil KD. Evaluation of furcation region response to periodontal therapy. J Periodontol. 1988;59:794-804. [pmid: 3066889].
Kalkwarf KL, Kaldahl WB, Patil KD. Patient preference regarding 4 types of periodontal therapy following 3 years of maintenance follow-up. J Clin Periodontol. 1992;19:788-793. [pmid: 1452806].
Kamma JJ, Lygidakis NA, Nakou M. Subgingival microflora and treatment in prepubertal periodontitis associated with chronic idiopathic neutropenia. J Clin Periodontol. 1998;25:759-765. [pmid: 9763332].
Kamma JJ, Nakou M, Mitsis FJ. The clinical and microbiological effects of systemic ornidazole in sites with and without subgingival debridement in early-onset periodontitis patients. J Periodontol. 2000;71:1862-1873. [pmid: 11156043].
Kasetsuwan J, Amornchat C, Sirirat M. [Comparison of some subgingival microflora from juvenile periodontitis before and after scaling and root planing]. [Thai]. J Dent Assoc Thailand. 1991;41:24-31.
Kawanami M, Sugaya T, Gama H, Tsukuda N, Tanaka S, Kato H. Periodontal healing after replantation of intentionally rotated teeth with healthy and denuded root surfaces. Dent Traumatol. 2001;17:127-133. [pmid: 11499762].
Kazakos GM, Cobb CM, Morrison SL, Barker BF, Killoy WJ. Gingival response to subgingival placement of monolithic tetracycline-impregnated fibers: microscopic observations. Int J Periodontics Restorative Dent. 1993;13:150-171. [pmid: 8360006].
Kelm GR, Buchanan W, Meredith MP, et al. Evaluation of ketorolac concentrations in plasma and gingival crevicular fluid following topical treatment with oral rinses and dentifrices. J Pharm Sci. 1996;85:842-847. [pmid: 8863274].
Kerry GJ, Morrison EC, Ramfjord SP, et al. Effect of periodontal treatment on tooth mobility. J Periodontol. 1982;53:635-638. [pmid: 6754904].
Killoy WJ. Assessing the effectiveness of locally delivered chlorhexidine in the treatment of periodontitis. J Am Dent Assoc. 1999;130:567-570. [pmid: 10203909].
Killoy WJ. The clinical significance of local chemotherapies. J Clin Periodontol. 2002;29 Suppl 2:22-29. [pmid: 12010521].
Killoy WJ. The use of locally delivered chlorhexidine in the treatment of periodontitis. Clinical results. J Clin Periodontol. 1998;25:953-958. ; discussion 978-979. [pmid: 9839852].
Kim KJ, Kim DK, Chung CP, Son S. Longitudinal monitoring for disease progression of localized juvenile periodontitis. J Periodontol. 1992;63:806-811. [pmid: 1328592].
Kim TS, Holle R, Hausmann E, Eickholz P. Long-term results of guided tissue regeneration therapy with non-resorbable and bioabsorbable barriers. II. A case series of infrabony defects. J Periodontol. 2002;73:450-459. [pmid: 11990447].
Kimura S, Toda H, Morita K, et al. [Microbiological evaluation of topical application of the controlled release strips containing ofloxacin (PT-01) in the human periodontal pocket]. [Japanese]. Nippon Shishubyo Gakkai Kaishi - J Japan Assoc Periodontology. 1988;30:1156-1167.
Kimura S, Toda H, Shimabukuro Y, et al. Topical chemotherapy in human periodontitis using a new controlled-release insert containing ofloxacin. I. Microbiological observation. J Periodontal Res. 1991;26:33-41. [pmid: 1825332].
Kinane DF. Local antimicrobial therapies in periodontal disease. Ann R Australas Coll Dent Surg. 2000;15:57-60. [pmid: 11709978].
Kinane DF. Periodontal diagnostics. Ann R Australas Coll Dent Surg. 2000;15:34-41. [pmid: 11709970].
Kinane DF, Radvar M. The effect of smoking on mechanical and antimicrobial periodontal therapy. J Periodontol. 1997;68:467-472. [pmid: 9182742].
Kinane DF, Radvar M. A six-month comparison of three periodontal local antimicrobial therapies in persistent periodontal pockets. J Periodontol. 1999;70:1-7. [pmid: 10052765].
Kleinfelder JW, Lange DE, Bocker W. Some effects of non-surgical therapy on gingival inflammatory cell subsets in patients with adult and early-onset periodontitis. J Periodontol. 2000;71:1561-1566. [pmid: 11063388].
Klinge B, Attstrom R, Karring T, Kisch J, Lewin B, Stoltze K. 3 regimens of topical metronidazole compared with subgingival scaling on periodontal pathology in adults. J Clin Periodontol. 1992;19:708-714. [pmid: 1447391].
Knowles J, Burgett F, Morrison E, Nissle R, Ramfjord S. Comparison of results following three modalities of periodontal therapy related to tooth type and initial pocket depth. J Clin Periodontol. 1980;7:32-47. [pmid: 6988468].
Kobayashi T, Satoh E, Sugita N, et al. [A rapid diagnosis for periodontitis based on the enzymatic activity of periodontopathic bacteria. The application of the SK-013 to the judgement on the effect of initial preparation]. [Japanese]. Nippon Shishubyo Gakkai Kaishi - J Japan Assoc Periodontology. 1990;32:249-260.
Kobayashi T, Yamamoto K, Sugita N, et al. The Fcgamma receptor genotype as a severity factor for chronic periodontitis in Japanese patients. J Periodontol. 2001;72:1324-1331. [pmid: 11699473].
Kocher T, Konig J, Dzierzon U, Sawaf H, Plagmann HC. Disease progression in periodontally treated and untreated patients--a retrospective study. J Clin Periodontol. 2000;27:866-872. [pmid: 11073331].
Kocher T, Konig J, Hansen P, Ruhling A. Subgingival polishing compared to scaling with steel curettes: a clinical pilot study. J Clin Periodontol. 2001;28:194-199. [pmid: 11168746].
Kocher T, Langenbeck M, Ruhling A, Plagmann HC. Subgingival polishing with a teflon-coated sonic scaler insert in comparison to conventional instruments as assessed on extracted teeth. (I) Residual deposits. J Clin Periodontol. 2000;27:243-249. [pmid: 10783837].
Kocher T, Plagmann HC. Root debridement of single-rooted teeth with a diamond-coated sonic scaler insert during flap surgery. A pilot study. J Clin Periodontol. 1999;26:201-205. [pmid: 10223389].
Kocher T, Topoll H. [Experimental studies on the effect of supra- and sub-gingival scaling with hand or ultrasonic instruments on the reduction of inflammation of the marginal gingiva in various oral hygiene methods]. [German]. Deutsche Zahnarztliche Zeitschrift. 1985;40:771-774. [pmid: 3913590].
Konig J, Plagmann HC, Langenfeld N, Kocher T. Retrospective comparison of clinical variables between compliant and non-compliant patients. J Clin Periodontol. 2001;28:227-232. [pmid: 11284535].
Kornman KS, Newman MG, Moore DJ, Singer RE. The influence of supragingival plaque control on clinical and microbial outcomes following the use of antibiotics for the treatment of periodontitis. J Periodontol. 1994;65:848-854. [pmid: 7990021].
Kornman KS, Robertson PB. Clinical and microbiological evaluation of therapy for juvenile periodontitis. J Periodontol. 1985;56:443-446. [pmid: 3915012].
Koshy C, Varma BR, Bhat KM. Evaluation of efficacy of Sofscale. A clinical and SEM study. Indian J Dent Res. 1999;10:63-67. [pmid: 10865393].
Kunihira DM, Caine FA, Palcanis KG, Best AM, Ranney RR. A clinical trial of phenoxymethyl penicillin for adjunctive treatment of juvenile periodontitis. J Periodontol. 1985;56:352-358. [pmid: 3925112].
Lafferty TA, Gher ME, Gray JL. Comparative SEM study on the effect of acid etching with tetracycline HCl or citric acid on instrumented periodontally-involved human root surfaces. J Periodontol. 1993;64:689-693. [pmid: 8410605].
Lamb JW3, Greenwell H, Drisko C, Henderson RD, Scheetz JP, Rebitski G. A comparison of porous and non-porous teflon membranes plus demineralized freeze-dried bone allograft in the treatment of class II buccal/lingual furcation defects: a clinical reentry study. J Periodontol. 2001;72:1580-1587. [pmid: 11759870].
Lamster IB. The host response in gingival crevicular fluid: potential applications in periodontitis clinical trials. J Periodontol. 1992;63:1117-1123. [pmid: 1479531].
Lamster IB, Holmes LG, Gross KB, et al. The relationship of beta-glucuronidase activity in crevicular fluid to probing attachment loss in patients with adult periodontitis. Findings from a multicenter study. J Clin Periodontol. 1995;22:36-44. [pmid: 7706537].
Landsberg CJ, Shimshoni Z. Management of periodontally involved maxillary anterior dentition: a 10-year report. Pract Periodontics Aesthet Dent. 2000;12:165-167. [pmid: 11404958].
Langendijk-Genevaux PS, Hanssen JT, van der Hoeven JS. Decrease of sulfate-reducing bacteria after initial periodontal treatment. J Dent Res. 2001;80:1637-1642. [pmid: 11597024].
Laurell L. Periodontal healing after scaling and root planing with the Kavo Sonicflex and Titan-S sonic scalers. Swed Dent J. 1990;14:171-177. [pmid: 2255995].
Laurell L, Pettersson B. Periodontal healing after treatment with either the Titan-S sonic scaler or hand instruments. Swed Dent J. 1988;12:187-192. [pmid: 3064333].
Lavigne CK, Nauman RK, Munley MM, Suzuki JB. In vitro evaluation of air-powder polishing as an adjunct to ultrasonic scaling on periodontally involved root surfaces. J Dent Hyg. 1988;62:504-509. [pmid: 3076192].
Lazzaro AJ, Bissada NF. Clinical and microbiologic changes following the irrigation of periodontal pockets with metronidazole or stannous fluoride. Periodontal Case Reports. 1989;11:12-19. [pmid: 2629007].
Lee JB, Lee MH, Kim SJ, Choi JI. Combined periodontal-prosthodontic treatment of early-onset periodontitis--an alternative to implant therapy. Int J Periodontics Restorative Dent. 2000;20:604-611. [pmid: 11203597].
Lekovic V, Camargo PM, Weinlaender M, Vasilic N, Kenney EB. Comparison of platelet-rich plasma, bovine porous bone mineral, and guided tissue regeneration versus platelet-rich plasma and bovine porous bone mineral in the treatment of intrabony defects: a reentry study. J Periodontol. 2002;73:198-205. [pmid: 11895286].
Lekovic V, Kenney EB, Carranza FA, Martignoni M. The use of autogenous periosteal grafts as barriers for the treatment of Class II furcation involvements in lower molars. J Periodontol. 1991;62:775-780. [pmid: 1765940].
Leon LE, Vogel RI. A comparison of the effectiveness of hand scaling and ultrasonic debridement in furcations as evaluated by differential dark-field microscopy. J Periodontol. 1987;58:86-94. [pmid: 3546672].
Leyes Borrajo JL, Garcia VL, Lopez CG, Rodriguez-Nunez I, Garcia FM, Gallas TM. Efficacy of chlorhexidine mouthrinses with and without alcohol: a clinical study. J Periodontol. 2002;73:317-321. [pmid: 11924590].
Lie T, Bruun G, Boe OE. Effects of topical metronidazole and tetracycline in treatment of adult periodontitis. J Periodontol. 1998;69:819-827. [pmid: 9706861].
Likar R, Koppert W, Blatnig H, et al. Efficacy of peripheral morphine analgesia in inflamed, non-inflamed and perineural tissue of dental surgery patients. J Pain Symptom Manage. 2001;21:330-337. [pmid: 11312048].
Liljemark WF, Bloomquist CG, Bandt CL, Pihlstrom BL, Hinrichs JE, Wolff LF. Comparison of the distribution of Actinomyces in dental plaque on inserted enamel and natural tooth surfaces in periodontal health and disease. Oral Microbiol Immunol. 1993;8:5-15. [pmid: 8510984].
Lindhe J, Heijl L, Goodson JM, Socransky SS. Local tetracycline delivery using hollow fiber devices in periodontal therapy. J Clin Periodontol. 1979;6:141-149.
Lindhe J, Liljenberg B. Treatment of localized juvenile periodontitis. Results after 5 years. J Clin Periodontol. 1984;11:399-410. [pmid: 6378984].
Lindhe J, Liljenberg B, Adielsson B. Effect of long-term tetracycline therapy on human periodontal disease. J Clin Periodontol. 1983;10:590-601. [pmid: 6581174].
Lindhe J, Nyman S. Long-term maintenance of patients treated for advanced periodontal disease. J Clin Periodontol. 1984;11:504-514. [pmid: 6384275].
Lindhe J, Nyman S. Scaling and granulation tissue removal in periodontal therapy. J Clin Periodontol. 1985;12:374-388. [pmid: 3891796].
Lindhe J, Westfelt E, Nyman S, Socransky SS, Heijl L, Bratthall G. Healing following surgical/non-surgical treatment of periodontal disease. A clinical study. J Clin Periodontol. 1982;9:115-128. [pmid: 7042768].
Listgarten MA, Grossberg D, Schwimer C, Vito A, Gaffar A. Effect of subgingival irrigation with tetrapotassium peroxydiphosphate on scaled and untreated periodontal pockets. J Periodontol. 1989;60:4-11. [pmid: 2646418].
Listgarten MA, Lindhe J, Hellden L. Effect of tetracycline and/or scaling on human periodontal disease. Clinical, microbiological, and histological observations. J Clin Periodontol. 1978;5:246-271. [pmid: 363749].
Liu CM, Hou LT, Wong MY, Lan WH. Comparison of Nd:YAG laser versus scaling and root planing in periodontal therapy. J Periodontol. 1999;70:1276-1282. [pmid: 10588490].
Loesche WJ, Giordano J, Hujoel PP. The utility of the BANA test for monitoring anaerobic infections due to spirochetes (Treponema denticola) in periodontal disease. J Dent Res. 1990;69:1696-1702. [pmid: 2212216].
Loesche WJ, Giordano JR. Metronidazole in periodontitis V: debridement should precede medication. Compendium - Supplement. 1994;15:1198. , 1201, 1203 passim; quiz 1218.
Loesche WJ, Giordano JR, Hujoel P, Schwarcz J, Smith BA. Metronidazole in periodontitis: reduced need for surgery. J Clin Periodontol. 1992;19:103-112. [pmid: 1602034].
Loesche WJ, Grossman N, Giordano J. Metronidazole in periodontitis (IV). The effect of patient compliance on treatment parameters. J Clin Periodontol. 1993;20:96-104. [pmid: 8436638].
Loesche WJ, Schmidt E, Smith BA, Caffessee R, Stoll J. Metronidazole therapy for periodontitis. J Periodontal Res. 1987;22:224-226. [pmid: 2955104].
Loesche WJ, Schmidt E, Smith BA, Morrison EC, Caffesse R, Hujoel PP. Effects of metronidazole on periodontal treatment needs. J Periodontol. 1991;62:247-257. [pmid: 2037955].
Loesche WJ, Syed SA, Morrison EC, Kerry GA, Higgins T, Stoll J. Metronidazole in periodontitis. I. Clinical and bacteriological results after 15 to 30 weeks. J Periodontol. 1984;55:325-335. [pmid: 6376759].
Lofthus JE, Waki MY, Jolkovsky DL, et al. Bacteremia following subgingival irrigation and scaling and root planing. J Periodontol. 1991;62:602-607. [pmid: 1770419].
Lohr KN, Carey TS. Assessing "best evidence": issues in grading the quality of studies for systematic reviews. Jt Comm J Qual Improv. 1999;25:470-479. [pmid: 10481816].
Loos B, Claffey N, Egelberg J. Clinical and microbiological effects of root debridement in periodontal furcation pockets. J Clin Periodontol. 1988;15:453-463. [pmid: 3053787].
Loos B, Kiger R, Egelberg J. An evaluation of basic periodontal therapy using sonic and ultrasonic scalers. J Clin Periodontol. 1987;14:29-33. [pmid: 3543066].
Lopez NJ, Gamonal JA. Effects of metronidazole plus amoxicillin in progressive untreated adult periodontitis: Results of a single 1-week course after 2 and 4 months. J Periodontol. 1998;69:1291-1298. [pmid: 9848540].
Lopez NJ, Gamonal JA, Martinez B. Repeated metronidazole and amoxicillin treatment of periodontitis. A follow-up study. J Periodontol. 2000;71:79-89. [pmid: 10695942].
Lovelace TB, Mellonig JT, Meffert RM, Jones AA, Nummikoski PV, Cochran DL. Clinical evaluation of bioactive glass in the treatment of periodontal osseous defects in humans. J Periodontol. 1998;69:1027-1035. [pmid: 9776031].
Lowenguth RA, Chin I, Caton JG, et al. Evaluation of periodontal treatments using controlled-release tetracycline fibers: microbiological response. J Periodontol. 1995;66:700-707. [pmid: 7473013].
Luder HU, Zappa U. Nature and attachment of cementum formed under guided conditions in human teeth. An electron microscopic study. J Periodontol. 1998;69:889-898. [pmid: 9736372].
Lyne SM, Glasscock ND, Allen DS. Clinical effectiveness of hydrogen peroxide-sodium bicarbonate paste on periodontitis treated with and without scaling and root planing. Dent Hyg. 1986;60:450-455.
MacAlpine R, Magnusson I, Kiger R, Crigger M, Garrett S, Egelberg J. Antimicrobial irrigation of deep pockets to supplement oral hygiene instruction and root debridement. I. Bi-weekly irrigation. J Clin Periodontol. 1985;12:568-577. [pmid: 3894436].
Machtei EE, Ben-Yehouda A. The effect of post-surgical flap placement on probing depth and attachment level: a 2-year longitudinal study. J Periodontol. 1994;65:855-858. [pmid: 7990022].
Machtei EE, Cho MI, Dunford R, Norderyd J, Zambon JJ, Genco RJ. Clinical, microbiological, and histological factors which influence the success of regenerative periodontal therapy. J Periodontol. 1994;65:154-161. [pmid: 8158512].
Machtei EE, Schmidt M, Hausmann E, et al. Outcome variables in periodontal research: means and threshold-based site changes. J Periodontol. 2000;71:555-561. [pmid: 10807118].
Magnusson I. The use of locally delivered metronidazole in the treatment of periodontitis. Clinical results. J Clin Periodontol. 1998;25:959-963. ; discussion 978-979. [pmid: 9839853].
Magnusson I, Lindhe J, Yoneyama T, Liljenberg B. Recolonization of a subgingival microbiota following scaling in deep pockets. J Clin Periodontol. 1984;11:193-207. [pmid: 6368611].
Mailhot JM, Potempa J, Stein SH, et al. A relationship between proteinase activity and clinical parameters in the treatment of periodontal disease. J Clin Periodontol. 1998;25:578-584. [pmid: 9696259].
Margiotta V, Gallo P, D'Angelo F. [Changes in the alveolar bone after periodontal therapy. A follow-up by computerized radiographic analysis]. [Italian]. Minerva Stomatol. 1994;43:461-472. [pmid: 7700223].
Massad JJ. An integrated approach to optimizing orofacial health, function, and esthetics: a 5-year retrospective study. Int J Periodontics Restorative Dent. 1998;18:70-79. [pmid: 9558558].
Matisko MW, Bissada NF. Short-term sequential administration of amoxicillin/clavulanate potassium and doxycycline in the treatment of recurrent/progressive periodontitis. J Periodontol. 1993;64:553-558. [pmid: 8393108].
Matthijs S, Adriaens PA. Chlorhexidine varnishes: a review. J Clin Periodontol. 2002;29:1-8. [pmid: 11846842].
Mattson JS, McLey LL, Jabro MH. Treatment of intrabony defects with collagen membrane barriers. Case reports. J Periodontol. 1995;66:635-645. [pmid: 7562356].
Maze GI, Reinhardt RA, Agarwal RK, et al. Response to intracrevicular controlled delivery of 25% tetracycline from poly(lactide/glycolide) film strips in SPT patients. J Clin Periodontol. 1995;22:860-867. [pmid: 8550863].
McCulloch CAG, Birek P, Overall C, Aitken S, Lee W, Kulkarni G. Randomized controlled trial of Doxycycline in prevention of recurrent periodontitis in high-risk patients: Antimicrobial activity and collagenase inhibition. J Clin Periodontol. 1990;17:616-622. [pmid: 2174446].
McDonald FL, Saari JT, Davis SS. A comparison of tooth accumulated materials from quadrants treated surgically or nonsurgically. J Periodontol. 1977;48:147-150. [pmid: 320304].
McFall WT Jr. Tooth loss in 100 treated patients with periodontal disease. A long- term study. J Periodontol. 1982;53:539-549. [pmid: 6957591].
McGuire MK. Prognosis versus actual outcome: a long-term survey of 100 treated periodontal patients under maintenance care. J Periodontol. 1991;62:51-58. [pmid: 2002432].
Meinberg TA, Barnes CM, Dunning DG, Reinhardt RA. Comparison of conventional periodontal maintenance versus scaling and root planing with subgingival minocycline. J Periodontol. 2002;73:167-172. [pmid: 11895281].
Michalowicz BS, Pihlstrom BL, Drisko CL, et al. Evaluation of periodontal treatments using controlled-release tetracycline fibers: maintenance response. J Periodontol. 1995;66:708-715. [pmid: 7473014].
Miller LS, Manwell MA, Newbold D, et al. The relationship between reduction in periodontal inflammation and diabetes control: a report of 9 cases. J Periodontol. 1992;63:843-848. [pmid: 1403592].
Minabe M, Kodama T, Kogou T, et al. Clinical significance of antibiotic therapy in guided tissue regeneration with a resorbable membrane. Periodontal Clin Investig. 2001;23:20-30. [pmid: 11575110].
Minabe M, Takeuchi K, Kumada H, Umemoto T. The effect of root conditioning with minocycline HCl in removing endotoxin from the roots of periodontally-involved teeth. J Periodontol. 1994;65:387-392. [pmid: 8046553].
Minabe M, Takeuchi K, Nishimura T, Hori T, Umemoto T. Therapeutic effects of combined treatment using tetracycline-immobilized collagen film and root planing in periodontal furcation pockets. J Clin Periodontol. 1991;18:287-290. [pmid: 2066441].
Miyata H, Kamoi K. [Effects of irrigation of pockets on clinical symptoms and oral bacterial flora in patients with periodontal disease--with scaling and root planing]. [Japanese]. Nippon Shishubyo Gakkai Kaishi - Journal of the Japanese Association of Periodontology. 1987;29:76-90.
Moher D, Cook DJ, Eastwood S, Olkin I, Rennie D, Stroup DF. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Quality of Reporting of Meta-analyses. Lancet. 1999;354:1896-900. [pmid: 10584742].
Moher D, Schulz KF, Altman D. The CONSORT statement: revised recommendations for improving the quality of reports of parallel-group randomized trials. JAMA. 2001;285:1987-1991. [pmid: 11308435].
Mombelli A, Gusberti FA, Lang NP. Treatment of recurrent periodontal disease by root planing and Ornidazole (Tiberal). Clinical and microbiological findings. J Clin Periodontolgy. 1989;16:38-45.
Mombelli A, Lehmann B, Tonetti M, Lang NP. Clinical response to local delivery of tetracycline in relation to overall and local periodontal conditions. J Clin Periodontol. 1997;24:470-477. [pmid: 9226387].
Mombelli A, Nyman S, Bragger U, Wennstrom J, Lang NP. Clinical and microbiological changes associated with an altered subgingival environment induced by periodontal pocket reduction. J Clin Periodontol. 1995;22:780-787. [pmid: 8682925].
Mombelli A, Schmid B, Rutar A, Lang NP. Local antibiotic therapy guided by microbiological diagnosis. J Clin Periodontol. 2002;29:743-749. [pmid: 12390571].
Mombelli A, Schmid B, Rutar A, Lang NP. Persistence patterns of Porphyromonas gingivalis, Prevotella intermedia/nigrescens, and Actinobacillus actinomyetemcomitans after mechanical therapy of periodontal disease. J Periodontol. 2000;71:14-21. [pmid: 10695934].
Mongardini C, van Steenberghe D, Dekeyser C, Quirynen M. One stage full- versus partial-mouth disinfection in the treatment of chronic adult or generalized early-onset periodontitis. I. Long-term clinical observations. J Periodontol. 1999;70:632-645. [pmid: 10397519].
Moran J, Addy M, Wade W, Newcombe R. The use of antimicrobial acrylic strips in the nonsurgical management of chronic periodontitis. Clinical Materials. 1990;6:123-135. [pmid: 10147516].
Moritz A, Schoop U, Goharkhay K, et al. Treatment of periodontal pockets with a diode laser. Lasers Surg Med. 1998;22:302-311. [pmid: 9671997].
Morrison SL, Cobb CM, Kazakos GM, Killoy WJ. Root surface characteristics associated with subgingival placement of monolithic tetracycline-impregnated fibers. J Periodontol. 1992;63:137-143. [pmid: 1552466].
Moseley R, Waddington RJ, Embery G. Hyaluronan and its potential role in periodontal healing. Dental Update. 2002;29:144-148. [pmid: 11989392].
Moskow BS. Longevity: a critical factor in evaluating the effectiveness of periodontal therapy. J Clin Periodontol. 1987;14:237-244. [pmid: 3294918].
Muller HP, Eger T. The overall significance of regenerative procedures in the treatment of furcations. Quintessence Int. 1997;28:321-328. [pmid: 9452695].
Muller HP, Hartmann J, Flores-de-Jacoby L. Clinical alterations in relation to the morphological composition of the subgingival microflora following scaling and root planing. J Clin Periodontol. 1986;13:825-832. [pmid: 3537017].
Muller HP, Heinecke A, Borneff M, Kiencke C, Knopf A, Pohl S. Eradication of Actinobacillus actinomycetemcomitans from the oral cavity in adult periodontitis. J Periodontal Res. 1998;33:49-58. [pmid: 9524321].
Muller HP, Lange DE, Muller RF. Failure of adjunctive minocycline-HCl to eliminate oral Actinobacillus actinomycetemcomitans. J Clin Periodontol. 1993;20:498-504. [pmid: 8354724].
Muramoto T, Taguchi S, Asazuma Y, et al. Relative influence of plaque control, scaling and root planing on occlusal sounds. J Oral Rehab. 1989;16:575-580.
Nakagawa T, Yamada S, Oosuka Y, et al. Clinical and microbiological study of local minocycline delivery (Periocline) following scaling and root planing in recurrent periodontal pockets. Bull Tokyo Dent Coll. 1991;32:63-70. [pmid: 1819445].
Nakou M, Kamma J, Gargalianos P, Laskaris G, Mitsis F. Periodontal microflora of HIV infected patients with periodontitis. Anaerobe. 1997;3:97-102. [pmid: 16887570].
Namgung YY, Yang MCK. Outlier reduction by an option-3 measurement scheme. Biometrics. 1994;50:173-182. [pmid: 8086600].
Nanba K, Ito K. Palatal radicular multigrooves associated with severe periodontal defects in maxillary central incisors. J Clin Periodontol. 2001;28:372-375. [pmid: 11314895].
Needleman IG, Giedrys-Leeper E, Tucker RJ, Worthington HV. Guided tissue regeneration for periodontal infra-bony defects. Cochrane Database Syst Rev. 2001;CD001724.
Neill ME, Mellonig JT. Clinical efficacy of the Nd:YAG laser for combination periodontitis therapy. Pract Periodontics Aesthet Dent. 1997;9:1-5. [pmid: 9573831].
Nelson SW. Subperiosteal and intraosseous connective tissue grafts for pocket reduction: a 9- to 13-year retrospective case series report. J Periodontol. 2001;72:1424-1435. [pmid: 11699486].
Nevins ML, Camelo M, Nevins M, et al. Human histologic evaluation of bioactive ceramic in the treatment of periodontal osseous defects. Int J Periodontics Restorative Dent. 2000;20:458-467. [pmid: 11203583].
Newman HN, Yeung FI, wan Yusof WZ, Addy M. Slow release metronidazole and a simplified mechanical oral hygiene regimen in the control of chronic periodontitis. J Clin Periodontol. 1984;11:576-582. [pmid: 6593329].
Newman MG, Kornman KS, Doherty FM. A 6-month multi-center evaluation of adjunctive tetracycline fiber therapy used in conjunction with scaling and root planing in maintenance patients: clinical results. J Periodontol. 1994;65:685-691. [pmid: 7608845].
Ng VW, Bissada NF. Clinical evaluation of systemic doxycycline and ibuprofen administration as an adjunctive treatment for adult periodontitis. J Periodontol. 1998;69:772-7726. [pmid: 9706854].
NHS Research and Development Centre of Evidence-Based Medicine. Levels of Evidence. accessed January 12, 2001. Web Page. Available at: http://www.york.ac.uk/inst/crd/.
Nichols FC, Levinbook H, Shnaydman M, Goldschmidt J. Prostaglandin E2 secretion from gingival fibroblasts treated with interleukin-1beta: effects of lipid extracts from Porphyromonas gingivalis or calculus. J Periodontal Res. 2001;36:142-152. [pmid: 11453112].
Niederman R, Abdelshehid G, Goodson JM. Periodontal therapy using local delivery of antimicrobial agents. Dent Clin North Am. 2002;46:665-77. , viii. [pmid: 12436823].
Novak MJ, Johns LP, Miller RC, Bradshaw MH. Adjunctive benefits of subantimicrobial dose doxycycline in the management of severe, generalized, chronic periodontitis. J Periodontol. 2002;73:762-769. [pmid: 12146536].
Noyan U, Yilmaz S, Kuru B, Kadir T, Acar O, Buget E. A clinical and microbiological evaluation of systemic and local metronidazole delivery in adult periodontitis patients. J Clin Periodontol. 1997;24:158-165. [pmid: 9083899].
Nylund K, Egelberg J. Antimicrobial irrigation of periodontal furcation lesions to supplement oral hygiene instruction and root debridement. J Clin Periodontol. 1990;17:90-95. [pmid: 2303575].
Nyman S, Westfelt E, Sarhed G, Karring T. Role of "diseased" root cementum in healing following treatment of periodontal disease. A clinical study. J Clin Periodontol. 1988;15:464-468. [pmid: 3053788].
O'Brien TP, Roszkowski MT, Wolff LF, Hinrichs JE, Hargreaves KM. Effect of a non-steroidal anti-inflammatory drug on tissue levels of immunoreactive prostaglandin E2, immunoreactive leukotriene, and pain after periodontal surgery. J Periodontol. 1996;67:1307-1316. [pmid: 8997678].
O'Leary R, Sved AM, Davies EH, Leighton TG, Wilson M, Kieser JB. The bactericidal effects of dental ultrasound on Actinobacillus actinomycetemcomitans and Porphyromonas gingivalis. An in vitro investigation. J Clin Periodontol. 1997;24:432-439. [pmid: 9205923].
Oberholzer R, Rateitschak KH. Root cleaning or root smoothing. An in vivo study. J Clin Periodontol. 1996;23:326-330. [pmid: 8739163].
Okada H, Kimura S, Ishikawa I, et al. [Topical application of the controlled release strips containing ofloxacin (PT-01) in periodontal therapy]. [Japanese]. Nippon Shishubyo Gakkai Kaishi - J Japan Assoc Periodontology. 1988;30:1141-1155.
Oosterwaal PJ, Mikx FH, van 't Hof MA, Renggli HH. Comparison of the antimicrobial effect of the application of chlorhexidine gel, amine fluoride gel and stannous fluoride gel in debrided periodontal pockets. J Clin Periodontol. 1991;18:245-251. [pmid: 1856305].
Oringer RJ. Modulation of the host response in periodontal therapy. J Periodontol. 2002;73:460-470. [pmid: 11990448].
Oringer RJ, Al-Shammari KF, Aldredge WA, et al. Effect of locally delivered minocycline microspheres on markers of bone resorption. J Periodontol. 2002;73:835-842. [pmid: 12211491].
Oringer RJ, Al-Shammari KF, Aldredge WA, et al. Effect of locally delivered minocycline micropheres on markers of bone resorption. J Periodontol. 2002;73:835-842. [pmid: 12211491].
Oringer RJ, Howell TH, Nevins ML, et al. Relationship between crevicular aspartate aminotransferase levels and periodontal disease progression. J Periodontol. 2001;72:17-24. [pmid: 11210069].
Orsini M, Orsini G, Benlloch D, et al. Comparison of calcium sulfate and autogenous bone graft to bioabsorbable membranes plus autogenous bone graft in the treatment of intrabony periodontal defects: a split-mouth study. J Periodontol. 2001;72:296-302. [pmid: 11327056].
Otogoto J, Ebashi S, Tanaka K, Fujikawa K, Ito K, Murai S. Subgingival plaque formation on single and polycrystal aluminum ceramics. J Nihon Univ Sch Dent. 1994;36:209-215. [pmid: 7989963].
Ozcan G, Taner IL, Doganay T, et al. Use of membranes containing 20% chlorhexidine and 40% doxycycline for treatment of chronic periodontal pockets. J Nihon Univ Sch Dent. 1994;36:191-198. [pmid: 7989961].
Page RC. Periodontitis and respiratory diseases: discussion, conclusions, and recommendations. Ann Periodontol. 2001;6:87-90. [pmid: 11887475].
Pais JM, Rosteiro FM. Nimesulide in the short-term treatment of inflammatory process of dental tissues: A double-blind controlled trial against oxyphenbutazone. J Int Med Res. 1983;11:149-154. [pmid: 6347746].
Palcanis KG. Surgical pocket therapy. Ann Periodontol. 1996;1:589-617. [pmid: 9118272].
Palmer RM, Matthews JP, Wilson RF. Adjunctive systemic and locally delivered metronidazole in the treatment of periodontitis: a controlled clinical study. Br Dent J. 1998;184:548-552. [pmid: 9682550].
Palmer RM, Matthews JP, Wilson RF. Non-surgical periodontal treatment with and without adjunctive metronidazole in smokers and non-smokers. J Clin Periodontol. 1999;26:158-163. [pmid: 10100041].
Palmer RM, Watts TL, Wilson RF. A double-blind trial of tetracycline in the management of early onset periodontitis. J Clin Periodontol. 1996;23:670-674. [pmid: 8841900].
Pannuti E, Trapani M, Verrocchi G, Paolantonio M, Cattabriga M. [A longitudinal clinical study of the efficacy of tetracyclines combined with root planing in patients with periodontal disease]. [Italian]. Minerva Stomatol. 1990;39:407-411. [pmid: 2199813].
Paolantonio M. Combined periodontal regenerative technique in human intrabony defects by collagen membranes and anorganic bovine bone. A controlled clinical study. J Periodontol. 2002;73:158-166. [pmid: 11895280].
Park JS, Suh JJ, Choi SH, et al. Effects of pretreatment clinical parameters on bioactive glass implantation in intrabony periodontal defects. J Periodontol. 2001;72:730-740. [pmid: 11453234].
Pedrazzoli V, Kilian M, Karring T. Comparative clinical and microbiological effects of topical subgingival application of metronidazole 25% dental gel and scaling in the treatment of adult periodontitis. J Clin Periodontol. 1992;19:715-722. [pmid: 1332988].
Pedrazzoli V, Kilian M, Karring T, Kirkegaard E. Effect of surgical and non-surgical periodontal treatment on periodontal status and subgingival microbiota. J Clin Periodontol. 1991;18:598-604. [pmid: 1795057].
Pepelassi EA, Tsiklakis K, Diamanti-Kipioti A. Radiographic detection and assessment of the periodontal endosseous defects. J Clin Periodontol. 2000;27:224-230. [pmid: 10783834].
Persson GR, Alves ME, Chambers DA, et al. A multicenter clinical trial of PerioGard in distinguishing between diseased and healthy periodontal sites. (I). Study design, methodology and therapeutic outcome. J Clin Periodontol. 1995;22:794-803. [pmid: 8682927].
Persson R, Svendsen J, Daubert K. A longitudinal evaluation of periodontal therapy using the CPITN index. J Clin Periodontol. 1989;16:569-574. [pmid: 2677056].
Pihlstrom B. Issues in the evaluation of clinical trials of periodontitis: a clinical perspective. J Periodontal Res. 1992;27:433-441. [pmid: 1507032].
Pihlstrom BL, McHugh RB, Oliphant TH, Ortiz-Campos C. Comparison of surgical and nonsurgical treatment of periodontal disease. A review of current studies and additional results after 61/2 years. J Clin Periodontol. 1983;10:524-541. [pmid: 6355204].
Pihlstrom BL, Oliphant TH, McHugh RB. Molar and nonmolar teeth compared over 6 1/2 years following two methods of periodontal therapy. J Periodontol. 1984;55:499-504. [pmid: 6384466].
Pihlstrom BL, Ortiz-Campos C, McHugh RB. A randomized four-years study of periodontal therapy. J Periodontol. 1981;52:227-242. [pmid: 7017103].
Pihlstrom BL, Wolff LF, Bakdash MB, et al. Salt and peroxide compared with conventional oral hygiene. I. Clinical results. J Periodontol. 1987;58:291-300. [pmid: 3035164].
Polson AM, Garrett S, Stoller NH, et al. Multi-center comparative evaluation of subgingivally delivered sanguinarine and doxycycline in the treatment of periodontitis. I. Study design, procedures, and management. J Periodontol. 1997;68:110-118. [pmid: 9058327].
Polson AM, Garrett S, Stoller NH, et al. Multi-center comparative evaluation of subgingivally delivered sanguinarine and doxycycline in the treatment of periodontitis. II. Clinical results. J Periodontol. 1997;68:119-126. [pmid: 9058328].
Polson AM, Stoller NH, Hanes PJ, Bandt CL, Garrett S, Southard GL. 2 multi-center trials assessing the clinical efficacy of 5% sanguinarine in a biodegradable drug delivery system. J Clin Periodontol. 1996;23:782-788. [pmid: 8877666].
Pontoriero R, Lindhe J. Guided tissue regeneration in the treatment of degree II furcations in maxillary molars. J Clin Periodontol. 1995;22:756-763. [pmid: 8682922].
Pontoriero R, Lindhe J. Guided tissue regeneration in the treatment of degree III furcation defects in maxillary molars. J Clin Periodontol. 1995;22:810-812. [pmid: 8682929].
Pontoriero R, Lindhe J, Nyman S, Karring T, Rosenberg E, Sanavi F. Guided tissue regeneration in the treatment of furcation defects in mandibular molars. A clinical study of degree III involvements. J Clin Periodontol. 1989;16:170-174. [pmid: 2723098].
Pourtaghi N, Radvar M, Mooney J, Kinane DF. The effect of subgingival antimicrobial therapy on the levels of stromelysin and tissue inhibitor of metalloproteinases in gingival crevicular fluid. J Periodontol. 1996;67:866-870. [pmid: 8884643].
Preshaw PM, Lauffart B, Brown P, Zak E, Heasman PA. Effects of ketorolac tromethamine mouthrinse (0.1%) on crevicular fluid prostaglandin E2 concentrations in untreated chronic periodontitis. J Periodontol. 1998;69:777-783. [pmid: 9706855].
Preshaw PM, Lauffart B, Zak E, Jeffcoat MK, Barton I, Heasman PA. Progression and treatment of chronic adult periodontitis. J Periodontol. 1999;70:1209-1220. [pmid: 10534076].
Preus HR, Lassen J, Aass AM, Ciancio SG. Bacterial resistance following subgingival and systemic administration of minocycline. J Clin Periodontol. 1995;22:380-384. [pmid: 7601919].
Pruthi VK, Milman SA. Treatment of rapidly progressive periodontitis: a review and case report. J Can Dent Assoc. Journal De l Association Dentaire Canadienne. 1990;56:949-953.
Pucher JJ, Shibley O, Dentino AR, Ciancio SG. Results of limited initial periodontal therapy in smokers and non-smokers. J Periodontol. 1997;68:851-856. [pmid: 9379329].
Purucker P, Mertes H, Goodson JM, Bernimoulin JP. Local versus systemic adjunctive antibiotic therapy in 28 patients with generalized aggressive periodontitis. J Periodontol. 2001;72:1241-1245. [pmid: 11577957].
Quirynen M, Bollen CM, Vandekerckhove BN, Dekeyser C, Papaioannou W, Eyssen H. Full- vs. partial-mouth disinfection in the treatment of periodontal infections: short-term clinical and microbiological observations. J Dent Res. 1995;74:1459-1467. [pmid: 7560400].
Quirynen M, Gizani S, Mongardini C, Declerck D, Vinckier F, Van Steenberghe D. The effect of periodontal therapy on the number of cariogenic bacteria in different intra-oral niches. J Clin Periodontol. 1999;26:322-327. [pmid: 10355625].
Quirynen M, Mongardini C, de Soete M, et al. The role of chlorhexidine in the one-stage full-mouth disinfection treatment of patients with advanced adult periodontitis. Long-term clinical and microbiological observations. J Clin Periodontol. 2000;27:578-589. [pmid: 10959784].
Quirynen M, Mongardini C, Pauwels M, Bollen CM, Van Eldere J, van Steenberghe D. One stage full- versus partial-mouth disinfection in the treatment of chronic adult or generalized early-onset periodontitis. II. Long-term impact on microbial load. J Periodontol. 1999;70:646-656. [pmid: 10397520].
Quirynen M, Mongardini C, van Steenberghe D. The effect of a 1-stage full-mouth disinfection on oral malodor and microbial colonization of the tongue in periodontitis. A pilot study. J Periodontol. 1998;69:374-382. [pmid: 9579625].
Quirynen M, Op Heij DG, Adriansens A, Opdebeeck HM, van Steenberghe D. Periodontal health of orthodontically extruded impacted teeth. A split- mouth, long-term clinical evaluation. J Periodontol. 2000;71:1708-1714. [pmid: 11128918].
Quirynen M, Teughels W, De Soete M, van Steenberghe D. Topical antiseptics and antibiotics in the initial therapy of chronic adult periodontitis: microbiological aspects. Periodontol 2000. 2002;28:72-90. [pmid: 12013349].
Rabbani GM, Ash MMJ, Caffesse RG. The effectiveness of subgingival scaling and root planing in calculus removal. J Periodontol. 1981;52:119-123. [pmid: 7014822].
Radvar M, MacFarlane TW, MacKenzie D, Whitters CJ, Payne AP, Kinane DF. An evaluation of the Nd:YAG laser in periodontal pocket therapy. Br Dent J. 1996;180:57-62. [pmid: 8785111].
Radvar M, Pourtaghi N, Kinane DF. Comparison of 3 periodontal local antibiotic therapies in persistent periodontal pockets. J Periodontol. 1996;67:860-865. [pmid: 8884642].
Raffetto N, Gutierrez T. Soft tissue therapy with lasers. RDH. 1999;19:38-40. , 42, 84-5 passim. [pmid: 10895728].
Ramberg P, Rosling B, Serino G, Hellstrom MK, Socransky SS, Lindhe J. The long-term effect of systemic tetracycline used as an adjunct to non-surgical treatment of advanced periodontitis. J Clin Periodontol. 2001;28:446-452. [pmid: 11350508].
Ramfjord SP. Long-term assessment of periodontal surgery versus curettage or scaling and root planing. Int J Technol Assess Health Care. 1990;6:392-402. [pmid: 2228455].
Ramfjord SP, Caffesse RG, Morrison EC, et al. 4 modalities of periodontal treatment compared over 5 years. J Clin Periodontol. 1987;14:445-452. [pmid: 3308969].
Rams TE, Feik D, Listgarten MA, Slots J. Peptostreptococcus micros in human periodontitis. Oral Microbiol Immunol. 1992;7:1-6. [pmid: 1528618].
Rams TE, Keyes PH. Non-surgical periodontal therapy on molar teeth with furcation involvement. Ala Dent Assoc. 1990;74:13-17.
Rams TE, Slots J. Local delivery of antimicrobial agents in the periodontal pocket. Periodontology. 2000;10:139-159.
Rasch MS, Mealey BL, Prihoda TJ, Woodard DS, McManus LM. The effect of initial periodontal therapy on salivary platelet-activating factor levels in chronic adult periodontitis. J Periodontol. 1995;66:613-623. [pmid: 7562354].
Reddy MS, Palcanis KG, Barnett ML, Haigh S, Charles CH, Jeffcoat MK. Efficacy of meclofenamate sodium (Meclomen) in the treatment of rapidly progressive periodontitis. J Clin Periodontol. 1993;20:635-640. [pmid: 8227450].
Reinhardt RA, Johnson GK, DuBois LM. Clinical effects of closed root planing compared to papilla reflection and fiber optic augmentation. J Periodontol. 1991;62:317-321. [pmid: 2072244].
Reinhardt RA, Masada MP, Johnson GK, DuBois LM, Seymour GJ, Allison AC. IL-1 in gingival crevicular fluid following closed root planing and papillary flap debridement. J Clin Periodontol. 1993;20:514-519. [pmid: 8354727].
Renvert S, Dahlen G, Snyder B. Clinical and microbiological effects of subgingival antimicrobial irrigation with citric acid as evaluated by an enzyme immunoassay and culture analysis. J Periodontol. 1997;68:346-352. [pmid: 9150039].
Renvert S, Dahlen G, Wikstrom M. Treatment of periodontal disease based on microbiological diagnosis. Relation between microbiological and clinical parameters during 5 years. J Periodontol. 1996;67:562-571. [pmid: 8794965].
Renvert S, Nilveus R, Dahlen G, Slots J, Egelberg J. 5-year follow up of periodontal intraosseous defects treated by root planing or flap surgery. J Clin Periodontol. 1990;17:356-363. [pmid: 2398132].
Renvert S, Wikstrom M, Dahlen G, Slots J, Egelberg J. Effect of root debridement on the elimination of Actinobacillus actinomycetemcomitans and Bacteroides gingivalis from periodontal pockets. J Clin Periodontol. 1990;17:345-350. [pmid: 2204636].
Renvert S, Wikstrom M, Helmersson M, Dahlen G, Claffey N. Comparative study of subgingival microbiological sampling techniques. J Periodontol. 1992;63:797-801. [pmid: 1328591].
Reynolds MA, Lavigne CK, Minah GE, Suzuki JB. Clinical effects of simultaneous ultrasonic scaling and subgingival irrigation with chlorhexidine. Mediating influence of periodontal probing depth. J Clin Periodontol. 1992;19:595-600. [pmid: 1447385].
Rieger L, Carson RE. The clinical effects of saline and aloe vera rinses on periodontal surgical sites. Okla Dent Assoc. 2002;92:40-43.
Riep B, Purucker P, Bernimoulin JP. Repeated local metronidazole-therapy as adjunct to scaling and root planing in maintenance patients. J Clin Periodontol. 1999;26:710-715. [pmid: 10589806].
Robertson PB, Buchanan SA, Armitage GC, Newbrun E, Taggart EJ, Hoover CI. Evaluation of clinical and microbiological measures to predict treatment response in severe periodontitis. J Periodontal Res. 1987;22:230-232. [pmid: 2955106].
Rocha M, Nava LE, Vazquez de la Torre C, Sanchez-Marin F, Garay-Sevilla ME, Malacara JM. Clinical and radiological improvement of periodontal disease in patients with type 2 diabetes mellitus treated with alendronate: a randomized, placebo-controlled trial. J Periodontol. 2001;72:204-209. [pmid: 11288794].
Roig R. [Comparative efficiency of 3 experimental ultrasonic instruments in vivo]. [French]. Journal De Parodontologie. 1990;9:253-256. [pmid: 2231394].
Rooney J, Wade WG, Sprague SV, Newcombe RG, Addy M. Adjunctive effects to non-surgical periodontal therapy of systemic metronidazole and amoxycillin alone and combined. A placebo controlled study. J Clin Periodontol. 2002;29:342-350. [pmid: 11966932].
Rosenberg ES, Evian CI, Listgarten MA. The composition of the subgingival microbiota after periodontal therapy. J Periodontol. 1981;52:435-441. [pmid: 7021794].
Rosling B, Hellstrom MK, Ramberg P, Socransky SS, Lindhe J. The use of PVP-iodine as an adjunct to non-surgical treatment of chronic periodontitis. J Clin Periodontol. 2001;28:1023-1031. [pmid: 11686823].
Rudhart A, Purucker P, Kage A, Hopfenmuller W, Bernimoulin JP. Local metronidazole application in maintenance patients. Clinical and microbiological evaluation. J Periodontol. 1998;69:1148-1154. [pmid: 9802715].
Rupprecht RD, Horning GM, Towle HJ3. A clinical evaluation of hydroxyapatite cement in the treatment of Class III furcation defects. J Periodontol. 2001;72:1443-1450. [pmid: 11699488].
Ryder MI, Pons B, Adams D, et al. Effects of smoking on local delivery of controlled-release doxycycline as compared to scaling and root planing. J Clin Periodontol. 1999;26:683-691. [pmid: 10522780].
Sakellari D, Belibasakis G, Chadjipadelis T, Arapostathis K, Konstantinidis A. Supragingival and subgingival microbiota of adult patients with Down's syndrome. Changes after periodontal treatment. Oral Microbiol Immunol. 2001;16:376-382. [pmid: 11737662].
Salvi GE, Mombelli A, Mayfield L, et al. Local antimicrobial therapy after initial periodontal treatment. J Clin Periodontol. 2002;29:540-550. [pmid: 12296782].
Sanders PC, Linden GJ, Newman HN. The effects of a simplified mechanical oral hygiene regime plus supragingival irrigation with chlorhexidine or metronidazole on subgingival plaque. J Clin Periodontol. 1986;13:237-242. [pmid: 3457810].
SAS Institute I, Wang M, Bushman BJ; Integrating Results Through Meta-Analytic Review Using SAS SSoftware. Cary, NC: SAS Institute, Inc.; 1999.
Sasaki J, Kaneko A, Karakida K, et al. [Comparative clinical study of azithromycin with tosufloxacin tosilate in the treatment of acute odontogenic infection]. Jpn J Antibiot. 1995;48:1093-1118. [pmid: 7474331].
Sasaki J, Morishima T, Sakamoto H, et al. A comparative double-blind study to determine the dosage of NY-198 (lomefloxacin) in oral and maxillofacial infections. Oral Therapeut Pharmacol. 1988;7:92-111.
Sato K, Yoneyama T, Okamoto H, Dahlen G, Lindhe J. The effect of subgingival debridement on periodontal disease parameters and the subgingival microbiota. J Clin Periodontol. 1993;20:359-365. [pmid: 8501276].
Saxen L, Asikainen S, Kanervo A, Kari K, Jousimies-Somer H. The long-term efficacy of systemic doxycycline medication in the treatment of localized juvenile periodontitis. Arch Oral Biol. 1990;35 Suppl:227S-229S. [pmid: 2088232].
Saxen L, Asikainen S, Sandholm L, Kari K. Treatment of juvenile periodontitis without antibiotics. A follow-up study. J Clin Periodontol. 1986;13:714-719. [pmid: 3531247].
Saxer UP. [Conventional surgical furcation therapy. Closed and open scaling]. [German]. Deutsche Zahnarztliche Zeitschrift. 1991;46:333-341. [pmid: 1817047].
Sbordone L, Ramaglia L, Amato G, Gulletta E, Valletta G. [Bacterial recolonization of deep periodontal lesions after nonsurgical therapy]. [Italian]. Minerva Stomatologica. 1988;37:361-371. [pmid: 3050436].
Sbordone L, Ramaglia L, Bucci E. Generalized juvenile periodontitis: report of a familial case followed for 5 years. J Periodontol. 1990;61:590-596. [pmid: 2213470].
Sbordone L, Ramaglia L, Gulletta E, Iacono V. Recolonization of the subgingival microflora after scaling and root planing in human periodontitis. J Periodontol. 1990;61:579-584. [pmid: 2213468].
Scabbia A, Cho KS, Sigurdsson TJ, Kim CK, Trombelli L. Cigarette smoking negatively affects healing response following flap debridement surgery. J Periodontol. 2001;72:43-49. [pmid: 11210072].
Schenk G, Flemmig TF, Betz T, Reuther J, Klaiber B. Controlled local delivery of tetracycline HCl in the treatment of periimplant mucosal hyperplasia and mucositis. A controlled case series. Clin Oral Implants Research. 1997;8:427-433.
Scheyer ET, Velasquez-Plata D, Brunsvold MA, Lasho DJ, Mellonig JT. A clinical comparison of a bovine-derived xenograft used alone and in combination with enamel matrix derivative for the treatment of periodontal osseous defects in humans. J Periodontol. 2002;73:423-432. [pmid: 11990444].
Schroer MS, Kirk WC, Wahl TM, Hutchens LHJ, Moriarty JD, Bergenholz B. Closed versus open debridement of facial grade II molar furcations. J Clin Periodontol. 1991;18:323-329. [pmid: 2066447].
Schwarz F, Sculean A, Georg T, Reich E. Periodontal treatment with an Er: YAG laser compared to scaling and root planing. A controlled clinical study. J Periodontol. 2001;72:361-367. [pmid: 11327064].
Sculean A, Barbe G, Chiantella GC, Arweiler NB, Berakdar M, Brecx M. Clinical evaluation of an enamel matrix protein derivative combined with a bioactive glass for the treatment of intrabony periodontal defects in humans. J Periodontol. 2002;73:401-408. [pmid: 11990441].
Sculean A, Chiantella GC, Windisch P, Donos N. Clinical and histologic evaluation of human intrabony defects treated with an enamel matrix protein derivative (Emdogain). Int J Periodontics Restorative Dent. 2000;20:374-381. [pmid: 11203577].
Sefton AM. Macrolides and changes in the oral flora. Int J Antimicrob Agents. 1999;11:S23-S29. [pmid: 10204636].
Serino G, Rosling B, Ramberg P, Hellstrom MK, Socransky SS, Lindhe J. The effect of systemic antibiotics in the treatment of patients with recurrent periodontitis. J Clin Periodontol. 2001;28:411-418. [pmid: 11350503].
Serino G, Rosling B, Ramberg P, Socransky SS, Lindhe J. Initial outcome and long-term effect of surgical and non-surgical treatment of advanced periodontal disease. J Clin Periodontol. 2001;28:910-916. [pmid: 11686808].
Sewon LA, Ampula L, Vallittu PK. Rehabilitation of a periodontal patient with rapidly progressing marginal alveolar bone loss: 1-year follow-up. J Clin Periodontol. 2000;27:615-619. [pmid: 10959789].
Shaw MJ, Shaw L. The effectiveness of differing dental health education programmes in improving the oral health of adults with mental handicaps attending Birmingham adult training centres. Comm Dent Health. 1991;8:139-145.
Shieh AT, Wang HL, O'Neal R, Glickman GN, MacNeil RL. Development and clinical evaluation of a root coverage procedure using a collagen barrier membrane. J Periodontol. 1997;68:770-778. [pmid: 9287069].
Shiloah J, Patters MR. DNA probe analyses of the survival of selected periodontal pathogens following scaling, root planing, and intra-pocket irrigation. J Periodontol. 1994;65:568-575. [pmid: 8083788].
Shiloah J, Patters MR. Repopulation of periodontal pockets by microbial pathogens in the absence of supportive therapy. J Periodontol. 1996;67:130-139. [pmid: 8667133].
Shiloah J, Patters MR, Dean JW3, Bland P, Toledo G. The prevalence of Actinobacillus actinomycetemcomitans, Porphyromonas gingivalis, and Bacteroides forsythus in humans 1 year after 4 randomized treatment modalities. J Periodontol. 1998;69:1364-1372. [pmid: 9926766].
Shiloah J, Patters MR, Dean JW3, Bland P, Toledo G. The survival rate of Actinobacillus actinomycetemcomitans, Porphyromonas gingivalis, and Bacteroides forsythus following 4 randomized treatment modalities. J Periodontol. 1997;68:720-728. [pmid: 9287061].
Shimada K, Mizuno T, Ohshio K, Kamaga M, Murai S, Ito K. Analysis of aspartate aminotransferase in gingival crevicular fluid assessed by using PocketWatch: a longitudinal study with initial therapy. J Clin Periodontol. 2000;27:819-823. [pmid: 11073324].
Sigurdsson TJ, Holbrook WP, Karadottir H, Magnusdottir MO, Wikesjo UM. Evaluating surgical, non-surgical therapy in periodontic patients. J Am Dent Assoc. 1994;125:1080-1087. [pmid: 8064049].
Sigusch B, Beier M, Klinger G, Pfister W, Glockmann E. A 2-step non-surgical procedure and systemic antibiotics in the treatment of rapidly progressive periodontitis. J Periodontol. 2001;72:275-283. [pmid: 11327054].
Silverstein L, Bissada N, Manouchehr-Pour M, Greenwell H. Clinical and microbiologic effects of local tetracycline irrigation on periodontitis. J Periodontol. 1988;59:301-305. [pmid: 3290430].
Simion M, Baldoni M, Vanden Bogaerde L, Salvato A. [Comparative analysis of therapy plans for rapidly progressing periodontitis]. [Italian]. Stomatologia Mediterranea. 1988;8:363-369. [pmid: 3078988].
Singletary MM, Crawford JJ, Simpson DM. Dark-field microscopic monitoring of subgingival bacteria during periodontal therapy. Periodontol. 1982;53:671-681.
Slots J. Selection of antimicrobial agents in periodontal therapy. J Periodontal Res. 2002;37:389-398. [pmid: 12366863].
Smith AJ, Addy M, Embery G. Gingival crevicular fluid glycosaminoglycan levels in patients with chronic adult periodontitis. J Clin Periodontol. 1995;22:355-361. [pmid: 7601916].
Smith GT, Greenbaum CJ, Johnson BD, Persson GR. Short-term responses to periodontal therapy in insulin-dependent diabetic patients. [erratum appears in J Periodontol 1996 Dec;67(12):1368.]. J Periodontol. 1996;67:794-802. [pmid: 8866319].
Smith SR, Foyle DM, Daniels J, et al. A double-blind placebo-controlled trial of azithromycin as an adjunct to non-surgical treatment of periodontitis in adults: clinical results. J Clin Periodontol. 2002;29:54-61. [pmid: 11846850].
Smulow JB, Turesky SS, Hill RG. The effect of supragingival plaque removal on anaerobic bacteria deep periodontal pockets. J Am Dent Assoc. 1983;107:737-742. [pmid: 6358321].
Socransky SJ, Pirrallo RG, Rubin JM. Out-of-hospital treatment of hypoglycemia: refusal of transport and patient outcome. Acad Emerg Med. 1998;5:1080-1085. [pmid: 9835470].
Socransky SS, Haffajee AD. Evidence of bacterial etiology: a historical perspective. Periodontol 2000. 1994;5:7-25. [pmid: 9673160].
Soder B, Nedlich U, Jin LJ. Longitudinal effect of non-surgical treatment and systemic metronidazole for 1 week in smokers and non-smokers with refractory periodontitis: a 5-year study. J Periodontol. 1999;70:761-771. [pmid: 10440638].
Soder PO, Frithiof L, Wikner S, et al. The effect of systemic metronidazole after non-surgical treatment in moderate and advanced periodontitis in young adults. J Periodontol. 1990;61:281-288. [pmid: 2191111].
Soskolne WA, Heasman PA, Stabholz A, et al. Sustained local delivery of chlorhexidine in the treatment of periodontitis: a multi-center study. J Periodontol. 1997;68:32-38. [pmid: 9029449].
Southard SR, Drisko CL, Killoy WJ, Cobb CM, Tira DE. The effect of 2% chlorhexidine digluconate irrigation on clinical parameters and the level of Bacteroides gingivalis in periodontal pockets. J Periodontol. 1989;60:302-309. [pmid: 2674394].
Stabholz A, Nicholas AA, Zimmerman GJ, Wikesjo UM. Clinical and antimicrobial effects of a single episode of subgingival irrigation with tetracycline HCl or chlorhexidine in deep periodontal pockets. J Clin Periodontol. 1998;25:794-800. [pmid: 9797051].
Stabholz A, Soskolne WA, Friedman M, Sela MN. The use of sustained release delivery of chlorhexidine for the maintenance of periodontal pockets: 2-year clinical trial. J Periodontol. 1991;62:429-433. [pmid: 1920009].
Stanford TWJ, Peterson J, Machen RL. CREST syndrome and periodontal surgery: a case report. J Periodontol. 1999;70:536-541. [pmid: 10368058].
Stassinakis A, Hugo B, Hotz P. [Personnel and instrumental differences in the treatment of root surfaces. A comparison on a phantom model]. [German]. Schweizer Monatsschrift Fur Zahnmedizin. 1995;105:623-628. [pmid: 7784877].
Stassinakis A, Hugo B, Lussi A. [A mathematical model for the treatment of root surfaces with rigid and flexible instruments]. [German]. Schweizer Monatsschrift Fur Zahnmedizin. 1995;105:617-622. [pmid: 7784876].
Stelzel M, Flores-de-Jacoby L. Topical metronidazole application as an adjunct to scaling and root planing. J Clin Periodontol. 2000;27:447-452. [pmid: 10883875].
Stelzel M, Flores-de-Jacoby L. Topical metronidazole application compared with subgingival scaling. A clinical and microbiological study on recall patients. J Clin Periodontol. 1996;23:24-29. [pmid: 8636453].
Stelzel M, Flores-de-Jacoby L. Topical metronidazole application in recall patients. Long-term results. J Clin Periodontol. 1997;24:914-919. [pmid: 9442429].
Stewart JE, Wager KA, Friedlander AH, Zadeh HH. The effect of periodontal treatment on glycemic control in patients with type 2 diabetes mellitus. J Clin Periodontol. 2001;28:306-310. [pmid: 11314885].
Stoller NH, Johnson LR, Garrett S. Periodontal regeneration of a class II furcation defect utilizing a bioabsorbable barrier in a human. A case study with histology. J Periodontol. 2001;72:238-242. [pmid: 11288798].
Stoller NH, Johnson LR, Trapnell S, Harrold CQ, Garrett S. The pharmacokinetic profile of a biodegradable controlled-release delivery system containing doxycycline compared to systemically delivered doxycycline in gingival crevicular fluid, saliva, and serum. J Periodontol. 1998;69:1085-1091. [pmid: 9802705].
Stroup DF, Berlin JA, Morton SC, et al. Meta-analysis of observational studies in epidemiology: a proposal for reporting. Meta-analysis Of Observational Studies in Epidemiology (MOOSE) group. JAMA. 2000;283:2008-2012. [pmid: 10789670].
Svardstrom G, Wennstrom JL. Periodontal treatment decisions for molars: an analysis of influencing factors and long-term outcome. J Periodontol. 2000;71:579-585. [pmid: 10807122].
Svensson P, Petersen JK, Svensson H. Efficacy of a topical anesthetic on pain and unpleasantness during scaling of gingival pockets. Anesthesia Progress. 1994;41:35-39. [pmid: 8638858]. [pmcid: 2148810].
Taggart JA, Palmer RM, Wilson RF. A clinical and microbiological comparison of the effects of water and 0.02% chlorhexidine as coolants during ultrasonic scaling and root planing. J Clin Periodontol. 1990;17:32-37. [pmid: 2404033].
Tagge DL, O'Leary TJ, El-Kafrawy AH. The clinical and histological response of periodontal pockets to root planing and oral hygiene. J Periodontol. 1975;46:527-533. [pmid: 1099189].
Taiyeb Ali TB, Waite IM. The effect of systemic ibuprofen on gingival inflammation in humans. J Clin Periodontol. 1993;20:723-728. [pmid: 8276982].
Takamatsu N, Yano K, He T, Umeda M, Ishikawa I. Effect of initial periodontal therapy on the frequency of detecting Bacteroides forsythus, Porphyromonas gingivalis, and Actinobacillus actinomycetemcomitans. J Periodontol. 1999;70:574-580. [pmid: 10397511].
Talonpoika JT, Hamalainen MM. Type I collagen carboxyterminal telopeptide in human gingival crevicular fluid in different clinical conditions and after periodontal treatment. J Clin Periodontol. 1994;21:320-326. [pmid: 8034776].
Tanaka Y. [A clinical evaluation of porous hydroxyapatite granules implants in human periodontal osseous defects]. [Japanese]. Nippon Shishubyo Gakkai Kaishi - J Jpn Assoc Periodontol. 1987;29:37-64.
Taner IL, Ozcan G, Doganay T, et al. Comparison of the antibacterial effects on subgingival microflora of two different resorbable base materials containing doxycycline. J Nihon Univ Sch Dent. 1994;36:183-190. [pmid: 7989960].
Tenenbaum H, Dahan M, Soell M. Effectiveness of a sanguinarine regimen after scaling and root planing. J Periodontol. 1999;70:307-311. [pmid: 10225548].
Tervonen T, Knuuttila M, Pohjamo L, Nurkkala H. Immediate response to nonsurgical periodontal treatment in subjects with diabetes mellitus. J Clin Periodontol. 1991;18:65-68. [pmid: 2045520].
Tessier JF, Kulkarni GV, Ellen RP, McCulloch CA. Probing velocity: novel approach for assessment of inflamed periodontal attachment. J Periodontol. 1994;65:103-108. [pmid: 8158505].
Thomas J, Walker C, Bradshaw M. Long-term use of subantimicrobial dose doxycycline does not lead to changes in antimicrobial susceptibility. J Periodontol. 2000;71:1472-1483. [pmid: 11022778].
Thomas JG, Metheny RJ, Karakiozis JM, Wetzel JM, Crout RJ. Long-term sub-antimicrobial doxycycline (Periostat) as adjunctive management in adult periodontitis: effects on subgingival bacterial population dynamics. Advances Dent Res. 1998;12:32-39. [pmid: 9972119].
Timmerman MF, van der Weijden GA, van Steenbergen TJ, Mantel MS, de Graaff J, van der Velden U. Evaluation of the long-term efficacy and safety of locally-applied minocycline in adult periodontitis patients. J Clin Periodontol. 1996;23:707-716. [pmid: 8877655].
Tinoco EM, Beldi MI, Campedelli F, et al. Clinical and microbiological effects of adjunctive antibiotics in treatment of localized juvenile periodontitis. A controlled clinical trial. J Periodontol. 1998;69:1355-1363. [pmid: 9926765].
Tonetti MS. Local delivery of tetracycline: from concept to clinical application. J Clin Periodontol. 1998;25:969-977. [pmid: 9839855].
Tonetti MS, Cortellini P, Carnevale G, Cattabriga M, de Sanctis M, Pini Prato GP. A controlled multicenter study of adjunctive use of tetracycline periodontal fibers in mandibular class II furcations with persistent bleeding. J Clin Periodontol. 1998;25:728-736. [pmid: 9763328].
Tonetti MS, Lang NP, Cortellini P, et al. Enamel matrix proteins in the regenerative therapy of deep intrabony defects. J Clin Periodontol. 2002;29:317-325. [pmid: 11966929].
Trombelli L, Scabbia A, Carotta V, Scapoli C, Calura G. Clinical effect of subgingival tetracycline irrigation and tetracycline-loaded fiber application in the treatment of adult periodontitis. Quintessence Int. 1996;27:19-25. [pmid: 9063208].
Tsai CC, Hong YC, Chen CC, Wu YM. Measurement of prostaglandin E2 and leukotriene B4 in the gingival crevicular fluid. J Dent. 1998;26:97-103. [pmid: 9540305].
Turner Y, Ashley FP, Wilson RF. Effectiveness of oral hygiene with and without root planing in treating subjects with chronic periodontitis. Br Dent J. 1994;177:367-371. [pmid: 7986629].
Tyring SK, Douglas JM Jr,, Corey L, Spruance SL, Esmann J. A randomized, placebo-controlled comparison of oral valacyclovir and acyclovir in immunocompetent patients with recurrent genital herpes infections. The Valaciclovir International Study Group. Arch Dermatol. 1998;134:185-191. [pmid: 9487210].
Ueda M, Teranishi Y, Hashizume A, et al. [Effectiveness of local delivery of ofloxacin using controlled-release strips (PT-01) in periodontal patients. Part 2. Successive delivery system and combination with scaling]. [Japanese]. Nippon Shishubyo Gakkai Kaishi - J Jpn Assoc Periodontol. 1989;31:299-309.
Unsal E, Akkaya M, Walsh TF. Influence of a single application of subgingival chlorhexidine gel or tetracycline paste on the clinical parameters of adult periodontitis patients. J Clin Periodontol. 1994;21:351-355. [pmid: 8034781].
US Department of Health and Human Services. Oral Health in America. A Report of the Surgeon General. Rockville, MD: National Institute of Dental and Craniofacial Research, National Institutes of Health; 2000.
Valletta R, Sbordone L, Ramaglia L, Ciaglia RN, Spagnuolo G, Lenci F. [Bacterial recolonization in the guided regeneration of the inter-radicular periodontal tissues]. [Italian]. Minerva Stomatol. 1990;39:161-170. [pmid: 2195311].
Van der Reijden WA, Dellemijn-Kippuw N, Stijne-van Nes AM, de Soet JJ, van Winkelhoff AJ. Mutans streptococci in subgingival plaque of treated and untreated patients with periodontitis. J Clin Periodontol. 2001;28:686-691. [pmid: 11422591].
Van der Weijden GA, Timmerman MF, Reijerse E, Wolffe GN, Van Winkelhoff AJ, Van der Velden U. The prevalence of A. actinomycetemcomitans, P. gingivalis and P. intermedia in selected subjects with periodontitis. J Clin Periodontoly. 1994;21:583-588.
Van Dyke TE, Offenbacher S, Braswell L, Lessem J. Enhancing the value of scaling and root-planing: Arestin clinical trial results. J Int Acad Periodontol. 2002;4:72-6. [pmid: 12670085].
van Steenbergen TJ, van der Velden U, Abbas F, de Graaff J. Microbiological and clinical monitoring of non-localized juvenile periodontitis in young adults: a report of 11 cases. J Periodontol. 1993;64:40-47. [pmid: 8381179].
van Steenberghe D, Bercy P, Kohl J, et al. Subgingival minocycline hydrochloride ointment in moderate to severe chronic adult periodontitis: a randomized, double-blind, vehicle-controlled, multicenter study. J Clin Periodontol. 1993;64:637-644.
van Steenberghe D, Rosling B, Soder PO, et al. A 15-month evaluation of the effects of repeated subgingival minocycline in chronic adult periodontitis. J Periodontol. 1999;70:657-667. [pmid: 10397521].
van Winkelhoff AJ, Bosch-Tijhof CJ, Winkel EG, van der Reijden WA. Smoking affects the subgingival microflora in periodontitis. J Periodontol. 2001;72:666-671. [pmid: 11394403].
van Winkelhoff AJ, Tijhof CJ, de Graaff J. Microbiological and clinical results of metronidazole plus amoxicillin therapy in Actinobacillus actinomycetemcomitans-associated periodontitis. J Periodontol. 1992;63:52-57. [pmid: 1313103].
Vandekerckhove BN, Bollen CM, Dekeyser C, Darius P, Quirynen M. Full- versus partial-mouth disinfection in the treatment of periodontal infections. Long-term clinical observations of a pilot study. J Periodontol. 1996;67:1251-1259. [pmid: 8997670].
Vandekerckhove BN, Quirynen M, van Steenberghe D. The use of tetracycline-containing controlled-release fibers in the treatment of refractory periodontitis. J Periodontol. 1997;68:353-361. [pmid: 9150040].
Vandekerckhove BNA, Bollen CML, Dekeyser C, Darius P, Quirynen M. Full versus partial-mouth disinfection in the treatment of periodontal infections. Long-term clinical observations of a pilot study. J Periodontol. 1996;67:1251-1259. [pmid: 8997670].
Vanooteghem R, Hutchens LH, Bowers G, et al. Subjective criteria and probing attachment loss to evaluate the effects of plaque control and root debridement. J Clin Periodontol. 1990;17:580-587. [pmid: 2212089].
Vasileva M, Atanassova E, Zapryanova M, Asadur T, Filipov M. Analgetic effect in stomatological affections. Mbi (Medico-Biologic Information). 1989:27-30.
Velasquez-Plata D, Scheyer ET, Mellonig JT. Clinical comparison of an enamel matrix derivative used alone or in combination with a bovine-derived xenograft for the treatment of periodontal osseous defects in humans. J Periodontol. 2002;73:433-440. [pmid: 11990445].
Vergis EN, Demas PN, Vaccarello SJ, Yu VL. Topical antibiotic prophylaxis for bacteremia after dental extractions. Oral Surgery Oral Medicine Oral Pathology Oral Radiology & Endodontics. 2001;91:162-165.
von Troil-Linden B, Alaluusua S, Wolf J, Jousimies-Somer H, Torppa J, Asikainen S. Periodontitis patient and the spouse: periodontal bacteria before and after treatment. J Clin Periodontol. 1997;24:893-899. [pmid: 9442426].
Vouros I, Konstantinidis A, Kirkou-Bata A. Effect of non-surgical periodontal therapy in an undergraduate dental clinic. Results one year following treatment. Journal De Biologie Buccale. 1992;20:11-17. [pmid: 1522081].
Vrotsos JA, Parashis AO, Theofanatos GD, Smulow JB. Prevalence and distribution of bone defects in moderate and advanced adult periodontitis. J Clin Periodontol. 1999;26:44-48. [pmid: 9923510].
Waite IM. A comparison between conventional gingivectomy and a non-surgical regime in the treatment of periodontitis. J Clin Periodontol. 1976;3:173-185. [pmid: 787013].
Walker C, Karpinia K. Rationale for use of antibiotics in periodontics. J Periodontol. 2002;73:1188-1196. [pmid: 12416778].
Walker C, Thomas J, Nango S, Lennon J, Wetzel J, Powala C. Long-term treatment with subantimicrobial dose doxycycline exerts no antibacterial effect on the subgingival microflora associated with adult periodontitis. J Periodontol. 2000;71:1465-1471. [pmid: 11022777].
Walker CB, Godowski KC, Borden L, et al. The effects of sustained release doxycycline on the anaerobic flora and antibiotic-resistant patterns in subgingival plaque and saliva. J Periodontol. 2000;71:768-774. [pmid: 10872958].
Wan Yusof WZ, Newman HN, Strahan JD, Coventry JF. Subgingival metronidazole in dialysis tubing and subgingival chlorhexidine irrigation in the control of chronic inflammatory periodontal disease. J Clin Periodontol. 1984;11:166-175. [pmid: 6584445].
Wang HL, Bunyaratavej P, Labadie M, Shyr Y, MacNeil RL. Comparison of 2 clinical techniques for treatment of gingival recession. J Periodontol. 2001;72:1301-1311. [pmid: 11699470].
Wang HL, Burgett FG, Shyr Y, Ramfjord S. The influence of molar furcation involvement and mobility on future clinical periodontal attachment loss. J Periodontol. 1994;65:25-29. [pmid: 8133412].
Wang Y, Goodman SD, Redfield RJ, Chen C. Natural transformation and DNA uptake signal sequences in Actinobacillus actinomycetemcomitans. J Bacteriol. 2002;184:3442-3449. [pmid: 12057937]. [pmcid: 135135].
Watts EA, Newman HN. Clinical effects on chronic periodontitis of a simplified system of oral hygiene including subgingival pulsated jet irrigation with chlorhexidine. J Clin Periodontol. 1986;13:666-670. [pmid: 3463571].
Wennstrom A, Wennstrom J, Lindhe J. Healing following surgical and non-surgical treatment of juvenile periodontitis. A 5-year longitudinal study. J Clin Periodontol. 1986;13:869-882. [pmid: 3537019].
Wennstrom JL, Newman HN, MacNeill SR, et al. Utilisation of locally delivered doxycycline in non-surgical treatment of chronic periodontitis. A comparative multi-centre trial of 2 treatment approaches. J Clin Periodontol. 2001;28:753-761. [pmid: 11442735].
Wennstrom J, Heijl L, Dahlen G, Grondahl K. Periodic subgingival antimicrobial irrigation of periodontal pockets (I). Clinical observations. J Clin Periodontol. 1987;14:541-550. [pmid: 3479456].
West SL, King V, Carey TS, et al. Systems to Rate the Strength of Scientific Evidence. Evidence Report/Technology Assessment No. 47. Rockville, Md.: Agency for Healthcare Research and Quality. AHRQ Publication No. 02-E016; 2002.
West TL, King WJ. Toothbrushing with hydrogen peroxide-sodium bicarbonate compared to toothpowder and water in reducing periodontal pocket suppuration and darkfield bacterial counts. J Periodontol. 1983;54:339-36. [pmid: 6348245].
Westfelt E, Bragd L, Socransky SS, Haffajee AD, Nyman S, Lindhe J. Improved periodontal conditions following therapy. J Clin Periodontol. 1985;12:283-293. [pmid: 3889071].
Westfelt E, Rylander H, Blohme G, Jonasson P, Lindhe J. The effect of periodontal therapy in diabetics. Results after 5 years. J Clin Periodontol. 1996;23:92-100. [pmid: 8849844].
Westfelt E, Rylander H, Dahlen G, Lindhe J. The effect of supragingival plaque control on the progression of advanced periodontal disease. J Clin Periodontol. 1998;25:536-541. [pmid: 9696252].
Wiebe CB, Silver JG, Larjava HS. Early-onset periodontitis associated with Weary-Kindler syndrome: a case report. J Periodontol. 1996;67:1004-1010. [pmid: 8910840].
Wieder SG, Newman HN, Strahan JD. Stannous fluoride and subgingival chlorhexidine irrigation in the control of plaque and chronic periodontitis. J Clin Periodontol. 1983;10:172-181. [pmid: 6573343].
Wiernicka M. [Possibilities and efficacy of treating perio-endodontic syndrome type III]. [Polish]. Annales Academiae Medicae Stetinensis. 1999;45:239-252. [pmid: 10909493].
Williams KB, Cobb CM, Taylor HJ, Brown AR, Bray KK. Effect of sonic and mechanical toothbrushes on subgingival microbial flora: a comparative in vivo scanning electron microscopy study of 8 subjects. Quintessence Int. 2001;32:147-154. [pmid: 12066676].
Williams RC, Paquette DW, Offenbacher S, et al. Treatment of periodontitis by local administration of minocycline microspheres: a controlled trial. J Periodontol. 2001;72:1535-1544. [pmid: 11759865].
Wilson TGJ, McGuire MK, Greenstein G, Nunn M. Tetracycline fibers plus scaling and root planing versus scaling and root planing alone: similar results after 5 years. J Periodontol. 1997;68:1029-1032. [pmid: 9407394].
Winkel EG, Van Winkelhoff AJ, Timmerman MF, Van der Velden U, Van der Weijden GA. Amoxicillin plus metronidazole in the treatment of adult periodontitis patients. A double-blind placebo-controlled study. J Clin Periodontol. 2001;28:296-305. [pmid: 11314884].
Wojcik MS, DeVore CH, Beck FM, Horton JE. Retained "hopeless" teeth: lack of effect periodontally-treated teeth have on the proximal periodontium of adjacent teeth 8-years later. J Periodontol. 1992;63:663-666. [pmid: 1507046].
Wolinsky LE, Camargo PM, Polson A, Ryder M, Garrett S. The significance of prior mechanical therapy for changes of periodontal status achieved by local delivery of a doxycyclinehyclate containing gel. J Clin Periodontol. 2001;28:1115-1120. [pmid: 11737508].
Wood WR, Greco GW, McFall WTJ. Tooth loss in patients with moderate periodontitis after treatment and long-term maintenance care. J Periodontol. 1989;60:516-520. [pmid: 2677303].
Worch KP, Listgarten MA, Korostoff JM. A multidisciplinary approach to the diagnosis and treatment of early-onset periodontitis: a case report. J Periodontol. 2001;72:96-106. [pmid: 11210080].
Wylam JM, Mealey BL, Mills MP, Waldrop TC, Moskowicz DC. The clinical effectiveness of open versus closed scaling and root planing on multi-rooted teeth. J Periodontol. 1993;64:1023-1028. [pmid: 8295086].
Yalcin F, Demirel K, Onan U. Evaluation of adjunctive tetracycline fiber therapy with scaling and root planing: short-term clinical results. Periodontal Clin Invest. 1999;21:23-27.
Yanagimura M, Hara K, Sasakura H, Hanada K. [Effects of periodontal and orthodontic therapy on periodontal health--a longitudinal study of periodontal condition associated with periodontal initial therapy in adults]. [Japanese]. Nippon Shishubyo Gakkai Kaishi - J Jpn Assoc Periodontol. 1987;29:568-578.
Yeom HR, Park YJ, Lee SJ, Rhyu IC, Chung CP, Nisengard RJ. Clinical and microbiological effects of minocycline-loaded microcapsules in adult periodontitis. J Periodontol. 1997;68:1102-1109. [pmid: 9407404].
Yeung FI, Newman HN, Addy M. Subgingival metronidazole in acrylic resin vs. chlorhexidine irrigation in the control of chronic periodontitis. J Periodontol. 1983;54:651-657. [pmid: 6580418].
Yilmaz S, Kuru B, Kuru L, Noyan U, Argun D, Kadir T. Effect of gallium arsenide diode laser on human periodontal disease: a microbiological and clinical study. Lasers Surg Med. 2002;30:60-66. [pmid: 11857606].
Yilmaz S, Kuru B, Noyan U, Kadir T, Acar O, Buget E. A clinical and microbiological evaluation of systemic and local metronidazole delivery in early onset periodontitis patients. J Marmara Univ Dent Facul. 1996;2:500-509.
Yoshinari N, Tohya T, Kawase H, et al. Effect of repeated local minocycline administration on periodontal healing following guided tissue regeneration. J Periodontol. 2001;72:284-295. [pmid: 11327055].
Yukna RA, Evans GH, Aichelmann-Reidy MB, Mayer ET. Clinical comparison of bioactive glass bone replacement graft material and expanded polytetrafluoroethylene barrier membrane in treating human mandibular molar class II furcations. J Periodontol. 2001;72:125-133. [pmid: 11288783].
Yukna RA, Yukna CN. Six-year clinical evaluation of HTR synthetic bone grafts in human grade II molar furcations. Periodontal Res. 1997;32:627-63.
Zambon JJ. Periodontal diseases: microbial factors. Ann Periodontol. 1996;1:879-925. [pmid: 9118283].
Zamet JS, Darbar UR, Griffiths GS, et al. Particulate bioglass as a grafting material in the treatment of periodontal intrabony defects. J Clin Periodontol. 1997;24:410-418. [pmid: 9205920].
Zaner DJ, Yukna RA, Malinin TI. Human freeze-dried dura mater allografts as a periodontal biological bandage. J Periodontol. 1989;60:617-623. [pmid: 2600748].
Zoman KH. Treatment of rapidly progressive periodontitis: a review and case report. Compend Contin Educat Dent. 1999;20:262-265. , 267-268, 270 passim.
Zuabi O, Machtei EE, Ben-Aryeh H, Ardekian L, Peled M, Laufer D. The effect of smoking and periodontal treatment on salivary composition in patients with established periodontitis. J Periodontol. 1999;70:1240-1246. [pmid: 10534080].
Zucchelli G, Bernardi F, Montebugnoli L, De SM. Enamel matrix proteins and guided tissue regeneration with titanium-reinforced expanded polytetrafluoroethylene membranes in the treatment of infrabony defects: a comparative controlled clinical trial. J Periodontol. 2002;73:3-12. [pmid: 11846197].