# References

1 Brown LJ, Johns BA, Wall TP. The economics of periodontal diseases. Periodontol. 2000;29:223-234.
2 Albandar JM, Brunelle JA, Kingman A. Destructive periodontal disease in adults 30 years of age and older in the United States, 1988-1994. J Periodontol. 1999;70:13-29. [pmid: 10052767].
3 Albandar JM, Kingman A. Gingival recession, gingival bleeding, and dental calculus in adults 30 years of age and older in the United States, 1988-1994. J Periodontol. 1999;70:30-43. [pmid: 10052768].
4 US Department of Health and Human Services. Oral Health in America. A Report of the Surgeon General. Rockville, MD: National Institute of Dental and Craniofacial Research, National Institutes of Health; 2000.
5 Socransky SS, Haffajee AD. Evidence of bacterial etiology: a historical perspective. Periodontol 2000. 1994;5:7-25. [pmid: 9673160].
6 Haffajee AD, Socransky SS. Microbial etiological agents of destructive periodontal diseases. Periodontol 2000. 1994;5:78-111. [pmid: 9673164].
7 Consensus Report: Periodontal Diseases: Epidemiology and diagnosisAnn Periodontol 1996 1 216 222 9118258
8 Zambon JJ. Periodontal diseases: microbial factors. Ann Periodontol. 1996;1:879-925. [pmid: 9118283].
9 Socransky SJ, Pirrallo RG, Rubin JM. Out-of-hospital treatment of hypoglycemia: refusal of transport and patient outcome. Acad Emerg Med. 1998;5:1080-1085. [pmid: 9835470].
10 Hujoel PP, Powell LV, Kiyak HA. The effects of simple interventions on tooth mortality: findings in one trial and implications for future studies. J Dent Res. 1997;76:867-874. [pmid: 9126183].
11 Quirynen M, Op Heij DG, Adriansens A, Opdebeeck HM, van Steenberghe D. Periodontal health of orthodontically extruded impacted teeth. A split- mouth, long-term clinical evaluation. J Periodontol. 2000;71:1708-1714. [pmid: 11128918].
12 De Soete M, Mongardini C, Peuwels M, et al. One-stage full-mouth disinfection. Long-term microbiological results analyzed by checkerboard DNA-DNA hybridization. J Periodontol. 2001;72:374-382. [pmid: 11327066].
13 Goodson JM. Antimicrobial strategies for treatment of periodontal diseases. Periodontol 2000. 1994;5:142-168. [pmid: 9673166].
14 Johnson V, Johnson BD, Sims TJ, et al. Effects of treatment on antibody titer to Porphyromonas gingivalis in gingival crevicular fluid of patients with rapidly progressive periodontitis. J Periodontol. 1993;64:559-565. [pmid: 8393109].
15 Hung HC, Douglass CW. Meta-analysis of the effect of scaling and root planing, surgical treatment and antibiotic therapies on periodontal probing depth and attachment loss. J Clin Periodontol. 2002;29:975-986. [pmid: 12472990].
16 Lindhe J, Nyman S. Long-term maintenance of patients treated for advanced periodontal disease. J Clin Periodontol. 1984;11:504-514. [pmid: 6384275].
17 Antczak-Bouckoms A, Joshipura K, Burdick E, Tulloch JF. Meta-analysis of surgical versus non-surgical methods of treatment for periodontal disease. J Clin Periodontol. 1993;20:259-268. [pmid: 8473536].
18 Kalkwarf KL, Kaldahl WB, Patil KD. Patient preference regarding 4 types of periodontal therapy following 3 years of maintenance follow-up. J Clin Periodontol. 1992;19:788-793. [pmid: 1452806].
19 McFall WT Jr . Tooth loss in 100 treated patients with periodontal disease. A long- term study. J Periodontol. 1982;53:539-549. [pmid: 6957591].
20 Renvert S, Wikstrom M, Dahlen G, Slots J, Egelberg J. Effect of root debridement on the elimination of Actinobacillus actinomycetemcomitans and Bacteroides gingivalis from periodontal pockets. J Clin Periodontol. 1990;17:345-350. [pmid: 2204636].
21 Sbordone L, Ramaglia L, Gulletta E, Iacono V. Recolonization of the subgingival microflora after scaling and root planing in human periodontitis. J Periodontol. 1990;61:579-584. [pmid: 2213468].
22 Haffajee AD, Cugini MA, Dibart S, Smith C, Kent RLJ, Socransky SS. Clinical and microbiological features of subjects with adult periodontitis who responded poorly to scaling and root planing. J Clin Periodontol. 1997;24:767-776. [pmid: 9350562].
23 Niederman R, Abdelshehid G, Goodson JM. Periodontal therapy using local delivery of antimicrobial agents. Dent Clin North Am. 2002;46:665-77. , viii. [pmid: 12436823].
24 Herrera D, Sanz M, Jepsen S, Needleman I, Roldan S. Review article: A systematic review on the effect of systemic antimicrobials as an adjunct to scaling and root planing in periodontitis patients. J Clin Periodontol. 2002;29:139.
25 Bader JD, Shugars DA, Rozier G, et al. Diagnosis and Management of Dental Caries. Evidence Report/Technology Assessment No. 36 (prepared by Research Triangle Institute and University of North Carolina at Chapel Hill Evidence-based Practice Center under Contract No. 290-97-0011). AHRQ Publication No. 01-E056. Rockville, MD: Agency for Healthcare Research and Quality; 2001.
26 Bonito AJ, Patton LL, Shugars DA, et al. Management of Dental Patients Who Are HIV-Positive. Rockville, Md.: Evidence Report/Technology Assessment No. 37. AHRQ Publication No. 01-E042. Agency for Healthcare Research and Quality; 2002.
27 Bader JD, Bonito AJ, Shugars. Cardiovascular Effects on Epinephrine on Hypertensive Dental Patients. Rockville, Md: Evidence Report/Technology Assessment No. 48. AHRQ Publication No. 02-E006. Agency for Healthcare Research and Quality; 2002.
28 Awartani FA, Zulqarnain BJ. Comparison of the clinical effects of subgingival application of metronidazole 25% gel and scaling in the treatment of adult periodontitis. Quintessence Int. 1998;29:41-48. [pmid: 9611474].
29 Review Manager (RevMan) [Computer Program] Version 4.2 for Windows. Oxford, England: The Cochrane Collaboration; 2002.
30 Braatz L, Garrett S, Claffey N, Egelberg J. Antimicrobial irrigation of deep pockets to supplement non-surgical periodontal therapy. II. Daily irrigation. J Clin Periodontol. 1985;12:630-638. [pmid: 3863836].
31 MacAlpine R, Magnusson I, Kiger R, Crigger M, Garrett S, Egelberg J. Antimicrobial irrigation of deep pockets to supplement oral hygiene instruction and root debridement. I. Bi-weekly irrigation. J Clin Periodontol. 1985;12:568-577. [pmid: 3894436].
32 Graca MA, Watts TL, Wilson RF, Palmer RM. A randomized controlled trial of a 2% minocycline gel as an adjunct to non-surgical periodontal treatment, using a design with multiple matching criteria. J Clin Periodontol. 1997;24:249-253. [pmid: 9144047].
33 Jeong SN, Han SB, Lee SW, Magnusson I. Effects of tetracycline-containing gel and a mixture of tetracycline and citric acid-containing gel on non-surgical periodontal therapy. J Periodontol. 1994;65:840-847. [pmid: 7990020].
34 Lie T, Bruun G, Boe OE. Effects of topical metronidazole and tetracycline in treatment of adult periodontitis. J Periodontol. 1998;69:819-827. [pmid: 9706861].
35 Tonetti MS, Cortellini P, Carnevale G, Cattabriga M, de Sanctis M, Pini Prato GP. A controlled multicenter study of adjunctive use of tetracycline periodontal fibers in mandibular class II furcations with persistent bleeding. J Clin Periodontol. 1998;25:728-736. [pmid: 9763328].
36 Stelzel M, Flores-de-Jacoby L. Topical metronidazole application as an adjunct to scaling and root planing. J Clin Periodontol. 2000;27:447-452. [pmid: 10883875].
37 Moran J, Addy M, Wade W, Newcombe R. The use of antimicrobial acrylic strips in the nonsurgical management of chronic periodontitis. Clinical Materials. 1990;6:123-135. [pmid: 10147516].
38 SAS Institute I, Wang M, Bushman BJ; Integrating Results Through Meta-Analytic Review Using SAS SSoftware. Cary, NC: SAS Institute, Inc.; 1999.
39 West SL, King V, Carey TS, et al. Systems to Rate the Strength of Scientific Evidence. Evidence Report/Technology Assessment No. 47. Rockville, Md.: Agency for Healthcare Research and Quality. AHRQ Publication No. 02-E016; 2002.
40 Lohr KN, Carey TS. Assessing "best evidence": issues in grading the quality of studies for systematic reviews. Jt Comm J Qual Improv. 1999;25:470-479. [pmid: 10481816].
41 Begg C, Cho M, Eastwood S, et al. Improving the quality of reporting of randomized controlled trials. The CONSORT statement. JAMA. 1996;276:637-639. [pmid: 8773637].
42 Balk EM, Bonis PA, Moskowitz H, et al. Correlation of quality measures with estimates of treatment effect in meta-analyses of randomized controlled trials. JAMA. 2002;287:2973-82. [pmid: 12052127].
43 Listgarten MA, Lindhe J, Hellden L. Effect of tetracycline and/or scaling on human periodontal disease. Clinical, microbiological, and histological observations. J Clin Periodontol. 1978;5:246-271. [pmid: 363749].
44 Lindhe J, Liljenberg B, Adielsson B. Effect of long-term tetracycline therapy on human periodontal disease. J Clin Periodontol. 1983;10:590-601. [pmid: 6581174].
45 Al-Joburi W, Chin Quee T, Lautar C, et al. Effects of adjunctive treatment of periodontitis with tetracycline and spiramycin. J Periodontol. 1989;60:533-539. [pmid: 2681673].
46 Haffajee AD, Dibart S, Kent RLJ, Socransky SS. Clinical and microbiological changes associated with the use of 4 adjunctive systemically administered agents in the treatment of periodontal infections. J Clin Periodontol. 1995;22:618-627. [pmid: 8583019].
47 Ramberg P, Rosling B, Serino G, Hellstrom MK, Socransky SS, Lindhe J. The long-term effect of systemic tetracycline used as an adjunct to non-surgical treatment of advanced periodontitis. J Clin Periodontol. 2001;28:446-452. [pmid: 11350508].
48 Goodson JM, Hogan PE, Dunham SL. Clinical responses following periodontal treatment by local drug delivery. J Periodontol. 1985;56:81-87. [pmid: 3866055].
49 Drisko CL, Cobb CM, Killoy WJ, et al. Evaluation of periodontal treatments using controlled-release tetracycline fibers: clinical response. J Periodontol. 1995;66:692-699. [pmid: 7473012].
50 Darhous MS, Zahran F, Ragy N. Bacteriological and clinical assessment of tetracycline as root conditioning in adjunct to periodontal surgery. Egypt Dent J. 1995;41:1167-1178. [pmid: 9497653].
51 Nylund K, Egelberg J. Antimicrobial irrigation of periodontal furcation lesions to supplement oral hygiene instruction and root debridement. J Clin Periodontol. 1990;17:90-95. [pmid: 2303575].
52 Minabe M, Takeuchi K, Nishimura T, Hori T, Umemoto T. Therapeutic effects of combined treatment using tetracycline-immobilized collagen film and root planing in periodontal furcation pockets. J Clin Periodontol. 1991;18:287-290. [pmid: 2066441].
53 Kinane DF, Radvar M. A six-month comparison of three periodontal local antimicrobial therapies in persistent periodontal pockets. J Periodontol. 1999;70:1-7. [pmid: 10052765].
54 Shiloah J, Patters MR. DNA probe analyses of the survival of selected periodontal pathogens following scaling, root planing, and intra-pocket irrigation. J Periodontol. 1994;65:568-575. [pmid: 8083788].
55 Trombelli L, Scabbia A, Carotta V, Scapoli C, Calura G. Clinical effect of subgingival tetracycline irrigation and tetracycline-loaded fiber application in the treatment of adult periodontitis. Quintessence Int. 1996;27:19-25. [pmid: 9063208].
56 Yalcin F, Demirel K, Onan U. Evaluation of adjunctive tetracycline fiber therapy with scaling and root planing: short-term clinical results. Periodontal Clin Invest. 1999;21:23-27.
57 Newman MG, Kornman KS, Doherty FM. A 6-month multi-center evaluation of adjunctive tetracycline fiber therapy used in conjunction with scaling and root planing in maintenance patients: clinical results. J Periodontol. 1994;65:685-691. [pmid: 7608845].
58 Friesen LR, Williams KB, Krause LS, Killoy WJ. Controlled local delivery of tetracycline with polymer strips in the treatment of periodontitis. J Periodontol. 2002;73:13-19. [pmid: 11846194].
59 Unsal E, Akkaya M, Walsh TF. Influence of a single application of subgingival chlorhexidine gel or tetracycline paste on the clinical parameters of adult periodontitis patients. J Clin Periodontol. 1994;21:351-355. [pmid: 8034781].
60 Minabe M, Takeuchi K, Kumada H, Umemoto T. The effect of root conditioning with minocycline HCl in removing endotoxin from the roots of periodontally-involved teeth. J Periodontol. 1994;65:387-392. [pmid: 8046553].
61 Ciancio SG, Slots J, Reynolds HS, Zambon JJ, McKenna JD. The effect of short-term administration of minocycline HCl on gingival inflammation and subgingival microflora. J Periodontol. 1982;53:557-561. [pmid: 6752371].
62 Atilla G, Balcan M, Bicakci N, Kazandi A. The effect of non-surgical periodontal and adjunctive minocycline-HCL treatments on the activity of salivary proteases. J Periodontol. 1996;67:1-6. [pmid: 8676266].
63 van Steenberghe D, Bercy P, Kohl J, et al. Subgingival minocycline hydrochloride ointment in moderate to severe chronic adult periodontitis: a randomized, double-blind, vehicle-controlled, multicenter study. J Clin Periodontol. 1993;64:637-644.
64 Jones AA, Kornman KS, Newbold DA, Manwell MA. Clinical and microbiological effects of controlled-release locally delivered minocycline in periodontitis. J Periodontol. 1994;65:1058-1066. [pmid: 7853130].
65 van Steenberghe D, Rosling B, Soder PO, et al. A 15-month evaluation of the effects of repeated subgingival minocycline in chronic adult periodontitis. J Periodontol. 1999;70:657-667. [pmid: 10397521].
66 Williams RC, Paquette DW, Offenbacher S, et al. Treatment of periodontitis by local administration of minocycline microspheres: a controlled trial. J Periodontol. 2001;72:1535-1544. [pmid: 11759865].
67 Henderson RJ, Boyens JV, Holborow DW, Pack AR. Scaling and root-planing treatment with adjunctive subgingival minocycline. A clinical pilot study over six months, of sites adjacent to and remote from the antibiotic application. J Int Acad Periodontol. 2002;4:77-87. [pmid: 12670086].
68 Van Dyke TE, Offenbacher S, Braswell L, Lessem J. Enhancing the value of scaling and root-planing: Arestin clinical trial results. J Int Acad Periodontol. 2002;4:72-6. [pmid: 12670085].
69 Loesche WJ, Syed SA, Morrison EC, Kerry GA, Higgins T, Stoll J. Metronidazole in periodontitis. I. Clinical and bacteriological results after 15 to 30 weeks. J Periodontol. 1984;55:325-335. [pmid: 6376759].
70 Rooney J, Wade WG, Sprague SV, Newcombe RG, Addy M. Adjunctive effects to non-surgical periodontal therapy of systemic metronidazole and amoxycillin alone and combined. A placebo controlled study. J Clin Periodontol. 2002;29:342-350. [pmid: 11966932].
71 Joyston-Bechal S, Smales FC, Duckworth R. A follow-up study 3 years after metronidazole therapy for chronic periodontal disease. J Clin Periodontol. 1986;13:944-949. [pmid: 3540025].
72 Soder PO, Frithiof L, Wikner S, et al. The effect of systemic metronidazole after non-surgical treatment in moderate and advanced periodontitis in young adults. J Periodontol. 1990;61:281-288. [pmid: 2191111].
73 Loesche WJ, Schmidt E, Smith BA, Morrison EC, Caffesse R, Hujoel PP. Effects of metronidazole on periodontal treatment needs. J Periodontol. 1991;62:247-257. [pmid: 2037955].
74 Loesche WJ, Giordano JR, Hujoel P, Schwarcz J, Smith BA. Metronidazole in periodontitis: reduced need for surgery. J Clin Periodontol. 1992;19:103-112. [pmid: 1602034].
75 Noyan U, Yilmaz S, Kuru B, Kadir T, Acar O, Buget E. A clinical and microbiological evaluation of systemic and local metronidazole delivery in adult periodontitis patients. J Clin Periodontol. 1997;24:158-165. [pmid: 9083899].
76 Palmer RM, Matthews JP, Wilson RF. Adjunctive systemic and locally delivered metronidazole in the treatment of periodontitis: a controlled clinical study. Br Dent J. 1998;184:548-552. [pmid: 9682550].
77 Aziz-Gandour IA, Newman HN. The effects of a simplified oral hygiene regime plus supragingival irrigation with chlorhexidine or metronidazole on chronic inflammatory periodontal disease. J Clin Periodontol. 1986;13:228-236. [pmid: 3517075].
78 Riep B, Purucker P, Bernimoulin JP. Repeated local metronidazole-therapy as adjunct to scaling and root planing in maintenance patients. J Clin Periodontol. 1999;26:710-715. [pmid: 10589806].
79 Griffiths GS, Smart GJ, Bulman JS, Weiss G, Shrowder J, Newman HN. Comparison of clinical outcomes following treatment of chronic adult periodontitis with subgingival scaling or subgingival scaling plus metronidazole gel. J Clin Periodontol. 2000;27:910-917. [pmid: 11140558].
80 Al-Mubarak SA, Karring T, Ho A. Clinical evaluation of subgingival application of metronidazole 25%, and adjunctive therapy. J Int Acad Periodontol. 2000;2:64-70. [pmid: 12666963].
81 Berglundh T, Krok L, Liljenberg B, Westfelt E, Serino G, Lindhe J. The use of metronidazole and amoxicillin in the treatment of advanced periodontal disease. A prospective, controlled clinical trial. J Clin Periodontol. 1998;25:354-362. [pmid: 9650870].
82 Flemmig TF, Milian E, Karch H, Klaiber B. Differential clinical treatment outcome after systemic metronidazole and amoxicillin in patients harboring Actinobacillus actinomycetemcomitans and/or Porphyromonas gingivalis. J Clin Periodontol. 1998;25:380-387. [pmid: 9650874].
83 Winkel EG, Van Winkelhoff AJ, Timmerman MF, Van der Velden U, Van der Weijden GA. Amoxicillin plus metronidazole in the treatment of adult periodontitis patients. A double-blind placebo-controlled study. J Clin Periodontol. 2001;28:296-305. [pmid: 11314884].
84 Watts EA, Newman HN. Clinical effects on chronic periodontitis of a simplified system of oral hygiene including subgingival pulsated jet irrigation with chlorhexidine. J Clin Periodontol. 1986;13:666-670. [pmid: 3463571].
85 Wennstrom J, Heijl L, Dahlen G, Grondahl K. Periodic subgingival antimicrobial irrigation of periodontal pockets (I). Clinical observations. J Clin Periodontol. 1987;14:541-550. [pmid: 3479456].
86 Southard SR, Drisko CL, Killoy WJ, Cobb CM, Tira DE. The effect of 2% chlorhexidine digluconate irrigation on clinical parameters and the level of Bacteroides gingivalis in periodontal pockets. J Periodontol. 1989;60:302-309. [pmid: 2674394].
87 Taggart JA, Palmer RM, Wilson RF. A clinical and microbiological comparison of the effects of water and 0.02% chlorhexidine as coolants during ultrasonic scaling and root planing. J Clin Periodontol. 1990;17:32-37. [pmid: 2404033].
88 Reynolds MA, Lavigne CK, Minah GE, Suzuki JB. Clinical effects of simultaneous ultrasonic scaling and subgingival irrigation with chlorhexidine. Mediating influence of periodontal probing depth. J Clin Periodontol. 1992;19:595-600. [pmid: 1447385].
89 Oosterwaal PJ, Mikx FH, van 't Hof MA, Renggli HH. Comparison of the antimicrobial effect of the application of chlorhexidine gel, amine fluoride gel and stannous fluoride gel in debrided periodontal pockets. J Clin Periodontol. 1991;18:245-251. [pmid: 1856305].
90 Soskolne WA, Heasman PA, Stabholz A, et al. Sustained local delivery of chlorhexidine in the treatment of periodontitis: a multi-center study. J Periodontol. 1997;68:32-38. [pmid: 9029449].
91 Jeffcoat MK, Bray KS, Ciancio SG, et al. Adjunctive use of a subgingival controlled-release chlorhexidine chip reduces probing depth and improves attachment level compared with scaling and root planing alone. J Periodontol. 1998;69:989-997. [pmid: 9776027].
92 Heasman PA, Heasman L, Stacey F, McCracken GI. Local delivery of chlorhexidine gluconate (PerioChip) in periodontal maintenance patients. J Clin Periodontol. 2001;28:90-95. [pmid: 11142674].
93 Azmak N, Atilla G, Luoto H, Sorsa T. The effect of subgingival controlled-release delivery of chlorhexidine chip on clinical parameters and matrix metalloproteinase-8 levels in gingival crevicular fluid. J Periodontol. 2002;73:608-615. [pmid: 12083533].
94 Grisi DC, Salvador SL, Figueiredo LC, Souza SL, Novaes AB, Grisi MF. Effect of a controlled-release chlorhexidine chip on clinical and microbiological parameters of periodontal syndrome. J Clin Periodontol. 2002;29:875-881. [pmid: 12445218].
95 Quirynen M, Mongardini C, de Soete M, et al. The role of chlorhexidine in the one-stage full-mouth disinfection treatment of patients with advanced adult periodontitis. Long-term clinical and microbiological observations. J Clin Periodontol. 2000;27:578-589. [pmid: 10959784].
96 Chin Quee T, Chan E, Clark C, et al. The role of adjunctive Rodogyl therapy in the treatment of advanced periodontal disease. A longitudinal clinical and microbiologic study. J Periodontol. 1987;58:594-601. [pmid: 3309251].
97 Bain CA, Beagrie GS, Bourgoin J, et al. The effects of spiramycin and/or scaling on advanced periodontitis in humans. J Can Dent Assoc. 1994;60:209. , 212-217. [pmid: 8156459].
98 Ng VW, Bissada NF. Clinical evaluation of systemic doxycycline and ibuprofen administration as an adjunctive treatment for adult periodontitis. J Periodontol. 1998;69:772-7726. [pmid: 9706854].
99 Smith SR, Foyle DM, Daniels J, et al. A double-blind placebo-controlled trial of azithromycin as an adjunct to non-surgical treatment of periodontitis in adults: clinical results. J Clin Periodontol. 2002;29:54-61. [pmid: 11846850].
100 Kimura S, Toda H, Shimabukuro Y, et al. Topical chemotherapy in human periodontitis using a new controlled-release insert containing ofloxacin. I. Microbiological observation. J Periodontal Res. 1991;26:33-41. [pmid: 1825332].
101 Eickholz P, Kim TS, Burklin T, et al. Non-surgical periodontal therapy with adjunctive topical doxycycline: a double-blind randomized controlled multicenter study. J Clin Periodontol. 2002;29:108-117. [pmid: 11895538].
102 Furuichi Y, Ramberg P, Krok L, Lindhe J. Short-term effects of triclosan on healing following subgingival scaling. J Clin Periodontol. 1997;24:777-782. [pmid: 9350563].
103 Listgarten MA, Grossberg D, Schwimer C, Vito A, Gaffar A. Effect of subgingival irrigation with tetrapotassium peroxydiphosphate on scaled and untreated periodontal pockets. J Periodontol. 1989;60:4-11. [pmid: 2646418].
104 Rosling B, Hellstrom MK, Ramberg P, Socransky SS, Lindhe J. The use of PVP-iodine as an adjunct to non-surgical treatment of chronic periodontitis. J Clin Periodontol. 2001;28:1023-1031. [pmid: 11686823].
105 Moher D, Cook DJ, Eastwood S, Olkin I, Rennie D, Stroup DF. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Quality of Reporting of Meta-analyses. Lancet. 1999;354:1896-900. [pmid: 10584742].
106 Moher D, Schulz KF, Altman D. The CONSORT statement: revised recommendations for improving the quality of reports of parallel-group randomized trials. JAMA. 2001;285:1987-1991. [pmid: 11308435].
107 Stroup DF, Berlin JA, Morton SC, et al. Meta-analysis of observational studies in epidemiology: a proposal for reporting. Meta-analysis Of Observational Studies in Epidemiology (MOOSE) group. JAMA. 2000;283:2008-2012. [pmid: 10789670].
108 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20:21-35. [pmid: 11306229].