# Appendix B

## QUALITY REVIEW CHECKLIST

Analysis
1. | Random Assignment of Treatment | Y | N/NR
2 | Blinding of Examiners | Y | N/NR
3 | Blinding of Subjects | Y | N/NR
4 | Use of Placebo | Y | N
5 | Total Sample Size ≥ 40 | Y | N
6 | Equal Sized Sample in Treatment and Control Groups | Y | N/NR
7 | Judge external validity to be Good based on data reported (on disease, qualifications for participation in study, study setting, and subjects characteristics) | Y | N/NR
8 | Attrition from enrolled group ≤ 10% | Y | N
9 | Multi-center Trial | Y | N/NR
10 | Use all enrolled subjects in the analysis (or only those who completed) | Y | N
11 | Reported if any Adverse Effects/Harms | Y | N
12 | Are appropriate statistical techniques employed (adjust for multiple comparisons [Duncan, Scheffe, etc.], take into account lack of independence between observations [GLM, Sudaan, etc]) | Y | N/NR
13 | Reported means and variances (for baseline and end for T and C groups, or as change from baseline to end) as well as number of sites/teeth/people for each group or reported difference between change for the T and C groups | Y | N/NR
OVERALL RATING: