# Appendix A

## DENTAL DATA ABSTRACTION FORM

## Abstraction Form

Question: HOW DOES THE EFFECTIVENESS OF SCALING AND ROOT PLANING ACCOMPANIED BY ADJUNCTIVE THERAPY FOR CHRONIC PERIODONTITIS COMPARE TO SCALING AND ROOT PLANING THERAPY BY ITSELF AT VARYING LENGTHS OF TIME POST-TREATMENT?

A. Administrative Information

1. Abstractor:___________________________________ 2.Abstract Date:________________

3. Abbreviated study citation

___________________________________________________________________________

first author journal abbr

___________________________________________________­­­________________________

year volume pages

4. Abbreviated article title: ______________________________________________________________________________

5. Included?

[image] No

If no, excluded because: (check one)

[image] SRP different in control/comparison group than in treatment group

[image] No SRP-only control/comparison group/sites

[image] Treatment groups/sites did not also receive SRP

[image] Literature review or meta-analysis

[image] Practice guideline or editorial

[image] Special population/disease studied, described as: with HIV/AIDS or diabetes; localized disease; juvenile or early onset disease; in smokers; around implants;

[image] Other (Specify): ___________________________________________________

[image] Yes (go to B. Study Design Information )

B. Study Design Information

1. Type of design (Check One):

[image] Randomized controlled trial(RCT)

[image] Non-Randomized controlled trial

[image] RCT with crossover

[image] Other (Specify)___________________________________________________________

__________________________________________________________________________

2. Is it a split-mouth design?

[image] Yes

[image] No

3. Does study investigate (check one):

[image] Single-rooted teeth

[image] Teeth bifurcated (molars)

[image] Both

[image] Not reported

4. Does study characterize periodontal disease as (check all that apply):

[image] Mild

[image] Moderate

[image] Severe

[image] Not reported

5. Placebo used in control/comparison (SRP only) group/sites?

[image] Yes

[image] No

6. Number of eligible active treatment groups: ________

7. Study period (Specify begin and end calendar month/year in which conducted)

From __________________ To ____________________

8. Study location(s) (Specify city/nation) _____________________________________________

9. Study/treatment site(s):

[image] Hospital dental clinic

[image] Graduate program university clinic

[image] Undergraduate dental clinic

[image] Health department clinic

[image] Private dental practice

[image] Not mentioned

[image] Other (Specify)_________________________________________________________

10. Duration of treatment:_______ days/ weeks/months

11. Specify eligible adjunctive therapy(ies):

[image] Amoxicillin

[image] Augmentin

[image] Chlorhexidine

[image] Doxycycline

[image] Metronidazole

[image] Minocycline

[image] Spiramycin

[image] Povodine iodine

[image] Tetracycline

[image] Azithromycin

[image] Clindamycin

[image] Other (Specify)_______________________________________________________

12. Dose, mode of delivery, and schedule of treatment group(s) (XX mgs, as a rinse (for local), Y times /day, week, month) and SRP only group (or with placebo if used):

Group 1(or only treatment group): __________________________________________

Group 2: _______________________________________________________________

Group 3:_______________________________________________________________

SRP only / or SRP with Placebo:________________________________________________

13. Duration of evaluation period:_____ days or _______ weeks or ______ months

14. Drug use compliance monitoring:

[image] Yes

[image] No

[image] Not reported

[image] Not applicable (e.g., professionally administered/applied)

15. Describe the SRP as they performed it: _____________________________________________ _____________________________________________________________________________

16. How much time on average was spent doing SRP? ___________________________________

17. Was it performed with

[image] An ultrasonic/Cavitron

[image] By hand

[image] Both

[image] Not reported

18. Describe supportive therapy provided to study participants and indicate frequency/intervals.

[image] Oral instruction How often: _______________________

[image] Plaque removal How often: _______________________

[image] Repeated SRP How often: _______________________

[image] Other _______________________________________________________________

[image] Not reported

19. Was baseline assessment performed before or after SRP?

[image] Before

[image] After

[image] Not Reported

20. Number of evaluation time points (e.g. 4 times not including baseline) ______ and regular intervals of __________ (e.g., every two weeks). If intervals vary, specify evaluation points: __________________________________________________________________________

21. Blinding to active drug:

[image] Examiners blind

[image] Patient blind

[image] Patients and examiners blind (double blind)

[image] No blinding

[image] Not reported

22. Outcomes (parameters measured) and citations:

CLINICAL MEASUREMENT

[image] Bleeding on Probing (BOP/SBI) Citation: _______________________________

[image] Plaque Index (PlI) Citation: _______________________________

[image] Probing Pocket Depth (PPD) Citation: _______________________________

[image] Clinical Attachment Level (CAL) Citation: _______________________________

[image] Gingival Index (GI) Citation: _______________________________

[image] Gingival Recession Citation: _______________________________

[image] Tooth Loss Citation: _______________________________

[image] Tooth Mobility Citation: _______________________________

[image] Other (Specify) Citation: _______________________________

RADIOGRAPHIC TECHNIQUES

[image] Bone Loss/Regeneration Citation: _______________________________

[image] Other (Specify) Citation: _______________________________

MICROBIOLOGICAL METHODS

[image] Chromatography Citation: _______________________________

[image] DNA/RNA probe Citation: _______________________________

[image] Crevicular fluid microbiota Citation: _______________________________

[image] Plaque microbiota Citation: _______________________________

[image] Other (Specify) Citation: _______________________________

PATIENT SELF REPORT

[image] Patient Satisfaction Citation: _______________________________

[image] Other (Specify) Citation: _______________________________

C. Sample Information

1. Description of population sampled (recurrent disease, never treated, clinic patients, private care)___ ___________________________________________________________________________________

___________________________________________________________________________________

2. Initial sample size -- persons (teeth):

_____________= Total subjects (sites)

_____________= Group 1 or only active drug group subjects (sites)

_____________= Group 2 (second active drug) subjects (sites)

_____________= Group 3 (third active drug) subjects (sites)

_____________= SRP only/SRP with placebo subjects (sites)

3. Subject/Site allocation to treatment/control conditions (Check one):

[image] Random

[image] Systematic

[image] Cluster

[image] Convenience

[image] Unknown

[image] Other (Specify)________________________________________________

4. Specific inclusion and exclusion criteria. (Specify tooth or person level considerations.)

[image] Pregnant/breast feeding excluded

[image] Concurrent drug therapy excluded

[image] Diabetes history excluded

[image] Diagnosed systemic infection excluded

[image] Serious medical illness excluded

[image] Need for prophylactic antibiotic before dental treatment excluded

[image] Use of study drug within ____ months excluded

[image] Hypersensitivity/allergic to study drug excluded

[image] At least _____ teeth in _____ quadrant/mouth (circle one) with ____mm pocket included

[image] Age at least _______ included

[image] Other: ___________________________________________________________________ _________________________________________________________________________ _________________________________________________________________________

D. Group Characteristics

Total (All Study Groups Combined)

1. Age: mean:____________ median: ___________ range: ____________________

2. Gender: number (%) male:_______________ number (%) female:______________

3. Race/Ethnicity: number (%) NH White: _______________

number (%) NH Black: _____________

number (%) Hispanic (independent of race): ______________

number (%) NH Asian/PacificIslander: __________

number (%) other (specify):________

Group 1

1. Age: mean:____________ median: ___________ range: ____________________

2. Gender: number (%) male:_______________ number (%) female:______________

3. Race/Ethnicity: number (%) NH White: _______________

number (%) NH Black: _____________

number (%) Hispanic (independent of race): ______________

number (%) NH Asian/PacificIslander: __________

number (%) Other(Specify):________

Group 2

1. Age: mean:_______ median: ______ range: ______________________

2. Gender: number (%) male:_______________ number (%) female:______________

3. Race/Ethnicity: number (%) NH White: _______________

number (%) NH Black: _____________

number (%) Hispanic (independent of race): ______________

number (%) NH Asian/PacificIslander: __________

number (%) Other(Specify):________

Group 3

1. Age: mean:_______ median: ______ range: ______________________

2. Gender: number (%) male:_______________ number (%) female:______________

3. Race/Ethnicity: number (%) NH White: _______________

number (%) NH Black: _____________

number (%) Hispanic (independent of race): ______________

number (%) NH Asian/PacificIslander: __________

number (%) Other(Specify):________

SRP only/SRP plus placebo Group

1. Age: mean:_______ median: ______ range: ______________________

2. Gender: number (%) male:_______________ number (%) female:______________

3. Race/Ethnicity: number (%) NH White: _______________

number (%) NH Black: _____________

number (%) Hispanic (independent of race): ______________

number (%) NH Asian/PacificIslander: __________

number (%) Other(Specify):________

E. Provider/Examiner information

1. Number of examiners:_________

2. Examiners received:

[image] Instruction in use of measures (written, pictures)

[image] Standardization (Practice on patients)

[image] Calibration (Gold standard examiner)

[image] None/ Not reported

[image] Not applicable (No clinical examination/measures: only one examiner)

3. How are examiners assigned to patients at assessments?

[image] Random at each assessment

[image] Repeat at each assessment

[image] Not reported

[image] Only one examiner

F. Analysis Information

1. Analysis adjusted for clustered observations

[image] Yes

[image] No

[image] Not reported

2. Type of analysis reported:

[image] Intent to treat

[image] All with any follow-up

[image] Full participants only

3. Reasons/criteria for exclusion from analysis: _____________________________________________________________________________________ ______________________________________________________________________________________

G. Outcome Information

1. Did study look for adverse effects?

[image] Yes, found none

[image] Yes, but none reported

[image] Yes, found adverse effects (number and type) by study group.

Specify: ______________________________________________________________________ ___________________________________________________________________________ ___________________________________________________________________________

[image] Never mentioned looking

2. Frequency with which modified Wideman flap procedure was performed in study?

[image] Always/Often (25% of time or more)

[image] Occasionally (5-24 % of time)

[image] Rarely or Never (0-4 % of time)

[image] Frequency Not Reported

Comparison of Assessment 1 (Baseline) to Assessment 2

| Assessment 1 (Baseline) | | | | Assessment 2 | | | | Group Comparisons Specify Coefficient, P-value/NS/Direction (+/-)
Group | SRP Only | Treat 1 | Treat 2 | Treat 3 | SRP Only | Treat 1 | Treat 2 | Treat 3 | Statistical Test or Measure | T1 to SRP | T2 to SRP | T3 to SRP | T1 to T2 | T2 to T3 | T1 to T3
Number in Group
Outcome Measures (Describe)
1
2
3
4
5
6

Comparison of Assessment 2 / Baseline to Assessment 3

| Assessment 3 | | | | Group Comparisons Specify Coefficient, P-value/NS, Direction (+/-)
Group | SRP Only | Treat 1 | Treat 2 | Treat 3 | Treat 1 to SRP | Treat 2 to SRP | Treat 3 to SRP | Treat 1 to Treat 2 | Treat 2 to Treat 3 | Treat 1 to Treat 3
Number in Group
Outcome Measures (Describe)
1
2
3
4
5
6

Comparison of Assessment 3 / Baseline to Assessment 4

| Assessment 4 | | | | Group Comparisons Specify Coefficient, P-value/NS, Direction (+/-)
Group | SRP Only | Treat 1 | Treat 2 | Treat 3 | Treat 1 to SRP | Treat 2 to SRP | Treat 3 to SRP | Treat 1 to Treat 2 | Treat 2 to Treat 3 | Treat 1 to Treat 3
Number in Group
Outcome Measures (Describe)
1
2
3
4
5
6

Comparison of Assessment 4 / Baseline to Assessment 5

| Assessment 5 | | | | Group Comparisons Specify Coefficient, P-value/NS, Direction (+/-)
Group | SRP Only | Treat 1 | Treat 2 | Treat 3 | Treat 1 to SRP | Treat 2 to SRP | Treat 3 to SRP | Treat 1 to Treat 2 | Treat 2 to Treat 3 | Treat 1 to Treat 3
Number in Group
Outcome Measures (Describe)
1
2
3
4
5
6

Comparison of Assessment 5 / Baseline to Assessment 6

| Assessment 6 | | | | Group Comparisons Specify Coefficient, P-value/NS, Direction (+/-)
Group | SRP Only | Treat 1 | Treat 2 | Treat 3 | Treat 1 to SRP | Treat 2 to SRP | Treat 3 to SRP | Treat 1 to Treat 2 | Treat 2 to Treat 3 | Treat 1 to Treat 3
Number in Group
Outcome Measures (Describe)
1
2
3
4
5
6