# Listing of Excluded Studies

### Key for Reasons for Exclusion

1. Studies with no original data
2. Nonintervention studies that do not measure literacy
3. Studies with no health outcomes
4. Studies examining normal reading development in children
5. Studies about dyslexia
6. Studies on the basic experimental science of reading ability (e.g., studies of brain function, MRI, EEG)
7. Studies performed in developing countries
8. Non-English language studies
9. Studies published in abstract form only
10. Case-report only
11. Ecological data only
12. Unable to obtain the article

### References

Abosede O A. Self-medication: an important aspect of primary health care. Soc Sci Med. 1984;19(7):699-703. [pmid: 6505739].
Notes: Reject #2
Abuwa P N, Alikor E A, Gbaraba P V, Mung K S, Oruamabo R S. Determinants of tetanus toxoid immunization of parturient women: a community-based study in Rivers State of Nigeria. West Afr J Med. 1997;16(3):174-8. [pmid: 9329287].
Notes: Reject #7
Ackers M L, Quick R E, Drasbek C J, Hutwagner L, Tauxe R V. Are there national risk factors for epidemic cholera? The correlation between socioeconomic and demographic indices and cholera incidence in Latin America. Int J Epidemiol. 1998;27(2):330-4. [pmid: 9602419].
Notes: Reject #7
Adams A, Duffield C. The value of drills in developing and maintaining numeracy skills in an undergraduate nursing programme. Nurs Educ Today. 1991;11(3):213-9.
Notes: Reject #2 or 3
Adams JR, Tomori C, Bennett CL. Improving health care for patients with low literacy skills... this is the sixth in a series of reports on the conference presentations. Oncol News Int 2000; 9(12):22, 51.
Notes: Reject #1
Adams JR, Tomori C, Bennett CL. Poor reading skills present barrier to cancer care and health... this is the fifth in a series of reports on the conference presentations. Oncol News Int 2000; 9(11):26, 40-1.
Notes: Reject #1
Adams-Price C E. Age, education, and literacy skills of adult Mississippians. Gerontol. 1993;33(6):741-6.
Notes: Reject #3
Adelsward V, Sachs L. The meaning of 6.8: numeracy and normality in health information talks. Soc Sci Med. 1996;43(8):1179-87. [pmid: 8903121].
Notes: Reject #2
Aden A S, Brannstrom I, Mohamud K A, Persson L A, Wall S. The growth chart--a road to health chart? Maternal comprehension of the growth chart in two Somali villages. Paediatr Perinat Epidemiol. 1990;4(3):340-50. [pmid: 2374751].
Notes: Reject # 7
Aden A S, Omar M M, Omar H M, Hogberg U, Persson L A, Wall S. Excess female mortality in rural Somalia--is inequality in the household a risk factor?. Soc Sci Med. 1997;44(5):709-15. [pmid: 9032838].
Notes: Reject #7
Agbonifo P O. The state of health as a reflection of the level of development of a nation. Soc Sci Med. 1983;17(24):2003-6. [pmid: 6670004].
Notes: Reject #2
Agho A O. In pursuit of computer literacy in health management education. J Health Admin Educat. 1995;13(2):287-304.
Notes: Reject #3
Agho A O, Williams A M. Actual and desired computer literacy among allied health students. J Allied Health. 1995;24(2):117-26. [pmcid: 414271].
Notes: Reject #3
Agyepong I A, Manderson L. Mosquito avoidance and bed net use in the Greater Accra Region, Ghana. J Biosoc Sci. 1999;31(1):79-92. [pmid: 10081239].
Notes: Reject #7
Ahluwalia J S, Richter K, Mayo M S, et al. African American smokers interested and eligible for a smoking cessation clinical trial: predictors of not returning for randomization. Ann Epidemiol. 2002;12(3):206-12. [pmid: 11897179].
Notes: Reject #3
Al-Tayyib A A, Rogers S M, Gribble J N, Villarroel M, Turner C F. Effect of low medical literacy on health survey measurements. Am J Pub Health. 2002;92(9):1478-80. [pmcid: 276449].
Notes: Reject #3
Albert S M, Teresi J A. Reading ability, education, and cognitive status assessment among older adults in Harlem, New York City. Am J Pub Health. 1999;89(1):95-7. [pmcid: 31719].
Notes: Reject #3
Albright C L, Bruce B, Howard-Pitney B, Winkleby M A, Fortmann S P. Development of a curriculum to lower dietary fat intake in a multiethnic population with low literacy skills. J Nutr Educ. 1997;29(4):215-23.
Notes: Reject #3
Alexander K. Product alert. A selected list of Spanish language and low literacy patient education web sites. J Pediatr Health Care. 2002;16(3):151-5.
Notes: Reject #1
Alheidt P. The effect of reading ability on Rorschach performance. J Pers Assess. 1980;44(1):3-10. [pmid: 7359304].
Notes: Reject #3
Almquist N L, Bisson S, Wynia A. Bringing an early pediatric literacy program to the clinic setting. J Pediatr Health Care. 1998;12(5):276-9. [pmid: 9987262].
Notes: Reject #2
Alspach G. Reading and bleeding: an insidious link. Critic Care Nurse. 1996;16(4):12-4.
Notes: Reject #1
Ammerman A S, DeVellis B M, Haines P S, et al. Nutrition education for cardiovascular disease prevention among low income populations--description and pilot evaluation of a physician-based model. Patient Educ Counsel. 1992;19(1):5-18.
Notes: Reject #3
Andrus M R, Roth M T. Health literacy: a review. Pharmacotherapy. 2002;22(3):282-302. [pmid: 11898888].
Notes: Reject #1
Annett M M. Focus on schools. Schools 2001: SLPs urged to take action in literacy. ASHA. 2001;6(16):13.
Notes: Reject #1
Annett MM. Reading between the lines: clinicians develop creative ways to promote SLPs' role in literacy. ASHA 2001; 6(8):1, 12.
Notes: Reject #1
Anonymous. 5 tips to teach staff to instruct illiterate patients. Homec Educ Manag. 1996;1(6):75-6.
Notes: Reject #1
Anonymous. Address low literacy issues to improve Medicaid risk member compliance, reduce costs. Public Sect Contract Rep. 1998;4(2 ):27-30. [pmid: 10177570].
Notes: Reject #1
Anonymous . Clear & simple: developing effective print materials for low-literate readers. Washington, DC: United States Department of Health and Human Services.Public Health Service, 1994.
Notes: Reject #1
Anonymous. Communicating with patients who have limited literacy skills. Report of the National Work Group on Literacy and Health. J Fam Practice. 1998;46(2):168-76.
Notes: Reject #1
Anonymous. Connecting literacy with health. Occup Ther Now. 2000;2(5):23-4.
Notes: Reject #12
Anonymous. Demographics update. Illiteracy and low literacy in the United States. J Vis Impair Blind. 1996;90(3):286-7.
Notes: Reject #1
Anonymous. EH professionals consider literacy as part of preemployment testing. Hosp Employee Health. 1989;8(7):92-4.
Notes: Reject #1
Anonymous. Eliminate written words if patients lack literacy: in-house production, video duplication control costs. Patient Educ Manag 1998; 5(12):153-4, 156.
Notes: Reject #1
Anonymous. The front page. Low literacy skills: an important barrier in healthcare. Cancer Pract. 2000;8(1):2-3.
Notes: Reject #1
Anonymous . Giving patients the tools is first step, ensuring they understand is the next: focus on teaching materials and techniques that improve comprehension. Patient Educ Manag 2000; 7(10):109-12, 120.
Notes: Reject #1
Anonymous. Health literacy rated low in one third of Medicare managed care enrollees. Am J Health-System Pharm. 1999;56(8):709-10.
Notes: Reject #1
Anonymous. Health literacy: report of the Council on Scientific Affairs. Ad Hoc Committee on Health Literacy for the Council on Scientific Affairs, American Medical Association. J Am Med Assoc. 1999;281(6):552-7.
Notes: Reject #1
Anonymous. Helping low-literacy parents care for sick children. Reflect Nurs Leadersh. 2002;28(3):32. [pmid: 12073807].
Notes: Reject #1
Anonymous. Implementing literacy-related intervention roles for speech-language pathologists. Semin Speech Lang. 2001;22(3):159-246.
Notes: Reject #1
Anonymous. Improve compliance, write to literacy level. Patient Educ Manag. 1997;4(4):42-4.
Notes: Reject #1
Anonymous. It's on paper, but do they understand it? Simple testing gets written handouts on target. Hosp Case Manag 1999; 7(4):75-6, 80.
Notes: Reject #1
Anonymous . Low health literacy hurts patient compliance: costing the health care system $73 billion a year. Case Management Advisor 2001; 12(9):141-2, 144.
Notes: Reject #1
Anonymous. National literacy and health program. Cannt Journal. 1996;6(2):10-1.
Notes: Reject #1
Anonymous. Notable: patient's reading level inversely tied to size of breast cancers at detection. Ob-Gyn Malpractice Prevention. 1995;2(12):90.
Notes: Reject #1
Anonymous . Numeracy skills. Paediatr Nurs 1998; 10(6):26-30; quiz 31-2.
Notes: Reject #1
Anonymous. On the mark. Measuring literacy and readability -- check what patients really understand and act on, not how far they have gone in school. Joint Comm Benchmark. 2000;2(1):10.
Notes: Reject #1
Anonymous . Patient education quarterly. Higher risk of re-admits when patient can't read: use materials, techniques to boost comprehension. Hosp Case Manag 2001; 9(2):27-8, 32.
Notes: Reject #1
Anonymous. Patient education. Teaching clients with low-literacy skills. Health Care Food Nutr Focus. 2000;17(4):10-1. [pmid: 11188114].
Notes: Reject #1
Anonymous. Patients' low health literacy is a 'significant threat' to quality care: problem has only begun to be addressed. Qi/Qtm. 2001;11(6):61-5.
Notes: Reject #1
Anonymous. Perspective. Literacy and health: what RNs can do to break the link between poor literacy and poor health. AARN News Lett. 1997;53(5):15. [pmid: 9386386].
Notes: Reject #1
Anonymous. Poor health literacy may contribute to excess diabetes-related complications among disadvantaged groups. Res Act 2002; (265):3.
Notes: Reject #1
Anonymous. Poor literacy, low income may deter cancer screening. Oncol News Int. 2000;9(3):17.
Notes: Reject #1
Anonymous. Position statement: health literacy. AMSN News. 2000;9(6):2.
Notes: Reject #1
Anonymous. Position statement on health and literacy. Can J Occupat Therapy. 1997;64(4):225-6.
Notes: Reject #1
Anonymous. Position statement on health and literacy. Can J Occupat Therapy. 2001;68(2):130-1.
Notes: Reject #1
Anonymous. Quick reference guide 1: numeracy skills. Nurs Standard 1999; 13(25):insert 2p.
Notes: Reject #1
Anonymous. Scientific and technical information simply put. Atlanta, GA: United States Department of Health and Human Services. Centers for Disease Control and Prevention.Office of Communication, 1999.
Notes: Reject #1
Anonymous. Stats and facts. The challenge of inadequate health literacy. Manag Care Interface. 2001;14(8):30-1. [pmid: 11517833].
Notes: Reject #1
Anonymous . Teach staff easy-to-read writing techniques. Patient Educ Manag 1998; 5(2):19-21, 28.
Notes: Reject #1
Anonymous. To improve communication, make literacy a priority. Patient Educat Manag 1998; 5(2):17-9, 28.
Notes: Reject #1
Anscher M S, Gold D T. Literacy and laryngectomy: how should one treat head and neck cancer in patients who cannot read or write?. South Med J. 1991;84(2):209-13. [pmid: 1990455].
Notes: Reject #2
Arpen S. Working with families who have low literacy skills -- ICEA teaching ideas sheet #16. Int J Childbirth Educ. 1994;9(1):44-5.
Notes: Reject #1
Assink E, Kattenberg G. Computerized assessment of verbal skill. J Psychol Res. 1993;22(4):427-44.
Notes: Reject #2
Atkinson P M, Parks D K, Cooley S M, Sarkis S L. Reach Out and Read: a pediatric clinic-based approach to early literacy promotion. J Pediatr Health Care. 2002;16(1):10-5. [pmid: 11802115].
Notes: Reject #1
Austin P E, Matlack R, Dunn K A, Kesler C, Brown C K. Discharge instructions: do illustrations help our patients understand them?. Ann Emerg Med. 1995;25(3):317-20. [pmid: 7532382].
Notes: Reject #2
Ayello EA. A critique of the AHCPR's 'Preventing pressure ulcers -- a patient's guide' as a written instructional tool. Decubitus 1993; 6(3):44-6, 48-50.
Notes: Reject #1
Bakdash M B, Odman P A, Lange A L. Distribution and readability of periodontal health education literature. J Periodontol. 1983;54(9):538-41. [pmid: 6579280].
Notes: Reject #2, #3
Baker D W. Reading between the lines: deciphering the connections between literacy and health. J Gen Intern Med. 1999;14(5):315-7. [pmid: 10337042]. [pmcid: 1496582].
Notes: Reject #1
Baker D W, Gazmararian J A, Sudano J, Patterson M. The association between age and health literacy among elderly persons. J Gerontol Series B-Psychol Sci Soc Sci. 2000;55(6):S368-74.
Notes: Reject #3
Baker D W, Gazmararian J A, Sudano J, Patterson M. The association between age and health literacy among elderly persons. J Gerontol Series B-Psychol Sci Soc Sci. 2000;55(6):S368-74.
Notes: Reject #3
Baker D W, Gazmararian J A, Sudano J, Patterson M, Parker R M, Williams M V. Health literacy and performance on the Mini-Mental State Examination. Aging Ment Health. 2002;6(1):22-9. [pmid: 11827619].
Notes: Reject #3
Baker D W, Parker R M, Williams M V, et al. The health care experience of patients with low literacy. Arch Fam Med. 1996;5(6):329-34. [pmid: 8640322].
Notes: Reject #3
Baker D W, Williams M V, Parker R M, Gazmararian J A, Nurss J. Development of a brief test to measure functional health literacy. Patient Educ Counsel. 1999;38(1):33-42.
Notes: Reject #3
Baker F M, Johnson J T, Velli S A, Wiley C. Congruence between education and reading levels of older persons. Psychiatric Serv. 1996;47(2):194-6.
Notes: Reject #3
Balsam AL, Merrigan D, Alich K, Mackey P, Green L, Reisman J. The Massachusetts Elderly Diabetes Education Program. Diabetes Educ 1993; 19(3):223, 225-6, 228.
Notes: Reject #3
Bar-Yam N B. Political issues. Low health literacy: a problem for all in the health care circle. Int J Childbirth Educat. 2002;17(3 ):21-3.
Notes: Reject #1
Barnes L P. The illiterate client: strategies in patient teaching. Am J Matern Child Nurs. 1992;17(3):127.
Notes: Reject #1
Barrett J, Pongor K, Stifter R, Nussbaum D. Selecting accessible software to enhance literacy. Volta Voices. 2001;8(1):16-21.
Notes: Reject #1
Bartlett J D. Optometry and literacy. J Am Optometr Assoc. 1990;61(2):82.
Notes: Reject #1
Bass PF3, Wilson J F, Griffith C H, Barnett D R. Residents' ability to identify patients with poor literacy skills. Academ Med. 2002;77(10):1039-41.
Notes: Reject #3
Baydar N, Brooks-Gunn J, Furstenberg F F. Early warning signs of functional illiteracy: predictors in childhood and adolescence. Child Develop. 1993;64(3):815-29. [pmid: 8339697].
Notes: Reject #2
Beardsall L, Huppert F. Short NART, CCRT and Spot-the-Word: comparisons in older and demented persons. Br J Clin Psychol. 1997;36 (Pt 4):619-22. [pmid: 9403152].
Notes: Reject #3
Beardsall L, Huppert F A. Improvement in NART word reading in demented and normal older persons using the Cambridge Contextual Reading Test. J Clin Experiment Neuropsychol. 1994;16(2):232-42.
Notes: Reject #3
Beitz JM. Education for health promotion and disease prevention: convince them, don't confuse them. Ostomy Wound Manag 1998; 44(3A Suppl):71S-6S; discussion 77S.
Notes: Reject #1
Belton A B. Reading levels of patients in a general hospital. Beta Release. 1991;15(1):21-4.
Notes: Reject #3
Benitez O, Devaux D, Dausset J. Audiovisual documentation of oral consent: a new method of informed consent for illiterate populations. Lancet. 2002;359(9315):1406-7. [pmid: 11978341].
Notes: Reject #3
Benjamin B A. Level of literacy in the nurses aide population. Baseline data for nursing staff development. J Nurs Staff Develop. 1997;13(3):149-54.
Notes: Reject #3
Benjamin BA. Relationship between literacy skills and actual and estimated job performance of the nurse's aide. Columbia University Teachers College, 1995.
Notes: Reject #12
Bennett K E, Haggard M P, Silva P A, Stewart I A. Behaviour and developmental effects of otitis media with effusion into the teens. Arch Dis Childhood. 2001;85(2):91-5. [pmid: 11466180].
Notes: Reject #3
Benson J G, Forman W B. Comprehension of written health care information in an affluent geriatric retirement community: Use of the test of functional health literacy. Gerontology. 2002;48(2):93-7. [pmid: 11867931].
Notes: Reject #3
Berg A, Hammitt K B. Assessing the psychiatric patient's ability to meet the literacy demands of hospitalization. Hosp Comm Psychiatr. 1980;31(4):266-8.
Notes: Reject #3
Berger D, Inkelas M, Myhre S, Mishler A. Developing health education materials for inner-city low literacy parents. Pub Health Rep. 1994;109(2):168-72. [pmid: 8153268]. [pmcid: 1403472].
Notes: Reject #1
Berland G K, Elliott M N, Morales L S, et al. Health information on the Internet: accessibility, quality, and readability in English and Spanish. J Am Med Assoc. 2001;285(20):2612-21.
Notes: Reject #2
Bernal H, Wooley S, Schensul J J. Methodology corner. The challenge of using Likert-type scales with low-literate ethnic populations. Nurs Res. 1997;46(3):179-81. [pmid: 9176508].
Notes: Reject #3
Bertelson P. The onset of literacy: liminal remarks. Cognition. 1986;24(1-2):1-30. [pmid: 3539488].
Notes: Reject #1
Best D. Clinical rounds. The development of a guide for stroke survivors and their families. Can J Cardiovasc Nurs. 1994;5(3):35-8. [pmid: 7741972].
Notes: Reject #1
Best D G. The development of a guide for stroke survivors and their families. Can J Cardiovasc Nurs. 1994;5(3):35-8. [pmid: 7741972].
Notes: Reject #1
Bialystok E. Preparing to read: the foundations of literacy. Adv Child Dev Behav. 1996;26:1-34. [pmid: 8787577].
Notes: Reject #1
Biber D, Reppen R, Conrad S. Developing linguistic literacy: perspectives from corpus linguistics and multi-dimensional analysis. J Child Lang 2002; 29(2):458-62; discussion 489-94.
Notes: Reject #1
Bigatti S M, Cronan T A, Anaya A. The effects of maternal depression on the efficacy of a literacy intervention program. Child Psychiatry Hum Dev. 2001;32(2):147-62. [pmid: 11758880].
Notes: Reject #2
Birch D A. A cooperative approach to promoting health literacy: the Current Health Issues Project. J Sch Health. 2000;70(2):69-71. [pmid: 10715829].
Notes: Reject #1
Birch D A. Teaching techniques. A cooperative approach to promoting health literacy: the Current Health Issues Project. J Sch Health. 2000;70(2):69-71. [pmid: 10715829].
Notes: Reject #1
Black D. Black looks ... at literacy. Journal of the Royal College of Physicians of London. 1991;25(4):282-3. [pmid: 1960678].
Notes: Reject #1
Black S A, Espino D V, Mahurin R, et al. The influence of noncognitive factors on the Mini-Mental State Examination in older Mexican-Americans: findings from the Hispanic EPESE. Established Population for the Epidemiologic Study of the Elderly. J Clin Epidemiol. 1999;52(11):1095-102. [pmid: 10527004].
Notes: Reject #3
Blanchard WA. Case study. Teaching an illiterate transplant patient. Anna Journal 1998; 25(1):69-70, 76.
Notes: Reject #10
Blank R D. Numeracy. Ann Intern Med. 1998;128(9):783. [pmid: 9556482].
Notes: Reject #1
Blinkhorn A S, Verity J M. Assessment of the readability of dental health education literature. Community Dent Oral Epidemiol. 1979;7(4):195-8. [pmid: 293237].
Notes: Reject #2, 3
Bodel M. Brain building basics: report on the development of a parenting & literacy skills program. Brain Inj 1998; 2(2):28-31, 45-8, 50.
Notes: Reject #3
Borikar A M, Bumstead J M. Literacy/numeracy provision and its effectiveness in psychiatric hospitals. British Journal of Occupational Therapy. 1988;51(11):395-6.
Notes: Reject #2
Boswell C, Cannon S, Aung K, Hammack B, Ienatsch G P, Prado M. Interdisciplinary collaboration: a study in progress. Public Health Nurs. 2002;19(4):235-7. [pmid: 12071896].
Notes: Reject #1
Bosworth H B, Oddone E Z. A model of psychosocial and cultural antecedents of blood pressure control. J Natl Med Assoc. 2002;94(4):236-48. [pmid: 11991336].
Notes: Reject #1
Brez S M, Taylor M. Assessing literacy for patient teaching: perspectives of adults with low literacy skills. J Adv Nurs. 1997;25 (5):1040-7. [pmid: 9147210].
Notes: Reject #1
Bright P, Jaldow E, Kopelman M D. The National Adult Reading Test as a measure of premorbid intelligence: a comparison with estimates derived from demographic variables. J Int Neuropsychol Soc. 2002;8(6):847-54. [pmid: 12240749].
Notes: Reject #2
Brill J R, Ohly S, Stearns M A. Training community-responsive physicians. Acad Med. 2002;77(7):747. [pmid: 12114168].
Notes: Reject #1
Britto PR, Brooks-Gunn J. Beyond shared book reading: dimensions of home literacy and low-income African American preschoolers' skills. New Dir Child Adol Dev 2001; (92):73-89; discussion 91-8.
Notes: Reject #1
Brooks D A. Nurse educator. Techniques for teaching ED patients with low literacy skills. J Emerg Nurs. 1998;24(6):601-3. [pmid: 9836825].
Notes: Reject #1
Brooks D A. Techniques for teaching ED patients with low literacy skills. J Emerg Nurs. 1998;24(6):601-3. [pmid: 9836825].
Notes: Reject #1
Brown JA, Nederend SE, Hays RD, Short PF, Farley DO . Special issues in assessing care of Medicaid recipients. Med Care 1999; 37(3 Suppl):MS79-88.
Notes: Reject #2
Brown P, Ames N, Mettger W et al. Closing the comprehension gap: low literacy and the Cancer Information Service. J Nat Canc Inst 1993; (14):157-63.
Notes: Reject #1
Browning N. Literacy of children with physical disabilities: a literature review. Can J OccupTher. 2002;69(3):176-82.
Notes: Reject #1
Brownson K. Education handouts: are we wasting our time?. J Nurses Staff Dev. 1998;14(4):176-82. [pmid: 9807333].
Notes: Reject #1
Brownson K. Improving patient education for poor readers -- CE 195. Nursing Spectrum. 1999;9(5):12-4.
Notes: Reject #12
Brownson K. Literacy: a challenge for the health care supervisor. Health Care Supervisor. 1998;17(2):45-54.
Notes: Reject #1
Brownson K. Literacy: a problem that managers must handle. Hosp Mater Manage Q. 1998;20(1):37-47. [pmid: 10181321].
Notes: Reject #1
Brownson K, Dowd S B. Informed consent: does the patient really understand?. Images. 1997;16(1 ):8-11.
Notes: Reject #1
Brunt A R, Schafer E. Gem no 271. Helping consumers with low literacy interpret the new food label. J Nutr Educ. 1997;29(4):224-5.
Notes: Reject #3
Buchbinder R, Hall S, Grant G, Mylvaganam A, Patrick M R. Readability and content of supplementary written drug information for patients used by Australian rheumatologists. Med JAust. 2001;174(11):575-8. [pmid: 11453330].
Notes: Reject #3
Bucks R S, Scott M I, Pearsall T, Ashworth D L. The Short NART: utility in a memory disorders clinic. Br Journal Clin Psychol. 1996;35 (Pt 1):133-41.
Notes: Reject #3
Burggraf V. Guest editorial. Illiteracy: a silent disability. J Gerontolo Nurs. 2002;28(8):6.
Notes: Reject #1
Busselman K M, Holcomb C A. Reading skill and comprehension of the dietary guidelines by WIC participants. J Am Diet Assoc. 1994;94(6):622-5. [pmid: 8195549].
Notes: Accept KQ#3
Butkowsky I S, Willows D M. Cognitive-motivational characteristics of children varying in reading ability: evidence for learned helplessness in poor readers. J Educ Psychol. 1980;72(3):408-22. [pmid: 7391337].
Notes: Reject #3
Butkus D E, Dottes A L, Meydrech E F, Barber W H. Effect of poverty and other socioeconomic variables on renal allograft survival. Transplantation. 2001;72(2):261-6. [pmid: 11477350].
Notes: Reject #2
Buxton T. Effective ways to improve health education materials. J Health Educ 1999; 30(1):47-50, 61.
Notes: Reject #1
Byrne M E, Crowe T A, Hale S T, Meek E E, Epps D. Metalinguistic and pragmatic abilities of participants in adult literacy programs. J Commun Disord. 1996;29(1):37-49. [pmid: 8722528].
Notes: Reject #3
Calahan C A. Temperament of primary caregivers and development of literacy. Percept Mo Skills. 1995;81(3 Pt 1):828-30.
Notes: Reject #3
Campbell K. Evidence based patient information. Differing standards of literacy are better catered for with computers. BMJ. 1999;318(7181):462. [pmid: 10084835]. [pmcid: 28218].
Notes: Reject #1
Canales S, Ganz P A, Coscarelli C A. Translation and validation of a quality of life instrument for Hispanic American cancer patients: methodological considerations. Qual Life Res. 1995;4(1):3-11. [pmid: 7711688].
Notes: Reject #3
Cardinal B J, Seidler T L. Readability and comprehensibility of the 'exercise lite' brochure. Percept Mo Skills. 1995;80(2):399-402.
Notes: Reject #3
Carey M P, Schroder K E. Development and psychometric evaluation of the brief HIV Knowledge Questionnaire. AIDS Educ Prev. 2002;14(2):172-82. [pmid: 12000234].
Notes: Reject #2
Carlisle C. A conceptual model described how adults responded to a simulated literacy assessment [commentary on Brez SM, Taylor M. Assessing literacy for patient teaching: perspectives of adults with low literacy skills. J ADV NURS 1997;25(5):1040-7]. Evidence-Based Nursing. 1998;1(1):29.
Notes: Reject #3
Carman PS, Van Horn B, Grumm M. Rosalie's Neighborhood. A Health Literacy Series for Parents with Young Children. Washington, DC: Institute for Educational Leadership , 1997.
Notes: Reject #3
Cartwright M. Numeracy needs of the beginning registered nurse. Nurse Education Today. 1996;16(2):137-43. [pmid: 8716545].
Notes: Reject #2
Castro S L, Morais J. Ear differences in illiterates. Neuropsychologia. 1987;25(2):409-17. [pmid: 3601045].
Notes: Reject #3
Cella D, Hernandez L, Bonomi A E, et al. Spanish language translation and initial validation of the functional assessment of cancer therapy quality-of-life instrument. Medical Care. 1998;36(9):1407-18. [pmid: 9749663].
Notes: Reject #1
Chelf J H, Agre P, Axelrod A, et al. Cancer-related patient education: an overview of the last decade of evaluation and research. Oncol Nurs Forum. 2001;28(7):1139-47. [pmid: 11517847].
Notes: Reject #1
Cherry-Cruz T. Tell me a story! Enhancing literacy through the techniques of storytelling. ASHA 2001; 6(23):4-5, 18.
Notes: Reject #1
Chesson A L J, Murphy P W, Arnold C L, Davis T C. Presentation and reading level of sleep brochures: are they appropriate for sleep disorders patients?. Sleep. 1998;21(4):406-12. [pmid: 9646386].
Notes: Reject #3
Chiaravalloti N D, DeLuca J. Self-generation as a means of maximizing learning in multiple sclerosis: an application of the generation effect. Arch Phys Med Rehabil. 2002;83(8):1070-9. [pmid: 12161827].
Notes: Reject #3
Christensen R C, Grace G D. The prevalence of low literacy in an indigent psychiatric population. Psychiatr Serv. 1999;50(2):262-3. [pmid: 10030488].
Notes: Reject #3
Ciampa C. Tobacco education in low-literacy individuals. Indiana Med. 1996;89(2):188-92. [pmid: 8867421].
Notes: Reject #1
Coey L. Readability of printed educational materials used to inform potential and actual ostomates. J Clin Nurs. 1996;5(6):359-66. [pmid: 8981858].
Notes: Reject #3
Cole M R. The high cost of low health literacy. Nursing Spectrum. 2000;12A(9):30-1.
Notes: Reject #1
Cole M R. The high risk of low health literacy. Nursing Spectrum. 2000;13(10):16-7.
Notes: Reject #1
Cole M R. The high risk of low literacy. Nursing Spectrum. 2000;10(20):10-1.
Notes: Reject #1
Coles G S, Roth L, Pollack I W. Literacy skills of long-term hospitalized mental patients. Hosp Community Psychiatry. 1978;29(8):512-6. [pmid: 669598].
Notes: Reject #3
Conerly R. Communicating cancer control messages to low-literate and diverse audiences. J Psychoso Oncol. 2001;19(3/4):147-59.
Notes: Reject #1
Conklin JW, More PK, Muller EW. Reading ability and success in nursing. Nurs Educ 1996; 21(1):22, 31.
Notes: Reject # 3
Conlin K K, Schumann L. Literacy in the health care system: a study on open heart surgery patients. J Am Acad Nurse Pract. 2002;14(1):38-42. [pmid: 11845640].
Notes: Reject #3
Cooley M E, Moriarty H, Berger M S, Selm-Orr D, Coyle B, Short T. Patient literacy and the readability of written cancer educational materials. Oncol Nurs Forum. 1995;22(9):1345-51. [pmid: 8539175].
Notes: Reject #3
Cooper E. Literacy program helps heal the mind. Health Prog. 1989;70(9):74-5. [pmid: 10295928].
Notes: Reject #1
Corrarino J E, Freda M C, Barbara M. Development of a health education booklet for pregnant women with low literacy skills. J Perinat Educ. 1995;4(3):23-8.
Notes: Reject #3
Corrarino J E, Walsh P J, Anselmo D. A program to educate woman who test positive for the hepatitis B virus during the perinatal period. MCN Am J Matern Child Nurs. 1999;24(3):151-5. [pmid: 10326319].
Notes: Reject #2
Craig W N, Craig H B. Framework for literacy: 1993 and beyond. Am Ann Deaf. 1993;138(2):68-71. [pmid: 8498273].
Notes: Reject #1
Crawford J R, Parker D M, Allan K M, Jack A M, Morrison F M. The Short NART: cross-validation, relationship to IQ and some practical considerations. Br Jof Clin Psychol. 1991;30 (Pt 3):223-9.
Notes: Reject #3
Cronan T A, Cruz S G, Arriaga R I, Sarkin A J. The effects of a community-based literacy program on young children's language and conceptual development. Am J Community Psychol. 1996;24(2):251-72. [pmid: 8795261].
Notes: Reject #2
Currier G W, Sitzman R, Trenton A. Literacy in the psychiatric emergency service. J Nerv Ment Dis. 2001;189(1):56-8. [pmid: 11206666].
Notes: Reject #3
D'Alessandro D M, Kingsley P, Johnson-West J. The readability of pediatric patient education materials on the World Wide Web. Arch Pediatr Adolesc Med. 2001;155(7):807-12. [pmid: 11434848].
Notes: Reject #3
Dafoe G H. Learning materials on violence for youth with low literacy. Can J Public Health. 2001;92(3):164. [pmid: 11962104].
Notes: Reject #1
Dagostino L, Carifio J. Scientific literacy: a goal of educating people in and for the health professions. Work: a Journal of Prevention, Assessment & Rehabilitation. 1997;9(3):199-208.
Notes: Reject #1
Daniel K L, Goldman K D, Lachenmayr S, Erickson J D, Moore C. Interpretations of a teratogen warning symbol. Teratology. 2001;64(3):148-53. [pmid: 11514945].
Notes: Reject #3
Daniele V A. Quantitative literacy. Am Ann Deaf. 1993;138(2):76-81. [pmid: 8498275].
Notes: Reject #1
Davidhizar R E, Brownson K. Literacy, cultural diversity, and client education. Health Care Manag. 1999;18(1):39-47.
Notes: Reject #1
Davis T C, Crouch M A, Long S W, et al. Rapid assessment of literacy levels of adult primary care patients. Fam Med. 1991;23(6):433-5. [pmid: 1936717].
Notes: Reject #3
Davis T C, Dolan N C, Ferreira M R, et al. The role of inadequate health literacy skills in colorectal cancer screening. Cancer Investigation. 2001;19(2):193-200. [pmid: 11296623].
Notes: Reject #2
Davis T C, Jackson R H, George R B, et al. Reading ability in patients in substance misuse treatment centers. Int J Addictions. 1993;28(6):571-82.
Notes: Reject #3
Davis T C, Long S W, Jackson R H, et al. Rapid estimate of adult literacy in medicine: a shortened screening instrument. Fam Med. 1993;25(6):391-5. [pmid: 8349060].
Notes: Reject #3
Davis T C, Mayeaux E J, Fredrickson D, Bocchini J A J, Jackson R H, Murphy P W. Reading ability of parents compared with reading level of pediatric patient education materials. Pediatrics. 1994;93(3):460-8. [pmid: 8115206].
Notes: Reject #3
Davis TC, Meldrum H, Tippy PKP, Weiss BD, Williams MV. Health literacy, part 1. How poor literacy leads to poor health care. Patient Care 1996; 30(16):94-8, 100, 103 passim.
Notes: Reject #1
Davis T C, Michielutte R, Askov E N, Williams M V, Weiss B D. Practical assessment of adult literacy in health care. Health Educ Behav. 1998;25(5):613-24. [pmid: 9768381].
Notes: Reject #1
Davis T C, Williams M V, Marin E, Parker R M, Glass J. Health literacy and cancer communication. CA Cancer J Clin. 2002;52(3):134-49. [pmid: 12018928].
Notes: Reject #1
De Geest S, von Renteln-Kruse W, Steeman E, Degraeve S, Abraham I L. Compliance issues with the geriatric population: complexity with aging. Nursing Clinics of North America. 1998;33(3):467-80. [pmid: 9719692].
Notes: Reject #1
DeGraffenreid J. Techniques for treating patients with low literacy skills. J Emerg Med Serv JEMS 2000; 25(11):66, 68.
Notes: Reject #1
Delaney-Black V, Covington C, Ondersma S J, et al. Violence exposure, trauma, and IQ and/or reading deficits among urban children. Arch Pediatr Adolesc Med. 2002;156(3):280-5. [pmid: 11876674].
Notes: Reject #3
Deloche G, Souza L, Braga L W, Dellatolas G. A calculation and number processing battery for clinical application in illiterates and semi-literates. Cortex. 1999;35(4):503-21. [pmid: 10574077].
Notes: Reject #3
Demajumder C. In practice. Learning health through adult literacy. Health Visit. 1996;69(5):191.
Notes: Reject #3
Derose K P, Baker D W. Limited English proficiency and Latinos' use of physician services. Medical Care Research & Review. 2000;57(1):76-91. [pmid: 10705703].
Notes: Reject
Dievler A. Literacy, education and health development: annotated bibliography. Health Policy Educ. 1982;3(1):113-20. [pmid: 10298650].
Notes: Reject #1
Dixon B. Standards of literacy. Br J Hosp Med. 1984;31(4):299. [pmid: 6722390].
Notes: Reject #1
Dixon E, Park R. Do patients understand written health information?. Nurs Outlook. 1990;38(6):278-81. [pmid: 2235538].
Notes: Reject #3
Doak C C, Doak L G, Friedell G H, Meade C D. Improving comprehension for cancer patients with low literacy skills: strategies for clinicians. CA Cancer J Clin. 1998;48(3):151-62. [pmid: 9594918].
Notes: Reject #1
Doak CC, Doak LG, Root JH. Teaching patients with low literacy skills. Philadelphia, PA: Lippincott-Raven Publ, 1996.
Notes: Reject #1
Doak L G, Doak C C. Lowering the silent barriers to compliance for patients with low literacy skills. Promot Health. 1987;8(4):6-8. [pmid: 10282858].
Notes: Reject #1
Doak L G, Doak C C, Meade C D. Strategies to improve cancer education materials. Oncol Nurs Forum. 1996;23(8):1305-12. [pmid: 8883075].
Notes: Reject #1
Dollahite J, Thompson C, McNew R. Readability of printed sources of diet and health information. Patient Educ Couns. 1996;27(2):123-34. [pmid: 8788342].
Notes: Reject #3
Donlon T F, McPeek W M, Chatham L R. Development of the brief test of literacy. Vital Health Stat 1. 1968;2(27):1-29. [pmid: 5301451].
Notes: Reject #3
Dooley ARJr. A collaborative model for creating patient education resources. Am J Health Behav 1996; 20(2):15-9, 61-2.
Notes: Reject #3
Dreger V, Tremback T. Home study program: optimize patient health by treating literacy and language barriers. AORN J 2002; 75(2):278, 280-3, 285 passim.
Notes: Reject #1
Dreger V, Tremback T. Optimize patient health by treating literacy and language barriers. AORN J 2002; 75(2):280-5, 287, 289-93; quiz 297-300, 303-4.
Notes: Reject #1
Dudley TE, Falvo DR, Podell RN, Renner J. Health literacy, part 2. The informed patient poses a different challenge. Patient Care 1996; 30(16):128-32, 134, 136-8.
Notes: Reject #1
Duffy M M, Snyder K. Can ED patients read your patient education materials?. J Emerg Nurs. 1999;25(4):294-7. [pmid: 10424958].
Notes: Reject #1
Duncan L G, Seymour P H. Socio-economic differences in foundation-level literacy. Br J Psychol. 2000;91 ( Pt 2):145-66. [pmid: 10832511].
Notes: Reject #3
Dykman R A, Ackerman P T. Attention deficit disorder and specific reading disability: separate but often overlapping disorders. J Learn Disabil. 1991;24(2):96-103. [pmid: 2010680].
Notes: Reject #3
Eberstadt N. Did Fidel fudge the figures? Literacy and health: the Cuban model. Caribbean Review 1986; 15(2):4-7, 37-8.
Notes: Reject #1
Ebrahimzadeh H, Davalos R, Lee P P. Literacy levels of ophthalmic patient education materials. Surv Ophthalmol. 1997;42(2):152-6. [pmid: 9381368].
Notes: Reject #3
Edlin M. Literacy and good health. Healthplan. 1998;39(3):52-8. [pmid: 10181752].
Notes: Reject #1
Edmondson K S, Spell J J. Written materials and the client with low literacy skills. Infants & Young Children. 1991;4(1):62-7.
Notes: Reject #1
Elder J P, Candelaria J, Woodruff S I, et al. Initial results of 'Language for Health': cardiovascular disease nutrition education for English-as-a-second-language students. Health Educ Res. 1998;13(4):567-75. [pmid: 10345907].
Notes: Reject #2
Elkind J. The incidence of disabilities in the United States. Hum Factors. 1990;32(4):397-405. [pmid: 2150063].
Notes: Reject #3
Elkind PD, Pitts K, Ybarra SL. Theater as a mechanism for increasing farm health and safety knowledge. Am J Industr Med 2002; Suppl 2:28-35.
Notes: Reject #2
Elson PR. Literacy and health. CMAJ 1993; 149(10):1379, 1382.
Notes: Reject #1
Eng T R, Maxfield A, Patrick K, Deering M J, Ratzan S C, Gustafson D H. Access to health information and support: a public highway or a private road?. JAMA. 1998;280(15):1371-5. [pmid: 9794322].
Notes: Reject #1
Ericksen C. School Nursing and Health Services: A Resource and Planning Guide. Bulletin No. 8328. Milwaukee, WI: Wisconsin Department of Public Instruction, 1998.
Notes: Reject #1
Erickson KA. All children are ready to learn: an emergent versus readiness perspective in early literacy assessment. Semin Speech Lang 2000; 21(3):193-202; quiz 202-3.
Notes: Reject #1
Estey A, Musseau A, Keehn L. Comprehension levels of patients reading health information. Patient Educ Couns. 1991;18(2):165-9.
Notes: Reject #3
Estey A, Musseau A, Keehn L. Patient's understanding of health information: a multihospital comparison. Patient Educ Couns. 1994;24(1):73-8. [pmid: 7862597].
Notes: Reject #3
Estrada C, Barnes V, Collins C, Byrd J C. Health literacy and numeracy. JAMA. 1999;282(6):527. [pmid: 10450711].
Notes: Reject #3
Estrada C A, Hryniewicz M M, Higgs V B, Collins C, Byrd J C. Anticoagulant patient information material is written at high readability levels. Stroke. 2000;31(12):2966-70. [pmid: 11108757].
Notes: Reject #2, #3
Eubanks P. Literacy crisis threatens hospital workforce. Hospitals 1990; 64(2):50, 52, 54 .
Notes: Reject #1
Evanoski C A. Health education for patients with ventricular tachycardia: assessment of readability. J Cardiovasc Nurs. 1990;4(2):1-6. [pmid: 2366063].
Notes: Reject #1
Evans J H, Collier J, Crook I, et al. Using multimedia for patient information--a program about nocturnal enuresis. Br J Urol. 1998;81 Suppl 3:120-2. [pmid: 9634036].
Notes: Reject #2
Evans M A, Shaw D, Bell M. Home literacy activities and their influence on early literacy skills. Can J Exp Psychol. 2000;54(2):65-75. [pmid: 10881391].
Notes: Reject #3
Evers D B. Teaching mothers about childhood immunizations. MCN Am J Matern Child Nurs. 2001;26(5):253-6. [pmid: 11552575].
Notes: Reject #3
Fain J A. Assessing nutrition education in clients with weak literacy skills. Nurs Pract Forum. 1994;5(1):52-5.
Notes: Reject #1
Fain JA. When your patient can't read. Am J Nurs 1994; 94(5):16B, 16D.
Notes: Reject #1
Farmer SM. Nurses must adapt communication skills to all literacy levels... 'Low literacy skills needn't hinder care' (April). RN 2002; 65(7):14.
Notes: Reject #1
Fetter M S. Recognizing and improving health literacy. Nursing. 1999;8(4):226-7.
Notes: Reject #1
Finan N. Visual literacy in images used for medical education and health promotion. J Audiov Media Med. 2002;25(1):16-23. [pmid: 12025486].
Notes: Reject #3
Fisher E. Low literacy levels in adults: implications for patient education. J Contin Educ Nurs. 1999;30(2):56-61. [pmid: 10382455].
Notes: Reject #1
Fleener F T, Scholl J F. Academic characteristics of self-identified illiterates. Percept Mot Skills. 1992;74(3 Pt 1):739-44. [pmid: 1608711].
Notes: Reject #3
Fleming A. The research oracle... patient literacy levels. Jarna. 1998;1(1):6-7.
Notes: Reject #1
Foley M E. Pediatric education materials: web-based patient information challenges most adult readers. Am J Nurs. 2001;101(10):37. [pmid: 12113009].
Notes: Reject #3
Foltz A, Sullivan J. Get real: clinical testing of patients' reading abilities. Cancer Nurs. 1998;21(3):162-6. [pmid: 9615506].
Notes: Reject #1
Foltz A, Sullivan J. Reading level, learning presentation preference, and desire for information among cancer patients. J Cancer Educ. 1996;11(1):32-8. [pmid: 8777153].
Notes: Reject #3
Foltz A T, Sullivan J M. Limited literacy revisited implications for patient education. Cancer Pract. 1999;7(3):145-50. [pmid: 10352077].
Notes: Reject #3
Forbis S G, Aligne C A. Poor readability of written asthma management plans found in national guidelines. Pediatrics. 2002;109(4):e52. [pmid: 11927725].
Notes: Reject #3
Freebody P, Freiberg J. Adult Literacy and Health. Reading and Writing as Keeping-Well Practices. Research into Practice Series No. 5. Adult Basic Education Resource and Information Service, National Languages and Literacy Institute of Australia: Melbourne, Victoria, Australia, 1997.
Notes: Reject #1
Freebody P, Freiburg J. Health Literacy and Social Practice: Response to Nutbeam. Literacy & Numeracy Studies. 1999;9(2):57-66.
Notes: Reject #1
Freer K J, Turner R. Participatory workplace literacy training in a hospital setting. J Healthc Educ Train. 1995;9(1):1-6. [pmid: 10142657].
Notes: Reject #3
Freer KJ. How the rural elderly view literacy in their lives. Educ Gerontol 1994; 20(2 (1994)):157-69.
Notes: Reject #3
Freimuth V S, Mettger W. Is there a hard-to-reach audience?. Public Health Rep. 1990;105(3):232-8. [pmid: 2113680]. [pmcid: 1580016].
Notes: Reject #3
French K S, Larrabee J H. Relationships among educational material readability, client literacy, perceived beneficence, and perceived quality. J Nurs Care Qual. 1999;13(6):68-82. [pmid: 10476626].
Notes: Reject #3
Gallagher A, Frith U, Snowling M J. Precursors of literacy delay among children at genetic risk of dyslexia. J Child Psychol Psychiatry. 2000;41(2):203-13. [pmid: 10750546].
Notes: Reject #3
Garcia Mangas J A, Viniegra Velazquez L. [Reading ability of family physicians]. [Spanish]. Rev Invest Clin. 1996;48(5):373-6. [pmid: 9005515].
Notes: Reject #8
Garduno-Espinosa J, Martinez-Garcia M C, Fajardo-Gutierrez A, et al. [Frequency and risk factors associated with metronidazole therapeutic noncompliance]. [Spanish]. Rev Invest Clin. 1992;44(2):235-40. [pmid: 1439312].
Notes: Reject #8, #7
Garello J A, Joss D M. Global health issue. World literacy: obstacles and opportunities. Work: a Journal of Prevention, Assessment & Rehabilitation. 1997;9(2):177-86.
Notes: Reject #1
Gausman Benson J, Forman W B. Comprehension of written health care information in an affluent geriatric retirement community: use of the Test of Functional Health Literacy. Gerontology. 2002;48(2):93-7. [pmid: 11867931].
Notes: Reject #3
Geiger BF, Myers O, Atchison JH, LaFollette JL. Developing Health-Literate Citizens through the Alabama Course of Study in Health Education: Moving from Facts to Actions. Columbus, OH: ERIC, 2000.
Notes: Reject #1
Gillette Y. Pictures to print: a software scaffold to written literacy. J Head Trauma Rehabil. 2001;16(5):484-97. [pmid: 11574043].
Notes: Reject #1
Glanville I K. Moving towards health oriented patient education (HOPE). Holist Nurs Pract. 2000;14(2):57-66. [pmid: 12119971].
Notes: Reject #1
Glazer H R, Kirk L M, Bosler F E. Patient education pamphlets about prevention, detection, and treatment of breast cancer for low literacy women. Patient Educ Couns. 1996;27(2):185-9. [pmid: 8788348].
Notes: Reject #3
Gohdes D. Diet therapy for minority patients with diabetes. Diabetes Care. 1988;11(2):189-91. [pmid: 3289867].
Notes: Reject #1
Gollop C J. Health information-seeking behavior and older African American women. Bull Med Libr Assoc. 1997;85(2):141-6. [pmcid: 226241]. [pmid: 9160150].
Notes: Reject #3
Golova N, Alario A J, Vivier P M, Rodriguez M, High P C. Literacy promotion for Hispanic families in a primary care setting: a randomized, controlled trial. Pediatrics. 1999;103(5 Pt 1):993-7. [pmid: 10224178].
Notes: Reject #3
Gordon D. MDs' failure to use plain language can lead to the courtroom. CMAJ. 1996;155(8):1152-4. [pmid: 8873641]. [pmcid: 1335375].
Notes: Reject #1
Gornemann I, Zunzunegui M V, Martinez C, Onis M D. Screening for impaired cognitive function among the elderly in Spain: reducing the number of items in the Short Portable Mental Status Questionnaire. Psychiatry Res. 1999;89(2):133-45. [pmid: 10646832].
Notes: Reject #3
Gottesman R L, Bennett R E, Nathan R G, Kelly M S. Inner-city adults with severe reading difficulties: a closer look. J Learn Disabil. 1996;29(6):589-97. [pmid: 8942303].
Notes: Reject #3
Gottesman R L, Kelly M S. Inadequate functional health literacy. J Am Med Assoc. 1996;275(11):840.
Notes: Reject #1
Grace G D, Christensen R C. Literacy and mental health care. Psychiatr Serv. 1998;49(1):7. [pmid: 9444674].
Notes: Reject #1
Greenberg D. A Critical Look at Health Literacy. Adult Basic Education. 2001;11(2):67-79.
Notes: Reject #1
Griffin P T, Kogut D. Validity of orally administered Beck and Zung Depression Scales in a state hospital setting. J Clin Psychol. 1988;44(5):756-9. [pmid: 3192714].
Notes: Reject #3
Grosse R N, Auffrey C. Literacy and health status in developing countries. Annu Rev Public Health. 1989;10:281-97. [pmid: 2655635].
Notes: Reject #1
Grosse R N, Perry B H. Correlates of life expectancy in less developed countries. Health Policy Educ. 1982;2(3-4):275-304. [pmid: 10256650].
Notes: Reject #7
Guidry J J, Fagan P. The readability levels of cancer-prevention materials targeting African Americans. J Cancer Educ. 1997;12(2):108-13. [pmid: 9229274].
Notes: Reject #3
Guidry J J, Fagan P, Walker V. Cultural sensitivity and readability of breast and prostate printed cancer education materials targeting African Americans. J Natl Med Assoc. 1998;90(3):165-9. [pmid: 9549980].
Notes: Reject #3
Gulis G. Life expectancy as an indicator of environmental health. Eur J Epidemiol. 2000;16 (2):161-5. [pmid: 10845266].
Notes: Reject #11
Gwatkin D R. Literacy, education and health development: policy implications. Health Policy Educ. 1982;3(1):109-12. [pmid: 10256658].
Notes: Reject #1
Habel M. Continuing education. Get your message across to low-literacy patients. Healthweek. 2000;5(12):20-2.
Notes: Reject #1
Habel M. Continuing education. Get your message across to low-literacy patients. Nurseweek. 2000;13(12):14-6.
Notes: Reject #1
Hall J M. Women survivors of childhood abuse: the impact of traumatic stress on education and work. Issues Ment Health Nurs. 2000;21(5):443-71. [pmid: 11261072].
Notes: Reject #2
Hanson-Divers E C. Developing a medical achievement reading test to evaluate patient literacy skills: a preliminary study. J Health Care Poor Underserved. 1997;8(1):56-69. [pmid: 9019026].
Notes: Reject #3
Hardy L K, Segatore M, Edge D S. Illiteracy: implications for nursing education. Nurse Educat Today. 1993;13(1):24-9.
Notes: Reject #1
Harlander C, Ruccione K. Fotoplatica: an innovative teaching method for families with low literacy and high stress. J Pediatr Oncol Nurs. 1993;10(3):112-4. [pmid: 7691087].
Notes: Reject #1
Harmon KS. Inbox. Wasted words: why spend time and money giving instruction that can't be understood? Hosp Health Networks 2001; 75(11):30, 32.
Notes: Reject #1
Harrison L L. Florida outreach for maternity patients with low literacy skills. MCN Am J Matern Child Nurs. 1990;15(6):381. [pmid: 2124323].
Notes: Reject #3
Hart R R, Norman W B, Sergent M W. The auditory form of the Ohio Literacy Test: preliminary correlational analysis with Wechsler Adult Intelligence Scale. Psychol Rep. 1979;45(2):629-30. [pmid: 538185].
Notes: Reject #3
Hartley L A. Congruence between teaching and learning self-care: a pilot study. Nurs Sci Q. 1988;1(4):161-7. [pmid: 3205481].
Notes: Reject #2
Hartman T J, McCarthy P R, Park R J, Schuster E, Kushi L H. Focus group responses of potential participants in a nutrition education program for individuals with limited literacy skills. J Am Diet Assoc. 1994;94(7):744-8. [pmid: 8021415].
Notes: Reject #3
Hayes K S. Literacy for health information of adult patients and caregivers in a rural emergency department. Clin Excell Nurs Practit. 2000;4(1):35-40.
Notes: Reject #3
Hayes R P, Bernard A M, Slocum W, et al. Diabetes in urban African Americans: assessment of diabetes-specific locus of control in patients with type 2 diabetes. Diabetes Educ. 2000;26(1):121-8. [pmid: 10776104].
Notes: Reject #2
Hearth-Holmes M, Murphy P W, Davis T C, et al. Literacy in patients with a chronic disease: systemic lupus erythematosus and the reading level of patient education materials. J Rheumatol. 1997;24(12):2335-9. [pmid: 9415638].
Notes: Reject #3
Hendricson W D, Russell I J, Prihoda T J, Jacobson J M, Rogan A, Bishop G D. An approach to developing a valid Spanish language translation of a health-status questionnaire. Medical Care. 1989;27(10):959-66. [pmid: 2796414].
Notes: Reject #3
Henry D. Healing words: working through literacy barriers. Healthweek. 1998;3(20):14.
Notes: Reject #1
Hertz E, Hebert J R, Landon J. Social and environmental factors and life expectancy, infant mortality, and maternal mortality rates: results of a cross-national comparison. Soc Sci Med. 1994;39(1):105-14. [pmid: 8066481].
Notes: Reject #11
Hess V T. Literacy and learning for hospital employees. J Nurs Staff Dev. 1998;14(3):143-6.
Notes: Reject #3
High P, Hopmann M, LaGasse L, Linn H. Evaluation of a clinic-based program to promote book sharing and bedtime routines among low-income urban families with young children. Archo Pediatr Adolesc Med. 1998;152(5):459-65.
Notes: Reject #2
High P, Hopmann M, LaGasse L, et al. Child centered literacy orientation: a form of social capital?. Pediatrics. 1999;103(4):e55. [pmid: 10103347].
Notes: Reject #3
High P C, LaGasse L, Becker S, Ahlgren I, Gardner A. Literacy promotion in primary care pediatrics: can we make a difference?. Pediatrics. 2000;105( 4 Pt 2):927-34. [pmid: 10742349].
Notes: Reject #1
Hildebrandt E, Robertson B. Self-care of older black adults in a South African community. Perspect Commun. 1995;16(3):136-43.
Notes: Reject #7
Hill K S. Commentary on Materials and strategies that work in low literacy health communication [original article by Plimpton S et al appears in PUBLIC HEALTH REP 1994;109(1):86-92]. Aone's Leadership Prospectives. 1995;3(2):16.
Notes: Reject #3
Hobbie C. Patient education review. Maximizing healthy communication: readability of parent educational materials. J Pediatr Health Care. 1995;9(2):92-3. [pmid: 7769548].
Notes: Reject #1
Hochhauser M. Can consumers understand managed care report cards?. Manag Care Interface. 1998;11(11):91-5. [pmid: 10187422].
Notes: Reject #3
Hochhauser M. Medical jargon and legalese: constant threats to patients' 'Bill of Rights' and other communications. Patient Care Manag. 2001;16(8):4-6.
Notes: Reject #1
Holtsberg P A, Poon L W, Noble C A, Martin P. Mini-Mental State Exam status of community-dwelling cognitively intact centenarians. Int Psychogeriatr. 1995;7(3):417-27. [pmid: 8821349].
Notes: Reject #2
Hooker E Z. Research corner. Can your research subjects read your study's informed consent form?. Sci Nurs. 1995;12(2):57-8. [pmid: 7624753].
Notes: Reject #1
Horn L, Cohen C I, Teresi J. The EASI: a self-administered screening test for cognitive impairment in the elderly. J Am Geriatr Soc. 1989;37(9):848-55. [pmid: 2760377].
Notes: Reject #2
Hosey G M, Freeman W L, Stracqualursi F, Gohdes D. Designing and evaluating diabetes education material for American Indians. Diabetes Educ. 1990;16(5):407-14. [pmid: 2390941].
Notes: Reject #3
Houts P S, Witmer J T, Egeth H E, Loscalzo M J, Zabora J R. Using pictographs to enhance recall of spoken medical instructions II. Patient Educ Couns. 2001;43(3):231-42. [pmid: 11384821].
Notes: Reject #3
Hussey L C. Overcoming the clinical barriers of low literacy and medication noncompliance among the elderly. J Gerontolog Nurs. 1991;17(3):27-9.
Notes: Reject #10
Hussey L C, Gilliland K. Compliance, low literacy, and locus of control. Nurs Clin North Am. 1989;24(3):605-11. [pmid: 2771784].
Notes: Reject #1
Hutton B M. Comment. Numeracy must become a priority for nurses. Br J Nurs. 2000;9(14):894. [pmid: 11261023].
Notes: Reject #1
Hutton B M. Do school qualifications predict competence in nursing calculations?. Nurs Educ Today. 1998;18(1):25-31.
Notes: Reject #2
Hutton B M. Numeracy must become a priority for nurses. Br J Nurs. 2000;9(14):894. [pmid: 11261023].
Notes: Reject #1
Hutton M. Numeracy skills for intravenous calculations. Nurs Stand 1998; 12(43):49-52; quiz 55-6.
Notes: Reject #1
Hutton M. RCN continuing education. Numeracy skills for intravenous calculations. Nursing Stand 1998; 12(43):49-52, 55-6.
Notes: Reject #1
Iacono T, Balandin S, Cupples L. Focus group discussions of literacy assessment and World Wide Web-based reading intervention. AAC: Augmentative & Alternative Communication. 2001;17(1):27-36.
Notes: Reject #3
Ireland M. Lost in translation... 'promoting health literacy' (February). AJN, Am J Nurs 2001; 101(6):14.
Notes: Reject #1
Jackson R H, Davis T C, Bairnsfather L E, George R B, Crouch M A, Gault H. Patient reading ability: an overlooked problem in health care. South Med J. 1991;84(10):1172-5. [pmid: 1925713].
Notes: Reject #3
Jackson R H, Davis T C, Murphy P, Bairnsfather L E, George R B. Reading deficiencies in older patients. Am J Medl Sci. 1994;308(2):79-82.
Notes: Reject #3
Jaycox S. Smoking literature and literacy levels. Am J Public Health. 1989;79(8):1058. [pmid: 2751031].
Notes: Reject #1
Jenks S. Researchers link low literacy to high health care costs. J Natl Cancer Inst. 1992;84(14):1068-9. [pmid: 1619678].
Notes: Reject #1
Jensen B J, Witcher D B, Upton L R. Readability assessment of questionnaires frequently used in sex and marital therapy. J Sex Marital Ther. 1987;13(2):137-41. [pmid: 3612824].
Notes: Reject #3
Jesudason V, Roy P, Dighe A, Chatterjee B B. Outcomes of literacy: how to measure them. Health Policy Educ. 1982;3(1):51-70. [pmid: 10256660].
Notes: Reject #1
Joel L A. Teach a woman, educate the world. Am J Nurs. 1994;94(7):7. [pmid: 7985740].
Notes: Reject #1
Johnson M E, Fisher D G. Evaluating three reading tests for use with alcohol and other drug-abusing populations. Alcohol Clin Exp Res. 1996;20(6):1125-9. [pmid: 8892538].
Notes: Reject #3
Johnson M E, Fisher D G, Davis D C, Cagle H H. Reading abilities of drug users in Anchorage, Alaska. J Drug Edu. 1995;25(1):73-80.
Notes: Reject #3
Johnson M E, Fisher D G, Davis D C, et al. Assessing reading level of drug users for HIV and AIDS prevention purposes. AIDS Educ Prev. 1996;8(4):323-34. [pmid: 8874649].
Notes: Reject #3
Johnson R K, Soultanakis R P, Matthews D E. Literacy and body fatness are associated with underreporting of energy intake in US low-income women using the multiple-pass 24-hour recall: a doubly labeled water study. J Am Dietetic Assoc. 1998;98(10):1136-40.
Notes: Reject #1
Jones V F, Franco S M, Metcalf S C, Popp R, Staggs S, Thomas A E. The value of book distribution in a clinic-based literacy intervention program. Clin Pediatr. 2000;39(9):535-41.
Notes: Reject #3
Joss D M. Global health issues literacy: has the time come?. Work: a Journal of Prevention, Assessment & Rehabilitation. 1998;10(2):193-7.
Notes: Reject #1
Kalichman S C, Benotsch E G, Weinhardt L, Austin J, Luke W, Cherry C. Health-related Internet use, coping, social support, and health indicators in people living with HIV/AIDS: preliminary results from a community survey. Health Psychol. 2003;22(1):111-6. [pmid: 12558209].
Notes: Reject #2
Kane J. Literacy of mental patients for whom community care is planned. Lancet. 1983;2(8342):173-4. [pmid: 6135022].
Notes: Reject #3
Kanonowicz L. National project to publicize link between literacy, health. CMAJ. 1993;148(7):1201-2. [pmid: 8457963]. [pmcid: 1490881].
Notes: Reject #1
Kaul L, Nidiry J J. Management of obesity in low-income African Americans. J Natl Med Assoc. 1999;91(3):139-43. [pmid: 10203915].
Notes: Reject #2
Kefalides P T. Illiteracy: the silent barrier to health care. Ann Intern Med. 1999;130(4 part 1):333-6. [pmid: 10068400].
Notes: Reject #1
Kellerman R, Weiss BD. Health literacy and the JAMA Patient Page. JAm Med Assoc 1999; 282(6):525-6; discussion 526-7.
Notes: Reject #2
Kelly C K. Helping low-literacy patients: what they don't know can hurt them. Prof Med Assist. 1999;32(1):8-13.
Notes: Reject #1
Kelly L J. The readability of hearing aid brochures. J Acad Rehabilitat Audiol. 1996;29:41-8.
Notes: Reject #3
Kerka S. Health and Adult Literacy. Practice Application Brief No. 7. Columbus, OH: ERIC Clearinghouse on Adult, Career, and Vocational Education, 2000.
Notes: Reject #1
Kickbusch I. Health literacy: a search for new categories. Health Promot Int. 2002;17(1):1-2. [pmid: 11847132].
Notes: Reject #1
Kickbusch I, Ratzan S C. Health literacy: making a difference in the USA. J Health Commun. 2001;6(2):87-8. [pmid: 11405081].
Notes: Reject #1
Kickbusch I S. Health literacy: addressing the health and education divide. Health Promot Int. 2001;16(3):289-97. [pmid: 11509466].
Notes: Reject #1
Kicklighter J R, Stein M A. Factors influencing diabetic clients' ability to read and comprehend printed diabetic diet material. Diabetes Educ. 1993;19(1):40-6. [pmid: 8458298].
Notes: Reject #3
Kilker K. Considering health literacy. Issue Brief Cent Med Educ. 2000;1(6):1-8.
Notes: Reject #1
Kim SP, Bennett CL, Chan C et al. QOL and outcomes research in prostate cancer patients with low socioeconomic status. Oncology 1999; 13(6):823-32; discussion 835-8.
Notes: Reject #1
Kimble L P, Dunbar S B, McGuire D B, De A, Fazio S, Strickland O L. Cardiac instrument development in a low-literacy population: the revised Chest Discomfort Diary. Heart Lung. 2001;30(4):312-20. [pmid: 11449218].
Notes: Reject #3
Kinzie M B, Schorling J B, Siegel M. Prenatal alcohol education for low-income women with interactive multimedia. Patient Educ Couns. 1993;21(1-2):51-60. [pmid: 8337205].
Notes: Reject #2
Klimczak N C, Bradford K A, Burright R G, Donovick P J. K-FAST and WRAT-3: are they really different?. Clin Neuropsychol. 2000;14(1):135-8. [pmid: 10855066].
Notes: Reject #3
Knauft MM. Workplace literacy: meeting change head-on. Nurs Staff Dev Insid 1993; 2(1):4, 8.
Notes: Reject #1
Knowlton M, Jansen K. Teaching a client with low literacy skills. Imprint. 1995;42(5):67-9. [pmid: 7498958].
Notes: Reject #10
Kohlmeier L, Mendez M, McDuffie J, Miller M. Computer-assisted self-interviewing: a multimedia approach to dietary assessment. Am J ClinNutr. 1997;65(4 Suppl):1275S-81S.
Notes: Reject #3
Kolasa KM, Peery A, Harris NG, Shovelin K. Food Literacy Partners Program: a strategy to increase community food literacy. Top Clin Nutr 2001; 16(4):1-10, 77-9.
Notes: Reject #3
Kruse A Y, Kjaergard L L, Krogsgaard K, et al. A randomized trial assessing the impact of written information on outpatients' knowledge about and attitude toward randomized clinical trials. The INFO trial group. Control Clin Trials. 2000;21(3):223-40. [pmid: 10822120].
Notes: Reject #2
Kubba H. Reading skills of otolaryngology outpatients: implications for information provision. J Laryngol Otol. 2000;114(9):694-6. [pmid: 11091832].
Notes: Reject #3
Kureshi J, Rocke A D, Tariq A Q. Perioperative knowledge and anxiety score of patients undergoing surgery. Middle East J Anesthesiol. 1995;13(3):325-33. [pmid: 8849988].
Notes: Reject #7
Landis M. Language and literacy, digitally speaking. Top Lang Disord 2002; 22(4):55-6, 91-4.
Notes: Reject #1
Lara M, Sherbourne C, Duan N, Morales L, Gergen P, Brook R H. An English and Spanish Pediatric Asthma Symptom Scale. Med Care. 2000;38(3):342-50. [pmid: 10718359].
Notes: Reject #2
Larson I, Schumacher H R. Comparison of literacy level of patients in a VA arthritis center with the reading level required by educational materials. Arthritis Care Res. 1992;5(1):13-6. [pmid: 1581366].
Notes: Reject #3
Lasater L, Mehler PS. The illiterate patient: screening and management. Hosp Pract 1998; 33(4 ):163-5, 169-70.
Notes: Reject #1
Lasch K E, Wilkes G, Montuori L M, Chew P, Leonard C, Hilton S. Using focus group methods to develop multicultural cancer pain education materials. Pain Manag Nurs. 2000;1(4):129-38. [pmid: 11709866].
Notes: Reject #2
Ledbetter C, Hall S, Swanson J M, Forrest K. Readability of commercial versus generic health instructions for condoms. Health Care Women Int. 1990;11(3):295-304. [pmid: 2391286].
Notes: Reject #3
Lee K S, Park S C, Khoshnood B, Hsieh H L, Mittendorf R. Human development index as a predictor of infant and maternal mortality rates. J Pediatr. 1997;131( 3):430-3. [pmid: 9329421].
Notes: Reject #2
Lee P P. Why literacy matters. Links between reading ability and health. Arch Ophthalmol. 1999;117(1):100-3. [pmid: 9930167].
Notes: Reject #1
LeFevre J A. Research on the development of academic skills: introduction to the special issue on early literacy and early numeracy. Can J Exp Psychol. 2000;54(2):57-64. [pmid: 10881390].
Notes: Reject #1
Leichter S B, Nieman J A, Moore R W, Collins P, Rhodes A. Readability of self-care instructional pamphlets for diabetic patients. Diabetes Care. 1981;4(6):627-30. [pmid: 7347670].
Notes: Reject #3
Lenert L, Kaplan RM. Validity and interpretation of preference-based measures of health-related quality of life. Med Care 2000; 38(9 Suppl):II138-50.
Notes: Reject #2
Levin-Zamir D, Peterburg Y. Health literacy in health systems: perspectives on patient self-management in Israel. Health Promot Int. 2001;16(1):87-94. [pmid: 11257858].
Notes: Reject #1
Levine DA. Health Literacy: Implications for Seniors. Symposium Proceedings . Research Triangle Park, NC: Research Triangle Inst., 2001.
Notes: Reject #1
LeVine R A, Dexter E, Velasco P, et al. Maternal literacy and health care in three countries: a preliminary report. Health Transit Rev. 1994;4(2):186-91. [pmid: 10150517].
Notes: Reject #7
Ley P, Florio T. The use of readability formulas in health care. Psychol Health Med. 1996;1(1):7-28.
Notes: Reject #1
Leyva Gonzalez F A, Viniegra Velazquez L. [Critical reading for medical residents in main specialties]. [Spanish]. Rev Invest Clin. 1999;51(1):31-8. [pmid: 10344165].
Notes: Reject #8
Licciardone J C, Smith-Barbaro P, Coleridge S T. Use of the internet as a resource for consumer health information: results of the second osteopathic survey of health care in America (OSTEOSURV-II). J Med Internet Res. 2001;3(4):E31. [pmid: 11772546].
Notes: Reject #2
Lindau S T, Tomori C, McCarville M A, Bennett C L. Improving rates of cervical cancer screening and Pap smear follow-up for low-income women with limited health literacy. Cancer Invest. 2001;19(3):316-23. [pmid: 11338888].
Notes: Reject #1
Lindesay J, Jagger C, Hibbett M J, Peet S M, Moledina F. Knowledge, uptake and availability of health and social services among Asian Gujarati and white elderly persons. Ethn Health. 1997;2(1-2):59-69. [pmid: 9395589].
Notes: Reject #7
Lipkus IM, Hollands JG. The visual communication of risk. J Natl Cancer Inst Monogr 1999; (25):149-63.
Notes: Reject #1
Lipkus I M, Samsa G, Rimer B K. General performance on a numeracy scale among highly educated samples. Medical Decis Making. 2001;21(1):37-44.
Notes: Reject #3
List M A, Lacey L, Hopkins E, Burton D. The involvement of low literate elderly women in the development and distribution of cancer screening materials. Fam Community Health. 1994;17(1):42-55.
Notes: Reject #3
Littlewood J. Mapping diarrhoeal disease in Nepal. J Child Health Care. 1999;3(4):17-20. [pmid: 10451336].
Notes: Reject #7
Logan P D, Schwab R A, Salomone JA3, Watson W A. Patient understanding of emergency department discharge instructions. South Med J. 1996;89(8):770-4. [pmid: 8701374].
Notes: Reject # 2
LoMaglio L J. Using the TOEFL to measure the reading proficiency levels of deaf college applicants. Am Ann Deaf. 1991;136(3):261-4. [pmid: 1950948].
Notes: Reject #3
Longo PJ, Donahue V. Amplifying the Health Literacy of Migrant Farmworkers. Richmond, VA : Virginia State Dept. of Education, Richmond. Div. of Adult Education Services. January 1, 1997.
Notes: Reject #2
Lorish C D, Maisiak R. The Face Scale: a brief, nonverbal method for assessing patient mood. Arthritis Rheum. 1986;29(7):906-9. [pmid: 3741503].
Notes: Reject #3
Luckner JL. Written-language assessment and intervention: links to literacy. Volta Rev 1996; 98(1):v-vi, 1-215.
Notes: Reject #3
Luker K, Caress A L. Rethinking patient education. J Advanc Nurs. 1989;14(9):711-8.
Notes: Reject #1
Lynch M E. When the patient is illiterate: how nurses can help. J Pract Nurs. 1992;42(1):41-2. [pmid: 1560400].
Notes: Reject #1
Lyons G K, Woodruff S I, Candelaria J I, Rupp J W, Elder J P. Development of a protocol to assess dietary intake among Hispanics who have low literacy skills in English. J Am Dietetic Assoc. 1996;96(12):1276-9.
Notes: Reject #2
Macario E, Emmons K M, Sorensen G, Hunt M K, Rudd R E. Factors influencing nutrition education for patients with low literacy skills. J Am Dietetic Assoc. 1998;98(5):559-64.
Notes: Reject #3
MacDiarmid S A, Goodson T C, Holmes T M, Martin P R, Doyle R B. An assessment of the comprehension of the American Urological Association Symptom Index. J Urol. 1998;159(3):873-4. [pmid: 9474172].
Notes: Reject #3
Mahloch J, Jackson J C, Chitnarong K, Sam R, Ngo L S, Taylor V M. Bridging cultures through the development of a cervical cancer screening video for Cambodian women in the United States. J Cancer Educ. 1999;14(2):109-14. [pmid: 10397488].
Notes: Reject #3
Malzberg B. Social and biological aspects of mental disease. Oxford, England: State Hosp. Press, 1940.
Notes: Reject #1
Manly J J, Jacobs D M, Sano M, et al. Effect of literacy on neuropsychological test performance in nondemented, education-matched elders. J Intl Neuropsychol Soc. 1999;5(3):191-202.
Notes: Reject #3
Manly J J, Jacobs D M, Touradji P, Small S A, Stern Y. Reading level attenuates differences in neuropsychological test performance between African American and White elders. [erratum appears in J Int Neuropsychol Soc 2002 May;8(4):605.]. J Intl Neuropsychol Soc. 2002;8(3):341-8.
Notes: Reject #3
Marder D A, Cloutier M M. Asthma education: are inner-city families getting the message?. Journal of Respiratory Diseases. 1999;20(9):630-5.
Notes: Reject #3
Martin K S. The ABCs of health education and teaching guides. Home Care Provid. 2000;5(4):116-7. [pmid: 10931391].
Notes: Reject #1
Martinez J A, Straccia L, Sobrani E, Silva G A, Vianna E O, Filho J T. Dyspnea scales in the assessment of illiterate patients with chronic obstructive pulmonary disease. Am J Med Sci. 2000;320(4):240-3. [pmid: 11061348].
Notes: Reject #7
Marwick C. Patients' lack of literacy may contribute to billions of dollars in higher hospital costs. J Am Med Assoc. 1997;278(12):971-2.
Notes: Reject #1
Mason D J. Promoting health literacy. Patient teaching is a vital nursing function. Am J Nurs. 2001;101(2):7. [pmid: 12585054].
Notes: Reject #1
Matthew J T. The need for numeracy in midwifery. Midwives Chron. 1988;101(1206):204-5. [pmid: 3419355].
Notes: Reject #1
Mayeaux E J J, Davis T C, Jackson R H, et al. Literacy and self-reported educational levels in relation to Mini-mental State Examination scores. Fam Med. 1995;27(10):658-62. [pmid: 8582559].
Notes: Reject #3
Mayeaux E J J, Murphy P W, Arnold C, Davis T C, Jackson R H, Sentell T. Improving patient education for patients with low literacy skills. Am Fam Physician. 1996;53(1):205-11. [pmid: 8546047].
Notes: Reject #1
Mazta S R, Ahelluwalia S K. Literacy campaign and health education go hand in hand. World Health Forum. 1995;16(2):184-5. [pmid: 7794461].
Notes: Reject #1
McComb TF, Duffy MM, Pearson IP. Making handouts easy to read. Contemp Pediatr 2000; 17(4):145-6, 148, 150.
Notes: Reject #1
McDonald T, Blignaut P J. A comparison of a manual and a computer system in a primary health care clinic. Curationis. 1998;21(3):8-13. [pmid: 11040583].
Notes: Reject #3
McDougall A C, Georgeiv G D. Educational material for the patient with leprosy. Lepr Revi. 1989;60(3):221-8.
Notes: Reject #1
McIntosh L. My patient can't read. Nurs Spectr. 2002;6(3):22.
Notes: Reject #1
Meade C D, Byrd J C. Patient literacy and the readability of smoking education literature. [see comments.] [erratum appears in Am J Public Health 1989 Jun;79(6):702.]. Am J Public Health. 1989;79(2):204-6. [pmid: 2913844]. [pmcid: 1349937].
Notes: Reject #3
Meade C D, Diekmann J, Thornhill D G. Readability of American Cancer Society patient education literature. Oncol Nurs Forum. 1992;19(1):51-5. [pmid: 1538988].
Notes: Reject #3
Meade C D, Smith C F. Readability formulas: cautions and criteria. Patient Educ Couns. 1991;17(2):153-8.
Notes: Reject #1
Meade C D, Thornhill D G. Illiteracy in healthcare. Nurs Manage. 1989;20(10):14-5. [pmid: 2586928].
Notes: Reject #1
Mendelsohn A L. Promoting language and literacy through reading aloud: the role of the pediatrician. Curr Probl Pediatr Adolesc Health Care. 2002;32(6):188-202. [pmid: 12087355].
Notes: Reject #1
Mendelsohn A L, Mogilner L N, Dreyer B P, et al. The impact of a clinic-based literacy intervention on language development in inner-city preschool children. Pediatrics. 2001;107(1):130-4. [pmid: 11134446].
Notes: Reject #3
Merriman B, Ades T, Seffrin J R. Health literacy in the information age: communicating cancer information to patients and families. CA Cancer J Clin. 2002;52(3):130-3. [pmid: 12018927].
Notes: Reject #1
Merritt S L, Gates M A, Skiba K. Readability levels of selected hypercholesterolemia patient education literature. Heart Lung. 1993;22(5):415-20. [pmid: 8226005].
Notes: Reject #2
Meyer J, Rainey J. Writing health education material for low-literacy populations. J Health Educ. 1994;25(6):372-4.
Notes: Reject #1
Michielutte R, Alciati M H, el Arculli R. Cancer control research and literacy. J Health Care Poor Underserved. 1999;10(3):281-97. [pmid: 10436728].
Notes: Reject #1
Mintzer M Z, Stitzer M L. Cognitive impairment in methadone maintenance patients. Drug Alcohol Depend. 2002;67(1):41-51. [pmid: 12062778].
Notes: Reject #3
Mohrmann C C, Coleman E A, Coon S K, et al. An analysis of printed breast cancer information for African American women. J Cancer Educ. 2000;15(1):23-7. [pmid: 10730799].
Notes: Reject #3
Moll J M. Doctor-patient communication in rheumatology: studies of visual and verbal perception using educational booklets and other graphic material. Ann Rheum Dis. 1986;45(3):198-209. [pmid: 3954469]. [pmcid: 1001852].
Notes: Reject #3
Montalto N J, Spiegler G E. Functional health literacy in adults in a rural community health center. West Virginia Med J. 2001;97(2):111-4.
Notes: Reject #3
Montgomery J. The challenge of literacy. ASHA. 1995;37(5):5. [pmid: 7779159].
Notes: Reject #1
Morgan K. Gerontology: responding to an ageing society. London, England: J. Kingsley Publishers in association with The British Society of Gerontology, 1992.
Notes: Reject #1
Morgan P P. Illiteracy can have major impact on patients' understanding of health care information. Can MedAssoc J. 1993;148(7):1196-7.
Notes: Reject #1
Morgan P P. Numeracy--what is it, and who needs it?. Can Med Assoc J. 1985;133(3):178. [pmid: 4016615]. [pmcid: 1346131].
Notes: Reject #1
Morra M E. Future trends in patient education. Semin Oncol Nurs. 1991;7(2):143-5. [pmid: 1831930].
Notes: Reject #1
Morrow G R. How readable are subject consent forms?. J Am Med Assoc. 1980;244(1):56-8.
Notes: Reject #3
Mullins R M. Reading ability and the use of condoms. Med J Aust. 1989;151(6):358-9. [pmid: 2593952].
Notes: Reject #1
Mumford M E. A descriptive study of the readability of patient information leaflets designed by nurses. J Adv Nurs. 1997;26(5):985-91. [pmid: 9372404].
Notes: Reject #3
Murphy P W, Chesson A L, Berman S A, Arnold C L, Galloway G. Neurology patient education materials: do our educational aids fit our patients' needs?. J Neurosci Nurs. 2001;33 (2):99-104. [pmid: 11326625].
Notes: Reject #3
Murphy PW, Davis TC. When low literacy blocks compliance. RN 1997; 60(10):58-63; quiz 64.
Notes: Reject #1
Murphy PW, Davis TC, Ventura MJ. Don't assume your patient can read. Office Nurse 1997; 10(4):33-5, 38, 40.
Notes: Reject #1
Murphy P W, Davis T C, Jackson R H, Decker B C, Long S W. Effects of literacy on health care of the aged: implications for health professionals. Educ Gerontol. 1993;19(4 ):311-6.
Notes: Reject #1
Nagamine W H, Ishida J T, Williams D R, Yamamoto R I, Yamamoto L G. Child literacy promotion in the emergency department. Pediatr Emerg Care. 2001;17(1):19-21. [pmid: 11265901].
Notes: Reject #2
Nath C R, Sylvester S T, Yasek V, Gunel E. Development and validation of a literacy assessment tool for persons with diabetes. Diabetes Educ. 2001;27(6):857-64. [pmid: 12211925].
Notes: Reject #3
Needlman R, Bauchner H, Zuckerman B. Literacy and the pediatrician. Pediatr Rev. 1990;11(9):259-60. [pmid: 2308888].
Notes: Reject #1
Needlman R, Fried L E, Morley D S, Taylor S, Zuckerman B. Clinic-based intervention to promote literacy. A pilot study. Am J Dis Child. 1991;145(8):881-4. [pmid: 1858725].
Notes: Reject #3
Neff J A, Zule W A. Predicting treatment-seeking behavior: psychometric properties of a brief self-report scale. Subst Use Misuse. 2000;35(4):585-99. [pmid: 10741542].
Notes: Reject #3
Ngoh L N, Shepherd M D. Design, development, and evaluation of visual aids for communicating prescription drug instructions to nonliterate patients in rural Cameroon. Patient Educ Couns. 1997;30(3):257-70. [pmid: 9104382].
Notes: Reject #7
Nichols-English G. Improving health literacy: a key to better patient outcomes. J Am Pharm Assoc. 2000;40(6):835-6.
Notes: Reject #1
Nurss J R, el-Kebbi I M, Gallina D L, et al. Diabetes in urban African Americans: functional health literacy of municipal hospital outpatients with diabetes. Diabetes Educ. 1997;23(5):563-8. [pmid: 9355373].
Notes: Reject #3
Nurss JR. Adult literacy and health care. Smith MC. Literacy for the twenty-first century: Research, policy, practices, and the National Adult Literacy Survey. Westport, CT: Praeger Publishers/Greenwood Publishing Group, Inc., 1998: 195-209.
Notes: Reject #1
Nurss J R, et al. Difficulties in Functional Health Literacy Screening in Spanish-Speaking Adults. J Read. 1995;38(8):632-37.
Notes: Reject #3
Nutbeam D. Literacies across the Lifespan: Health Literacy. Literacy & Numeracy Studies. 1999;9(2):47-55.
Notes: Reject #1
O'Carroll R E, Prentice N, Murray C, van Beck M, Ebmeier K P, Goodwin G M. Further evidence that reading ability is not preserved in Alzheimer's disease. Br J Psychiatr. 1995;167(5):659-62.
Notes: Reject #3
Ollo C, Lindquist T, Alim T N, Deutsch S I. Predicting premorbid functioning in crack-cocaine abusers. Drug Alcohol Depend. 1995;40(2):173-5. [pmid: 8745140].
Notes: Reject #3
Olson I A, Diack H, Harrold P J. Significance of literacy in the performance of students in the first year of the Nottingham Medical Course. Br Med J. 1973;1(5848):282-4. [pmid: 4685320]. [pmcid: 1588074].
Notes: Reject #3
Olson R B, Cohen N, Atallah E, Cunningham J. Gem no. 322. NIBBLE for adult basic education: Website and lessons for low-literate learners... Nutrition Information Bulletin Board and Learning Experience. J Nutr Educ. 2000;32(5):285A.
Notes: Reject #1
Olson RM, Blank D, Cardinal E, Hopf G, Chalmers RK . Understanding medication-related needs of low-literacy patients. J Am Pharm Assoc 1996; NS36(7):424-9.
Notes: Reject #1
Osborne H. Health communications can affect the bottom line. Patient Care Manag. 2001;16(9):9-10.
Notes: Reject #1
Osborne H. In other words... Can they understand? Testing patient education materials with intended readers. On-Call. 2001;4(11):26-7.
Notes: Reject #12
Osborne H. In other words... Getting through... lives can depend on simplifying the written word. On-Call. 1999;2(9):42-3.
Notes: Reject #12
Osborne H. In other words... literacy and the older adult. On-Call. 1999;2(10):42-3.
Notes: Reject #12
Osborne H. In other words... Making the match... choosing patient education materials. On-Call. 2002;5(1):30-1.
Notes: Reject #12
Osborne H. In other words... When you need to know.. literacy resources for health professionals. On-Call. 2001;4(2):34-5.
Notes: Reject #12
Ott B B, Hardie T L. Readability of written materials: implications for critical care nurses. Dimens Crit Care Nurs. 1995;14(6):328-34. [pmid: 8631215].
Notes: Reject #3
Overland J E, Hoskins P L, McGill M J, Yue D K. Low literacy: a problem in diabetes education. Diabet Med. 1993;10(9):847-50. [pmid: 8281731].
Notes: Reject #3
Paque L, Warrington E K. A longitudinal study of reading ability in patients suffering from dementia. J Intl Neuropsychol Soc. 1995;1 (6):517-24.
Notes: Reject #3
Parikh N S, Parker R M, Nurss J R, Baker D W, Williams M V. Shame and health literacy: the unspoken connection. Patient Educ Couns. 1996;27(1 ):33-9. [pmid: 8788747].
Notes: Reject #3
Parker R M, Baker D W, Williams M V, Nurss J R. The test of functional health literacy in adults: a new instrument for measuring patients' literacy skills. J Gen Intern Med. 1995;10(10):537-41. [pmid: 8576769].
Notes: Reject #3
Parker R M, Jacobson T A. The role of health literacy in narrowing the treatment gap for hypercholesterolemia. Am J Manag Care. 2000;6(12):1340-2. [pmid: 11151811].
Notes: Reject #1
Parker R M, Schwartzberg J G. Guest editorial. What patients do -- and don't -- understand: widespread ignorance has triggered a silent epidemic. Postgrad Med. 2001;109(5):13-6. [pmid: 11381662].
Notes: Reject #1
Parker R M, Williams M V, Baker D W, Nurss J R. Literacy and contraception: exploring the link. Obstetr Gynecol. 1996;88(3 Suppl):72S-7S.
Notes: Reject #1
Parker R. Health literacy: A challenge for American patients and their health care providers. Health Promot Intl. 2000;15(4):277-83.
Notes: Reject #1
Parmar S, Baltej S, Vaidyanathan S. Teaching the procedure of clean intermittent catheterisation. Paraplegia. 1993;31(5):298-302. [pmid: 8332375].
Notes: Reject #7
Paskett E D, Tatum C, Wilson A, Dignan M, Velez R. Use of a photoessay to teach low-income African American women about mammography. J Cancer Educa. 1996;11(4):216-20.
Notes: Reject #3
Patberg J P, Yonas A. The effects of the reader's skill and the difficulty of the text on the perceptual span in reading. J Exp Psychol Hum Percept Perform. 1978;4(4):545-52. [pmid: 722246].
Notes: Reject #3
Patel C, Nicol A. Adaptation of African-American cultural and food preferences in end-stage renal disease diets. Adv Ren Replace Ther. 1997;4(1):30-9. [pmid: 8996618].
Notes: Reject #1
Perbohner A. Improving health: patient education resources on the Internet. Health Care on the Internet. 1999;3(3):29-39.
Notes: Reject #1
Perdue BJ, Degazon C. You make the diagnosis. Case study: diagnoses and interventions with low literacy. Nurs Diagn 1999; 10(1):4, 36-9.
Notes: Reject #1
Perez C M, Widom C S. Childhood victimization and long-term intellectual and academic outcomes. Child Abuse Negl. 1994;18(8):617-33. [pmid: 7953902].
Notes: Reject #3
Pernotto DA, Bairnsfather L, Sodeman W. 'Informed consent' interactive videodisc for patients having a colonoscopy, a polypectomy, and an endoscopy. Medinfo 1995; 8 Pt 2:1699.
Notes: Reject #3
Peterson F L, Cooper R J, Laird J M. Enhancing teacher health literacy in school health promotion: a vision for the new millennium. J Sch Health. 2001;71(4):138-44. [pmid: 11354982].
Notes: Reject #1
Petersson K M, Reis A, Askelof S, Castro-Caldas A, Ingvar M. Language processing modulated by literacy: a network analysis of verbal repetition in literate and illiterate subjects. J Cogn Neurosci. 2000;12(3):364-82. [pmid: 10931764].
Notes: Reject #6
Petersson K M, Reis A, Ingvar M. Cognitive processing in literate and illiterate subjects: a review of some recent behavioral and functional neuroimaging data. Scand J Psychol. 2001;42(3):251-67. [pmid: 11501739].
Notes: Reject #6
Philipson S J, Doyle M A, Gabram S G, Nightingale C, Philipson E H. Informed consent for research: a study to evaluate readability and processability to effect change. J Investig Med. 1995;43(5):459-67. [pmid: 8528757].
Notes: Reject #3
Phillips J M. Commentary on Educating patients with limited literacy skills: the effectiveness of printed and videotaped materials about colon cancer [original article by Meade K et al appears in AM J PUBLIC HEALTH 1994;84(1):119-21]. ONS Nursing Scan in Oncology. 1994;3(4):6-7.
Notes: Reject #1
Pi J, Olive J M, Esteban M. [Mini Mental State Examination: association of the score obtained with the age and degree of literacy in an aged population]. [Spanish]. Med Clin. 1994;103(17):641-4.
Notes: Reject #8
Pinto A, Scheer P, Tuqa S, Ebrahim G J, Abel R, Mukherjee D S. Does health intervention ameliorate the effects of poverty related diseases? II. The role of female literacy. J Trop Pediatr. 1985;31(5):257-62. [pmid: 4068081].
Notes: Reject #7
Pirisi A. Low health literacy prevents equal access to care. Lancet. 2000;356(9244):1828. [pmid: 11117924].
Notes: Reject #1
Pizzichini M M, Rennie D, Senthilselvan A, Taylor B, Habbick B F, Sears M R. Limited agreement between written and video asthma symptom questionnaires. Pediatr Pulmonol. 2000;30(4):307-12. [pmid: 11015131].
Notes: Reject #3
Plimpton S, Root J. Materials and strategies that work in low literacy health communication. Public Health Rep. 1994;109(1):86-92. [pmid: 8303020]. [pmcid: 1402246].
Notes: Reject #3
Plomer K, Schneider L, Barley G, Cifuentes M, Dignan M. Improving medical students' communication with limited-literacy patients: project development and implementation. J Cancer Educ. 2001;16(2):68-71. [pmid: 11440064].
Notes: Reject #3
Podschun G D. Teen Peer Outreach-Street Work Project: HIV prevention education for runaway and homeless youth. Public Health Rep. 1993;108(2):150-5. [pmid: 8464971]. [pmcid: 1403354].
Notes: Reject #3
Pope S K, Whiteside L, Brooks-Gunn J, et al. Low-birth-weight infants born to adolescent mothers. Effects of coresidency with grandmother on child development. J Am Med Assoc. 1993;269(11):1396-400.
Notes: Reject #2
Portes P R, Cuentas T E, Zady M. Cognitive socialization across ethnocultural contexts: literacy and cultural differences in intellectual performance and parent-child interaction. J Genet Psychol. 2000;161(1):79-98. [pmid: 10705586].
Notes: Reject #3
Powers R D. Emergency department patient literacy and the readability of patient-directed materials. Ann Emerg Med. 1988;17(2):124-6. [pmid: 3337429].
Notes: Reject #3
Quirk P A. Screening for literacy and readability: implications for the advanced practice nurse. Clin Nurse Spec. 2000;14(1):26-32. [pmid: 11188460].
Notes: Reject #1
Raich P C, Plomer K D, Coyne C A. Literacy, comprehension, and informed consent in clinical research. Cancer Invest. 2001;19(4):437-45. [pmid: 11405182].
Notes: Reject #1
Randolfi E A. Teaching online consumer health skills. International Electronic Journal of Health Education. 1998;1(4):201-6.
Notes: Reject #3
Ratzan S C. Health literacy: communication for the public good. Health Promot. 2001;16(2):207-14.
Notes: Reject #1
Reason R. Re: Critical response to dyslexia, literacy and psychology assessment. Dyslexia. 2001;7(3):174. [pmid: 11765984].
Notes: Reject #1
Reese E, Cox A. Quality of adult book reading affects children's emergent literacy. Dev Psychol. 1999;35(1):20-8. [pmid: 9923461].
Notes: Reject #4
Reid J M V. Assessing the literacy of adults who are visually impaired: conceptual and measurement issues. Journal of Visual Impairment & Blindness. 1998;92(7):447-53.
Notes: Reject #1
Reis A, Petersson K M, Castro-Caldas A, Ingvar M. Formal schooling influences two- but not three-dimensional naming skills. Brain Cogn. 2001;47(3):397-411. [pmid: 11748896].
Notes: Reject #3
Renkert S, Nutbeam D. Opportunities to improve maternal health literacy through antenatal education: an exploratory study. Health Promot. 2001;16(4):381-8.
Notes: Reject #2
Revell L. Understanding, identifying, and teaching the low-literacy patient. Sem Periop Nurs. 1994;3(3):168-71.
Notes: Reject #1
Richards M, Hardy R, Wadsworth M E. Long-term effects of breast-feeding in a national birth cohort: educational attainment and midlife cognitive function. Public Health Nutr. 2002;5(5):631-5. [pmid: 12372156].
Notes: Reject #3
Rieder M J, Morrison C. A survey of information provided by North American Teratogenic Information Services. Reprod Toxicol. 1994;8(5):425-6. [pmid: 7841662].
Notes: Reject #3
Riley L. The hidden disability -- what nurses can do about illiteracy. Nurs Spectr. 2002;11(3):10-1.
Notes: Reject #1
Ritchie K A, Hallerman E F. Cross-validation of a dementia screening test in a heterogeneous population. Int J Epidemiol. 1989;18(3):717-9. [pmid: 2807680].
Notes: Reject #2
Rollins G. AHA NOVA award winners 2002. Hospitals direct scarce resources to help their communities get healthy, fit, strong. Hosp Health Netw 2002; 76(7):49-55, 2.
Notes: Reject #1
Root J, Stableford S. Easy-to-read consumer communications: a missing link in Medicaid managed care. J Health Polit Pol Law. 1999;24(1):1-26.
Notes: Reject #1
Roter D, Rudd R, Koch-Weser S. Health literacy and the JAMA Patient Page. J Am Med Assoc. 1999;282(6):526-7.
Notes: Reject #3
Roter D L, Rudd R E, Comings J. Patient literacy. A barrier to quality of care. J Gen Intern Med. 1998;13(12):850-1. [pmid: 9844085]. [pmcid: 1497046].
Notes: Reject #1
Rudd P, Ramesh J, Bryant-Kosling C, Guerrero D. Gaps in cardiovascular medication taking: the tip of the iceberg. J Gen Intern Med. 1993;8(12):659-66. [pmid: 8120681].
Notes: Reject #2
Rudd R, Zahner L, Banh M. Findings from a National Survey of State Directors of Adult Education. NCSALL Reports #9. Boston, MA.: National Center for the Study of Adult Learning and Literacy, 1999.
Notes: Reject #1
Rudd RE, Colton T, Schacht R. An Overview of Medical and Public Health Literature Addressing Literacy Issues: An Annotated Bibliography. NCSALL Reports #14. Boston, MA: National Center for the Study of Adult Learning and Literacy, 2000.
Notes: Reject #1
Rudd RE, Moeykens BA. Adult Educators' Perceptions of Health Issues and Topics in Adult Basic Education Programs. NCSALL Reports #8. Boston, MA. National Center for the Study of Adult Learning and Literacy, 1999.
Notes: Reject #2
Rutledge D N, Donaldson N E. Improving readability of print materials in patient care & health services. Online J Clin Innov. 1998;1(3):1-27.
Notes: Reject #1
Ryan JW, Kim JG. Can literacy instruction contribute to the training of traditional birth attendants?. WHO Offset Publication 1986; (95):90-5.
Notes: Reject #1
Rymes-Barley C. A secret inability to comply. The price of illiteracy. Can Pharmaceut J 1989; 122(2):86-8, 91-4.
Notes: Reject #1
Sanders L M, Gershon T D, Huffman L C, Mendoza F S. Prescribing books for immigrant children: a pilot study to promote emergent literacy among the children of Hispanic immigrants. Arch Ped Adolesc Med. 2000;154(8):771-7.
Notes: Reject #3
Sandiford P, Cassel J, Sanchez G, Coldham C. Does intelligence account for the link between maternal literacy and child survival?. Soc Sci Med. 1997;45(8):1231-9. [pmid: 9381236].
Notes: Reject #7
Scarborough H S, Dobrich W, Hager M. Preschool literacy experience and later reading achievement. J Learn Disabil. 1991;24(8):508-11. [pmid: 1940609].
Notes: Reject #2
Schein J D. Reading, writing and rehabilitation. Am Rehab. 2000;25(3):32-4.
Notes: Reject #1
Schillinger D. Improving the quality of chronic disease management for populations with low functional health literacy: a call to action. Dis Manage. 2001;4(3):103-9.
Notes: Reject #1
Schillinger D, Piette J, Grumbach K, et al. Closing the loop: physician communication with diabetic patients who have low health literacy. Arch Int Med. 2003;163(1):83-90. [pmid: 12523921].
Notes: Reject #1
Schmand B, Smit J H, Geerlings M I, Lindeboom J. The effects of intelligence and education on the development of dementia. A test of the brain reserve hypothesis. Psychol Med. 1997;27(6):1337-44. [pmid: 9403905].
Notes: Reject #3
Schultz M. Low literacy skills needn't hinder care. RN. 2002;65(4):45-8. [pmid: 11992993].
Notes: Reject #1
Schwartz L M, Woloshin S, Black W C, Welch H G. The role of numeracy in understanding the benefit of screening mammography. Ann Int Med. 1997;127(11):966-72. [pmid: 9412301].
Notes: Reject #2
Schwartzberg J G. Low health literacy: what do your patients really understand?. Nurs Econom. 2002;20(3):145-7.
Notes: Reject #1
Schwartzberg J G. Patient safety. Low health literacy: what do your patients really understand?. Nurs Econom. 2002;20(3):145-7.
Notes: Reject #1
Senechal M, LeFevre JA. Storybook reading and parent teaching: links to language and literacy development. New Direct Child Adolesc Develop 2001; (92):39-52; discussion 91-8.
Notes: Reject #1
Serxner S. How readability of patient materials affects outcomes. J Vascul Nurs. 2000;18(3):97-101.
Notes: Reject #1
Sharif I, Reiber S, Ozuah P O. Exposure to Reach Out and Read and vocabulary outcomes in inner city preschoolers. J Natl Med Assoc. 2002;94(3):171-7. [pmid: 11918387].
Notes: Reject #4
Sharif I, Rieber S, Ozuah P O. The pediatric forum: effective elements of literacy intervention: book, talk, or both? [erratum appears in Arch Pediatr Adolesc Med 2002 Aug;156(8):780.]. Arch Ped Adolesc Med. 2002;156(5):518-9.
Notes: Reject #2
Sharp L K, Knight S J, Nadler R, et al. Quality of life in low-income patients with metastatic prostate cancer: divergent and convergent validity of three instruments. Qual Life Res. 1999;8(5):461-70. [pmid: 10474287].
Notes: Reject #2
Sharp S M. Issues in human subject research. Readability of informed consent documents in medical device trials. Res Pract. 2000;1(6):211-4.
Notes: Reject #3
Shaw R A, Crane J, Pearce N, et al. Comparison of a video questionnaire with the IUATLD written questionnaire for measuring asthma prevalence. Clinic Experiment Allergy. 1992;22(5):561-8.
Notes: Reject #2
Shea S, Basch C E, Wechsler H, Lantigua R. The Washington Heights-Inwood Healthy Heart Program: a 6-year report from a disadvantaged urban setting. Am J Pub Health. 1996;86(2):166-71. [pmid: 8633731]. [pmcid: 1380323].
Notes: Reject #2
Sheridan S L, Pignone M. Numeracy and the medical student's ability to interpret data. Effective Clinic Pract. 2002;5(1):35-40.
Notes: Reject #3
Shire N. Effects of race, ethnicity, gender, culture, literacy, and social marketing on public health. J Gender-Specific Med. 2002;5(2):48-54.
Notes: Reject #1
Shogan M G. Creating clear and simple parent education materials. Mother Baby J. 1998;3(5):21-5.
Notes: Reject #1
Siecker B R. Literacy is the medium of the message. Am Pharm. 1978;18(9):46. [pmid: 677012].
Notes: Reject #1
Silverstein M, Iverson L, Lozano P. An English-language clinic-based literacy program is effective for a multilingual population. Pediatrics. 2002;109(5):E76-6.
Notes: Reject #3
Slavkin H C. Science, technology and health literacy for the 21st century. A future for dentistry. Percy T. Phillips Memorial Lecture. NY State Dent J. 1998;64(10):25-8.
Notes: Reject #1
Slimack N, Tomori C, Bennett CL. Quality of life assessment in culturally diverse populations... first in a series of reports on the conference presentations. Oncol News Int 2000; 9(6):10, 12.
Notes: Reject #1
Snyder C. Can your patient read?. Nurs Spectrum. 2001;11(6):5.
Notes: Reject #1
Snyder R D. The right not to read. Pediatrics. 1979;63(5):791-4.
Notes: Reject #1
Spell J J, Edmondson K. Adult illiteracy and early childhood professionals. Infants Young Children. 1991;3(3):59-67.
Notes: Reject #1
Spracher MM. ASHA hosts three-day literacy workshop: speakers address prevention, identification, intervention. ASHA Leader 2000; 5(20):3, 12.
Notes: Reject #1
Spracher MM. Learning about literacy: SLPs play key role in reading, writing. ASHA Leader 2000; 5(8):1, 18-9.
Notes: Reject #1
St Leger L. Schools, health literacy and public health: possibilities and challenges. Health Prom Int. 2001;16(2):197-205.
Notes: Reject #1
Stanovich K E. Does reading make you smarter? Literacy and the development of verbal intelligence. Advan Child Develop Behav. 1993;24:133-80.
Notes: Reject #3
Stanovich K E, Cunningham A E. Studying the consequences of literacy within a literate society: the cognitive correlates of print exposure. Mem Cog. 1992;20(1):51-68.
Notes: Reject #3
Stein T. Unhealthy mismatch: major gaps in Americans' understanding of medical concepts. Healthweek. 2000;5(10):17.
Notes: Reject #1
Stein T. Unhealthy mismatch: major gaps in Americans' understanding of medical concepts. Nurseweek. 2000;13(11):10.
Notes: Reject #1
Stephens S T. Patient education materials: are they readable?. Oncol Nurs Forum. 1992;19(1):83-5. [pmid: 1538991].
Notes: Reject #1
Stevenson J, Fredman G. The social environmental correlates of reading ability. J Child Psychol Psychiatr Allied Disciplines. 1990;31(5):681-98. [pmcid: 262841].
Notes: Reject #3
Stewart J L. Commentary on Fotoplatica: an innovative teaching method for families with low literacy and high stress [original article by Harlander C et al appears in J PEDIATR ONCOL NURS 1993;10(3):112-4]. ONS Nurs Scan Oncol. 1994;3(1):5.
Notes: Reject #1
Storch SA, Whitehurst GJ. The role of family and home in the literacy development of children from low-income backgrounds. New Directions Child Adolesc Dev 2001; (92):53-71; discussion 91-8.
Notes: Reject #3
Struempler B J, Marshall A C. Gem no. 293. Using low-literacy newsletters to provide nutrition education for limited-resource individuals. J Nutr Educ. 1999;31(1):60C-1C.
Notes: Reject #3
Sudore R. Low-Literacy Patient Education Handouts. Fifth Street Clinic Site, 525 5th St., San Francisco, CA 94103.: University of California - San Francisco Homeless Clinic , 1999.
Notes: Reject #1
Sumerford S. Creating a community of readers to fight functional illiteracy. Am Lib. 1997;28(5):44-5.
Notes: Reject #1
Sutherland L A, Campbell M, Ornstein K, Wildemuth B, Lobach D. Development of an adaptive multimedia program to collect patient health data. Am J Prev Med. 2001;21(4):320-4. [pmid: 11701304].
Notes: Reject #2
Svensson I, Lundberg I, Jacobson C. The prevalence of reading and spelling difficulties among inmates of institutions for compulsory care of juvenile delinquents. Dyslexia: the Journal of the British Dyslexia Association. 2001;7(2):62-76. [pmcid: 422639].
Notes: Reject #3
Swanson J M, Forrest K, Ledbetter C, Hall S, Holstine E J, Shafer M R. Readability of commercial and generic contraceptive instructions. Image J Nurs Sch. 1990;22(2):96-100. [pmid: 2365397].
Notes: Reject #3
Sweeney M A, Gulino C. Interactive video in health care: blending patient care, computer technology, and research results. J Biocommun. 1988;15(4):6-11. [pmid: 3073157].
Notes: Reject #3
Tallal P. The science of literacy: from the laboratory to the classroom. Proc Natl Acad Sci U S A. 2000;97(6):2402-4. [pmcid: 33971]. [pmid: 10716977].
Notes: Reject #1
Tappe M K, Galer-Unti R A. Health educators' role in promoting health literacy and advocacy for the 21st century. J School Health. 2001;71(10):477-82.
Notes: Reject #1
Temple M A. Teaching techniques. Using debate to develop health literacy. J School Health. 1997;67(3):116-7.
Notes: Reject #1
Terdy D. Workforce literacy: do we have a choice?. J Healthc Mater Manage 1991; 9(10):36, 38, 40 passim.
Notes: Reject #1
Thomas J J. Enhancing patient education: addressing the issue of literacy. Phys Disabil Spec Int Sect Q. 1999;22(4):3-4.
Notes: Reject #1
Thornberry J, Bhaskar B, Krulewitch C J, et al. Audio computerized self-report interview use in prenatal clinics: audio computer-assisted self interview with touch screen to detect alcohol consumption in pregnant women: application of a new technology to an old problem. Comp Inform Nurs. 2002;20 (2):46-52.
Notes: Reject #3
Tirre W C. Can reading ability be measured with tests of memory and processing speed?. J Gen Psychol. 1992;119(2):141-60. [pmid: 1506845].
Notes: Reject #3
Tones K. Health literacy: new wine in old bottles?. Health Educ Res. 2002;17(3):287-90. [pmid: 12120844].
Notes: Reject #1
Tooth L, Clark M, McKenna K. Poor functional health literacy: the silent disability for older people. Aust J Age. 2000;19(1):14-22.
Notes: Reject #1
Treacy J T, Mayer D K. Perspectives on cancer patient education. Semin Oncol Nurs. 2000;16(1):47-56. [pmid: 10701240].
Notes: Reject #1
Treiman R, Cassar M. Can children and adults focus on sound as opposed to spelling in a phoneme counting task?. Dev Psychol. 1997;33(5):771-80. [pmid: 9300210].
Notes: Reject #3
Tucker C C, Thornton S R. Workplace literacy education: writing skills. J Healthc Educ Train. 1992;6(3):15-8. [pmid: 10118373].
Notes: Reject #2, #3
Turner C F, Miller H G. Monitoring trends in drug use: strategies for the 21st century. Subst Use Misuse. 1997;32(14):2093-103. [pmid: 9440154].
Notes: Reject #1
Tuttle D W, Hatlen P. Point/counterpoint. Is listening literacy? An effective alternative... comprehensive literacy. J Visual Impair Blind. 1996;90(3):173-5.
Notes: Reject #1
Tziraki C, Sutton S, Eisner E, Saunders L S. National Cancer Institute's Ethnic and Low Literacy Nutrition Education Project. J Nutr Educ. 1994;26(2):101-6.
Notes: Reject #3
Valla J P, Bergeron L, Smolla N. The Dominic-R: a pictorial interview for 6- to 11-year-old children. J Am Acad Child Adolesc Psychiatry. 2000;39(1):85-93. [pmid: 10638071].
Notes: Reject #2
van de Walle E. Fertility transition, conscious choice, and numeracy. Demography. 1992;29(4):487-502. [pmcid: 441298].
Notes: Reject #2
Van Moorsel G. Do you Mini-Med School? Leveraging library resources to improve Internet consumer health information literacy. Med Ref Serv Q. 2001;20(4):27-37. [pmid: 11865760].
Notes: Reject #1
Vessey J A. Health promotion for children... commentary on High PC, LaGasse L, Becker S et al (2000). Literacy promotion in primary care pediatrics: can we make a difference? PEDIATRICS, 105(4), 927-934. J Child Fam Nurs. 2000;3(5):326-7. [pmid: 11022475].
Notes: Reject #1
Walker E A. Characteristics of the adult learner. Diabetes Educ. 1999;25(6 Suppl):16-24. [pmid: 10711081].
Notes: Reject #1
Walker G. Family planning, maternal mortality, and literacy. Lancet. 1986;2(8499):162. [pmcid: 192443].
Notes: Reject #1
Wallerstein N. Health and safety education for workers with low-literacy or limited-English skills. Am J Ind Med. 1992;22(5):751-65. [pmid: 1442804].
Notes: Reject #1
Walsh D, Shaw D G. The design of written information for cardiac patients: a review of the literature. J Clin Nurs. 2000;9(5):658-67.
Notes: Reject #1
Wands S E, Yassi A. 'Let's Talk Back': a program to empower laundry workers. Am J Ind Med. 1992;22(5):703-9. [pmid: 1442799].
Notes: Reject #3
Weidmer B, Brown J, Garcia L. Translating the CAHPS 1.0 Survey Instruments into Spanish. Consumer Assessment of Health Plans Study. Med Care 1999; 37(3 Suppl):MS89-96.
Notes: Reject #3
Weinrich SP. Prostate cancer: the high risk of low literacy. Reflections 1999; 25(4):22-4, 45 .
Notes: Reject #1
Weiss B D. Health literacy: an important issue for communicating health information to patients. Chung Hua i Hsueh Tsa Chih - Chinese Med J. 2001;64(11):603-8.
Notes: Reject #1
Weiss B D. Identifying and communicating with patients who have poor literacy skills. Fam Med. 1993;25(6):369-70. [pmid: 8349054].
Notes: Reject #1
Weiss B D, Coyne C. Communicating with patients who cannot read. New England J Med. 1997;337(4):272-4. [pmid: 9227936].
Notes: Reject #1
Weiss B D, Hart G, Pust R E. The relationship between literacy and health. J Health Care Poor Underserved. 1991;1(4):351-63. [pmcid: 368261].
Notes: Reject #1
Weiss B D, Reed R, Kligman E W, Abyad A. Literacy and performance on the Mini-Mental State Examination. J Am Geriatr Soc. 1995;43(7):807-10. [pmid: 7602038].
Notes: Reject #3
Weiss B D, Reed R L, Kligman E W. Literacy skills and communication methods of low-income older persons. Patient Educ Couns. 1995;25(2):109-19. [pmid: 7659623].
Notes: Reject #3
Weiss B D. Communicating with patients who have limited literacy skills. J Fam Pract. 1998;46(2):168-76. [pmid: 9487325].
Notes: Reject #1
Wells J A. Readability of HIV/AIDS educational materials: the role of the medium of communication, target audience, and producer characteristics. Patient Educ Couns. 1994;24(3):249-59. [pmid: 7753718].
Notes: Reject #3
Wells JA, Ruscavage D, Parker B, McArthur L. Literacy of women attending family planning clinics in Virginia and reading levels of brochures on HIV prevention. Fam Plann Perspect 1994; 26(3):113-5, 131.
Notes: Reject #2
Wengreen H J, Munger R G, Wong S S, West N A, Cutler R. Comparison of a picture-sort food-frequency questionnaire with 24-hour dietary recalls in an elderly Utah population. Pub Health Nutr. 2001;4(5):961-70. [pmid: 11784409].
Notes: Reject #3
Westaway M S, Wolmarans L. Depression and self-esteem: rapid screening for depression in black, low literacy, hospitalized tuberculosis patients. Soc Sci Med. 1992;35(10):1311-5. [pmid: 1439914].
Notes: Reject #2
Wheeler L A, Wheeler M L, Ours P, Swider C. Evaluation of computer-based diet education in persons with diabetes mellitus and limited educational background. Diabetes Care. 1985;8(6):537-44. [pmcid: 287996].
Notes: Reject #2
Wielgosz A T. Impact of the social environment on blood pressure in women. Can J Cardiol. 1996;12 Suppl D:13D-15D. [pmid: 8665425].
Notes: Reject #1
Williams D M, Counselman F L, Caggiano C D. Emergency department discharge instructions and patient literacy: a problem of disparity. Am J Emerg Med. 1996;14(1):19-22. [pmid: 8630148].
Notes: Reject #3
Williams M V. Recognizing and overcoming inadequate health literacy, a barrier to care. Cleveland Clin J Med. 2002;69(5):415-8.
Notes: Reject #1
Williams M V, Parker R M, Baker D W, et al. Inadequate functional health literacy among patients at two public hospitals. J Am Med Assoc. 1995;274(21):1677-82.
Notes: Reject #3
Williams S A, Swanson M S. The effect of reading ability and response formats on patients' abilities to respond to a patient satisfaction scale. J Cont Educat Nurs. 2001;32(2):60-7.
Notes: Reject # 3
Williams S A, Swanson M S. The effect of reading ability and response formats on patients' abilities to respond to a patient satisfaction scale. J Cont Educat Nurs. 2001;32(2):60-7.
Notes: Reject # 3
Wilson F L. Are patient information materials too difficult to read?. Home Healthc Nurs. 2000;18(2):107-15.
Notes: Reject #3
Wilson F L. Measuring patients' ability to read and comprehend: a first step in patient education. Nursingconnections. 1995;8(4):17-25. [pmcid: 134589].
Notes: Reject #3
Wilson F L. Measuring patients' ability to read and comprehend: a first step in patient education. Nursingconnections. 2000;13(3):19-27. [pmcid: 324594].
Notes: Reject #1
Wilson F L. Research you can use. Are patient information materials too difficult to read?. Home Healthc Nurs. 2000;18(2):107-15.
Notes: Reject #3
Wilson F L. The suitability of United States Pharmacopoeia Dispensory Information psychotropic drug leaflets for urban patients with limited reading skills. Arch Psychiat Nurs. 1999;13(4):204-11.
Notes: Reject #3
Winkleby M A, Howard-Pitney B, Albright C A, Bruce B, Kraemer H C, Fortmann S P. Predicting achievement of a low-fat diet: a nutrition intervention for adults with low literacy skills. Prevent Med. 1997;26(6):874-82.
Notes: Reject #3
Winslow EH. Research for practice. Caring for patients with limited literacy. Am J Nurs 1998; 98(7):55, 57.
Notes: Reject #1
Wofford J L, Currin D, Michielutte R, Wofford M M. The multimedia computer for low-literacy patient education: a pilot project of cancer risk perceptions. Medgenmed [Computer File]: Medscape General Medicine. 2001;3(2):23. [pmcid: 514526].
Notes: Reject #3
Woloshin S, Schwartz L M, Moncur M, Gabriel S, Tosteson A N. Assessing values for health: numeracy matters. Med Decision Making. 2001;21(5):382-90.
Notes: Reject #3
Wong M. Self-care instructions: do patients understand educational materials?. Focus Crit Care. 1992;19(1):47-9. [pmid: 1537418].
Notes: Reject #1
Woodrow P. Numeracy skills. Nurs Stand 1998; 12(30):48-53; quiz 54-5.
Notes: Reject #1
Yajima S, Takano T, Nakamura K, Watanabe M. Effectiveness of a community leaders' programme to promote healthy lifestyles in Tokyo, Japan. Health Promotion Int. 2001;16(3):235-43.
Notes: Reject #2
Yasenchak P A, Bridle M J. A low-literacy skin care manual for spinal cord injury patients. Patient Educ Counsel. 1993;22(1):1-5.
Notes: Reject #2
Yoos H L, McMullen A, Bezek S, et al. An asthma management program for urban minority children. J Pediatr Health Care. 1997;11(2):66-74. [pmid: 9155350].
Notes: Reject #3
Zarcadoolas C, Timm E, Bibeault L. Brownfields: a case study in partnering with residents to develop an easy-to-read print guide. J Environ Health. 2001;64(1):15-20.
Notes: Reject #2, #3
Ziegler J. How illiteracy drives up health costs. Bus Health 1998; 16(4):53-4, 57, 61.
Notes: Reject #1
Zimm A. The need to understand: addressing issues of low literacy and health. On-Call. 1998;1(4):20-3.
Notes: Reject #1
Zimmerman T, Shenenberger D W. Health literacy and diabetic control. J Am Med Assoc. 2002;288(21):2688.
Notes: Reject #1
Zion A B, Aiman J. Level of reading difficulty in the American College of Obstetricians and Gynecologists patient education pamphlets. Obstetr Gynecol. 1989;74(6):955-60.
Notes: Reject #3
Zung W W, Gianturco J. Further validation of the Ohio literacy test: correlation with the Wechsler adult intelligence scale and grade achieved in school. J Clin Psychol. 1968;24(2):197-8. [pmid: 5650543].
Notes: Reject #3