# References and Included Studies

1 National Literacy Act of 1991. Pub. L. No. 102–73, 105 Stat. 333: 1991.
2 Kirsch I, Jungeblut A, Jenkins L, et al. Adult literacy in America: A first look at the findings of the National Adult Literacy Survey. 3rd edition. Vol. 201. Washington, D.C.: National Center for Education; US Department of Education; 2002.
3 Comings J, Reder S, Sum A. Building a level playing field: the need to expand and improve the national and state adult education and literacy systems. Cambridge, Mass: National Center for the Study of Adult Learning and Literacy; 2001.
4 Davis T C, Crouch M A, Wills G, et al. The gap between patient reading comprehension and the readability of patient education materials. J Fam Pract. 1990;31:533-8. [pmid: 2230677].
5 Pincus T, Callahan L F, Burkhauser R V. Most chronic diseases are reported more frequently by individuals with fewer than 12 years of formal education in the age 18–64 United States population. J Chronic Dis. 1987;40(9):865-74. [pmid: 3597688].
6 Parker R M, Baker D W, Williams M V, et al. The test of functional health literacy in adults: a new instrument for measuring patients' literacy skills. J Gen Intern Med. 1995;10:537-41. [pmid: 8576769].
7 Gazmararian J A, Baker D W, Williams M V, et al. Health literacy among Medicare enrollees in a managed care organization. J Am Med Assn. 1999;281(6):545-51.
8 Schillinger D, Piette J, Grumbach K, et al. Closing the loop: physician communication with diabetic patients who have low health literacy. Arch Int Med. 2003;163(1):83-90. [pmid: 12523921].
9 American Medical Association. Ad Hoc Committee on Health Literacy for the Council on Scientific Affairs. J Am Med Assoc. 1999;281:552-7.
10 OED Online. Oxford English Dictionary [Web Page]. 2003; Available at dictionary.oed.com. (Accessed 16 July 2003).
11 Nutbeam D. Health literacy as a public health goal: a challenge for contemporary health education and communication strategies into the 21st century. Health Promot Intl. 2000;15:259-67.
12 Wide Range Inc. Wide Range Achievement Test (WRAT 3). Wilmington, DE: Wide Range Inc.; 1993.
13 Davis T C, Long S W, Jackson R H, et al. Rapid estimate of adult literacy in medicine: a shortened screening instrument. Fam Med. 1993;25:391-5. [pmid: 8349060].
14 Schwartz L M, Woloshin S, Black W C, et al. The role of numeracy in understanding the benefit of screening mammography. Ann Intern Med. 1997;127(11):966-72. [pmid: 9412301].
15 Baker D W, Gazmararian J A, Sudano J, et al. The association between age and health literacy among elderly persons. J Gerontol Series B-Psychol Scien Soc Scien. 2000;55(6):S368-74.
16 Fry E. Fry's readibility graph: clarifications, validity, and extensions to level 17. J Reading 1977; 242–52.
17 Doak C, Doak L, Root J. Teaching patients with low literacy skills. Philadelphia, PA: Lippincott; 1996.
18 Harvard School of Public Health. Health literacy rules [Web Page]. Available athttp://www.hsph.harvard.edu/healthliteracy/literature.html. (Accessed 1 October 2002).
19 National Library of Medicine. Current bibliographies in medicine 2000-1: health literacy [Web Page]. Available athttp://www.nlm.nih.gov/pubs/cbm/hliteracy.html. (Accessed 1 October 2002).
20 West SL, King V, Carey TS, et al. Systems to rate the strength of scientific evidence. Evidence Report, Technology Assessment No. 47. Rockville, MD: Agency for Healthcare Research and Quality; 2002. AHRQ Publication No. 02-E016.
21 Greer N, Mosser G, Logan G, et al. A practical approach to evidence grading. Joint Commission J Qual Improv. 2000;26(12):700-12.
22 Gazmararian J, Baker D, Parker R, et al. A multivariate analysis of factors associated with depression: evaluating the role of health literacy as a potential contributor. Arch Int Med. 2000;160(21):3307-14. [pmid: 11088094].
23 Scott T L, Gazmararian J A, Williams M V, et al. Health literacy and preventive health care use among Medicare enrollees in a managed care organization. Med Care. 2002;40(5):395-404. [pmid: 11961474].
24 Baker D W, Gazmararian J A, Williams M V, et al. Functional health literacy and the risk of hospital admission among Medicare managed care enrollees. Am J Pub Health. 2002;92(8):1278-83. [pmid: 12144984]. [pmcid: 1447230].
25 Baker D W, Parker R M, Williams M V, et al. The relationship of patient reading ability to self-reported health and use of health services. Am J Pub Health. 1997;87(6):1027-30. [pmid: 9224190]. [pmcid: 1380944].
26 Baker D W, Parker R M, Williams M V, et al. Health literacy and the risk of hospital admission. J Gen Int Med. 1998;13(12):791-8.
27 Davis T C, Arnold C, Berkel H J, et al. Knowledge and attitude on screening mammography among low-literate, low-income women. Cancer. 1996;78(9):1912-20. [pmid: 8909311].
28 Lindau S T, Tomori C, Lyons T, et al. The association of health literacy with cervical cancer prevention knowledge and health behaviors in a multiethnic cohort of women. Am J Obstet Gynecol. 2002;186(5):938-43. [pmid: 12015518].
29 Miller C K, O'Donnell D C, Searight H R, et al. The Deaconess Informed Consent Comprehension Test: an assessment tool for clinical research subjects. Pharmacotherapy. 1996;16(5):872-8. [pmid: 8888082].
30 Moon R Y, Cheng T L, Patel K M, et al. Parental literacy level and understanding of medical information. Pediatrics. 1998;102(2):e25. [pmid: 9685471].
31 Spandorfer J M, Karras D J, Hughes L A, et al. Comprehension of discharge instructions by patients in an urban emergency department. Ann Emerg Med. 1995;25(1):71-4. [pmid: 7802373].
32 TenHave T R, Van Horn B, Kumanyika S, et al. Literacy assessment in a cardiovascular nutrition education setting. Patient Educat Counsel. 1997;31(2):139-50.
33 Fortenberry J D, McFarlane M M, Hennessy M, et al. Relation of health literacy to gonorrhoea related care. Sex Trans Infect. 2001;77(3):206-11.
34 Arnold C L, Davis T C, Berkel H J, et al. Smoking status, reading level, and knowledge of tobacco effects among low-income pregnant women. Prevent Med. 2001;32(4):313-20.
35 Conlin K K, Schumann L. Research. Literacy in the health care system: a study on open heart surgery patients. J Am Acad Nurse Pract. 2002;14(1):38-42. [pmid: 11845640].
36 Wilson F L, McLemore R. Patient literacy levels: a consideration when designing patient education programs. Rehab Nursing. 1997;22(6):311-7.
37 Gazmararian J A, Parker R M, Baker D W. Reading skills and family planning knowledge and practices in a low-income managed-care population. Obstet Gynecol. 1999;93(2):239-44. [pmid: 9932563].
38 Kalichman S C, Rompa D. Functional health literacy is associated with health status and health-related knowledge in people living with HIV-AIDS. J Acq Immune Def Synd Hum Retrovirol. 2000b;25(4):337-44.
39 Kalichman S C, Rompa D, Cage M. Reliability and validity of self-reported CD4 lymphocyte count and viral load test results in people living with HIV/AIDS. Int J STD & AIDS. 2000;11(9):579-85. [pmid: 11138915].
40 Kalichman S C, Benotsch E, Suarez T, et al. Health literacy and health-related knowledge among persons living with HIV/AIDS. Am J Prev Med. 2000;18(4):325-31. [pmid: 10788736].
41 Miller L G, Liu H, Hays R D, et al. Knowledge of antiretroviral regimen dosing and adherence: a longitudinal study. Clin Infect Dis. 2003;36(4):514-8. [pmid: 12567311].
42 Williams M V, Baker D W, Parker R M, et al. Relationship of functional health literacy to patients' knowledge of their chronic disease. A study of patients with hypertension and diabetes. Arch Int Med. 1998;158(2):166-72. [pmid: 9448555].
43 Williams M V, Baker D W, Honig E G, et al. Inadequate literacy is a barrier to asthma knowledge and self-care. Chest. 1998;114(4):1008-15. [pmid: 9792569].
44 Fredrickson D D, Washington R L, Pham N, et al. Reading grade levels and health behaviors of parents at child clinics. Kansas Med. 1995;96(3):127-9.
45 Hawthorne G. Preteenage drug use in Australia: the key predictors and school-based drug education. J Adolesc Health. 1996;20(5):384-95. [pmid: 9168386].
46 Kaufman H, Skipper B, Small L, et al. Effect of literacy on breast-feeding outcomes. South Med J. 2001;94(3):293-6. [pmid: 11284516].
47 Davis T C, Byrd R S, Arnold C L, et al. Low literacy and violence among adolescents in a summer sports program. J Adolesc Health. 1999;24(6):403-11. [pmid: 10401968].
48 Stanton W R, Feehan M, McGee R, et al. The relative value of reading ability and IQ as predictors of teacher-reported behavior problems. J Learn Disabil. 1990;23(8):514-7. [pmid: 2246604].
49 Kalichman S C, Ramachandran B, Catz S. Adherence to combination antiretroviral therapies in HIV patients of low health literacy. J Gen Int Med. 1999;14(5):267-73.
50 Golin C E, Liu H, Hays R D, et al. A prospective study of predictors of adherence to combination antiretroviral medication. J Gen Intern Med. 2002;17(10):756-65. [pmid: 12390551]. [pmcid: 1495120].
51 Li B, Brown W, Ampil F, et al. Patient compliance is critical for equivalent clinical outcomes for breast cancer treated by breast-conservation therapy. Ann Surg. 2000;231(6):883-9. [pmid: 10816632]. [pmcid: 1421078].
52 Frack S A, Woodruff S I, Candelaria J, et al. Correlates of compliance with measurement protocols in a Latino nutrition-intervention study. Am J Prevent Med. 1997;13(2):131-6.
53 Ross L A, Frier B M, Kelnar C J, et al. Child and parental mental ability and glycaemic control in children with Type 1 diabetes. Diabetic Med. 2001;18(5):364-9. [pmid: 11472446].
54 Schillinger D, Grumbach K, Piette J, et al. Association of health literacy with diabetes outcomes. J Am Med Assoc. 2002;288(4):475-82.
55 Battersby C, Hartley K, Fletcher A E, et al. Cognitive function in hypertension: a community based study. J Hum Hyperten. 1993;7(2):117-23.
56 Kalichman S C, Rompa D. Emotional reactions to health status changes and emotional well-being among HIV-positive persons with limited reading literacy. J Clin Psychol Med Set. 2000a;7(4):203-11.
57 Zaslow M J, Hair E C, Dion M R, et al. Maternal depressive symptoms and low literacy as potential barriers to employment in a sample of families receiving welfare: are there two-generational implications?. Women Health. 2001;32(3):211-51. [pmid: 11480894].
58 Gordon M M, Hampson R, Capell H A, et al. Illiteracy in rheumatoid arthritis patients as determined by the Rapid Estimate of Adult Literacy in Medicine (REALM) score. Rheumatol. 2002;41(7):750-4.
59 Fisch M, Unverzagt F, Hanna M, et al. Information preferences, reading ability, and emotional changes in outpatients during the process of obtaining informed consent for autologous bone-marrow transplantation. J Cancer Educat. 1998;13(2):71-5.
60 Andrasik F, Kabela E, Quinn S, et al. Psychological functioning of children who have recurrent migraine. Pain. 1988;34(1):43-52. [pmid: 3405619].
61 Bennett C L, Ferreira M R, Davis T C, et al. Relation between literacy, race, and stage of presentation among low-income patients with prostate cancer. J Clin Oncol. 1998;16(9):3101-4. [pmid: 9738581].
62 Weiss B D, Hart G, McGee D L, et al. Health status of illiterate adults: relation between literacy and health status among persons with low literacy skills. J Am Board Fam Pract. 1992;5(3):257-64. [pmid: 1580173].
63 Sullivan L M, Dukes K A, Harris L, et al. A comparison of various methods of collecting self-reported health outcomes data among low-income and minority patients. Med Care. 1995;33(4 Suppl):AS183-94. [pmid: 7723446].
64 Weiss B D, Blanchard J S, McGee D L, et al. Illiteracy among Medicaid recipients and its relationship to health care costs. J Health Care Poor Underserved. 1994;5(2):99-111. [pmid: 8043732].
65 Hugo J, Skibbe A. Facing visual illiteracy in South African health education: a pilot study. J Audiovisual Media Med. 1991;14(2):47-50.
66 Mulrow C, Bailey S, Sonksen P H, et al. Evaluation of an Audiovisual Diabetes Education Program: negative results of a randomized trial of patients with non-insulin-dependent diabetes mellitus. J Gen Intern Med. 1987;2(4):215-9. [pmid: 2441013].
67 Lillington L, Royce J, Novak D, et al. Evaluation of a smoking cessation program for pregnant minority women. Cancer Pract. 1995;3(3):157-63. [pmid: 7599672].
68 Poresky R H, Daniels A M. Two-year comparison of income, education, and depression among parents participating in regular Head Start or supplementary Family Service Center Services. Psychol Reports. 2001;88(3 Pt 1):787-96.
69 Bill-Harvey D, Rippey R, Abeles M, et al. Outcome of an osteoarthritis education program for low-literacy patients taught by indigenous instructors. Patient Educat Counsel. 1989;13(2):133-42.
70 Fouad M N, Kiefe C I, Bartolucci A A, et al. A hypertension control program tailored to unskilled and minority workers. Ethnicit Dis. 1997;7(3):191-9.
71 Powell E C, Tanz R R, Uyeda A, et al. Injury prevention education using pictorial information. Pediatrics. 2000;105(1):e16. [pmid: 10617753].
72 Coleman E A, Coon S, Mohrmann C, et al. Developing and testing lay literature about breast cancer screening for African American women. Clin J Oncol Nurs. 2003;7(1):66-71. [pmid: 12629937].
73 Davis T C, Berkel H J, Arnold C L, et al. Intervention to increase mammography utilization in a public hospital. J Gen Intern Med. 1998;13(4):230-3. [pmid: 9565385]. [pmcid: 1496943].
74 Davis T C, Bocchini J A J, Fredrickson D, et al. Parent comprehension of polio vaccine information pamphlets. Pediatrics. 1996;97(6 Pt 1):804-10. [pmid: 8657518].
75 Davis T C, Holcombe R F, Berkel H J, et al. Informed consent for clinical trials: a comparative study of standard versus simplified forms. J Nat Cancer Inst. 1998;90(9):668-74. [pmid: 9586663].
76 Eaton M L, Holloway R L. Patient comprehension of written drug information. Am J Hosp Pharm. 1980;37(2):240-3. [pmid: 7361799].
77 Fitzgibbon M L, Stolley M R, Avellone M E, et al. Involving parents in cancer risk reduction: a program for Hispanic American families. Health Psychol. 1996;15(6):413-22. [pmid: 8973920].
78 Gans K M, Lovell H J, Fortunet R, et al. Gem no. 289. Low-literacy audio intervention for lowering fat intake. J Nutr Educat. 1998;30(6):410B.
79 Hartman T J, McCarthy P R, Park R J, et al. Results of a community-based low-literacy nutrition education program. J Comm Health. 1997;22(5):325-41.
80 Hayes K S. Randomized trial of geragogy-based medication instruction in the emergency department. Nurs Res. 1998;47(4):211-8. [pmid: 9683116].
81 Howard-Pitney B, Winkleby M A, Albright C L, et al. The Stanford Nutrition Action Program: a dietary fat intervention for low-literacy adults. Am J Pub Health. 1997;87(12):1971-6. [pmid: 9431286]. [pmcid: 1381239].
82 Hussey L C. Minimizing effects of low literacy on medication knowledge and compliance among the elderly. Clin Nurs Res. 1994;3(2):132-45. [pmid: 7513587].
83 Jacobson T A, Thomas D, Morton F, et al. Use of a low-literacy patient education tool to enhance pneumococcal vaccination rates. A randomized controlled trial. J Am Med Assoc. 1999;282(7):646-50.
84 Kim S P, Knight S J, Tomori C, et al. Health literacy and shared decision making for prostate cancer patients with low socioeconomic status. Cancer Investigat. 2001;19(7):684-91.
85 Kumanyika S K, Adams-Campbell L, Van Horn B, et al. Outcomes of a cardiovascular nutrition counseling program in African-Americans with elevated blood pressure or cholesterol level. J Am Diet Assoc. 1999;99(11):1380-91. [pmid: 10570675].
86 Murphy P W, Davis T C, Mayeaux E J, et al. Teaching nutrition education in adult learning centers: linking literacy, health care, and the community. J Comm Health Nurs. 1996;13(3):149-58.
87 Pepe M V, Chodzko-Zajko W J. Impact of older adults' reading ability on the comprehension and recall of cholesterol information. J Health Educat. 1997;28(1):21-7.
88 Raymond E G, Dalebout S M, Camp S I. Comprehension of a prototype over-the-counter label for an emergency contraceptive pill product. Obstet Gynecol. 2002;100(2):342-9. [pmid: 12151161].
89 Murphy P W, Chesson A L, Walker L, et al. Comparing the effectiveness of video and written material for improving knowledge among sleep disorders clinic patients with limited literacy skills. Southern Med J. 2000;93(3):297-304. [pmid: 10728518].
90 Michielutte R, Bahnson J, Dignan M B, et al. The use of illustrations and narrative text style to improve readability of a health education brochure. J Cancer Educat. 1992;7(3):251-60.
91 Davis T C, Fredrickson D D, Arnold C, et al. A polio immunization pamphlet with increased appeal and simplified language does not improve comprehension to an acceptable level. Patient Educat Counsel. 1998;33(1):25-37.
92 Meade C D, McKinney W P, Barnas G P. Educating patients with limited literacy skills: the effectiveness of printed and videotaped materials about colon cancer. Am J Pub Health. 1994;84(1):119-21. [pmid: 8279598]. [pmcid: 1614927].
93 Wydra E W. The effectiveness of a self-care management interactive multimedia module. Oncol Nursing Forum. 2001;28(9):1399-407.
94 Williams M V, Parker R M, Baker D W, et al. Inadequate functional health literacy among patients at two public hospitals. J Am Med Assoc. 1999;281:545-51.
95 Rudd RE, Moeykens BA, Colton TC. Health and literacy: a review of medical and public health literature. In: Comings J, Garners B, Smith C, eds. Annual Review of Adult Learning and Literacy. New York: Jossey-Bass, 1999.
96 Williams S A, Swanson M S. The effect of reading ability and response formats on patients' abilities to respond to a patient satisfaction scale. J Contin Educat Nursing. 2001;32(2):60-7.