# Results

This chapter presents the results of our literature search and our findings for both key questions, which were illustrated in Figure 1 and discussed in Chapter 2. KQ 1 asked if literacy skills are related to (a) use of health care services, (b) health outcomes, (c) costs, and (d) disparities in outcomes or utilization according to race, ethnicity, culture, or age. KQ 2 asked, for people with low literacy skills, whether effective interventions exist to (a) improve use of services, (b) improve health outcomes, (c) affect health care costs, and (d) improve outcomes or service use among various population groups defined by race, ethnicity, cultural background, or age.

We report our results in the two main sections of this chapter, reporting first on specific details about the yields of the literature searches and characteristics of the studies and then on the four main subquestions of interest for each key question. Summary tables presenting selected information on each study are contained at the end of this chapter for KQ 1 (Table 5) and KQ 2 (Table 6). Additional tables presenting findings grouped by selected outcomes appear at the end of this chapter. Detailed evidence tables appear in Appendix C.

Table 5. Summary of studies of relationship between health services, outcomes, costs, or disparities and literacy (KQ 1)

Study | Design | Health Measure | Literacy Measure | Results
Use of Health Care Services
Knowledge of Health Care Services
Davis et al., 1996 ^27^ | Cross-sectional | Knowledge and attitudes regarding mammography screening | REALM | Higher literacy level was associated with reasons why women get mammograms.
Lindau et al., 2002 ^28^ | Cross-sectional | Cervical cancer screening practices | REALM | Higher literacy was associated with being more knowledgeable of the purpose of Pap test.
Miller et al., 1996 ^29^ | Cross-sectional | Adequacy of clinical trials information (informed consent) | WRAT | Higher literacy level was moderately correlated with understanding informed consent.
Moon et al., 1998 ^30^ | Prospective cohort | Understanding of medical information and ability to follow therapy prescribed for child | REALM | No correlation between literacy and parental knowledge of health maintenance procedures or child health measures.
Spandorfer et al., 1995 ^31^ | Prospective observational cohort | Emergency department discharge instructions | WRAT | Higher literacy level was associated with comprehension of instructions.
TenHave et al., 1997 ^32^ | Cross-sectional | Heart health knowledge | CARDES | Higher literacy level was associated with greater knowledge of matters relating to use of these health services.
Risk of Hospitalization
Baker et al., 2002 ^24^ | Prospective cohort | Hospitalization | S-TOFHLA | Patients with inadequate literacy were more likely than patients with adequate literacy to be hospitalized.
Baker et al., 1998 ^26^ | Prospective cohort | Hospitalization | TOFHLA | Patients with inadequate literacy were more likely than patients with adequate literacy to be hospitalized.
Physician Visits
Baker et al., 1997 ^25^ | Cross-sectional | Self-reported health and use of health services | TOFHLA | There was no association between literacy status and self-reported access to physician visits after adjusting for age, health status, and economic indicators.
Screening and Prevention
Fortenbury et al., 2001 ^33^ | Cross-sectional | Receipt of a screening for gonorrhea in the past year | REALM | Higher literacy was associated with an increase in the probability of having a gonorrhea test in the past year.
Scott et al., 2002 ^23^ | Cross-sectional | New Medicare enrollees in a national managed care organization preventive care utilization | S-TOFHLA | Patients with inadequate literacy were more likely to have never had a Pap smear or a mammogram in the past 2 years.
| | | | Patients with inadequate literacy were less likely to have had either an influenza or pneumococcal immunization.
Health Outcomes
Knowledge or Comprehension of Outcomes
Arnold et al., 2001 ^34^ | Cross-sectional | Knowledge, attitudes, and practice of tobacco use among pregnant women | REALM | Literacy was a predictor for knowledge of effects of smoking and secondhand smoke.
Conlin and Schumann, 2002 ^35^ | Cross-sectional | Analysis of standard discharge instructions and forms for open heart surgery after recovery from open heart surgery | REALM | Literacy level was correlated with understanding standard discharge instructions and forms.
Gazmararian et al., 1999 ^37^ | Cross-sectional | Family planning knowledge and practices among Medicaid managed care enrollees | S-TOFHLA | Women wanting to know more about birth control were more likely to have low reading skills.
| | | | Incorrect knowledge of “time of month most likely to get pregnant” was higher among women with low reading skills.
Kalichman et al., 2000 ^40^ | Cross-sectional | HIV-infected patients' knowledge and understanding of their status and perceptions of treatment effects on transmission risks | Modified TOFHLA | Lower literacy was associated with not understanding CD4 counts or meaning of viral load. Lower literacy was associated with incorrect beliefs about HIV treatments and transmission risks.
Kalichman and Rompa, 2000 ^38^ | Cross-sectional | Health status awareness and understanding of HIV infection status, disease, and treatment- related knowledge | Modified TOFHLA | Lower literacy was associated with lack of knowledge and understanding of HIV-related health markers.
| | | | Higher literacy group had higher knowledge of HIV disease and treatment than lower literacy group.
| | | | Lower literacy group had more negative perceptions and experiences related to HIV-AIDS.
Kalichman et al., 2000 ^39^ | Cross-sectional | Reliability and validity of self-reported HIV- related health markers in HIV-infected adults | Modified TOFHLA | Lower literacy was more likely to have discrepant self-reported CD4 counts or viral loads.
Miller et al., 2003 ^41^ | Prospective cohort | Dosing and compliance of HIV-infected individuals taking antiretroviral medication | S-TOFHLA | Lower medication knowledge was significantly associated with lower literacy.
Williams et al., 1998 ^42^ | Cross-sectional | Chronic disease and treatment among patients with diabetes or hypertension | TOFHLA | Patients with low literacy had less knowledge about diabetes and hypertension.
Williams et al., 1998 ^43^ | Cross-sectional | Knowledge about asthma | REALM | Knowledge increased with literacy.
Wilson and McLemore, 1997 ^36^ | Cross-sectional | Patients hospitalized for knee or hip surgery “self-care” knowledge after education with written discharge instructions | REALM | The relationship between literacy and self-care knowledge after written education materials was not significant.
Health Behaviors and Adherence
Arnold et al., 2001 ^34^ | Cross-sectional | Knowledge, attitude, and practices of tobacco use among pregnant women | REALM | No difference in the unadjusted rates of smoking according to literacy status.
Davis et al., 1999 ^47^ | Cross-sectional | Violent behavior in adolescents | Slosson Oral Reading Test | Youth who were more than two grades behind expected reading level were more likely than others to carry a weapon including a gun, take a weapon to school, miss school because it was unsafe, and be in a physical fight that required medical treatment.
Frack et al., 1997 ^52^ | Cross-sectional | Compliance with research protocols in a clinical trial | Cloze procedure | Patients who followed up as directed had a higher average literacy score than those who never followed up.
Fredrickson et al., 1995 ^44^ | Cross-sectional | Breast-feeding | WRAT | An association was found between low reading ability and never breast-feeding.
Fredrickson et al., 1995 ^44^ | Cross-sectional | Smoking | WRAT | An association between low reading ability and smoking.
Golin et al, 2002 ^50^ | Prospective cohort | Adherence among HIV-infected patients taking antiretrovirals | S-TOFHLA | No relationship between literacy and adherence was found.
Hawthorne, 1996 ^45^ | Cross-sectional | Tobacco use among 11 and 12 year olds | NR | A relationship between literacy and ever having used tobacco among boys but not among girls. The relationship between literacy and using tobacco in the past month was strong among both boys and girls.
Hawthorne, 1996 ^45^ | Cross-sectional | Alcohol use in adolescence | NR | Odds of having misused alcohol were higher among boys with lower literacy levels than among boys with higher literacy levels. No significant relationship emerged for girls by literacy level.
Kalichman et al., 1999 ^49^ | Cross-sectional | Adherence to treatment for HIV and AIDS | Modified TOFHLA | Lower literacy was associated with greater odds of poor adherence.
Kaufman et al., 2001 ^46^ | Cross-sectional | Breast-feeding | REALM | Women with literacy levels at or above 9th grade were more likely to breast-feed for at least 2 months than mothers with literacy at the 7th or 8th grade level.
Li et al., 2000 ^51^ | Retrospective case study | Adherence to breast conservation therapy in women with early-stage breast cancer | REALM | Literacy did not ignore predict adherence to radiation, chemotherapy, or clinical appointments.
Stanton et al., 1990 ^48^ | Prospective cohort | Problem behavior in children | Burt Word Reading Test | Reading ability was an independent predictor of teacher-reported problem behavior.
Williams et al., 1998 ^43^ | Cross-sectional | Correct use of metered dose inhaler by patients with asthma | REALM | Patients with higher literacy had better metered dose inhaler technique.
Biochemical and Biometric Health Outcomes
Battersby et al., 1993 ^55^ | Case-control | Diagnosis of hypertension | Schonell Graded Word Reading Test | No difference in reading ability between patients with or without hypertension was found.
Kalichman and Rompa, 2000 ^56^ | Cross-sectional | HIV infection | Modified TOFHLA | No significant association between reading comprehension and undetectable viral load.
Kalichman et al., 2000 ^40^ | Cross-sectional | HIV infection, optimism, and perceptions of care | Modified TOFHLA | Patients with better reading comprehension had greater odds of having an undetectable viral load than those with worse reading comprehension. No significant association between reading comprehension and undetectable viral load was found. Patients with lower literacy tended to be more optimistic about their future living with HIV.
Kalichman and Rompa, 2000 ^38^ | Cross-sectional | HIV infection, optimism, and perceptions of care | Modified TOFHLA | Better readers had greater odds of having an undetectable viral load than worse readers. Worse readers had greater odds of having a CD4 count less than 300 than did better readers. Patients with lower literacy had more distrust of providers and were less likely to believe that treatment helps.
Ross et al., 2001 ^53^ | Cross-sectional | Glycemic control in children with type 1 diabetes | WRAT3, children; NART, mothers | No significant correlation between literacy in children aged 5 to 17 and glycemic control. Parent's literacy was correlated with the child's glycemic control.
Schillinger et al., 2002 ^54^ | Cross-sectional | Glycemic control in adults with type 2 diabetes | S-TOFHLA | Patients with lower literacy had worse glycemic control. The glycemic level was found to be inversely related to literacy.
Williams et al., 1998 ^42^ | Cross-sectional | Glycemic control in adults with type 2 diabetes | TOFHLA | Knowledge of diabetes was lower for patients with a low literacy status. No differences were found in the control of diabetes according to literacy status.
Williams et al., 1998 ^42^ | Cross-sectional | Patients diagnosed with hypertension | TOFHLA | Knowledge of hypertension was lower for patients with low literacy status. No differences were found in the control of hypertension according to literacy status.
Measures of Disease Prevalence, Incidence, or Morbidity
Andrasik et al., 1988 ^60^ | Case-control | Children with and without migraines | WRAT | No significant difference in literacy scores between the two groups was found.
Bennett et al., 1998 ^61^ | Cross-sectional | Stage of presentation of prostate cancer | REALM | Men with lower literacy were more likely to present with late-stage prostate cancer than those with higher literacy. After adjusting for race, age, and location of care, the investigators found that the relationship between literacy and stage of presentation was smaller and no longer statistically significant.
Fisch et al., 1998 ^59^ | Cross-sectional | Emotional balance after receiving informed consent materials for a bone marrow transplant | WRAT | No significant relationship between the patterns of affects changes and literacy.
Gazmararian et al., 2000 ^22^ | Cross-sectional | Self-reports of depression in a Medicare population | S-TOFHLA | The odds of being depressed were greater for those people with inadequate literacy compared to those with adequate literacy. After adjusting for demographic, social support, health behavior, and health status factors, the correlation was no longer statistically significant. A significant relationship between literacy and depression could not be observed. No significant relationship was found after adjusting for age and health status.
Gordon et al., 2002 ^58^ | Cross-sectional | Arthritis and functional status of patients with rheumatoid arthritis | REALM | Health activity did not differ according to literacy dichotomized at the 9th grade level.
Gordon et al., 2002 ^58^ | Cross-sectional | Self-report of depression in patients with rheumatoid arthritis | REALM | Patients with more anxiety and depression were greater among those who read below the 9th grade level than among those who read at or above the 9th grade level.
Kalichman and Rompa, 2000 ^56^ | Cross-sectional | Self-reported depression in HIV-infected patients | Modified TOFHLA | Total scores on the depression scales did not differ by literacy status. Some depression subscales were higher (representing more depression) for participants with lower literacy.
TenHave et al., 1997 ^32^ | Cross-sectional | Self-reports of depression in adults participating in a cardio-vascular dietary education program | CARDES | Lower scores on the literacy assessment were statistically significantly associated with higher scores on the depression assessment after adjusting for age, suggesting a greater propensity for depression among those with lower literacy.
Zaslow et al., 2001 ^57^ | Cohort | Mothers' reports of child's depression and antisocial behavior | Test of Applied Literary Skills | Risk of depression was higher among mothers who had lower literacy skills. No relationship was detected between maternal literacy and depression or antisocial behavior among their children.
Global Health Status Measures
Baker et al., 1997 ^25^ | Cross-sectional | Overall health status | TOFHLA | Patients with inadequate literacy had about twice the odds of reporting poor health than patients with adequate literacy.
Gazmararian, et al., 1999 ^7^ | Cross-sectional | Medicare managed care health plan | S-TOFHLA | Patients with inadequate literacy were significantly more likely to self-report fair or poor health than patients with adequate literacy.
Sullivan et al., 1995 ^63^ | Cross-sectional | General health status of patients with type 2 diabetes | QLS | No difference in scores on the SF-36 according to whether the subject “passed” or “failed” the QLS.
Weiss et al., 1992 ^62^ | Cross-sectional | Health status | Tests of Adult Basic Education and Mott Basic Language Skills Program | People with lower literacy scored worse than those with higher literacy on both the physical and psychosocial subcomponents.
Cost of Health Care
Weiss et al., 1994 ^64^ | Retrospective cohort | Costs of health care in Medicaid patients | Instrument for the Diagnosis of Reading | No relationship between literacy and Medicaid charges.
Disparities in Health Outcomes or Use of Health Services
Bennett et al., 1998 ^61^ | Cross-sectional | Men who presented with late-stage prostate cancer | REALM | Black patients were significantly more likely than white patients to present with late-stage cancer. After adjusting for literacy, age, and location of care, the odds ratio was smaller and no longer statistically significant.

Note: REALM, Rapid Estimate of Adult Literacy in Medicine; WRAT, Wide Range Achievement Test; CARDES, Cardiovascular Education Dietary System; TOFHLA, Test of Functional Health Literacy in Adults; S-TOFHLA, Short-TOFHLA; NR, not reported.

Table 6. Summary of studies of interventions to improve health-related outcomes in low literacy populations (KQ 2)

Study | Design | Intervention | Literacy Measure | Results
Use of Health Care Services
Davis et al., 1998 ^73^ | RCT (randomized at the level of appointment day and analyzed at person level) | Combinations of video, verbal recommendation, and brochure. | REALM | The full intervention with video improved mammography rate at 6 months but not at 24 months compared with a verbal recommendation alone or verbal recommendation with a brochure.
Outcomes: Knowledge and Comprehension
Coleman et al., 2003 ^72^ | Non-RCT | Educational materials on breast cancer self-examination for African-American women using versions with drawings or photographs. | None | Women using both versions had increased knowledge of breast cancer screening, confidence in breast self-examination, and performance scores when practicing with silicone models. However, women who had the photographic version had higher rates of finding lumps in the silicone breast models.
Davis et al., 1996 ^74^ | Non-RCT | Specially prepared lower grade level parent educational pamphlet with instructional graphics about polio vaccine and standard pamphlet. | REALM | Comprehension was better and time needed to read was less for the lower grade level pamphlet than for the standard pamphlet for all but persons in the lowest literacy level.
Davis et al., 1998 ^91^ | RCT | Two low-literacy pamphlets (6th grade level) for parents on polio vaccine, one with instructional graphics and one without. | REALM | Parents preferred the pamphlet with graphics over the one without and scored higher comprehension with it as well.
Davis et al., 1998 ^75^ | Non-RCT | Special low-literacy consent form (7th grade level) and standard consent form (16th grade level) for participation in clinical cancer research studies. | REALM | Participants preferred the lower grade level version of the consent form. Participants with a lower literacy level more heavily preferred the lower grade level version. There was no difference, however, between the two forms in participant comprehension.
Eaton and Holloway, 1980 ^76^ | RCT | Standard educational materials on warfarin (10th grade level) and simplified materials (5th grade level). | Adult Basic Learning Examination | Patient knowledge of warfarin was higher with higher literacy and with simplified materials.
Kim et al., 2001 ^84^ | Posttest only | A specially designed CD-ROM educational program given to men newly diagnosed with prostate cancer. | REALM | Knowledge of prostate cancer varied greatly, and greater knowledge was associated with higher literacy as measured by the REALM. Typically preferences for treatment made after using the CD-ROM but before conferring with the physician were quite different from the treatment actually received after conferring with the physician.
Meade et al., 1994 ^92^ | RCT | Simply written brochure, a videotape (with similar contents) about colorectal cancer, and no educational intervention. | WRAT | Printed and videotaped materials were equally effective in increasing knowledge and recall of colon cancer information and more effective than no educational intervention. Similar results regardless of literacy level.
Michielutte et al., 1992 ^90^ | RCT | Two cervical cancer information brochures: one used two-color illustrated, narrative text (SMOG grade level 8.4); the second used simple, bulleted text with no illustrations (SMOG grade level 7.7). | WRAT-R, (adapted for this study) | The two-color illustrated brochure with narrative text increased the comprehension level among low-literacy women as compared to the bulleted text with no illustrations. High-literacy women had similar comprehension regardless of brochure.
Murphy et al., 2000 ^89^ | Non-RCT | A 13-minute sleep apnea video written at 12th grade level and a brochure written at the 12th grade level. | REALM | Video improved two areas of knowledge for low-level readers as compared to the brochure and only improved one area of knowledge among high-level readers.
Powell et al., 2000 ^71^ | Non-RCT | Special low-literacy injury prevention information sheet (using drawings) and standard injury prevention sheet. | None | Most parents recall receiving printed information about injury prevention at a child's clinic visit when asked several weeks later; however, their recall of specific information on injury prevention was limited and no better in the group receiving the special information sheet with pictorials.
Raymond et al., 2002 ^88^ | Posttest only | Prototype package insert for emergency contraceptive pills. | REALM | Most women participants were able to understand the key information for safe and effective use of the drug. However, less literate women were less likely to understand the information to meet most of the educational objectives of the insert than more literate women.
Wydra, 2001 ^93^ | RCT | An interactive videodisc designed to help cancer patients improve self-care of illness-related fatigue. | WRAT3 | Patients who used the videodisc had greater improvement in self-care ability than those who did not use it, and they received more education and covered more content. They also reported less fatigue and making fewer changes in routine due to fatigue. Similar results regardless of literacy level.
Outcomes: Health Behaviors
Bill-Harvey et al., 1989 ^69^ | Separate sample pretest/posttest | Special 10-hour educational intervention (SMOG grade level 8) administered by community members designed for low-literacy patients with osteoarthritis. | None | The intervention group had increased knowledge, greater exercise behavior, and improved attitude.
Gans et al., 1998 ^78^ | Pretest/posttest | Special CD and picture food book developed for low-literacy persons to improve diet and reduce blood cholesterol. | None | Preliminary data indicate that persons exposed to the intervention achieved reductions in dietary fat intake in the 3 months after exposure to the intervention.
Hartman et al., 1997 ^79^ | RCT | Diet/nutrition intervention designed for low-literacy patients to change low-fat eating pattern and standard nutrition education materials. | Adult Basic Learning Examination, Level II | The low-fat intervention was associated with improvements in eating behaviors related to substituting low-fat for high-fat foods and with overall low-fat eating behavior.
Howard-Pitney et al., 1997 ^81^ | RCT (randomized at the classroom level and analyzed at individual level) | Special nutrition education program (six 90-minute sessions and 12-week maintenance sessions) focusing on lowering dietary fat intake and the usual nutrition education focusing on general nutrition in a low-literacy population (66% at 8th grade level or below). | WRAT | Intervention group showed greater improvement on nutrition knowledge, attitudes toward eating a low-fat diet, and self-efficacy for achieving a low-fat diet.
Hussey, 1994 ^82^ | Non-RCT | Verbal teaching to elderly patients about medications with or without a color-coded medication schedule. | Comprehension Subtest of Gates-MacGinitie Reading Test | Knowledge in both groups of patients increased, but compliance to medication schedule improved more among those in the color-coded intervention group overall and especially among those who had initial low compliance.
Lillington et al., 1995 ^67^ | RCT (randomized at clinic level but analyzed at individual level) | Pregnant smokers and ex-smokers received specially designed, culturally appropriate materials on smoking cessation written at 3rd grade level that included one-on-one counseling, a self-help guide, booster postcards, and an incentive contest, or just standard materials. | None | The special materials intervention was more effective than the standard materials in achieving higher quit rates during pregnancy among baseline smokers, and lower relapse rates 6 weeks postpartum among baseline ex-smokers.
Murphy et al., 1996 ^86^ | Non-RCT | African-American adult basic education class participants at or below 6th grade reading level in a specially designed 8-hour intervention to improve dietary behaviors. | REALM | The intervention increased knowledge of food measurements and portion sizes.
Outcomes: Biochemical or Biometric Markers
Fouad et al.,1997 ^70^ | Non-RCT | Year-long worksite antihypertension educational intervention designed for low-literacy workers. | None | Intervention participants who were unskilled showed a drop in their systolic and diastolic blood pressures.
Kumanyika et al., 1999 ^85^ | RCT | A cardiovascular nutrition education program for African-Americans with elevated cholesterol or high blood pressure (four monthly classes in addition to food pictures, video and audio recordings, and written nutrition guide with pictures given to both full intervention and self-help groups). | Specially designed scale | Total cholesterol and low density lipoprotein cholesterol decreased in both groups. Blood pressure (systolic and diastolic) improved for persons with initial elevated blood pressure in both groups.
Mulrow et al., 1987 ^66^ | RCT | Monthly educational sessions about diabetes knowledge (with or without videotapes) over 11 months versus a single session. | None | After 7 months, the intervention with the videotapes resulted in greater weight loss than the intervention without videotapes or the one-time education session. The weight loss was not sustained at the 11-month followup.
Outcomes: Disease-Related Functional Status
Poresky and Daniels, 2001 ^68^ | RCT | Comprehensive family services center versus a standard Head Start program. | Comprehensive Adult Student Assessment Scale | Overall family well-being increased in the comprehensive service center group—higher income, increased literacy, and decreased parents with high depression scores.
Costs
None Identified | — | — | — | —
Disparities in Health Outcomes or Use of Health Services
Fitzgibbon et al., 1996 ^77^ | RCT | Twelve-week culture-specific dietary intervention for Hispanic families (mothers were attending literacy program). | None | Mothers in the intervention group reduced their percent fat and saturated fat intake. There was no change in the control group.
Hayes, 1998 ^80^ | RCT | A “geragogy-based” intervention (large print, easy to read, organized for elderly) for medication instruction or usual approach to discharge from emergency departments. | REALM | The group of persons discharged and receiving the geragogy-based medication instruction had more knowledge of medications than those who got the standard discharge.
Hugo and Skibbe, 1991 ^65^ | Posttest only | Low-literacy South African population's ability to identify content on breast-feeding from color or black and white images. | None | Most women expressed a preference for breast-feeding after exposure to the intervention. In addition, women were more able to understand the instructions conveyed in the color photographs than in the black and white one.
Jacobson et al., 1999 ^83^ | RCT | A low-literacy one-page handout on pneumococcal vaccination and a one-page low-literacy handout on nutrition used in conjunction with a patient-physician dialogue. | None | Group receiving the pneumococcal handout had more discussions about it with their physician and were more likely to receive the immunization than group receiving handout on nutrition.
Pepe and Chodzko-Zajko, 1997 ^87^ | Single sample pre-test/posttest | A cholesterol education video delivered at 2 week followup visit for low-literacy seniors. | REALM | After viewing the video and 1 month later, participants had greater knowledge of cholesterol and cardiovascular disease. However, knowledge was associated with literacy as measured by the REALM.

Note: RCT, randomized controlled trials; REALM, Rapid Estimate of Adult Literacy in Medicine; WRAT, Wide Range Achievement Test; WRAT-R, WRAT-Revised; SMOG, a readability formula.

## Results of Literature Search

The literature search yielded 3,868 articles (3,015 unduplicated) (Table 4). Of these, we excluded 2,330 articles after reviewing the abstracts and pulled 684 articles for complete review. In addition to the database search, we solicited articles from Web-based bibliographies, the TEAG, and other experts in the field of health literacy; these sources provided 265 articles (within the total 3,015), of which 25 were not identified in our database searches and warranted full article review. Across all 684 articles retained for full article review, we included in our evidence report 67 articles found in MEDLINE, 5 articles from other databases, and 1 article suggested by our TEAG or other experts, totaling 73 articles in all. Of these, 44 address KQ 1 and 29 address KQ 2.

## Key Question 1: Relationship of Literacy to Various Outcomes and Disparities

### Literature Search and Included Studies

We identified 44 articles describing results that address the relationship between literacy and use of health care services, health outcomes, and costs of health care, as well as results limited to specific racial, ethnic, cultural, or age groups. Figure 2 shows the accumulation of studies by year for KQ 1 and 2. We found that the accumulated number of studies began to increase substantially around 1995, implying an increase in research projects beginning several years earlier. Of the total, 4 articles concern various study results from a cohort of patients enrolled in a Prudential Medicare Managed Care program. ^7,^ ^22–24^ Two articles present results based on data from a cohort of patients receiving services at Grady Hospital in Atlanta, Georgia, and Harbor-UCLA Medical Center in Los Angeles, CA. ^25,^ ^26^ Study designs included cross-sectional (32), cohort (9), case-control (2), and retrospective case series (1).

Figure 2. Cumulative number of articles addressing KQ 1 and KQ 2 by year of publication

Note: Appendixes and Evidence Tables cited in this report are provided electronically at http://www.ahrq.gov/clinic/epcindex.htm

Disadvantages of a cross-sectional study design include the inability to measure incident outcomes and to assign cause and effect. However, when cross-sectional studies measure literacy, we can often safely assume that the same level of literacy predated the health outcome. This assumption, although obviously not true in children, may also not necessarily apply to elderly adults, in whom literacy levels may change over time. Additionally, medical illness may affect literacy more profoundly in these groups than in nonelderly adults.

Data analysis and presentation varied widely across the studies. Most studies reported the unadjusted (bivariate) relationship between literacy and the health-related outcome of interest. Twenty-eight of the 44 articles discussed the relationship between literacy and the health-related outcome after adjusting for at least one covariate. The most common covariate included in models was age, followed by education (13 articles). Most studies descriptively presented information on the participants' age, ethnicity, and education levels; about half included information on participants' income level. Less than half of the models adjusted for race or ethnicity; even less common were adjustments for income, insurance status, and health status. Sixteen studies included descriptive information about the participants' insurance status, but only 4 included insurance in a multivariate analysis.

The number of participants enrolled ranged from 34 to 3,260. In studies with relatively few participants, point estimates of the relationship between literacy and the outcome had large confidence intervals. Because of a lack of statistical power in these circumstances, relationships between literacy and outcomes may remain unrecognized. We present 95 percent confidence intervals when available or calculable rather than simple statements about statistical significance so the reader can observe where this may have been a concern.

Table 7 groups KQ 1 studies based on the literacy measurement tool used in the analysis and, further, the levels used to separate study participants. We found that literacy was most often measured with the REALM (12 studies), the TOFHLA or S-TOFHLA (16 studies), or the WRAT (6 studies). Within these groups, the literacy levels used to compare study participants varied widely among studies.

Table 7. Measurement tools and criteria used to measure literacy in KQ 1 articles

Study | Measurement Tool | Literacy Measurement Levels
Stanton et al., 1990 ^48^ | Burt Word Reading Test, 1974 Revision | NR
TenHave et al., 1997 ^32^ | CARDES (developed for this study) | < 5th grade
| | 5th to 8th grade
| | > 8th grade
Frack et al., 1997 ^52^ | Cloze procedure measured Spanish-language literacy | Mean
Weiss et al., 1994 ^64^ | Instrument for the Diagnosis of Reading (IDL) | Grade equivalent: 0 through = 8th grade
Kalichman and Rompa, 2000 ^38^ | Modified TOFHLA reading comprehension section | “Lower health literacy”
| | “Higher health literacy”
| | Cut-off for higher health literacy at 80% correct on TOFHLA subtest
Hawthorne, 1996 ^45^ | NR | Low, middle, high
Sullivan et al., 1995 ^63^ | Questionnaire Literacy Screen (QLS) | Pass: all answers correct
| | Fail
Arnold et al., 2001 ^34^ | REALM | = 3rd grade
Conlin and Schumann, 2002 ^35^ | | 4th to 6th grade
Davis et al., 1996 ^27^ | | 7th to 8th grade
Gordon et al, 2002 ^58^ | | = 9th grade
Moon et al., 1998 ^30^
Williams et al., 1998 ^43^
Wilson and McLemore, 1997 ^36^
Li et al., 2000 ^51^ | REALM | 4th to 6th grade
| | 7th to 8th grade
| | = 9th grade
Bennett et al., 1998 ^61^ | REALM | = 6th grade
| | > 6th grade
Fortenberry et al., 2001 ^33^ | REALM | < 9th grade
Kaufman et al., 2001 ^46^ | | = 9th grade or higher
Lindau et al., 2002 ^28^
Battersby et al., 1993 ^55^ | Schonell Graded Word Reading Test | Mean
Schillinger et al., 2002 ^54^ | S-TOFHLA, English or Spanish version | Inadequate
Scott et al., 2002 ^23^ | | Marginal
| | Adequate
Davis et al., 1999 ^47^ | Slosson Oral Reading Test, Revised | Reading level 2 or more grade levels behind (referred to as low reading level)
Gazmararian et al., 1999 ^37^ | S-TOFHLA | Low, good
Golin et al., 2002 ^50^ | S-TOFHLA | 36-point scale
Baker et al., 2002 ^24^ | S-TOFHLA | Inadequate
Gazmararian et al., 1999 ^7^ | | Marginal
Gazmararian et al., 2000 ^22^ | | Adequate
Miller et al., 2003 ^41^ | S-TOFHLA | Mean
Weiss et al., 1992 ^62^ | Tests of Adult Basic | = 4th grade
| Education and Mott Basic | 5th to 6th grade
| Language Skills Program | 7th to 8th grade
| | = 9th grade
Zaslow et al., 2001 ^57^ | Test of Applied Literacy Skills (TALS), developed by Educational Testing Service | 5 levels
| | Levels 1 to 2 considered low literacy
Baker et al., 1997 ^25^ | TOFHLA | Adequate
Baker et al., 1998 ^26^ | | Marginal
Williams et al., 1998 ^42^ | | Inadequate
Kalichman et al., 1999 ^49^ | TOFHLA reading comprehension section only | Lower literacy: score below 85% correct
Kalichman et al., 2000 ^39^ | | Higher literacy: score 86% correct or higher
Kalichman and Rompa, 2000 ^56^
Kalichman et al., 2000 ^40^ | TOFHLA reading comprehension section only | Lower literacy: score below 80% correct
| | Higher literacy: score 80% correct or higher
Andrasik et al., 1988 ^60^ | WRAT | NR
Fredrickson et al., 1995 ^44^ | WRAT | < 4th grade
| | 4th to 5th grade
| | 6th to 7th grade
| | 8th to 10th grade
| | 11th to 12th grade
| | 13+ grade
Fisch et al., 1998 ^59^ | WRAT | Mean
Miller et al., 1996 ^29^
Spandorfer et al., 1995 ^31^
Ross et al., 2001 ^53^ | WRAT3 (children) | WRAT3: mean
| NART (mothers) | NART: mean

Note: NA, not applicable; NR, not reported; TOFLA, Test of Functional Health Literacy in Adults; S-TOFHLA, Short TOFHLA; CARDES, Cardiovasular Dietary Education System: WRAT, Wide Range Achievement Test; WRAT3, Wide Range Achievement Test, 3rd edition; NART, National Adult Reading Test.

### Use of Health Care Services

KQ 1a concerned the relationship between low literacy skills and the use of health care services (Evidence Table 1). Studies in this review focused on the association between literacy and knowledge of health care services, the risk of hospitalization, physician visits, and screening and prevention.

Knowledge of Health Care Services. Six studies measured the relationship between literacy levels and knowledge of the use of health care services (Table 8). ^27–32^ They measured knowledge or comprehension of mammography, ^27^ cervical cancer screening, ^28^ informed consent, ^29^ childhood health maintenance procedures and parental understanding of child diagnosis and medication, ^30^ emergency department discharge instructions, ^31^ and “Heart Health Knowledge.” ^32^ With the exception of the Moon et al. ^30^ study, all these investigations demonstrated a statistically significant association between higher literacy level and knowledge of matters relating to use of these health services.

Table 8. Studies of knowledge or comprehension of health service use (KQ 1a)

Study | Population | Results
Davis et al., 1996 ^27^ | Low-income women at an ambulatory clinic at Louisiana State University at Shreveport | Lower literacy correlated with lower knowledge about mammograms (adjusted)
Lindau et al., 2002 ^28^ | Women in women's health clinics at an academic medical center in Chicago, predominantly Medicaid insurance | Higher literacy associated with more knowledge about cervical cancer screening (adjusted)
Miller et al., 1996 ^29^ | Participants enrolling in anti-infective clinical trials | Moderate correlation between literacy and understanding of informed consent (unadjusted)
Moon et al., 1998 ^30^ | Parents of children in urban and suburban pediatric practices in Washington, DC | No correlation between literacy and parental knowledge of health maintenance procedures or child health measures (adjusted)
Spandorfer et al., 1995 ^31^ | Impoverished inner-city patients at an emergency department in Philadelphia | Reading ability was best predictor of knowledge of discharge instructions (adjusted)
TenHave et al., 1997 ^32^ | Community members coming to a cholesterol screening at a local supermarket | Higher literacy associated with more “Heart Healthy Knowledge” (P value not reported) (unadjusted)

Hospitalization. Two studies prospectively evaluated the risk of hospitalization according to literacy status. ^24,^ ^26^ In both, adjusted (multivariate) analyses showed that a lower literacy level was significantly associated with increased risk of hospitalization. In a study done in a public hospital, Baker et al. ^26^ compared the effects of literacy and education on the odds of being hospitalized over a 1-year period. The odds of hospitalization were 1.69 higher (95% confidence interval [CI] 1.13, 2.53) for patients with inadequate literacy than for patients with adequate literacy on the TOFHLA, after adjusting for age, sex, race, health status, receiving financial assistance, and health insurance but not education. No significant differences were found between patients with marginal literacy and those with adequate literacy. Adjusted models controlling for years of education instead of literacy yielded no significant differences in risk of hospitalization.

In a second study among patients aged 65 and older enrolled in Medicare managed care plans, the odds of being hospitalized were 1.29 times higher (95% CI 1.07, 1.55) for patients with inadequate literacy than for patients with adequate literacy after adjusting for age, sex, race/ethnicity, language, income, and educational status. ^24^ People with marginal or adequate literacy did not differ significantly in the odds of being hospitalized.

Physician Visits. The one study examining the relationship between literacy and number of health care visits used self-reported visit data. Baker et al. ^25^ asked 2,659 patients about their number of physician visits in the past 3 months, presence of regular source of care, and whether they had received needed medical care during the past 3 months. After adjusting for confounders (age, health status, and economic indicators, which were proxies for income), they found no significant relationship between literacy status measured by the TOFHLA and self-reported access to physician visits. However, these subjects had been recruited from emergency rooms and walk-in clinics and may represent only the population that has accessed the health care system in those ways. We cannot assume that the lack of relationship between literacy and physician visits generalizes to the population as a whole, which would include those who have not needed medical care in the recent past and those seen in private physician offices.

Screening and Prevention. Two studies dealt with the relationship between literacy levels and three measures of health promotion and disease prevention interventions (screening for sexually transmitted diseases, cancer, and immunizations). ^23,^ ^33^

Sexually Transmitted Disease Screening. Fortenberry et al. ^33^ found a positive relationship between literacy and screening for gonorrhea. Patients were selected from clinical and nonclinical sites in four cities around the country. Literacy assessments were incomplete for many of the patients; thus, to control for potential selection bias, the researchers estimated a two-stage model. Controlling for incomplete data and several patient characteristics, including insurance status and suspected infection, a reading level at or above the ninth grade was associated with a 10 percent increase in the probability of having a gonorrhea test in the past year.

Cancer Screening. Scott et al. ^23^ evaluated cancer screening rates by measuring the percentage of women who had never had a Pap smear or had not had a mammogram in the past 2 years. Participants in the study were 65 years of age and older and new enrollees in a Medicare managed care health plan. Adjusted (multivariate) analyses controlling for age, race, education, and income produced mixed results. Compared with patients with adequate literacy, patients with inadequate literacy had greater odds of never having had a Pap smear (odds ratio [OR] 1.7; 95% CI 1.0, 3.1) and greater odds of not having had a mammogram in the past 2 years (OR 1.5; 95% CI 1.0, 2.2). However, women who had marginal literacy (between inadequate and adequate) had even greater odds of never having had a Pap smear than women with adequate literacy (OR 2.4; 95% CI 1.2, 4.7) or inadequate literacy. In contrast, their odds of never having had a mammogram were no different than the odds of women with adequate literacy.

Immunization. The study of cancer screening also evaluated the relationship between literacy and adult immunization. ^23^ The authors evaluated the odds of patients having received selected preventive health services. In an adjusted analysis controlling for age, sex, race, education, and income, patients with inadequate literacy had 1.4 (95% CI 1.1, 1.9) times the odds of not having had an influenza immunization and 1.3 (95% CI 1.1, 1.7) times the odds of not having had a pneumococcal immunization compared with patients with adequate literacy. Those with marginal and adequate literacy did not differ significantly in these measures.

### Health Outcomes

KQ 1b concerns the relationship between low literacy and health outcomes (Evidence Table 1). The articles reviewed include those concerning knowledge or comprehension as an outcome in and of itself, health behavior and adherence, and measures of disease prevalence, incidence, or morbidity.

Knowledge or Comprehension as an Outcome. Ten studies used knowledge either as one of several outcomes or as the only outcome (Table 9). These studies measured knowledge about smoking, ^34^ postoperative care, ^35,^ ^36^ contraception, ^37^ human immunodeficiency virus (HIV), ^38–41^ hypertension, ^42^ diabetes, ^42^ and asthma. ^43^ In general, these studies found a positive, significant relationship between literacy level and participants' knowledge of these health issues. All but 3 adjusted for covariates. The only study that did not demonstrate a statistically significant higher knowledge score with higher literacy level included a bivariate (unadjusted) analysis concerning knowledge about self-care after discharge following orthopedic surgery. ^36^

Table 9. Studies of knowledge or comprehension of health outcomes (KQ 1b)

Study | Population | Results
Arnold et al., 2001 ^34^ | Predominantly Medicaid or uninsured pregnant women | Low literacy predicted lower knowledge about smoking effects (adjusted)
Conlin and Schumann, 2002 ^35^ | Patients recovering from open heart surgery at a teaching hospital | Lower literacy correlated with lower score on knowledge test of discharge instructions (unadjusted)
Gazmararian et al., 1999 ^37^ | Female Medicaid managed care enrollees in Memphis, Tennessee | Lower literacy associated with less knowledge of time most likely to get pregnant during menstrual cycle (adjusted)
Kalichman et al., 2000 ^40^ | HIV-infected individuals living in Atlanta, Georgia | Higher literacy associated with higher likelihood of understanding the meaning of the CD4 count or viral load (adjusted)
Kalichman and Rompa, 2000 ^38^ | HIV-infected individuals living in Atlanta, Georgia | Lower literacy associated with less understanding of meaning of CD4 counts and viral load; lower literacy associated with less knowledge of disease and treatment based on 14-item questionnaire (adjusted)
Kalichman et al., 2000 ^39^ | HIV-infected individuals living in Atlanta, Georgia | Higher literacy associated with knowledge of CD4 counts and viral load (adjusted)
Miller et al., 2003 ^41^ | HIV-infected patients in a public hospital affiliated clinic | Literacy associated with knowledge of antiretroviral medication (unadjusted)
Williams et al., 1998 ^42^ | Patients with diabetes or hypertension attending a primary care clinic at a public hospital in Los Angeles or Atlanta | Higher literacy associated with more knowledge about hypertension and diabetes (adjusted)
Williams et al., 1998 ^43^ | Adult asthma patients in the emergency department at Grady Memorial Hospital | Higher literacy associated with more asthma knowledge (adjusted)
Wilson and McLemore, 1997 ^36^ | Patients hospitalized for knee or hip surgery | No correlation between literacy level and patients' level of knowledge about self-care after receiving written education materials (unadjusted)

Health Behaviors and Adherence. Studies concerned with literacy levels and health behaviors of various sorts centered on smoking, alcohol use, breast-feeding, asthma, problematic behaviors among children, and general ideas of adherence to health care regimens and recommendations.

Smoking. Three studies evaluated the relationship between literacy and smoking. ^34,^ ^44,^ ^45^ The objective of the largest study, by Hawthorne ^45^ (n = 3,019), was to identify predictors of early adolescent drug use, including smoking, among students in Australia. The study categorized students into low, middle, or high levels of literacy (the literacy assessment instrument and category divisions were unstated) and looked at the relationship between literacy and whether a student self-reported ever using tobacco or using tobacco in the past month. An adjusted analysis revealed a significant relationship between literacy (low literacy vs. high literacy) (OR 1.7; 95% CI 1.1, 2.7) and ever having used tobacco among boys but no significant relationship among girls. By contrast, the relationship between literacy and using tobacco in the past month was stronger than “ever used” and significant among both boys and girls.

Fredrickson et al. ^44^ selected adults waiting for child-related services in private and public clinics in Wichita, Kansas. They reported a significant (P < 0.05) unadjusted association between low reading ability (measure unspecified) and smoking, but they did not specify the magnitude of the association or adjust for confounders. Arnold et al. ^34^ also evaluated the relationship between literacy and smoking practices among 600 pregnant women. They found no difference in the unadjusted rates of smoking according to literacy status.

Alcohol use in Adolescence. Hawthorne ^45^ evaluated the relationship between literacy level in adolescents and alcohol use. Although the odds of ever having used alcohol were not different according to literacy status, the odds of having misused alcohol were higher among boys with lower literacy levels than among boys with higher literacy levels (OR 2.6; 95% CI 1.4, 4.8). No significant relationship emerged for girls by literacy level (OR 2.1; 95% CI 0.8, 5.5).

Breast-feeding. Two unadjusted cross-sectional studies evaluated the relationship between literacy and breast-feeding, ^44,^ ^46^ and both found a positive significant relationship. Kaufman et al. ^46^ studied 61 new mothers in Albuquerque, New Mexico, and reported that those with literacy levels at or above ninth grade were more likely to breast-feed for at least 2 months than mothers with literacy at the seventh or eighth grade level (54% vs. 23%, P = 0.018). Fredrickson et al. ^44^ conducted a much larger study (646 mothers) and found a significant association (P < 0.05) between low reading ability (not specified) and never breast-feeding.

Asthma. Williams et al. ^43^ studied the relationship between literacy and correct metered dose inhaler (MDI) technique in a cross-sectional study of 469 patients. Patients with higher literacy had better MDI technique based on measuring the number of steps performed correctly after adjusting for education and whether the patient had a regular source of care (difference in number of correct steps out of six steps = 1.3 steps; 95% CI 0.9, 1.7).

Problem Behavior in Children. One cross-sectional study of 386 adolescents from low-income neighborhoods evaluated the relationship between literacy and behavior; ^47^ another cohort study of 779 children born in one hospital in New Zealand evaluated the relationship between reading ability and “problem behaviors” in younger children. ^48^ After controlling for age, race, and sex, youth who were more than two grades behind expected reading level based on the Slosson Oral Reading Test were more likely than others to carry a weapon including a gun, take a weapon to school, miss school because it was unsafe, and be in a physical fight that required medical treatment. ^47^ Stanton et al. ^48^ found that reading ability was an independent predictor of teacher-reported problem behavior, even after adjustment for early problem behavior and family adversity. They also demonstrated that reading ability was lower at higher levels of family adversity.

Adherence. Four studies evaluated the relationship between literacy and adherence; ^49–52^ three found no significant relationship. Two studies measured adherence among patients taking antiretrovirals for HIV infection using quite different study designs. Golin et al. ^50^ measured adherence over 48 weeks using electronic bottle caps, pill counts, and self-reports among 117 patients in a university HIV clinic using a prospective cohort design. In an unadjusted analysis, they did not find a relationship between literacy and adherence (r = -0.01, P = 0.88). By contrast, Kalichman et al. ^49^ studied 184 patients in an HIV clinic using a cross-sectional study design. After adjusting for race, income, social support, and education, they found that lower literacy was associated with a greater odds of poor adherence (OR 3.9; 95% CI 1.1, 13.4), defined as recall of missing any dose during the previous 48 hours. The more rigorous prospective longitudinal design used by Golin et al. included objective quantification of adherence, while the cross-sectional study by Kalichman et al. relied on patient recall of adherence.

Li et al. ^51^ evaluated adherence to breast conservation therapy among a small sample of 55 low-income women with early-stage breast cancer. In an unadjusted analysis, literacy did not significantly predict adherence to radiation, chemotherapy, or clinical appointments; overall, only 36 percent of patients had full adherence.

Frack et al. ^52^ evaluated several factors associated with compliance with research protocols among Latino participants in a clinical trial. Spanish literacy was measured using the Cloze procedure. (Every fifth to seventh word was deleted from a text, and the subject was asked to fill in the missing words. A literacy score was then assigned based on the percentage correct). The patients who followed up as directed had a higher average literacy score than those who never followed up (P < 0.05 for the unadjusted difference).

Biochemical and Biometric Health Outcomes. Eight studies targeted questions about the relationship between literacy and health outcomes measured with clinical laboratory tests for diabetes, hypertension, and HIV infection.

Diabetes. Three studies assessed the relationship between literacy and diabetes outcomes. ^42,^ ^53,^ ^54^ Ross and colleagues ^53^ evaluated glycemic control, measured by glycosylated hemoglobin (HbA1c), in children with type 1 diabetes mellitus and its relationship to the child's and the parent's literacy using a cross-sectional design. They found no significant unadjusted correlation between WRAT scores for children aged 5 to 17 and glycemic control (r = 0.1). However, the parent's score on the National Adult Reading Test (NART) was correlated with the child's glycemic control (r = 0.28; P = 0.01) and, in a model adjusted for age and sex of the child, duration of diabetes, daily insulin dose, child literacy score, and social class, the NART score continued to be a significant predictor.

Both Williams et al. ^42^ and Schillinger et al. ^54^ evaluated the relationship between patient literacy and HbA1c in adults with type 2 diabetes mellitus using a cross-sectional study design. The Williams et al. study was designed primarily to look at diabetes-related knowledge. HbA1c values were available for only 55 patients (48% of the sample). Average HbA1c levels were higher (representing worse glycemic control) among those with inadequate literacy than among those with adequate literacy on the TOFHLA, but the unadjusted difference was not statistically significant (8.3% vs. 7.5%, P = 0.16).

The main aim of the Schillinger et al. ^54^ study was to measure the relationship between literacy and glycemic control among 408 patients from a public hospital internal medicine or family practice clinic. Patients with lower literacy appeared to have worse glycemic control. Among patients with inadequate literacy on the S-TOFHLA (n = 156), 20 percent had “tight” glycemic control (HbA1c < 7.2), compared with 33 percent of those with adequate literacy (n = 198) (adjusted OR 0.57; P = 0.05). After controlling for age, race/ethnicity, sex, education, language, insurance, depressive symptoms, social support, receipt of diabetes education, treatment regimen, and years with diabetes, the HbA1c level was found to be inversely related to the S-TOFHLA score (the HbA1c increased by 2 percent for every 1 point decrease in the S-TOFHLA score).

Schillinger et al. ^54^ also evaluated the relationship between literacy and self-reported diabetes complications. In adjusted models, patients with inadequate literacy were more likely than those with adequate literacy to report retinopathy (OR 2.33; 95% CI 1.2, 4.6) and cerebrovascular disease (OR 2.71; 95% CI 1.1, 7.0). Lower extremity amputation (OR 2.48; 95% CI 0.74, 8.3), nephropathy (OR 1.71; 95% CI 0.75, 3.9), and ischemic heart disease (OR 1.73; 95% CI 0.83, 3.6), were more common among patients with inadequate literacy, but differences were not statistically significant. This may be related to the sample size and the rarity of these events.

Hypertension. Two studies ^42,^ ^55^ evaluated the relationship between literacy and hypertension, but neither identified an independent relationship between literacy and presence or control of hypertension. Williams et al. ^42^ performed a cross-sectional study in two public hospitals among patients diagnosed with hypertension. In a bivariate comparison, they found that patients with inadequate literacy, measured by the TOFHLA, had higher systolic blood pressures than those with adequate literacy (155 mm Hg vs. 147 mm Hg, P = 0.04, n = 408). However, after adjusting for age, the difference was no longer significant.

Battersby et al. ^55^ performed a case-control study to compare literacy of patients with a diagnosis of hypertension to age-, race-, and sex-matched controls without hypertension (n = 180). They did not find a statistically significant difference in reading ability between patients with or without hypertension (Schonell Graded Word Reading Test: cases 78.4, controls 81.3).

HIV Infection. The relationship between literacy and control of HIV infection has been reported in three cross-sectional studies. ^38,^ ^40,^ ^56^ All studies were conducted by the same research group and enrolled patients from an HIV-positive population in Atlanta, Georgia. Each study was conducted independently, but about 60 percent of the patients participated in all three studies (S. Kalichman, personal communication, May 2003). Each study measured literacy using a modified TOFHLA and dichotomized literacy into high and low levels (an approach that differs from the recommended cut-offs of inadequate, marginal, and adequate literacy). In these studies, the cut-off between lower and higher literacy was set at getting 85 percent correct on the reading comprehension section of the TOFHLA, which is well into the adequate literacy level using the standard TOFHLA categories; hence, some patients categorized as low literacy in these studies would be categorized as adequate on the conventional TOFHLA. None of these studies adjusted for potential confounders in their analyses; as a whole, they found mixed results.

One study found that patients with better reading comprehension had 2.9 (95% CI 1.1, 8.1) times the odds of having an undetectable viral load than those with worse reading comprehension. ^40^ Another study showed that better readers had 6.2 (95% CI 2.1, 18.5) times the odds of having an undetectable viral load than worse readers. ^38^ In addition, worse readers had 2.3 (95% CI 1.1, 5.1) times the odds of having a CD4 count less than 300 than did better readers. The third study found no significant association between reading comprehension and undetectable viral load. ^56^ Given these conflicting results, drawing definite conclusions regarding HIV infection markers and reading comprehension is difficult.

Kalichman et al. ^38,^ ^40^ also measured the associations between literacy and optimism and perceptions of care. After controlling for education, the research team found that patients with lower literacy tended to be more optimistic about their future living with HIV ^40^ but had more distrust of providers and were less likely to believe that treatment helps. ^38^

Measures of Disease Prevalence, Incidence, or Morbidity. Several studies examined the association between literacy and a variety of disease-specific measures relating to depression, asthma, cancer, and migraine.

Depression or Other Emotional Conditions. Five studies evaluating the relationship between literacy and depression yielded mixed results (Table 10). ^22,^ ^32,^ ^56–58^ All of these studies used self-report questionnaires to measure depression; two evaluated depression in the context of specific chronic diseases (rheumatoid arthritis ^58^ and HIV infection ^56^ ).

Table 10. Studies of the relationship between literacy and depression (KQ 1b)

Study | Population | Results
Gazmararian et al., 2000 ^22^ | Elderly persons without dementia in a Medicare health plan | Marginal literacy associated with lower rate of depression (adjusted)
TenHave et al., 1997 ^32^ | Mostly black middle-aged and elderly persons attending a supermarket cholesterol screening | Lower literacy associated with higher depression scores (adjusted)
Kalichman and Rompa, 2000 ^56^ | Mostly black middle-aged HIV-positive patients | Lower literacy associated with more symptoms of depression (unadjusted)
Gordon et al., 2002 ^58^ | Mostly white middle-aged rheumatoid arthritis patients | Lower literacy associated with higher rate of depression (unadjusted)
Zaslow et al., 2001 ^57^ | Black young adult mothers who qualified for Aid to Families with Dependent Children | Lower literacy associated with higher rate of depression (unadjusted)

The largest study, a cross-sectional evaluation of Medicare managed care patients conducted by Gazmararian et al., ^22^ assessed depression using the well-validated Geriatric Depression Scale (GDS). The authors approached 6,734 patients; 3,171 participated, in a response rate of about 47 percent. This study found an unadjusted OR of being depressed of 2.7 (95% CI 2.2, 3.4) for those people with inadequate literacy compared to those with adequate literacy assessed by the S-TOFHLA. However, after adjusting for demographic, social support, health behavior, and health status factors, the adjusted OR of 1.2 (95% CI 0.9, 1.7) was no longer statistically significant. Although the authors concluded that a significant relationship between literacy and depression could not be observed, the limited response rate may have introduced bias. For example, if people with low literacy who are depressed were more likely to refuse to participate in the study, then differences between the groups would be harder to detect.

TenHave et al. ^32^ evaluated depression scores among subjects recruited for participation in a cardiovascular dietary education program and, as a part of the work, also evaluated a screening instrument to assess literacy. They measured depression (Beck Depression Inventory Short Form) and literacy (Cardiovascular Dietary Education System [CARDES] scale, a tool developed during this study) in 339 patients. Lower scores on the literacy assessment were statistically significantly associated with higher scores on the depression assessment after adjusting for age, suggesting a greater propensity for depression among those with lower literacy (P = 0.0001).

Zaslow et al. ^57^ evaluated depression and literacy among mothers and the relationship between maternal literacy and their children's depression and antisocial behavior. Risk of depression was higher among mothers who had lower literacy skills in an unadjusted analysis (estimated relative risk [RR] 1.60; 95% CI 1.21, 2.12). No relationship was detected between maternal literacy and depression or antisocial behavior among their children (P > 0.10).

Kalichman and Rompa ^56^ compared scores on the Center for Epidemiologic Studies Depression (CES-D) scale with scores on the TOFHLA in a group of patients infected with HIV. The total scores on the depression scales did not differ by literacy status. They found that scores on some CES-D questions or subscales were higher (representing more depression) for participants with lower literacy.

Gordon et al. ^58^ administered the Hospital Anxiety and Depression (HAD) scale to 123 consecutive patients with rheumatoid arthritis: literacy was assessed by the REALM. The percentage of patients with a score of 15 or above on the HAD scale (meaning more anxiety and depression) was greater among those who read below the ninth grade level than among those who read at or above the ninth grade level (61% vs. 44%, P = 0.011), but they did not adjust for confounders.

Of these five studies, four found statistically significant associations between lower literacy and higher rates of depression. However, the largest study failed to show this relationship. The discrepancy in results among these studies may be related to study design and analysis. For instance, because each study used different literacy assessments, the cut-off between high and low literacy was different between studies. Additionally, the populations were quite different. The Gazmararian et al. ^22^ study included only patients over age 65 who did not necessarily have a coexistent chronic condition. TenHave et al. ^32^ enrolled community-dwelling people who were 40 to 70 years of age. Gordon et al. ^58^ enrolled only patients with rheumatoid arthritis, Kalichman and Rompa ^56^ enrolled only patients with HIV infection, and Zaslow et al. ^57^ enrolled mothers receiving Aid for Families with Dependent Children (AFDC). Because of the substantial differences in patient populations, reaching any general conclusions about this relationship is problematic.

Differences between studies in adjustments for covariates also complicate interpretation of these data. Gazmararian et al. ^22^ did not find a significant relationship after adjusting for age and health status. TenHave et al. ^32^ adjusted for age but not health status and found a significant relationship. In unadjusted analyses, Kalichman and Rompa, ^56^ Zaslow et al., ^57^ and Gordon et al. ^58^ found significant relationships for most of their depression-related outcome measures.

One other study evaluated the relationship between literacy and “emotional balance” after receiving informed consent for a bone marrow transplant. ^59^ This study measured reading ability using the WRAT and the Derogatis Affects Balance Scale to measure changes in affect after patients had given informed consent. The researchers found “no significant relationship between the patterns of affects changes and WRAT scores.” ^59^ ^(p 74)^

Arthritis and Functional Status. One cross-sectional study of 123 consecutive patients with rheumatoid arthritis evaluated functional status and literacy. ^58^ Functional status was measured using the Health Activities Questionnaire (HAQ). In a bivariate relationship, HAQ scores did not differ according to literacy dichotomized at the ninth grade level on the REALM.

Migraine. One case-control study evaluated the relationship between literacy (measured by the WRAT) among 32 children with migraine headaches and 32 control children without migraine headaches, all between 8 and 17 years of age. ^60^ In unadjusted analyses, the authors did not find a significant difference in literacy scores between the two groups.

Prostate Cancer. One cross-sectional study evaluated the relationship between literacy and stage of presentation of prostate cancer. ^61^ Bennett et al. dichotomized literacy at the sixth grade level using the REALM and found, in an unadjusted analysis, that men with lower literacy (n = 66) were more likely to present with late-stage prostate cancer than those with higher literacy (n = 146) (55% vs. 38%, P = 0.022). After adjusting for race, age, and location of care, the investigators found that the relationship between literacy and stage of presentation was smaller and no longer statistically significant (OR 1.6; 95% CI 0.8, 3.4).

Global Health Status Measures. Four cross-sectional studies evaluated the relationship between literacy and a global health status measure (Table 11). ^7,^ ^25,^ ^62,^ ^63^ Three teams found an association between lower literacy and worse health status. Weiss et al. ^62^ assessed global health status using the Sickness Impact Profile (SIP) in a group of relatively young participants (mean age 29 years). Literacy was dichotomized at the fourth grade reading level on the Test of Adult Basic Education (TABE) and Mott Basic Language Skills Program. After adjusting for age, sex, ethnicity, marital status, insurance status, occupation, and income, the investigators determined that people with lower literacy scored worse than those with higher literacy on the overall SIP (10.4% vs. 6.0%, P = 0.02) and on both the physical and psychosocial subcomponents of the SIP. Baker et al. ^25^ asked 2,659 patients at two public hospitals to report their overall health status. Both English- and Spanish-speaking patients participated; literacy was assessed in the preferred language. After controlling for age, sex, race, and socioeconomic indicators, they found that patients with inadequate literacy had about twice the odds of reporting poor health as patients with adequate literacy. Finally, Gazmararian et al. ^7^ asked 3,260 patients who were 65 years of age and older and enrolled in a Medicare managed care health plan to report their overall health status. In their bivariate comparison, patients with inadequate literacy were significantly more likely to self-report fair or poor health than patients with adequate literacy (43% vs. 20%, P < 0.001).

Table 11. Studies of the relationship between literacy and global health status (KQ 1b)

Study | Population | Results
Weiss et al., 1992 ^62^ | Young English-speaking adult students in an adult education class | Lower literacy associated with poorer health status score (adjusted)
Baker et al., 1997 ^25^ | Middle-aged English- and Spanish-speaking patients of hospital walk-in clinics or emergency departments | Lower literacy associated with poorer health status rating (adjusted)
Sullivan et al., 1995 ^63^ | Middle-aged and elderly patients with type 2 diabetes | No difference in physical functioning and literacy
Gazmararian et al., 1999 ^7^ | Elderly Spanish- and English-speaking Medicare beneficiaries without dementia | Lower literacy associated with poorer health status rating (unadjusted)

By contrast, Sullivan et al. ^63^ measured general health status among patients with type 2 diabetes using the Medical Outcomes Study Short Form 36 (SF-36). Literacy was assessed using the Questionnaire Literacy Screen (QLS), which was being developed at the time of the study. In an unadjusted analysis, they found no difference in scores on the SF-36 according to whether the subject “passed” or “failed” the QLS.

### Costs of Health Care

To answer KQ 1c, we searched for studies examining the relationship between low literacy and the costs of health care. The one study we found that examined this relationship contacted Medicaid patients by telephone or letter and enrolled 402 (75% participation rate). ^64^ Most patients in this study enrolled in Medicaid because of pregnancy rather than medical need or medical indigence (MNMI) (B. Weiss, personal communication, September 2003). The researchers measured literacy using the Instrument for the Diagnosis of Reading (IDL) and gathered charges from Medicaid records. They found no relationship between literacy and Medicaid charges (r^2 =^ 0.0016, P = 0.43). Weiss et al. ^64^ also evaluated several components of charges, such as inpatient care, outpatient care, and emergency care, but did not identify any relationship between literacy and component charges.

A subsequent unpublished statistical analysis including only nonpregnant patients (n = 74) found that the 18 patients with a reading level at or below third grade had higher mean Medicaid charges than the 56 who read above the third grade level ($10,688 vs. $2,891; P = 0.025) (B. Weiss, personal communication, September 2003). Because the reanalysis is preliminary and exploratory, further research is needed to support this finding.

### Disparities in Health Outcomes or Health Care Service Use

KQ 1d concerns the relationship between low literacy skills and health outcomes or health care service use by race, ethnicity, culture, or age. Only one study directly examined the role of literacy as a mediator of disparities in health outcomes or health care service use. In a cross-sectional study of men with prostate cancer, Bennett et al. ^61^ evaluated the proportion who presented with late-stage prostate cancer according to literacy level and race. In a bivariate analysis, black patients were significantly more likely than white patients to present with late-stage cancer (unadjusted 49.5% vs. 35.9%, P = 0.045 [calculated OR 1.74]). After adjusting for literacy, age, and location of care, the odds ratio was smaller and no longer statistically significant (OR 1.4; 95% CI 0.7, 2.7). The authors suggest that literacy may be mediating some of the racial difference in stage of presentation for prostate cancer.

While not examining differences between groups, 10 studies were primarily focused on particular race/ethnicity groups or seniors: in 2 studies, 90 percent or more of participants were white; ^58,^ ^59^ in 3 studies, 90 percent or more of participants were black; ^26,^ ^32,^ ^57^ in 1 study, all participants were Hispanic; ^52^ and in 4 studies, all participants were 60 years of age and older. ^7,^ ^22–24^

### Summary

Based on the published data identified by our systematic review, literacy level has been found to be related to knowledge and comprehension, hospitalization, global measures of health, and some chronic diseases. In many cases, however, the evidence is mixed and depends on the analytic methods used by the original investigators. For example, although literacy may be related to health outcomes in bivariate associations, when covariates such as education or socioeconomic status are controlled for, the relationship often becomes less strong and statistically nonsignificant. Furthermore, most of the data came from cross-sectional studies that were unable to measure changes in incident outcomes over time.

## Key Question 2: Interventions for People With Low Literacy

### Literature Search and Included Studies

Number and Type of Studies. We identified 29 articles describing interventions to mitigate the effects of low literacy on health outcomes. Table 6 summarizes these studies, which are reported in greater detail in Evidence Table 2. Most intervention studies were published within the past 10 years, reflecting the relative novelty of this line of research.

Included studies were generally of three types: randomized controlled trials, nonrandomized controlled trials (in which assignment to intervention or control groups was done by the day or the week or some other nonrandom process), and uncontrolled, single-group “before-and-after” studies. The number of participants enrolled ranged from 28 to 1,744; most studies had between 100 and 500 participants. Nearly all intervention studies were conducted in the United States; only the studies by Hugo and Skibbe ^65^ (South Africa) and Mulrow and colleagues ^66^ (United Kingdom) were not. Most studies were conducted in single sessions. Interventions to improve dietary behavior and a small group of other studies ^66–71^ followed participants longitudinally to assess changes in outcomes after an intervention.

As shown in Table 12, 19 of 29 intervention studies measured the literacy of each participant. Of these, 10 used the REALM, 4 used the WRAT, and 5 used a variety of other instruments; no intervention study used the TOFHLA. The criteria used to define literacy level categories varied across studies. The remaining 10 studies did not measure literacy directly but, rather, were conducted among populations known from previous assessments to have a large proportion of people with poor literacy skills. In addition to literacy, most studies reported participants' mean age, ethnicity, and mean education levels. Information on participants' income level and health insurance status was available for fewer studies.

Table 12. Measurement tools and criteria used to measure literacy in KQ 2 articles

Study | Measurement Tool | Literacy Measurement Levels
Eaton and Holloway, 1980 ^76^ | Adult Basic Learning Examination (ABLE) | NR
Hartman et al., 1997 ^79^ | ABLE, Level II | = 8th grade
| | 9th to 12th grade
| | > 12th grade
Hussey, 1994 ^82^ | Comprehension Subtest of the Gates-MacGinitie Reading Test | NR
Poresky and Daniels, 2001 ^68^ | Comprehensive Adult Student Assessment Scale | Continuous measurement
Davis et al., 1998 ^73^ | REALM | = 3rd grade
Davis et al., 1998 ^75^ | | 4th to 6th grade
Murphy et al., 2000 ^89^ | | 7th to 8th grade
Hayes, 1998 ^80^ | | = 9th grade
Raymond et al., 2002 ^88^
Kim et al., 2001 ^84^ | REALM | = 3rd grade
Davis et al., 1996 ^74^ | | 4th to 6th grade
| | 7th to 8th grade
| | = 9th grade
| | Mean score
Davis et al., 1998 ^91^ | REALM | Mean, median
Murphy et al., 1996 ^86^ | REALM | Mean
Pepe and Chodzko-Zajko, 1997 ^87^ | REALM | = 9th grade
| | < 9th grade
Kumanyika et al., 1999 ^85^ | Specially designed scale | = 8th grade
| | > 8th grade
Howard-Pitney et al., 1997 ^81^ | WRAT | = 8th grade
| | > 8th grade
Meade et al., 1994 ^92^ | WRAT | = 7th grade
| | < 7th grade
Wydra, 2001 ^93^ | WRAT3 | = Average (= 109)
| | > Average
Michielutte et al., 1992 ^90^ | WRAT-R (adapted for this study) | Dichotomized into high and low literacy at the median score
Bill-Harvey et al., 1989 ^69^ | None | NA
Coleman et al., 2003 ^72^
Fitzgibbon et al., 1996 ^77^
Fouad et al., 1997 ^70^
Gans et al., 1998 ^78^
Hugo and Skibbe, 1991 ^65^
Jacobson et al., 1999 ^83^
Lillington et al., 1995 ^67^
Mulrow et al., 1987 ^66^
Powell et al., 2000 ^71^

Note: NA, not applicable; NR, not reported; REALM, Rapid Estimate of Adult Literacy in Medicine; WRAT, Wide Range Achievement Test; WRAT3, WRAT 3rd edition; WRAT-R, WRAT, Revised

Types of Interventions. The included studies tested a wide range of interventions for improving health outcomes in patients with poor literacy. Most interventions attempted to make health information more available to patients with limited literacy. Interventions designed to improve information delivery were often compared against standard information delivery or materials known to be more difficult to read. Some studies compared standard written information against specially designed pictographs, booklets, videotapes, or CD-ROMs designed for low-literacy audiences; others compared written information of different readability levels.

Bill-Harvey and colleagues ^69^ tested an intervention for osteoarthritis that was delivered by trained community leaders. Some studies, such as the one by Mulrow and colleagues, ^66^ used a multiple group design to test different combinations of a multimodal intervention. Most interventions were delivered at one session, although several studies, particularly those directed to dietary change, used multiple sessions.

Overall, these studies often had important limitations in design. They included (1) common use of uncontrolled before-and-after design; (2) failure to measure literacy or analyze results by literacy level; (3) failure to account for multiple comparisons in the analysis; and (4) inability to isolate the impact of overcoming literacy barriers compared with other co-interventions.

Types of Outcomes. Included studies measured the following outcomes of interest: knowledge and comprehension, health behaviors (e.g., smoking rates, dietary patterns, self-care), biochemical or other intermediate markers (e.g., cholesterol levels, weight, HbA1c, blood pressure), use of health services (pneumococcal vaccination rates, mammography rates), and disease-related functional status. Knowledge outcomes were most commonly used. Few studies directly measured health outcomes that participants could feel and report on directly, such as depression or measures of functional status.

Most included studies only compared outcomes from the intervention and the control groups, or evaluated a change in outcome if the study was a before-and-after design. ^65,^ ^67–88^ However, five studies stratified the analysis to examine the effect of the intervention according to literacy status. ^89–93^ This type of analysis is necessary to directly measure how the intervention performs for individuals with differing literacy levels.

### Use of Health Care Services

KQ 2a concerns the impact of interventions to improve the use of health care services among individuals with low literacy skills. The only article in this category concerned preventive services. In a nonrandomized controlled trial, Davis and colleagues ^73^ found that an intervention consisting of a 12-minute video, coaching tool, verbal recommendation, and brochure significantly improved mammography utilization at 6 months (but not 24 months), compared with the verbal recommendation and brochure alone.

### Health Outcomes

Knowledge and Comprehension. Improvement in knowledge was the most common outcome examined in the studies included for KQ 2. In most cases, participant knowledge improved after receiving the intervention. In five studies, investigators measured patient literacy and stratified the effect of the intervention by literacy status. ^89–93^

In a controlled trial among patients at a sleep apnea clinic, Murphy and colleagues ^89^ used an 11-item questionnaire to compare the effect of a videotape educational tool against the effect of a brochure written at a readability level similar to the videotape's script. Participants with low literacy displayed higher knowledge with the video than with the brochure for 2 of the 11 questions (one about the types of sleep apnea, the other about treatment options for obstructive sleep apnea); for patients with higher literacy, the only percentage that was significantly higher among those who saw the video than among those who read the brochure was for those who correctly answered a question about the cause of sleep apnea.

Michielutte and colleagues ^90^ compared the effect of a brochure with illustrations on cervical cancer with the effect of a brochure using only text in a randomized trial. Patients with lower literacy on the WRAT (score < 46) understood the illustrated materials better than the text materials (61% vs. 35% of women, P = 0.007). For patients with higher literacy, no significant difference was detected (70% vs. 72%).

Wydra ^93^ performed a randomized trial among cancer patients to examine the effect of an interactive videodisc to improve self-care of cancer fatigue symptoms against no intervention. Patients who received the intervention reported greater self-care ability, but this effect was not significantly related to the literacy level of the patient (P = 0.31).

In another controlled trial, Davis and colleagues ^91^ compared a locally developed pamphlet about the polio vaccine designed for patients with low literacy and a pamphlet from the Centers for Disease Control and Prevention (CDC) that had also been designed for easy readability. Comprehension did not differ between the two pamphlets among patients with lower literacy (third grade reading level or less); among all other higher literacy groups, the locally developed pamphlet was associated with increased comprehension.

In a randomized trial of 1,100 patients at the Milwaukee County Hospital primary care clinic, Meade and colleagues ^92^ examined the effectiveness of educational materials on colorectal cancer that were intended to be appropriate for people with low literacy. Participants were assigned to one of two interventions (a videotape or an easy-to-read brochure) or to a usual care control group. Patients receiving either intervention had significantly greater improvements in knowledge scores after reviewing the educational materials than did the control group (26% for the video, 23% for the brochure, 3% for controls). Both low- and high-literacy groups, stratified at less than seventh grade or seventh grade and higher based on their WRAT scores, who received either intervention showed significantly improved knowledge between the pre- and posttests. However, the rates of improvement in the two literacy groups were not significantly different.

A number of other studies found that their low-literacy interventions improved everyone's knowledge or improved knowledge for all but those in the lowest category of literacy. Coleman and colleagues ^72^ found that knowledge of and confidence in performing breast self-examination increased among African-American women regardless of whether they used educational materials with drawings or photographs. Davis and colleagues ^75^ found a preference for more simplified language among candidates to participate in a research project who were asked to sign consent forms, but there was no difference in comprehension of the study associated with the literacy level of the forms. However, in another trial, Davis and colleagues ^74^ reported better comprehension for all but persons with the lowest literacy level when a simplified brochure with graphics was used to instruct parents about polio vaccine.

Eaton and colleagues ^76^ reported that more simplified drug education materials increased patient knowledge but that being more literate was equally important in accounting for drug knowledge. Kim and colleagues, ^84^ using a CD-ROM to educate men about prostate cancer treatments, found participants' levels of knowledge about treatment to be quite variable and directly associated with literacy level. Powell and colleagues ^71^ tested the use of information sheets with drawings to educate parents on injury prevention and found that the drawings made no difference in their recall of specific information after several weeks. In a test of prototype package insert information for emergency contraceptive pills, Raymond and colleagues ^88^ found that, although most women could understand enough information for the safe and effective use of the pills, less literate women typically understood less than the desired amount of information.

Health Behaviors. Several studies addressed the effect of interventions on health behaviors. The behaviors included smoking, dietary patterns, exercise or physical activity, or medication adherence. Outcomes were mixed.

Lillington and colleagues ^67^ found that pregnant smokers and ex-smokers who received a specially designed intervention with materials written at the third grade reading level were more likely to achieve abstinence during pregnancy and 6 weeks postpartum than those who received standard materials. The magnitude of the effect was greater among those who were current smokers at entry than for ex-smokers (ORs for abstinence at 9 months gestation, 1.7 and 1.06, respectively; ORs for abstinence at 6 weeks postpartum, 2.17 and 1.28, respectively). Bill-Harvey and colleagues ^69^ reported that their community-based osteoarthritis intervention improved exercise behavior in a 6-week, before-and-after uncontrolled trial. Hussey ^82^ found that medication adherence among patients 65 years and older improved over time when they were given verbal teaching concerning medication compliance; adding a color-coded medication schedule did not provide additional benefit, however. Interventions addressing dietary behaviors produced small or no changes. ^78,^ ^79,^ ^81,^ ^89^

Biochemical or Biometric Markers. Several studies used changes in biochemical or biometric markers to test the effect of their interventions. Fouad et al. ^70^ found modest differences in blood pressure (net change 2.1 mm Hg) among participants in a specially designed workplace hypertension education and behavior change program when they were compared with nonparticipating controls. Kumanyika and colleagues ^85^ found no significant difference in postprogram cholesterol levels among African-Americans who were assigned to a special cardiovascular nutrition program compared with their preprogram levels; net differences in blood pressure were 3.2 mm Hg among women and 1.7 mm Hg among men, but neither of these results was statistically significant. Hartman and colleagues ^79^ also found no significant difference in cholesterol levels with a dietary intervention aimed at people of low literacy. Finally, in a randomized trial in London, Mulrow and colleagues ^66^ tested the effect of a special educational intervention for patients with diabetes. HbA1c did not differ between groups at either 7- or 11-month followup; weight loss improved moderately with the intervention at 7 months, but the difference did not persist at the 11-month followup.

Measures of Disease Prevalence, Incidence, or Morbidity. Few studies examined the effect of interventions on health outcomes that people can actually feel. The uncontrolled before-and-after trial by Bill-Harvey and colleagues ^69^ found that an osteoarthritis education intervention could improve the functionality of people with osteoarthritis. In the only study to examine the effect of an intervention that included direct literacy-skill building, Poresky and Daniels ^68^ found that a comprehensive family services center, compared with a standard Head Start program, could improve parental reading skill and reduce the prevalence of paternal depression.

Global Health Status. We identified no study of a literacy intervention that used a self-reported instrument to measure health-related quality of life or health status.

### Costs of Health Care

KQ 2c concerns the impact of interventions to affect the cost of care among individuals with low literacy skills. We found no study assessing costs, charges, or reimbursements for these types of interventions in this population.

### Disparities in Health Outcomes or Health Care Service Use

KQ 2d concerns the impact of interventions to improve health care utilization or outcomes among different racial, ethnic, cultural, or age groups. Although no studies compared differences between groups, some interventions were targeted toward particular populations defined by race, including three in which 90 percent or more were black, ^83,^ ^85,^ ^86^ and one (in South Africa) in which all participants were identified as “coloured.” ^65^ Regarding ethnicity, one study involved only Hispanic participants. ^77^ Finally, four studies only enrolled participants who were 60 years of age and older. ^80,^ ^82,^ ^84,^ ^87^ None of these investigations, however, examined the interaction between literacy level and race, ethnicity, or culture in light of the intervention.

### Summary

Studies of interventions designed to reduce the impact of low health literacy on health outcomes have increased over the past 10 years. Available data from multiple studies generally suggest that these types of interventions can increase knowledge and comprehension; limited evidence also suggests that they can improve functional outcomes and reduce morbidity.

Nonetheless, further work in this area will be needed to determine if this effect is robust. Little information is available to determine whether interventions can consistently improve health behaviors, biochemical markers, or specific and global health markers. Many of the studies that produced no statistically or clinically significant differences examined outcomes that are difficult to change, such as dietary behavior.