# Appendix C. Evidence Tables

Because the evidence tables stand alone from the detailed explanation of methods and issues presented in the main evidence report, we recap here briefly the organization and content of the tables. Particularly relevant is the set of key questions we addressed, certain core items of information in the tables, and our quality grading scheme. We also provide an extensive glossary of every abbreviation, acronym, or other initialism used in the evidence tables, but insofar as possible we have attempted to spell out terms. For more detailed information, we refer readers to the full evidence report to be found at www.ahrq.gov.

## Key Questions

The evidence tables in this appendix summarize all empirical articles discussed in Chapter 3 of our evidence report. We first present articles answering Key Question 1, followed by those answering Key Question 2; articles are then arranged alphabetically by author(s).

Our key questions and their paired subsets are as follows:

- Key Question 1: Are low literacy skills related to:
  a. Use of health care services?
  b. Health outcomes?
  c. Costs of health care?
  d. Disparities in health outcomes or health care service use according to race, ethnicity, culture, or age?
- Key Question 2: For individuals with low literacy skills, what are effective interventions to:
  a. Improve use of health care services?
  b. Improve health outcomes?
  c. Affect the costs of health care?
  d. Improve health outcomes and/or health care service use among different racial, ethnic, cultural, or age groups?

## Information in Evidence Tables

The tables contain information about the study citation (with references to these studies to be found at the end of the appendix), the study population and setting, the objectives of the research, the interventions, study outcomes (and literacy measures, where relevant), and the quality score (see below). When the investigators did analyses adjusting for covariates in multivariate models (such as sociodemographic or health characteristics of the study population), we have noted that those analyses are adjusted and provided a listing of the covariates in question. Analyses relying on simplier bivariate relationships are noted as unadjusted.

## Grading the Quality of Individual Studies

We rated the quality of each article based on the criteria in the quality rating form reproduced in Appendix B. We present these scores in the last column of each evidence table entry. The eight quality scores correspond to the first eight questions included on the quality rating form. Because we included both intervention and observational studies in our review, several quality rating form questions were relevant only to certain studies. In those cases, the quality rating for that item in the evidence table entry is “not applicable” (NA). We also collected information on the study's funding source for the ninth (last) item on the quality rating form; however, that information (when available) was not included in a quantitative score and instead is presented separately in the last column of each evidence table entry.

The two study team members who abstracted the summary information concerning the article also independently rated the quality of each article. For each of the eight categories, articles were rated as “good,” “fair,” “poor,” or “NA.” We converted the good/fair/poor ratings into numeric values in which poor = 0, fair = 1, and good = 2. We excluded from our evaluation criteria for a particular study any items designated NA. Instances in which one rater provided a score for an item and the second said the item was NA were reconciled between the two raters. We did not reconcile any other ratings between the two abstractors.

Each of the eight quality scores we present in the evidence table represents a simple average of the scores provided by the two raters. The total score is then the average of each of these scores with each item weighed equally. Corresponding to our individual item ratings, we concluded that, overall, an article should be considered poor with a rating of < 1.0, fair with a rating of = 1.0 and < 1.5, and good with a rating of = 1.5.

Glossary of Abbreviations and Acronyms Used in Evidence Tables

Abbreviation/Acronym | Definition
* | Calculated by evidence report authors
AA | African-American
ABLE | Adult Basic Learning Examination
ABMT | Autologous bone marrow transplant
AC | Asthma clinic
ADEPT | Adherence and Efficacy to Protease Inhibitor Therapy study
ADL | Activities of daily living
AFDC | Aid for Families with Dependent Children
AIDS | Acquired immune deficiency syndrome
BCT | Breast-conservation therapy
BMI | Body mass index
BSE | Breast self-exam
CARDES | Cardiovascular Dietary Education System
CBE | Clinical breast exam
CD | Compact disc
CD-ROM | Compact disc—read-only memory
CI | Confidence interval
COPD | Chronic obstructive pulmonary disease
CPAP | Continuous positive airway pressure
DBP | Diastolic blood pressure
DICCT | Deaconess Informed Consent Comprehension Test
dl | Deciliter
DM | Diabetes mellitus
DMHDS | Dunedin Multidisciplinary Health and Development Study
ED | Emergency department
EFNEP | Expanded Food and Nutrition Education Program
FSC | Family Service Center
GED | General equivalency degree
Grady | Grady Memorial Hospital, Atlanta, GA
HAART | Highly active antiretroviral therapy
Harbor | Harbor-UCLA Medical Center, Torrance, CA
HbA1c | Glycosylated hemoglobin
Hg | Mercury
HIV | Human immunodeficiency virus
HMO | Health maintenance organization
HTN | Hypertension
IADL | Instrumental activities of daily living
IDL | Instrument for the diagnosis of reading
IQ | Intelligence quotient
IUD | Intra-uterine device
kcal | Kilocalories
kg | Kilogram
KMS | Knowledge of Medication Subtest
LAE | Los Angeles English speaking (Harbor-UCLA Medical Center)
LAS | Los Angeles Spanish speaking (Harbor-UCLA Medical Center)
l | Liter
MDI | Metered dose inhaler
mg | Milligrams
MKS | Medication Knowledge Score
mm | Millimeters
mmol | Millimoles
MMSE | Mini-Mental State Examination
NA | Not applicable
NART | National Adult Reading Test
NR | Not reported
NS | Not significant
OCP | Oral contraceptive pill
OR | Odds ratio
P | Probability
PACE | Pima County adult education program, Tucson, AZ
PAG | Pictorial anticipatory guidance
Pap test | Papanicolaou smear
PCKQ | Prostate Cancer Knowledge Questionnaire
PORT | Patient Outcomes Research Team
QLS | Questionnaire Literacy Screen
r | Correlation coefficient
RA | Research assistant
RCT | Randomized controlled trial
REALM | Rapid Estimate of Adult Literacy in Medicine
RR | Relative risk
RSPM | Raven Standard Progressive Matrices
SBP | Systolic blood pressure
SD | Standard deviation
SES | Socio-economic status
SF-36 | Short Form 36
Sig | Significant
SIP | Sickness Impact Profile
SMOG | Readability formula
SNAP | Stanford Nutrition Action Program
SPMSQ | Short Portable Mental Status Questionnaire
STD | Sexually transmitted diseases
S-TOFHLA | Short Test of Functional Health Literacy in Adults
SWOG | Southwestern Oncology Group
TABE | Test of Adult Basic Education
TALS | Test of Applied Literacy Skills
TIPP | The Injury Prevention Program
TOFHLA | Test of Functional Health Literacy in Adults
UCLA | University of California, Los Angeles
US | United States
VA | Department of Veterans Affairs
WAIS-R | Wechsler Adult Intelligence Scale-Revised
WIC | Women, Infants, and Children
WRAT | Wide Range Achievement Test
WRAT3 | Wide Range Achievement Test, 3rd edition
WRAT-R | Wide Range Achievement Test-Revised
yr(s) | Year(s)

Evidence Table 1: Key Question 1

Study Description | Research Objective | Eligibility Criteria | Total Sample Size | Demographic and Other Characteristics | Education | Literacy Measurement | Main Outcomes and Results | | | Covariates Used in Multivariate Analysis | Quality Score
Citation: | To investigate differences between children with and without migraine headaches | Cases: | 64 (32 cases, 32 controls) | Age: | NA | Measurement Tool: | WRAT scores did not differ between cases and controls | | | No multivariate analysis concerning literacy included | Total:1.25
Andrasik et al., 1988 | | Met definition for migraine headache as assessed by two study investigators, selected consecutively at project admission | | 8 to 17 | | WRAT | | | | | 1. 0.5; 2. NA; 3. 1; 4. 2; 5. NA; 6. 2; 7. 1; 8. 1
| | | | Sex | | Literacy Levels:
Design: | | | | NR | | NR
Case-control
| | | | Race/Ethnicity:
Setting: | | Controls: | | NR
NR | | Recruited from friends of cases; could not have more than six headaches/yr or headaches that met definition for migraines, matched to cases by sex and age
| | | | Income:
Duration: | | | | NR | | | | | | | Funding Source:
One interview | | | | | | | | | | | National Institute of Neurological and Communicative Disorders and Stroke
| | | | Insurance Status:
| | | | NR
| | | | Other Characteristics:
| | | | NR
Citation: | To assess reading level, tobacco knowledge, attitudes, and practices of tobacco use among pregnant women | Pregnant | 623 invited | Age: | Mean last grade completed among those > 18: 11th | Measurement Tool: | Smoking rates (unadjusted): | | | Reading level | Total: 1.67
Arnold et al., 2001 | | Adult or adolescent women | | Mean: 23 | | REALM | No sig difference according to literacy level: | | | Age | 1. 2; 2. NA; 3. 1.5; 4. 2; 5. NA; 6. 2; 7. 1; 8. 1.5
| | | 23 refused | Range: 12 to 45 | | | | | | Race
| | AA or white | | | | Literacy Levels: | <3rd: 15% | | | Marital status
Design: | | | 600 enrolled | Sex: | | Mean reading level among those > 18 yrs: 7th to 8th | 4th to 6th: 14% | | | Number of pregnancies
Cross-sectional | | | | Female: 100% | 112 women not included in educational assessment because age 18 or younger | | 7th to 8th: 18% | | | Living with a smoker
| | | | | | | > 9th: 25% | | | Current smoking status
Knowledge, attitudes, and practices assessed through structured questionnaire | | | | Race/Ethnicity: | | < 7th grade reading level
| | | | White: 51% | | White: 9% | Knowledge about effects of smoking (adjusted):
| | | | AA: 49% | | AA: 28% | Literacy sig predictor and negatively related to outcome
| | | | Income: | | 7th to 8th reading level | | | | | Funding Source:
| | | | NR | | White: 26% | Knowledge about effects of second hand smoke (adjusted): | | | | Louisiana Cancer and Lung Trust Fund
| | | | Insurance Status: | | AA: 41% | Literacy sig predictor (p<0.001)
Setting: | | | | % Medicaid/uninsured among all clinic patients: | | >9th grade reading level
Obstetrics clinics at Louisiana State University in Shreveport and E.A. Conway Hospital in Monroe, Louisiana | | | | Louisiana State University: 78% | | White: 66%
| | | | E.A. Conway: 95% | | AA: 31%
| | | | Other Characteristics:
| | | | Marital status:
| | | | Married:
Duration: | | | | White: 53%
September 1995 to April 1996 | | | | AA: 20%
| | | | Not employed:
| | | | White: 70%
| | | | AA: 71%
Citation: | To explore the relationship between functional health literacy and the risk of hospital admission | Included: | 3,260 | Age: | Yrs of School: | Measurement Tool: | Time to first hospital admission (adjusted): | | | Age | Total: 1.8
Baker et al., 2002 | | Medicare beneficiaries | | Adequate: 71.6 ± 5.6 | Adequate: | S-TOFHLA, administered in English or Spanish | Inadequate versus adequate literacy: RR = 1.29, 95% CI (1.07, 1.55) | | | Sex | 1. 1.5; 2. NA; 3. 1.5; 4. 2; 5. 2; 6. 2; 7. 1.5; 8. 2
| | Age: = 65 | 7,471 contacted | Marginal: 74.1 ± 6.3 | 0 to 8 yrs: 7.1% | | | | | Race
| | 3 months after enrollment in plan | | Inadequate: 75.6 ± 7.2 | 9 to 11 yrs: 14.9% | | | | | Education
Design: | | | | | 12 yrs or GED: 38.3% | | | | | Income
Prospective cohort | | Language: English or Spanish | 3390 refused | | > 12 yrs: 39.7% | Literacy Levels: | Marginal versus adequate literacy: | | | Smoking
| | | | Sex: | | Adequate: 64%* | RR = 1.21, 95% CI (0.97, 1.50) | | | Alcohol use
| | | | Female: | | Marginal: 11% | | | | Chronic disease
| | | | | Marginal: | Inadequate: 25% | No sig difference by literacy level in models with interaction terms, for those with self-reported physical health 1 SD > mean | | | Self-reported physical
| | | | | | | | | | Self-reported mental health
Setting: | | Excluded: | 737 ineligible | Adequate: 57.9% | 0 to 8 yrs: 24.2% | | | | | Literacy | Funding Source:
Four Prudential managed care plans (Cleveland, Ohio; Houston, Texas; ampa, Florida; Ft. Lauderdale-Miami, Florida (south Florida) | | Dementia if missed one or more screening questions (not able to correctly identify year, month, state, year of birth, home address) | | Marginal: 53.8% | 9 to 11 yrs: 25.6% | | | | | | Robert Wood Johnson Foundation
| | | | Inadequate: 57.8% | 12 yrs or GED: 30.2% | | Inadequate versus adequate literacy: RR = 1.60, 95% CI (1.24, 2.07)
| | | 84 did not complete | | > 12 yrs: 20% | | Marginal versus adequate literacy:
| | | | Race/Ethnicity: | | | RR = 1.42, 95% CI (1.02, 1.96)
| | | TOFHLA | Adequate: | Inadequate: | | Rates of hospitalization one or more times (unadjusted):
| | | | White: 84.0% | 0 to 8 yrs: 40.9% | | Adequate literacy: 26.7%
| | | (Response rate: 49%*) | AA: 6.6% | 9 to 11 yrs: 24.3% | | Marginal literacy:33.9%
| | If severe visual acuity impairment not correctable with eyeglasses | | English speaking | 12 yrs or GED: 22.8% | | Inadequate literacy: 34.9%
| | | | Hispanic: 1.6% | > 12 yrs: 12% | | Difference between the 3 groups: (P < 0.001)
| | | | Spanish speaking | | | Rehospitalization rate for those with one hospitalization (unadjusted):
| | | | Hispanic: 6.6% | | | No sig difference by literacy level
| | | | Marginal:
Duration: | | | | White: 68.0%
18 to 24 months | | | | AA: 12.6%
| | | | English speaking
| | | | Hispanic: 2.5%
| | | | Spanish speaking
| | | | Hispanic: 16.4%
| | | | Inadequate:
| | | | White: 25.2%
| | | | AA: 58.6%
| | | | English speaking
| | | | Hispanic: 2.3%
| | | | Spanish speaking
| | | | Hispanic: 13%
| | | | Income (< $15,000):
| | | | Adequate: 36.6%
| | | | Margin: 56%
| | | | Inadequate: 67.1%
| | | | Other Characteristics:
| | | | Number of chronic conditions (mean):
| | | | Adequate: 1.9
| | | | Marginal: 2.1
| | | | Inadequate: 2.2
Citation: | To determine the association between patient literacy and hospitalization | Included: | 979 completed intake interview | Age: | Yrs of School: | Measurement Tool: | Risk of hospitalization one or more times in 2-year period (unadjusted): | | | Age | Total: 1.79
Baker et al., 1998 | | Patients enrolled sequentially presenting to the ED or walk-in clinic with nonurgent problems between 9 a.m. and 5 p.m. | | Adequate: 36.2 | | TOFHLA, administered in English or Spanish | | | | Sex | 1. 2; 2. NA; 3. 2; 4. 2; 5. 1; 6. 2; 7. 1.5; 8. 2
| | | | Marginal: 43.7 | | | | | | Race
| | | | Inadequate: 53.1 | Adequate: | | Adequate: 14.9% | | | Overall self-reported health
Design: | | | | Mean: 40 | = 6: 1% | | Marginal: 16.4% | | | Owns car
Prospective cohort | | | 958 had records available | | 7 to 11: 22% | Literacy Levels: | Inadequate: 31.5% | | | Food assistance
| To compare role of literacy with education level | | | Sex: | 12:50% | Adequate: 53% | Sig difference between three literacy levels (P < 0.001) | | | Owns telephone
| | | | Female: 59% | >12:27% | Marginal: 13% | | | | Insurance coverage
Setting: | | | | | | Inadequate: 35% | Difference between marginal and adequate not sig | | | Literacy
Urban public hospital (Grady Memorial), Atlanta, Georgia | | Excluded: | | Race/Ethnicity: | Marginal: | | | | | | Funding Source:
| | Age: < 18 | | AA: 92% | = 6: 0% | | Risk of hospitalization one or more times in 2-year period (adjusted): | | | | NR
| | Unintelligible speech | | | 7 to 11: 57% | | Not controlling for education:
| | Overt psychiatric illness | | Income Markers: | 12: 33% | | Inadequate versus adequate literacy: OR = 1.69, 95% CI (1.13, 2.53)
| | | | No phone: 39% | > 12: 11% | | Marginal versus adequate literacy: Not sig
| | Police custody | | No car: 76% | | | Not controlling for health literacy:
Duration: | | English as a second language | | Food assistance: 42% | Inadequate: | | < 12 yrs versus > 12 yrs: Not sig
2 yrs | | | | | = 6: 22% | | 12 yrs versus > 12 yrs: Not sig
| | Too ill to participate | | | 7 to 11: 55% | | Risk of hospitalization among those hospitalized in the year prior to study entry (adjusted—controlling for literacy, age, receiving food assistance, and insurance):
| | | | Insurance Status: | | | Inadequate versus adequate:
| | Vision worse than 20/100 | | | 12: 20% | | OR = 3.15, 95% CI (1.45, 6.85)
| | | | Medicare or private: 24%* | > 12: 3% | | Marginal versus adequate: Not sig
| | | | Medicaid: 20%*
| | | | Uninsured: 56%
| | | | Other Characteristics:
| | | | Self-reported health:
| | | | Good to excellent: 53%
| | | | Fair: 32%
| | | | Poor: 16%
| | | | Hospitalized at least once during 2-year period:
| | | | 21%
Citation: | To study the relationship between health literacy and self-reported health and use of health services | Included: | Grady: 979, 77% of those approached | Age: | Yrs of School: | Measurement Tool: | Poor self-reported health versus not (unadjusted): | | | Age | Total: 1.83
Baker et al., 1997 | | Adults with nonurgent medical problems | | Mean: | | TOFHLA | | | | Sex | 1. 1.5; 2. NA; 3. 2; 4. 2; 5. NA; 6. 1.5; 7. 2; 8. 2
| | | | Grady: 43.0 | Grady: | | Sig and greatest among those with inadequate literacy at all three sites (P < 0.001) | | | Race
| | | | LAE: 38.0 | < 7: 8% | Administered: | | | | Sociceconomic markers
Design: | | | | LAS: 38.2 | 7 to 11: 38% | English to English speakers | | | | Income
Cross-sectional | | Excluded: | LAE or LAS: | | 12: 38% | | | | | Literacy
| | Unintelligible speech | 767 | Sex: | > 12: 17% | Spanish to Spanish speakers | Poor self-reported health versus not (adjusted):
| | | | Female: | | Large print for those with poor vision | Grady:
Setting: | | Overt psychiatric illness | 84% of all those approached in Los Angeles | Grady: 58.8% | LAE: | | Low versus adequate literacy: OR = 2.12, 95% CI (1.38, 3.24)
Emergency departments and walk-in clinics at public hospitals in Atlanta, Georgia (Grady Memorial) and Los Angeles County, California (Harbor-UCLA Medical Center in Torrance) | | | | LAE: 49.5% | < 7: 2% | | | | | | Funding Source:
| | Illness that precluded participation | | LAS: 64.5% | 7 to 11: 26% | Literacy Levels: | Marginal versus adequate literacy:
| | | | | 12: 43% | Grady: | Not sig | | | | NR
| | | | Race/Ethnicity: | > 12: 29% | Adequate: 35%
| | Visual acuity less than 20/100 | | Grady: | | Marginal: 3% | LAE:
| | | | White: 8% | LAS: | Inadequate: 52% | Low versus adequate literacy:
| | | | AA: 92% | < 7: 55% | LAE: | OR = 2.19, 95% CI (1.34, 3.59)
| | | | LAE: | 7 to 11: 27% | Adequate: 78% | Marginal versus adequate literacy:
| | | | White: 29% | 12: 8% | Marginal: 9% | OR = 1.80, 95% CI (1.06, 3.06)
| | | | AA: 47% | > 12: 11% | Inadequate: 13%
| | | | Latino: 21% | | LAS: | LAS:
| | | | LAS: | | Adequate: 38% | Low versus adequate literacy: OR = 1.72, 95% CI (1.20, 2.48)
| | | | Latino: 100% | | Marginal: 20%
| | | | Income Markers: | | Inadequate: 42% | Marginal versus adequate literacy:
| | | | Grady: | | | Not sig
| | | | Own car: 25% | LAS: | | Poor self-reported health versus not (adjusted)—alternative specifications:
| | | | Own phone: 61% | | | Yrs of school completed used in analysis rather than literacy (< 7 yrs versus high school graduate); sig predictor for LAS group but not LAE or Grady
| | | | Food assistance: 42% | | | Yrs of school not sig predictor after adjusting for literacy
| | | | LAE: | | | Ambulatory care use (adjusted):
Duration: | | | | Own car: 45% | | | Literacy not sig
One interview | | | | Own phone: 50%
| | | | Food assistance: 36%
| | | | LAS:
| | | | Own car: 38%
| | | | Own phone: 78%
| | | | Food assistance: 26%
| | | | Insurance Status:
| | | | NR
| | | | Other Characteristics:
| | | | Grady: Poor health: 16%
| | | | LAE: Poor health: 21%
| | | | LAS: Poor health: 32%
Citation: | To test the association in patients with hypertension between cognitive functioning and literacy | Cases: | 90 cases | Age: | Mean age when leaving school: | Measurement Tool: | Schonell scores did not differ appreciably between patients with and without HTN | | | No multivariate analysis concerning literacy included | Total: 1.58
Battersby et al., 1993 | | Drawn from an up-to-date registry of hypertensive patients | | Cases: 62.5 (9.2) | | Schonell Graded Word | | | | | 1. 2; 2. NA; 3. 1.5; 4. 2; 5. NA; 6. 2; 7. 1; 8. 1
| | | 90 controls | Controls: 62.6 (9.2) | | Reading Test
| | | | Range: 40 to 70 | Cases: 15.0
Design: | | | | | Controls: 14.6 | Literacy Levels:
Case-control | | DBP = 100 mm Hg or SBP of = 180 mm Hg in preceding year or currently on drug treatment for hypertension | | | | Mean (SD)
| | | | Sex: | | Cases: 78.4 (19.8)
Setting: | | | | Female: 53% | | Controls: 81.3 (17.9)
Two West London, innercity general practices
| | | | Race/Ethnicity: | | | | | | | Funding Source:
| | | | White: 87% | | | | | | | NR
| | | | Afro/Caribbean: 12%
| | Controls:
Duration: | | Drawn from same registry and matched on age, sex, race, and health center but with DBP = 90 mm Hg, no record of antihypertensive treatment, DBP of = 100 mm Hg or SBP of = 180 mm Hg
One interview | | | | Income:
| | | | NR
| | | | Insurance Status:
| | | | NR
| | | | Other Characteristics:
| | | | NR
| | Excluded:
| | Patients with stroke or transient ischaemic attack
Citation: | To evaluate the association of poor literacy skills with higher rates of presentation of advanced stages of prostate cancer among low-income black and white men who receive care in equal-access medical systems | English speaking | 212 (4% refusal rate) | Age: | NR | Measurement Tool: | Presence of stage D metastatic disease at presentation (unadjusted): | | | City where care received | Total: 1.92
Bennett et al., 1998 | | Waiting for appointment in prostate cancer clinic | | Mean: 70.8 (SD 7.9) | | REALM | Literacy level=6th grade: 54.6% | | | Age | 1. 2; 2. NA; 3. 2; 4. 2; 5. NA; 6. 2; 7. 1.5; 8. 2
| | | | | | | | | | Race
| | | | | | | | | | Literacy
| | | | | | Literacy Levels:
| | | | Sex: | | Percent <6th grade by: | Literacy level > 6th grade: 37.7%
Design: | | | | Male: 100%
Cross-sectional | | | | | | Race: | Difference: (P < 0.03)
| | | | | | White: 8.7%
| | | | Race/Ethnicity: | | Black: 52.3%
Setting: | | | | White: 49%* | | Age: | Presence of stage D metastatic disease at presentation (adjusted):
VA hospital in Chicago and university-based hospital in Shreveport, Louisiana | | | | Black:51%* | | <65: 35.4% | Literacy level =6th grade versus > 6th grade: OR = 1.6, 95% CI (0.8, 3.4)(P = NS) | | | | Funding Source:
| | | | | | 65 to 74: 25.8% | | | | | VA
| | | | | | > 74: 35.8%
| | | | Income: | | | | | | | Agency for Healthcare Policy Research and Quality
| | | | NR
| | | | Insurance Status:
| | | | NR
Duration
One interview
| | | | Other Characteristics:
| | | | NR
Citation: | To determine if patients recovering from open heart surgery were able to read and understand written discharge instructions | Included: | 34 selected | Age: | Number of Patients: | Measurement Tool: | Correlation between REALM score and a cumulative score on a five-question knowledge test | | | No multivariate analysis concerning literacy included | Total: 0.83
Conlin and Schumann, 2002 | | Nonrandom, convenience purposive sample | | Mean: 62.4 (SD 9.6) | | REALM | | | | | 1. 1; 2. NA; 3. 1; 4. 2; 5. NA; 6. 1; 7. 0; 8. 0
| | | 4 refused | Range: 40 to 79 | 8th grade: 3%*
| | | | | 10th grade: 3%* | Literacy Levels:
| | Recovering from open-heart surgery | 30 tested | Sex: | 11th grade: 3%* | = 3rd grade: 3%*
Design: | | | | Female: 20% | 12th grade: 43%* | 7th to 8th grade: 17%* | Patient given knowledge test on post-operative care instructions given in English during hospitalization
Cross-sectional | | Selected by cardiac rehabilitation nurse | | | 13th grade: 47%*
| | | | Race/Ethnicity: | | High school: 80%*
| | No significant visual and/or acuity insufficiency | | NR
Setting:
Large teaching hospital, post-coronary bypass recovery ward | To analyze the level of difficulty of standard discharge instructions and consent forms for open heart surgery | | | Income: | | | Pearson r coefficient = 0.67, level of statistical significance not given | | | | Funding Source:
| | | | NR
| | Excluded: | | | | | | | | | NR
| | Those in severe discomfort or having complications from their recent surgery | | Insurance Status: | | | Comparable correlation with education achievement: r = 0.13
| | | | NR
Duration: | | | | Other Characteristics:
One interview | | | | NR
Citation: | To study the relationship of reading ability to the knowledge and attitudes that low-income women have regarding screening mammography | Age: = 40 | 595 invited | Age: | Average last grade completed: 10th | Measurement Tool: | Knowledge about mammograms: | | | Age | Total: 1.50
Davis, Arnold, et al., 1996 | | No mammogram in last year | | Mean: 56 | | REALM | | | | Education | 1. 1.5; 2. NA; 3. 1; 4. 2; 5. NA; 6. 1.5; 7. 2; 8. 1
| | | 35 refused | Range: 40 to 92 | | | Raw REALM score positively correlated with knowledge about why women get mammograms: r = 0.22 (P < 0.0001) but not sig related to when to have the first mammogram or how often to have a mammogram | | | Income level
| | Waiting in outpatient clinics | | | | Literacy Levels: | | | | Literacy
Design: | | | 115 ineligible as had mammograms in last year | Sex: | Highest grade completed: | Mean = 40 (4th to 6th)
Cross-sectional | | | | Female: 100% | | 0 to 3rd grade: 25%
| | | | | = 6th:16% | 4th to 6th grade: 22%
30-item structured face-to-face interview | | | | Race/Ethnicity: | 7th to 8th: 15% | 7th to 8th grade: 30%
| | | | White: 30% | 9th to 11th: 27% | > 9th grade: 24%
| | | | AA: 69% | High school graduate rate: 42%
| | | | Other: 1% | | | Unadjusted REALM positively correlated with knowledge index composed of three factual questions: r = 0.17 (P = 0.0008); adjusted relationship also sig | | | | Funding Source:
| | | 445 participated | | | | | | | | National Cancer Institute
Setting: | | | | Income:
Ambulatory care clinic and eye clinic at Louisiana State University, Shreveport | | | | < $10,000: 83%
| | | 417 used in literacy estimates | $10,000 to $20,000: 14% | | | | | | | Cancer Center for Excellence and Research, Treatment and Education at Louisiana State University
| | | | > $20,000: 3%
| | | | Insurance Status: | | | Attitudes:
| | | | NR | | | Lower reading level (unadjusted) sig associated with more concern about mammograms being harmful or painful or troublesome (P < 0.05); not statistically sig after adjustment
Duration: | | | | Other Characteristics:
Summer 1994 | | | | NR
| | | | | | | Influence:
| | | | | | | Association between literacy and influence of physician not sig; literacy level inversely associated with influence from friends/relatives (unadjusted)
| | | | | | | (P < 0.05)
Citation: | To investigate the relationship between lower literacy and violent behavior in adolescents | Participants in summer program who were entering grades 6 to 12 (data collected over 3 yrs of programs, 1994 to 1996) | 386 | Age: | Old for grade: 25% | Measurement Tool: | Association between low reading ability and violent behaviors, as measured by Youth Risk Behavior Survey (adjusted): | | | Age | Total: 1.75
Davis et al., 1999 | | | | | Range: 11 to 18 | Middle school: 64% | Slosson Oral Reading Test-Revised | | | | Race | 1. 1.5; 2. NA; 3. 1.5; 4. 2; 5. NA; 6. 2; 7. 1.5; 8. 2
| | | | 11 to 12: 42% | High school: 36% | | | | | Sex
| | | | 13 to 14: 40% | | | | | | Low reading measured as reading = two grades below grade level
Design: | | | | 15 to 16: 15% | | Literacy Levels:
Cross-sectional | | | | 17 to 18: 4% | | Reading level two or more grade levels behind (referred to as low reading level): 43% | Weapon carrying past 30 days: OR = 1.9, 95% CI (1.1, 3.5)
Setting: | | Recruited from nine predominately low-income neighborhoods
Summer track and field program for youths in low-income neighborhoods in Shreveport, Louisiana | | | | Sex: | | | Gun carrying past 30 days: OR = 2.6, 95% CI (1.1, 6.2)
| | | | Female: 34%
| | | | | | | Weapon carrying at school past 30 days: OR = 2.1, 95% CI (0.9, 4.5)
| | | | | | | | | | | Funding Source:
| | | | Race/Ethnicity:
| | | | AA: 86% | | | Missed school because felt unsafe: OR = 2.3, 95% CI (1.3, 4.3) | | | | NR
| | | | Income:
| | | | NR | | | In physical fight and required treatment past 1 year: OR = 3.1, 95% CI (1.6, 6.1)
| | | | Insurance Status:
| | | | NR | | | Had property damage at school in past 12 months (P = NS)
Duration:
One interview
| | | | Other Characteristics: | | | In physical fight in past 12 months (P = NS)
| | | | History of suspension from school: 35%
Citation: | To describe the information preferences, reading ability, and emotional balance (affect) of adult patients at the time of outpatient informed consent | Any patient admitted for ABMT | 108 patients had ABMT | Age: | < 12th grade: 7% | Measurement Tool: | Relationship between changes on the Derogatis Affects Balance Scale (an objective mood scale) and reading ability before and after informed consent (unadjusted): | | | No multivariate analysis concerning literacy included | Total: 1.25
Fisch et al., 1998 | | | | Mean: 42.7 (SD 10.5) | | WRAT3 | | | | | 1. 1; 2. NA; 3. 1; 4. 2; 5. NA; 6. 1.5; 7. 2; 8. 0
| | | | Range: 18 to 64 | 12th grade: 33%
| | Patients coming to the clinic to provide informed consent on the days the study research nurse was available | 1 refused to have reading assessment | | | Literacy Levels:
Design: | | | | Sex: | Post high school vocational: 17% | Mean: 113.7 ± 7.39 (described as high-average range)
Cross-sectional | | | | Female: 63%
| | | | | | | No sig relationship found between the patterns of changes in affect and WRAT scores
Setting: | | | | Race/Ethnicity:
Outpatient informed consent visit prior to ABMT at Indiana University Hospital, Indianapolis | | | 77 came at a time the research assistant was unavailable | White: 94% | College graduate: 26%
| | | | AA: 3%
| | | | Other: 3%
| | | | | Post-graduate studies: 17% | | | | | | Funding Source:
| | | | Income: | | | | | | | Walther Cancer Institute
| | | | NR
| | | 30 enrolled | Insurance Status:
| | | | NR
Duration:
Enrolled December 1994 to March 1996 | | | | Other Characteristics:
| | | | Self-reported reading ability:
| | | | Excellent: 30%
| | | | Good: 53%
| | | | Fair: 17%
| | | | Diagnosis:
| | | | Breast cancer: 46%
| | | | Lymphoma: 27%
Citation: | To assess the relationship between health literacy and receipt of a screening test for gonorrhea in the past year | Respondents recruited from clinics, community-based organizations, and street intercept | Initial sample: 1,035 | Age: | Mean education (n = 930):11.8 yrs | Measurement Tool: | Gonorrhea test in the last year (adjusted) (n = 722): | | | Suspected infection | Total: 1.33
Fortenberry et al., 2001 | | | | Mean: 26.34 | | REALM | | | | Self-check for STDs | 1. 1; 2. NA; 3. 1; 4. 1.5; 5. NA; 6. 1.5; 7. 1.5; 8. 1.5
| | | | Range: 12 to 55 | | | For the average respondent, those with > 9th grade literacy, compared to those with lower literacy, associated with a 10% increase in the probability of having a gonorrhea test in the past year: OR = 1.37, 95% CI (1.02, 1.93) | | | Self-efficacy for health care
| | | | | | | | | | Self-rated health
Design: | | | 722 used in analysis | Sex: | | Literacy Levels: | | | | Insurance
Cross-sectional | | | | Female: 59%* | | (n = 909) | | | | Clinic recruitment site
| | | | | | Dichotomized: | | | | Age
Setting: | | | (Response rate: NR) | Race/Ethnicity: | | 9th grade or higher: 65% | | | | REALM > 9th grade
Four of seven research sites (Denver, Colorado; Indianapolis, Indiana; Central Harlem, New York City, New York; Birmingham, Alabama) involved in the Gonorrhea Community Action Project | | | | NR
| | | | Income: | | | | | | | Funding Source:
| | | | NR | | | Perceived risk for gonorrhea (unadjusted):
| | | | | | | | | | | Centers for Disease Control and Prevention
| | | | Insurance Status: | | | REALM score negatively related so that the lower the literacy, the greater the perceived risk (P < 0.0001)
| | | | Source of payment for health care:
| | | | Insurance: 59%
| | | | Self-pay: 27% | | | | | | | National Institute of Mental Health
| | | | Free care: 5%
| | | | Other Characteristics:
| | | | Clinic site recruitment: 64%
| | | | Gonorrhea test in past year: 54%
| | | | Self-suspected gonorrhea: 28%
Duration:
One interview | | | | Self-efficacy for health care seeking: Mean 5.64 on 7-point Likert scale from “very unsure of ability to go for check-up” to “very sure of ability to go for check-up”
| | | | Self-reported health:
| | | | Good/excellent: 74%
Citation: | To investigate compliance with measurement protocols among Latino subjects participating in a cardiovascular disease prevention intervention targeting low-English literate adults | Attending English as a second language classes in three adult education centers in San Diego | 338 | Age: | = 9 yrs: 48% | Measurement Tool: | Factors associated with level of compliance with research protocols (unadjusted): | | | No multivariate analysis concerning literacy included | Total: 1.17
Frack et al.,1997 | | | | Mean: 28.1 (SD 9.4) | | Cloze procedure measured Spanish-language literacy | | | | | 1. 0.5; 2. NA; 3. 1; 4. 1.5; 5. NA; 6. 1.5; 7. 2; 8. 0.5
| | | (Represents ~54% of total number that heard recruitment presentation)
| | | | Sex: | | | Spanish literacy (mean):
Design: | | | | Female: About 50% | | | On-time group literacy sig higher than noncomplier group (P < 5.05)
Cross-sectional | | | | | | Literacy Levels (mean):
| | | | Race/Ethnicity:
Setting: | | | | Latino: 100% | | On-time compliers:65.7
English as a second language classes in three adult education centers in the San Diego area during the period of February to August 1994
| | | | Income: | | Late compliers: 64.9
| | | | On-time compliers: 1.96 (1.24) | | Noncompliers: 60.0 | | | | | Funding Source:
| | | | Late compliers: 2.26 (1.24) | | | | | | | National Heart, Lung, and Blood Institute
| | | | Noncompliers: 1.77 (0.98)
| Three groups created: (1) those who complied on time with the study's followup physical measurement protocols (on–time compliers), (2) those who complied late (late compliers), and (3) those who did not comply (noncompliers)
| | | | Income Categories:
| | | | 1 = < $700
| | | | 2 = ($700 to $1,099)
| | | | 3 = ($1,100 to $1,499)
| | | | Insurance Status: NR
Duration:
Initial interview, 3-and 6-month followup assessments
| | | | Other Characteristics:
| | | | Employed: 53%
| | | | Living in US < 3 yrs: 33%
Citation: | To describe the epidemiology of parent reading abilities at 12 representative midwestern clinics | Any parent or adult caretaker waiting for child-related services | 646 enrolled | Age: | Mean yrs of school: 12.1 | Measurement Tool: | Rates of smoking, never breast–feeding, and lack of private health insurance sig associated with low reading ability (P < 0.05) | | | No multivariate analysis concerning literacy included | Total: 0.92
Fredrickson et al., 1995 | | | | Mean: 27.8 | | WRAT | | | | | 1. 1.5; 2. NA; 3. 1; 4. 2; 5. NA; 6. 0.5; 7. 0.5; 8. 0
| | | Less than 4% of those eligible declined | Range: 13 to 63
| | | | | | Literacy Levels:
Design: | | English or Spanish speaking | | Sex: | | Mean grade: 8.7
Cross-sectional | | | | Female: 92% | | < 9th grade: 45% | No association with obesity found
| | | | | | < 6th grade: 22%
Setting: | | | | Race/Ethnicity: | | < 4th grade: 13%
Twelve pediatric, prenatal, or immunization clinics in Kansas: 2 private, 2 university, 2 indigent, and 6 Wichita-Sedgwich County health clinics | To determine whether low literacy was associated with adverse health behaviors | | | White: 59% | | 10% were Spanish speaking and scored lower on the WRAT
| | | | Income: NR | | | | | | | Funding Source: NR
| | | | | | 41% of English speakers scored less than 9th grade
| | | | Insurance Status:
| | | | Insurance: 76%
| | | | Other Characteristics: NR
Duration:
Receiving care during June to July 1994
One interview
Citation: | To determine whether older adults with inadequate health literacy were more likely to report depressive symptoms and whether health literacy was an independent predictor of depression symptomatology | Included: | 3,171 | Age: | At least a high school education: 64% | Measurement Tool: | Depression: | | | Sex | Total: 1.67
Gazmararian et al., 2000 | | Age: = 65 | | 65 to 74: 64% | | S-TOFHLA | Measured by global depression scale | | | Age | 1. 2; 2. NA; 3. 1; 4. 2; 5. NA; 6. 1.5; 7. 1.5; 8. 2
| | 3 months after enrollment in plan | 7,471 contacted | Range: = 65 | | | | | | BMI
| | | | | | Literacy Levels: | Score ranges from 0 to 15 where 0 to 4 = not depressed, 5 to 9 = mild depression, 10 to 15 = moderate to severe depression | | | Drinking
Design: | | Medicare beneficiaries living in the community | | Sex: | | Adequate: 65.6% | | | | Chronic conditions
Cross-sectional | | | 3,247 refused | Female: 57% | | Marginal: 11.3% | | | | Marital status
| | | | | | Inadequate: 23.1% | | | | Tangible support
Setting: | | Language: English or Spanish | | Race/Ethnicity: | | | | | | Exercise
Four Prudential managed care plans (Cleveland, Ohio; Houston, Texas; Tampa, Florida; Ft. Lauderdale-Miami, Florida) | | | 737 not eligible | White: 76% | | | Outcome: | | | Education
| | | | | | | Depressed (mild-severe to not depressed) (adjusted) | | | Annual Income
| | Excluded: | | Income: | | | | | | ADL Limitations | Funding Source:
| | Dementia: If missed one or more screening questions (not able to correctly identify year, month, state, year of birth, home address) | 143 no show | = $10,000: 34% | | | | | | General health
| | | | | | | Literacy: | | | Literacy | Partially supported by Robert Wood Johnson Foundation
| | | | Insurance Status: | | | Inadequate versus adequate literacy: OR = 1.2, 95% CI (0.9, 1.7)
| | | 84 incomplete surveys | Medicare: 100%
| | | | Other Characteristics: | | | Marginal versus adequate literacy: OR = - 0.5, 95% CI (0.3, 0.8)
| | | | Social support: Married: 54.9%
| | | 68 severe dementia
Duration: | | Visual acuity: Excluded if severe impairment | | Tangible or social support: | | | Education:
One interview | | | | | | | No sig difference between > high school and lesser educational attainment categories
| | | 21 | None or little of the time: 20.1%
| | “Severe” category of the MMSE missing five or more responses on depression scale | incomplete data on depression scale
| | | | Some of the time: 19.3%
| | | | Most of the time: 18.5%
| | | (Response rate: 49%) | All of the time: 42.1%
| | | | Exercise: = 4 times/week: 43.2%
| | | | 3 times/week: 15.1%
| | | | 1 to 2 times/week: 15.1%
| | | | < 1 time/week: 26.6%
| | | | Health conditions:
| | | | 0: 10.9%
| | | | 1: 21.6%
| | | | 2: 23.8%
| | | | 3 to 4: 31.5%
| | | | = 5: 12.2%
| | | | ADL limited: 4.3%
| | | | IADL limited: 30%
| | | | Self-rated health:
| | | | Good/excellent: 73.2%
| | | | Depressed: 13%
Citation: | To determine the prevalence of low functional health literacy among community-dwelling Medicare enrollees in a national managed care organization | Included: | 3,260 | Age: | Grade school or less: 17.3% | Measurement Tool: | Inadequate or marginal health literacy versus adequate (adjusted): | | | Study location | Total: 1.67
Gazmararian, Baker, et al., 1999 | | Age: = 65 | | 65 to 69: 37% | | S-TOFHLA, administered in English or Spanish | | | | Race/language | 1. 2; 2. NA; 3. 1; 4. 2; 5. NA; 6. 2; 7. 1.5; 8. 1.5
| | 3 months enrollment in plan | 7,471 contacted | 70 to 74: 27.3% | | | | | | Sex
| | | | 75 to 79: 19.3% | | | Mild to moderate cognitive impairment versus none: OR = 5.24, 95% CI (4.21, 6.53) | | | Age
| | Language: English or Spanish | | 80 to 85: 11% | Some high school: 18.4% | | | | | Education completed
Design: | | | 3,247 refused | > 85: 5.4% | | Literacy Levels: | | | | Occupation
Cross-sectional | | Medicare beneficiaries | | | | English: | | | | Cognitive impairment
| | | | Sex: | High school: 33.6% | Adequate: 66.1% | Percentage with inadequate or marginal health literacy versus adequate (unadjusted):
Setting: | | Excluded: | 737 ineligible | Female: 57.4% | | Marginal: 10.4%
Four Prudential managed care plans (Cleveland, Ohio; Houston, Texas; Tampa, Florida; Ft. Lauderdale-Miami, Florida) | | Dementia if missed one or more screening questions (not able to correctly identify year, month, state, year of birth, home address) | | | | Inadequate: 23.5%
| | | | Race/Ethnicity: | More than high school: 30.7% | Spanish: | Sig more likely to be in fair/poor health versus excellent/good (P < 0.001) | | | | Funding Source:
| | | 3,487 agreed to participate | White: 76% | | Adequate: 46.1%
| | | | Black: 11.8% | | Marginal: 19.7% | | | | | NR
| | | | English speaking Hispanic: 2% | | Inadequate: 34.2% | Sig more likely to have one or more chronic conditions (P < 0.05)
| | | 143 no show | Spanish speaking Hispanic: 9.2%
| | Visual acuity if severe impairment not correctable with eyeglasses | | | | | Not sig related to number of medications (per day)
| | | | Other: 1%
| | | 84 incomplete surveys
| | | | Income:
Duration: | | | | <$10,000: 18.2%
One interview | | | | <10,000 to $14,999: 21.6%
| | | (Response rate: 51%*)
| | | | Insurance Status:
| | | | Medicare: 100%
| | | | Other Characteristics:
| | | | Occupation during longest period of time in adult life:
| | | | Primary white collar: 21.3%
| | | | Secondary white collar: 27.1%
| | | | Primary blue collar: 12.2%
| | | | Secondary blue collar: 31.6%
| | | | At least one or more chronic condition: 66.5%
| | | | Number of medications:
| | | | None: 20%
| | | | 1 to 2 per day: 36.5%
| | | | = 3 per day: 43.5%
| | | | Self-reported health; Good/excellent: 72.8%
Citation: | To examine the relationship between reading ability and family planning knowledge and practices among Medicaid managed care enrollees | Age: 18 to 45 | 406 | Age: | < high school: 11%* | Measurement Tool: | Wanted to know more about birth control (adjusted): | | | Age | Total: 1.33
Gazmararian, Parker, et al., 1999 | | | | 19 to 24: 35%* | | S-TOFHLA to measure health literacy | | | | Race | 1. 2; 2. NA; 3. 1; 4. 1.5; 5. NA; 6. 1; 7. 1.5; 8. 1
| | Sex: Women enrolled in Prudential HealthCare Community Plan as of March 1, 1996 | 2,917 age eligible | 25 to 29: 21%* | | | OR = 2.30, 95% CI (1.12, 4.73) higher among low versus good reading skills women | | | Marital status
| | | | =30: 43%* | High school: 40%* | | | | | Reading skill
| | | | | | Passage from Medicaid Rights and Responsibility form written at 10th grade level
Design: | | | 1,136 located | Sex:
Cross-sectional | | | | Female: 100% | > high school: 49%* | | Incorrect knowledge of time of month most likely to get pregnant (adjusted):
Setting: | | | 204 refused to participate | Race/Ethnicity:
TennCare (Medicaid) members of Prudential HealthCare Community Plan (managed care) in Memphis, Tennessee | | | | White: 23%* | | | OR = 4.54, 95% CI (2.18, 9.48) higher among low versus good reading skills women
| | | | Black: 73%* | | Literacy Levels: | | | | | Funding Source:
| | | | Other: 3%* | | Those who answered less than 80% of reading skills questions correctly identified as having low reading skills
| | | 216 not eligible | | | | | | | | Partially supported by Robert Wood Johnson Foundation
| | | | Income: | | | Proportion of women ever using various types of birth control who have low literacy (unadjusted):
| | | | < 100% poverty level: 50%
| | | 95 additional not eligible
| | | | Insurance Status: | | | IUD 17.9%, douching 13.9%, rhythm 13.7%, sponge 8.5%, condom 8.4%, foam 8.1%, withdrawal 6.6%, OCP 8.1%, levonorgestrel 13.3%, Medroxyprogesterone 10.1%
| | | | Medicaid: 100%
| | | Age: <18
Duration: | | | | Other Characteristics:
One interview | | | (Response rate: 49%*) | Employed: 57%
| | | | | | | Pregnancy intendedness and current use of contraception:
| | | | | | | Did not vary by reading level (unadjusted)
| | | | | | | Women who did not know when they were more likely to become pregnant during their monthly cycle (unadjusted):
| | | | | | | 18.5% had low reading versus 4.9% of those who did know (P = 0.001)
Citation: | To assess predictors of long-term adherence to newly initiated combination antiretroviral therapy using an accurate, objective adherence measure | Enrolled in the ADEPT study | 140 enrolled in study | Age: | < high school | Measurement Tool: | Adherence to complex antiretroviral therapy (unadjusted): | | | Ethnicity | Total: 1.79
Golin et al., 2002 | | | | Mean: 38 | | S-TOFHLA administered in English or Spanish | Literacy: r = -0.01 (P = 0.88) | | | Education | 1. 2; 2. NA; 3. 1.5; 4. 2; 5. 1; 6. 2; 7. 2; 8. 2
| | | | | | | | | | Income
| | HIV infected | | Range: 23 to 67 | graduate: 35% | | | | | Alcohol use
| | Newly initiating a protease inhibitor or non-nucleoside reverse transcriptase inhibitor | | | | | | | | Cuurrent active drug use
Design: | | | 60% of those eligible | Sex: | High school | Literacy Levels: | Adherence to a protease inhibitor or non-nuvlroside reverse transcriptase inhibitor (adjusted): | | | Dose frequency
Prospective cohort | | | | Female: 20% | graduate: 48% | Mean: 30 | | | | Number of reminders
| | | | | | Range on a 36-point scale: (10 to 36)
Setting: | | | 117 had = tow 4-week period for adherence measure-ment and so available for analysis | AA:27% | graduate:17% | | High schook graduate versus less education, positive relationship (p = 0.05)
Public hospital-affiliated HIV clinic between February 1998 and April 1999 | | Spoken English or Spanish | | white: 16% | | | | | | | Funding Source:
| | | | Hispanic: 47% | | | | | | | National Institutes of Health
Adherence data available for at least two 4-week periods | | Other: 10%
| | | | Income:
| | | | =$10,000: 63%
| | | | Insurance Status:
Duration: | | | | NR
48 weeks
| | | | Other Characteristics:
| | | | Working: 30%
| | | | Durarion of diagnosis:
| | | | Mean: 24 months
| | | | Range: 1 to 120 months
| | | | CD4 count nadir: 149
| | | | Range: 0 to 1,130
| | | | Intravenous drug use as source of HIV: 17%
| | | | Currently in drug study: 40%
| | | | Antiretroviral doses/day:
| | | | Mean: 13.4
| | | | Range: 0 to 34
Citation: | To determine the prevalence of illiteracy in a cohort of rheumatoid arthritis patients and the impact of illiteracy on disease severity and function | All patients attending four consecutive clinics for rheumatoid arthritis patients | 127 approached | Age: | NR | Measurement Tool: | Low literacy associated with anxiety and depression (unadjusted): | | | No multivariate analysis concerning literacy level included | Total: 1.33
Gordon et al., 2002 | | | | Median: 56 | | REALM | Percent = 15 on hospital anxiety and depression scale: | | | | 1. 1.5; 2. NA; 3. 1; 4. 2; 5. NA; 6. 2; 7. 1; 8. 0.5
| | | | Range: 19 to 77 | | Literacy Levels:
| | | | | | = 9th grade%*
Design: | | | | Sex: | | 7th to 8th grade: 12% | =9th grade (literate group): 44%
Cross-sectional | | | 123 participated | Female: 79% | | 4th to 6th grade: 2%* | < 9th grade (illiterate group): 20 (P = 0.5)
| | | | | | < 3rd grade: 1%
Setting: | | | | Race/Ethnicity:
Tertiary referral clinic for rheumatic diseases in Glasgow, Scotland | | | | white: 98% | | | Health Assessment Questionnaire score (unadjusted): | | | | Funding Source:
| | | | Income: | | | = 9th grade (literate group): 1.875 | | | | NR
| | | | Carstairs deprivation index: | | | < 9th grade (illiterate group): 20 P=0.5
| | | | Group6 or 7:43% (most deprived
Duration: | | | | Group 1,2, or 3: 24% (most affluent) | | | Extent of disability including antirheumatic drugs used or number of major joining arthroplastics:
One questionnaire | | | | | | | Association with literacy not sig (data not shown)
| | | | Insurance Statu:
| | | | National Health Service
| | | | Other Characteristics:
| | | | NR
Citation: | To identify key predictors of early adolescent social drug use | Students in selected schools | 3,019 | Age: | NR | Measurement Tool: | Results presented as OR, 95% CI | | | Parents drink | Total: 1.42
Hawthorne, 1996 | | | | 11: 61% | | NR | CI | | | Parents smoke | 1. 1; 2. NA; 3. 2; 4. 0; 5. NA; 6. 1.5; 7. 2; 8. 2
| | | | | | | | | | Parents' occupation
| | | “99% participation rate” | 12: 39% | | Literacy Levels: | Ever having used tobacco (adujsted): | | | Parents' birthplace
| | | | | | Scale NR | Literacy low versus high: | | | Parents' occupation | Home language
Design: | | | | Sex: | | | | | | School SES rating
| | | | Female: 46% | | Literacy analyzed in three categories: | Boys: OR = 1.7 (1.1, 2.7) | | | Personal tobaco use (alcohol models)
| | | 1,620 boys | | | | Girls: OR = 1.1 (0.6, 2.0)
Setting: | | | | Race/Ethnicity: | | Low | Literacy middle versus high: | | | Personal alocohol use (tobacco models)
Stratified sample of 6th year students (ages 11 and 12) from 86 schools in Melbourne, Australia | | | 1,399 girls | NR | | Middle | Boys: OR = 1.3 (1.0, 1.7)
| | | | | | High | Girls: OR = 1.1 (0.8, 1.3) | | | Friends smoke | Funding Source:
| | | Re-analysis of existing data | Income: | | | Friends drink
| | | | NR | | | Having used tobacco in the past month (adjusted): | | | Age | Victoria
| | | | | | | Literacy low versus high: | | | Personal birthplace | Health
| | | | Insurance Status: | | | | | | Analgesic use | Promotion
| | | | NR | | | Boys: OR = 4.2(2.0, 8.9) | | | Hours of drug education | Foundation
| | | | | | | Girls: OR = 4.4 (1.8, 10.7) | | | Drug knowledge
| | | | Other Characteristics: | | | Literacy middle versus high: | | | Attitudes to others
Duration: | | | | Birthplace: | | | Boys: OR = 1.7 (1.0, 2.9) | | | Attitudes to rewards
One interview | | | | Australia: 83% | | | Girls: OR = 2.0 (1.1, 3.8) | | | Attitudes to health
| | | | Other: 17%
| | | | Parental ocupation: | | | Ever having used alcohol (adusted):
| | | | Professional or managers: 39% | | | Literacy low versus high:
| | | | Clerks, sales, service: 11% | | | Boys: OR = 1.1 (0.6, 2.0)
| | | | | | | Girls: OR = 0.8(0.3, 2.2)
| | | | Tradespersons, laborers, cleaners: 35% | | | Literacy middle versus high:
| | | | | | | Boys: OR = 0.9 (0.7, 1.4)
| | | | Houseworker or unemployed: 15% | | | Girls: OR = 1.2 (0.7, 2.0)
| | | | Spoke a language other than English at home: 27% | | | Having used alcohol in the past month (adjusted):
| | | | | | | Literacy low versus high:
| | | | Parents born outside Australia: 49% | | | Boys: OR = 1.9(0.9, 3.8)
| | | | | | | Girls: OR = 1.2 (0.4, 3.4)
| | | | | | | Literacy middle versus high:
| | | | | | | Boys: OR = 0.9 (0.6,1.4)
| | | | | | | Girls: OR = 0.9 (0.5, 1.7)
| | | | | | | Having misused alcohol (adjusted):
| | | | | | | Literacy low versus high:
| | | | | | | Boys: OR = 2.6 (1.4, 4.8)
| | | | | | | Girls: OR = 2.1 (0.8, 5.5)
| | | | | | | Literacy middle versus high:
| | | | | | | Boys: OR = 1.6 (1.1, 2.4)
| | | | | | | Girls: OR = 1.2 (0.6, 2.2)
Citation: | To test the hypothesis that poor health literacy is associated with less knowledge and understanding of one's own HIV-disease status and negative perceptions of provider communications | HIV positive | 294 | Age: | Mean: 13.0 yrs | Measurement Tool: | Knowledge measures (adjusted): | | | Yrs of education | Total: 1.08
Kalichman, Benotsch, et al., 2000 | | Fluent in English | | Mean: 39.7 | | TOFHLA reading comprehension section only | Does not know CD4 count: | | | | 1. 1; 2. NA; 3. 1; 4. 1.5; 5. NA; 6. 1.5; 7. 1; 8. 0.5
| | | | Range: 24 to 67 | < 12 yrs: 21% | | Lower versus higher literacy: OR = 1.9, 95% CI (0.9, 4.1)
| | | | | 12 yrs: 32%
| | | | Sex: | > 12 yrs: 47% | | Understands meaning of CD4 count:
Design: | | | | Female: 22% | | Literacy Levels: | Higher versus lower literacy: OR = 2.5, 95% CI (1.2, 5.4)
Cross-sectional | | | | Male: 78%
| | | | Transgender: 0.5% | | “Lower health literacy”: 18% | Does not know viral load:
Setting: | | | | | | | Lower versus higher literacy: OR = 1.8, 95% CI (0.9, 3.5)
Recruited from AIDS service organizations, health care providers, social service agencies, community residences for people with HIV/AIDS, infectious disease clinics, fliers, word of mouth | | | | Race/Ethnicity: | | “Higher health literacy”: 82%
| | | | White: 24% | | | Understands meaning of viral load:
| | | | AA: 70% | | Cut-off for higher health literacy at 80% correct on TOFHLA subtest | Higher versus lower literacy: OR = 3.4, 95% CI (1.3, 9.1) | | | | Funding Source:
| | | | Other: 6%
| | | | | | | | | | | National Institue of Mental Health
| | | | Income: | | | Optimism toward treatment (adjusted):
| To examine the relationship between health literacy and misperceptions about antiretroviral therapies | | | < $10,000/yr: 61% | | Score: | Community upbeat about stopping AIDS:
| | | | | | 0% to 20%: 2% | Lower versus higher literacy: OR = 2.4, 95% CI (1.1, 5.1)
| | | | Insurance Status: | | 21% to 40%: 2%
| | | | NR | | 41% to 60%: 3% | Believes there will be a cure for HIV in next few yrs:
| | | | | | 61% to 80%: 11%
| | | | Other Characteristics: | | 81% to 90%: 23% | Lower versus higher literacy: OR = 3.1, 95% CI (1.5, 6.6)
| | | | NR | | 91% to 100%: 59%
| | | | | | | Perceived effects of treatment on transmission risks (adjusted):
Atlanta, Georgia | | | | | | | Taking drug cocktails makes it less likely to transmit HIV during sex:
Duration: | | | | | | | Lower versus higher literacy: OR = 3.0, 95% CI (1.4, 6.3)
One interview
| | | | | | | Safe to have unsafe sex if undetectable viral load:
| | | | | | | Lower versus higher literacy: OR = 5.8, 95% CI (2.2, 15.5)
| | | | | | | New AIDS treatment makes it easier to relax about unsafe sex:
| | | | | | | Lower versus higher literacy: OR = 6.0, 95% CI (2.6, 3.6)
| | | | | | | Health status and health behaviors (unadjusted):
| | | | | | | Undetectable viral load:
| | | | | | | Higher versus lower literacy:
| | | | | | | OR = 2.9, 95% CI (1.1, 8.1)
| | | | | | | At least one doctor visit per month:
| | | | | | | Lower versus higher literacy: OR = 2.3, 95% CI (1.2, 4.4)
Citation: | To test the significance of health literacy relative to other predictors of adherence to treatment for HIV and AIDS | HIV positive | 318 | Age: | Mean yrs (SD): | Measurement Tool: | Adherence to combination antiretroviral therapies over a 2-day recall (adjusted): | | | Age < 35 | Total: 1.50
Kalichman et al., 1999 | | | | Nonadherent: | | TOFHLA reading comprehension section only | | | | Ethnic minority | 1. 1.5; 2. NA; 3. 1; 4. 1.5; 5. NA; 6. 1.5; 7. 1.5; 8. 2
| | | 184 on HAART and used for analysis (triple combination drug therapy) | Mean: 38.2 | Nonadherent: | | | | | Income < $10,000
| | | | Adherent: | 12.2 (2.7) | | <12 yrs education versus = 12 yrs: OR = 3.3, 95% CI (1.1, 10.7) (P < 0.05) | | | Education < 12 yrs
Design: | | | | Mean: 40.4 | Adherent: 13.7 (2.3) | | | | | Number of HIV symptoms
Cross-sectional | | | | | | | | | | Alcohol use
| | | | Sex: | | Literacy Levels: | Lower literacy versus higher literacy: OR = 3.9, 95% CI (1.1, 13.4) (P < 0.05) | | | Other drug use
Setting: | | | | Nonadherent male: 67% | | “Lower” literacy (those who scored below 85% correct): 16% | | | | Social support
Recruited from AIDS service organizations, health care providers, social service agencies, community residences for people with HIV/AIDS, infectious disease clinics, fliers, word of mouth | | | | Adherent male: 78% | | | | | | Emotional distress
| Adherents (n = 148) compared to nonadherents (n = 36) (those who missed at least one dose of their antiretroviral medication in the past 2 days) | | | | | | | | | Provider attitudes
| | | | Race/Ethnicity: | | | Barriers to adherence in past 30 days by literacy (lower versus higher) (unadjusted): | | | Lower literacy | Funding Source:
| | | | Nonadherent:
| | | | White: 17% | | | | | | | National Institute of Mental Health
| | | | AA: 75% | | | Lower literacy more likely to report confusion (P < 0.01)
| | | | Other: 8%
| | | | Adherent: | | | Lower literacy more likely to report depression (P < 0.05)
| | | | White: 45%
| | | | AA: 49% | | | Lower literacy report wanting to cleanse their body (P < 0.05) | | | | Center for AIDS Intervention Research
| | | | Other: 6%
| | | | | | | No sig difference by literacy level in forget dose, did not have pills, too busy, too many pills, slept through dose, side effects
| | | | Income:
| | | | < $10,000/yr
| | | | Nonadherent: 66%
| | | | Adherent: 62%
Atlanta, Georgia
| | | | Insurance Status:
| | | | NR
Duration: | | | | Other Characteristics:
One interview | | | | NR
Citation: | To examine differences in emotional reactions to changes in health status between individuals living with HIV/AIDS who have lower versus higher health literacy skills | HIV positive | 294 | Age: | Mean: 13 yrs (SD 2.3) | Measurement Tool: | Percent undetectable viral load (unadjusted): | | | No multivariate analysis concerning literacy included | Total: 1.25
Kalichman and Rompa, 2000a | | Fluent English speaker | Mean: 39.7 | | | TOFHLA reading comprehension section only | | | | | 1. 1.5; 2. NA; 3. 1; 4. 1.5; 5. NA; 6. 1.5; 7. 1; 8. 1
| | | | Range: 24 to 67 | <12 yrs: 21% | | Lower health literacy: 32%
| | | | | 12 yrs: 32% | | Higher health literacy: 38%
Design: | | | | Sex: | >12 yrs: 47% | | Difference: (P =NS)
Cross-sectional | | | | Female: 22% | | Literacy Levels:
| | | | Male: 78% | | “Lower health literacy”: 26% | Emotional reactions to scenarios concerning increase in viral load among HIV-positive persons (unadjusted):
Setting: | | | | Transgender: 0.5%
Recruited from AIDS service organizations, health care providers, social service agencies, community residences for people with HIV/AIDS, infectious disease clinics, fliers, word of mouth | | | | | | “Higher health literacy”: 74%
| | | | Race/Ethnicity:
| | | | White: 24% | | Cut-off for higher health literacy: 85% correct on reading comprehension section of TOFHLA | Lower health literacy more likely than higher to be devastated (P =0.03) | | | | Funding Source:
| | | | AA: 70%
| | | | Other: 6% | | | | | | | National Institute of Mental Health
| | | | | | | Lower health literacy less likely than higher to be optimistic (P =0.01)
| | | | Income:
| | | | <$10,000/yr: 61%
| | | | | | | No sig difference in feeling afraid, depressed, hopeful, or relieved by literacy level
| | | | Insurance Status: | | | | | | | Center for AIDS Intervention Research
| | | | NR
| | | | Other Characteristics: | | | Emotional reactions to scenarios concerning decrease in viral load (unadjusted):
| | | | Undetectable viral load
| | | | Lower health literacy: 32%
| | | | | | | Lower health literacy more likely to be devastated (P = 0.02), afraid (P = 0.03), depressed (P = 0.01)
Atlanta, Georgia | | | | Higher health literacy: 38% (P =NS)
Duration: | | | | | | | Lower health literacy less likely to be hopeful (P = 0.01), optimistic (P = 0.01)
1 day
| | | | | | | Number of symptoms of affective depression (unadjusted):
| | | | | | | Greater in lower literacy versus higher group (P < 0.01)
| | | | | | | Level of social support (unadjusted):
| | | | | | | Less among lower literacy versus higher group (P < 0.01)
Citation: | To test the hypothesis that poorer health literacy is associated with health status, awareness and understanding of one's HIV disease status, and HIV disease and treatment-related knowledge | HIV positive | 339 | Age: | Mean: 12.7 yrs | Measurement Tool: | All OR compare lower versus higher health literacy: | | | Education | Total: 0.92
Kalichman and Rompa, 2000b | | Fluent English speaker | | Mean: 42 | <12 yrs: 23% | TOFHLA reading comprehension section only | | | | | 1. 1; 2. NA; 3. 1; 4. 1; 5. NA; 6. 1; 7. 1; 8. 0.5
| | | | Range:22 to 69 | 12 yrs: 57%
| | | | | >12 yrs: 20% | | Undetectable viral load (unadjusted):
Design: | | | | Sex:
Cross-sectional | | | | Female: 32%* | | Literacy Levels: | OR = 6.2, 95% CI (2.1, 18.5)
| | | | Transgender: 1% | | “Lower health literacy”: 25%
Setting: | | | | | | | Taking antiretrovirals (unadjusted):
Recruited from AIDS service organizations, health care providers, social service agencies, community residences for people with HIV/AIDS, infectious disease clinics, fliers, word of mouth | | | | Race/Ethnicity: | | “Higher health literacy”: 75%
| | | | White: 19%* | | | OR = 1.9, 95% CI (1.1, 3.2)
| | | | AA: 78%* | | Cut-off for higher health literacy at 80% correct on TOFHLA subtest | | | | | Funding Source:
| | | | Other: 3%* | | | <300 CD4 cells/mm^3^ (unadjusted):
| | | | | | | | | | | National Institute of Mental Health
| | | | Income: | | | OR = 2.3, 95% CI (1.1, 5.1)
| | | | <$20,000/yr: 85%*
| | | | | | | Hospitalized = three times (unadjusted):
| | | | Insurance Status:
| | | | NR | | | OR = 1.7, 95% CI (1.0, 3.0)
| | | | Other Characteristics: | | | Perceives health is good (unadjusted):
| | | | Mean CD4 count: 314.6 cells/mm^3^
| | | | | | | OR = 0.5, 95% CI (0.2, 1.0)
| | | | Mean log viral load: 3.2 copies/ml
| | | | | | | Knowledge and understanding of HIV-related health markers (adjusted):
Atlanta, Georgia | | | | Undetectable viral load: 36%
Duration: | | | | | | | Does not know CD4 cell count:
One interview | | | | | | | OR = 1.9, 95% CI (1.1, 3.5)
| | | | | | | Does not understand meaning of CD4 count: OR = 1.7, 95% CI (0.9, 3.3)
| | | | | | | Does not know viral load:
| | | | | | | OR = 2.3, 95% CI (1.3, 3.9)
| | | | | | | Does not understand meaning of viral load: OR = 2.2, 95% CI (1.1, 4.8)
| | | | | | | HIV disease and treatment knowledge test score (adjusted):
| | | | | | | Higher literacy group scored higher than lower (P < 0.1)
| | | | | | | Perceptions and experiences related to HIV/AIDS (adjusted):
| | | | | | | More negative among lower literacy group (P < 0.05)
Citation: | To test the reliability and validity of self-reported CD4 lymphocyte counts and viral load in a community sample of HIV-infected men and women | HIV positive | 174 | Age: | Mean: 12.6 | Measurement Tool: | Knew most recent CD4 count (unadjusted): | | | Education | Total: 1.08
Kalichman, Rompa, and Cage, 2000 | | English speaker | | Mean: 40.5 | yrs (SD 2.3) | TOFHLA reading comprehension section only | | | | Income | 1. 1; 2. NA; 3. 1; 4. 1; 5. NA; 6. 1.5; 7. 1; 8. 1
| | | | Sex: | | | Percent correct on literacy test: | | | Health literacy
Design: | | | | Female: 34% | | | Knew: 86.7%
Cross-sectional | | | | Male: 64% | | | Did not know: 77.8%
| | | | Transgender: 2% | | Literacy Levels: | Difference: (P = 0.01)
Setting: | | | | | | Cut-off for higher health literacy: 85% correct on reading comprehension section of TOFHLA
Recruited from AIDS service organizations, health care providers, social service agencies, community residences for people with HIV/AIDS, infectious disease clinics, fliers, word of mouth | | | | Race/Ethnicity: | | | Knew most recent viral load (unadjusted):
| | | | White: 16% | | | Percent correct on literacy test:
| | | | AA: 77% | | | Knew: 89.5% | | | | Funding Source:
| | | | Hispanic/Latino: 4% | | | Did not know: 77.4%
| | | | Other: 4% | | Compare percent correct on literacy test | Difference: (P = 0.01) | | | | National Institute of Mental Health
| | | | | | | Congruence between self-reported and chart-abstracted CD4 cell counts and viral loads (unadjusted):
| | | | Income: | | | | | | | Center for AIDS Intervention Research
| | | | <$10,000/yr: 67% | | | Percent correct on literacy test:
| | | | Insurance Status: | | | Congruent: 92.2%
| | | | NR | | | Discrepant: 86.8%
| | | | | | | Difference: (P = 0.03)
| | | | Other Characteristics:
| | | | Mean yrs aware of HIV status: 8.1 (SD 4.6) | | | Discrepant self-reported CD4 counts or viral loads (adjusted):
Atlanta, Georgia | | | | | | | Lower versus higher literacy: OR = 3.7, 95% CI (1.1, 12.5)
Duration:
1 month for 30 patients in sample
One visit for rest of patients
Citation: | To examine the relationship between new mothers' literacy skills and their decision to breas t-feed or bottle-feed their infants | New first-time mothers with infant between 2 and 12 months old | 61 enrolled | Age: | NR | Measurement Tool: | Percent breast-feeding exclusively for at least 2 months (unadjusted): | | | No multivariate analysis concerning literacy included | Total: 1.33
Kaufman et al., 2001 | | | | 18 to 20: 49% | | REALM | | | | | 1. 1; 2. NA; 3. 1; 4. 2; 5. NA; 6. 1.5; 7. 2; 8. 0.5
| | | | 21 to 25: 28% | | Literacy Levels: | =9th grade reading: 54%
| | English as first language | | 26 to 30: 16% | | =9th: 64%* | 7th to 8th grade reading: 23%
Design: | | | | 31 to 35: 7% | | 7th to 8th: 36%* | Difference: (P =0.018)
Cross-sectional | | Age: = 18 | | | | | | | | | Funding Source:
| | Without vision deficits | | Sex: | | | | | | | NR
Setting: | | | | Female: 100%
Public health clinic, Albuquerque, New Mexico, including clinic and WIC office
| | | | Race/Ethnicity:
| | | | White non-Hispanic: 41%
| | | | Hispanic: 39%
| | | | Other: 20%
| | | | Income:
Duration: | | | | < $10,000/yr: 21%
One interview | | | | $10,000 to $20,000/yr: 38%
| | | | $21,000 to $30,000/yr: 23%
| | | | Insurance Status:
| | | | NR
| | | | Other Characteristics:
| | | | NR
Citation: | To determine the compliance with a standard BCT program in a predominantly indigent, minority population of patients with early breast cancer | Women with stage I or II breast cancer undergoing BCT from January 1990 to May 1995 | 55 | Mean Age: | NR | Measurement Tool: | Only 36% of patients had full compliance | | | No multivariate analysis concerning literacy included | Total: 1.14
Li et al., 2000 | | | | Compliant: 48 | | REALM | | | | | 1. 1; 2. NA; 3. 0.5; 4. 2; 5. 1; 6. 1.5; 7. 1.5; 8. 0.5
| | | Compliant: 20 | Noncompliant:50 | | Literacy Levels: | Compliance with BCT (unadjusted):
Design: | | | | | | Compliant (n=16)
Retrospective case study | | | | Sex: | | 4th to 6th: 6%* | 64% did not complete some aspect of BCT program
| | BCT defined as lumpectomy (partial mastectomy, segmentectomy, quadrantectomy) of the lesion with a microscopic tumor-free margin and complete level I and II axillary node dissection followed by radiation therapy | Non-compliant: 35 | Female: 100% | | 7th to 8th: 6%*
Setting: | | | | Race/Ethnicity: | | >9th: 88%* | Lower literacy may be associated with lower compliance (data not shown)
University surgical oncology service in a Shreveport, Louisiana, public hospital | | | | Compliant group: | | Noncompliant (n=23):
| | | | White: 25% | | 4th to 6th: 17%*
| | | | Black: 75% | | 7th to 8th: 17%* | | | | | Funding Source:
| To compare the clinical outcomes of this group with those reported in clinical trials and to examine the socioeconomic factors that may have contributed to the rate of compliance | | | Noncompliant group: | | >9th: 65%* | | | | | National Cancer Institute
| | | | White: 40%
| | | | Black: 60%
| | | | Income
Duration | | | | NR
Median followup of 42 months
| | | | Insurance Status:
| | | | Medicare: 18%*
| | | | Commercial: 5%*
| | | | Uninsured: 76%*
| Compliance defined as compliance with radiation therapy and clinical followup | | | Other Characteristics:
| | | | NR
Citation: | To describe the relationship between health literacy, ethnicity, and cervical cancer screening practices | Age: = 18 | 601 approached | Age: | 1 to 6 yrs: 1% | Measurement Tool: | Knowledgeable of purpose of Pap test (adjusted): | | | Education | Total: 1.67
Lindau et al., 2002 | | Language: English speaking | | Mean: 27 | 7 to 8 yrs: 3% | REALM | | | | Employment | 1. 2; 2. NA; 3. 2; 4. 2; 5. NA; 6. 2; 7. 1; 8. 1
| | | | Range: 18 to 54 | 9 to 12 yrs: 48% | | Literacy > 9th grade versus= 9th grade: OR = 2.25, 95% CI (1.05, 4.80) | | | Insurance
| | Women only, clinic patients | 584 eligible | | | Literacy Levels: | | | | Age
Design: | | | | Sex: | > 12 yrs: 47% | Median score: 63 (score = 61 = high school level) | | | | Ethnicity
Cross-sectional | | | 529 participated (91%) | Female: 100% | | 7th to 8th grade: 30% | | | | Literacy
Setting: | | | | Race/Ethnicity: | | = 6th grade: 9% | Likelihood of seeking care in an emergency room or acute care facility (unadjusted):
Women's health clinics at an academic medical center in Chicago, Illinois | To evaluate physician recognition of low literacy | | | White: 14% | | | Below adequate literacy (less than high school) less likely than high school (P< 0.001)
| | | | AA: 58% | | | | | | | Funding Source:
| | | | Hispanic: 18% | | | | | | | Northwestern Memorial Foundation
| | | | Income: | | | Likelihood of seeking care from a known provider (unadjusted):
| | | | NR | | | Below adequate literacy (less than high school) less likely than high school (P< 0.001)
Duration: | | | | Insurance Status: | | | Physician perceptions of literacy (unadjusted):
January to December 1999 | | | | Medicaid: 72% | | | Estimations poorest among the lowest readers, overestimating the reading level 80% of the time
| | | | Private insurance: 20% | | | Sensitivity of routine clinical encounter for detecting low literacy was poor (40.4%), many false-negative assessments
| | | | No insurance: 8%
| | | | Other Characteristics:
| | | | NR
Citation: | To investigate the association of knowledge of medication dosing with adherence among patients taking antiretroviral medication | HIV infected | 140 enrolled | Age: | < 12 yrs: 35.2% | Measurement Tool: | MKS at week 8 (unadjusted): | | | Income | Total: 1.71
Miller et al., 2003 | | Enrolled in the ADEPT study, a new HAART regimen | | Mean: 37 | | S-TOFHLA, administered in English or Spanish | Literacy: r = 0.31 (P= 0.005) | | | Education | 1. 2; 2. NA; 3. 1.5; 4. 2; 5. 1; 6. 1.5; 7. 2; 8. 2
| | | 128 had = two study visits and so available for the analyses | Range: 22 to 67 | 12 to 15 yrs: 48.4% | | | | | Age
Design: | | Spoke English or Spanish | | Sex: | =16 yrs: 16.4% | | Lower MKS prediction based on repeated measures at 0, 8, 24, and 48 weeks (adjusted): | | | Clinical trial participation
Prospective cohort | | | | Female: 20.3% | | | | | | Language
| | Attended = two ADEPT study visits during 48-week study | | | | Literacy Levels: | | | | Social support
| | | | Race/Ethnicity: | | Mean: 29.9 (SD 7.1) | Associated with lower literacy (P= 0.03) | | | Use of a device to complete knowledge survey
Setting: | | | | White: 15.6% | | Range: 10 to 36
Public hospital-affiliated HIV clinic between February 1998 and April 1999 | | | | AA: 26.6% | | | For each 1-point increase in the 36-point literacy score, MKS increased by 0.5% | | | Number of pills
| | | | Hispanic: 46.9% | | | | | | Literacy
| | | | Other/mixed: 10.9% | | | | | | | Funding Source:
| | | | Income: | | | | | | | National Institutes of Health
| | | | <$10,000: 59.7%
Duration:
One interview | | | | Insurance Status:
| | | | NR
Additional question on dosing at weeks 0, 8, 24, and 48
| | | | Other Characteristics:
| | | | Duration HIV infection:
| | | | Mean: 13.3 ± 32.7 month
| | | | Number of pills per day: 14.3 ± 5.7
Citation: | To obtain basic descriptive statistical data for the DICCT | Entering one of four prospective, randomized, double-blind, multicenter, ambulatory trials of anti-infective agents | 275 | Age: | Mean: 14.4 yrs (SD 2.3) | Measurement Tool: | DICCT score (unadjusted): | | | No multivariate analysis concerning literacy included | Total: 1.33
Miller et al., 1996 | | | | Mean: 36 (SD 12.8) | | WRAT | Correlation with WRAT: r = 0.38, suggesting moderate correlation (P< 0.01) | | | | 1. 1; 2. NA; 3. 2; 4. 2; 5. NA; 6. 1.5; 7. 1; 8. 0.5
| | | | Range: 18 to 78 | High school: 26%
Design: | | | | Sex: | 4-year college: 28% | Literacy Levels:
Cross-sectional | To determine interscorer agreement of the scale | | | Female: 62%* | | Mean: 116.9 ± 14.8 | Correlation with WAIS-R vocabulary subtest: r = 0.44, suggesting moderate correlation (P= 0.01)
| | | | | Range: 10 to 24 yrs | Range: 70 to 140
Setting: | | Sequentially enrolled | | Race/Ethniciy: | | Mean is equivalent to reading level > 12th grade
Ambulatory clinical trials of anti-infective agents | | | | NR | (Data not available for 61 subjects)
| To examine the DICCT's criterion validity | | | Income: | | | | | | | Funding Source:
| | | | NR | | | | | | | NR
Duration: | | | | Insurance Status:
One interview | To obtain participants' subjective ratings of the adequacy of clinical trials information | | | NR
| | | | Other Characteristics:
| | | | NR
Citation: | To ascertain the impact of literacy level on parents' understanding of medical information and ability to follow therapy prescribed for their children | Included: | 679 invited | Age: | Mean: | Measurement Tool: | Parental knowledge of health maintenance procedures and child health measures: | | | Parental age | Total: 1.93
Moon et al., 1998 | | Parents accompanying their children for acute care visits between January 30, 1996, and May 31, 1996 | | Mean: 32.4 | 13.43 yrs (SD 2.09) | REALM | | | | Race | 1. 2; 2. NA; 3. 2; 4. 2; 5. 1.5; 6. 2; 7. 2; 8. 2
| | | 17 excluded | Range: 13 to 78 | | | | | | Parental education
| | | | | Range: 7 to 16 yrs | Literacy Levels: | Up-to-date well-child visits: | | | REALM score
Design: | | | | Sex: | | = 3rd: 1.9% | Unadjusted (P = 0.009) and adjusted (P = NS) correlation with REALM
Prospective cohort | | | | Female: 85.8% | | 4th to 6th: 7.6%
| | | 633 enrolled | | | 7th to 8th: 34.7%
| | Excluded: | | Race/Ethnicity: | | = 9th: 55.8% | Knowledge of when the next well-child visit: Unadjusted: (P = 0.026) and adjusted (P = NS) correlation with REALM
Setting: | | English not primary language | | White: 32.2% | | | | | | | Funding Source:
Five sites in metropolitan Washington, DC area: urban hospital-based ambulatory care center, urban HMO pediatric ambulatory care center, and three suburban practices | | | | AA: 65.7% | | | Up-to-date dental visits: Unadjusted (P = 0.05) and adjusted (P = NS) correlation with REALM | | | | NR
| | Adult present not the primary caretaker for the child | | Hispanic: 1.6% | | | Number of chronic medical problems: Unadjusted (P = NS) and adjusted (P = NS) correlation with REALM
| | | | Income: | | | Number of hospitalizations: Unadjusted (P = NS) and adjusted (P = NS) correlation with REALM
| | Not available for telephone followup | | NR | | | Parental perception of how sick child is: Unadjusted (P = 0.0049) and sig correlation with REALM in adjusted model (lowliterate parents considered their children to be more sick)
| | Child being seen for well-child care | | Insurance Status: | | | Parental understanding of medical information (adjusted):
| | | | Commercial: 49.8% | | | Diagnosis: Correlation with REALM (P = NS)
| | | | Medicaid: 42.7% | | | Medication name/instructions: Correlation with REALM (P = NS)
| | | | Uninsured: 7.6% | | | Medication purpose: Correlation with REALM (P = NS)
| | | | | | | Obtain medicine same day: Correlation with REALM (P = NS)
| | | | Other Characteristics: | | | Miss no doses: Correlation with REALM (P = NS)
| | | | Hollingshead social status scale: Mean: 3.9
January to May 1996
| | | | (corresponding to smaller business owners and skilled manual workers)
Duration:
Two interviews, second 48 to 96 hours after the first
Citation: | To examine the relationship between mother's and child's measured intelligence and social class and glycemic control in children with type 1 diabetes | Included: | 78 children and their mothers | Age: | NR | Measurement Tool: | Glycemic control measured by averaging four values obtained over 1 yr | | | Age | Total: 1.58
Ross et al., 2001 | | Children attending the clinic and their mothers | | Median: 12 | | Children: WRAT3 | | | | Sex | 1. 1.5; 2. NA; 3. 1.5; 4. 2; 5. NA; 6. 2; 7. 1; 8. 1.5
| | | | Ragne: 5 to 17 | | Mothers: NART | | | | Duration of Diabetes
Design: | | | 150 recruited | Sex: | | | | | | Daily insulin dose
Cross-sectional | | Excluded: | | Female: 51% | | Literacy Levels: | Correlation between WRAT3 and glycemic control (unadjusted): | | | WRAT
| | Age: < 5 | | | | Mean, standardized: | | | | RSPM
Setting: | | Children with special needs | 102 eligible | Race/Ethnicity: | | Boys: 101.1 | | | | NART
Diabetes clinic at Royal Hospital for Sick Children in Edinburgh, Scotland | | | | NR | | Girls: 106.9 | r = 0.21 (raw score), r = 0.10 (standardized) (P = NS) | | | Social class
| | Families in which English was not the first language | | | | Mean NART mothers:
| | | | Income: | | 20.2
| | | | Social class: | | | Correlation between maternal NART score and glycemic control (unadjusted): | | | | Funding Source:
| | Duration of diabetes | | 1: 5% | | | | | | | Novo Nordisk Pharmaceuticals Ltd.
| | | | 2: 35% | | | r = 0.28 (P = 0.01)
| | One sibling if two affected in one family | | 3 (nonmanual): 16% | | | Glycemic control (adjusted):
Duration: | | | | 3 (manual): 17% | | | Sig predictors were child's age, NART
One interview | | | | 4: 1%
| | Children accompanied by their fathers | | 5: 26%
| | | | Insurance Status:
| | | | NR
| | | | Other Characteristics:
| | | | Mean duration of diabetes:
| | | | 5 yrs
| | | | Range: 1 to 13 yrs
Citation: | To examine the association between health literacy and diabetes outcomes among patients with type 2 diabetes | Included: | 858 potentially eligible | Age: | Some high school or less: 46% | Measurement Tool: | Relationship between literacy (measured as continuous S-TOFHLA score) and HbA1C(adjusted): | | | Age | Total: 2.0
Schillinger et al., 2002 | | > 30 yrs old English or Spanish speaking | | Mean: 58.1 | | S-TOFHLA, English or Spanish version | | | | Sex | 1. 2; 2. NA; 3. 2; 4. 2; 5. NA; 6. 2; 7. 2; 8. 2
| | | | SD: 11.4 | | | | | | Race
| | | | High school graduate or GED: | | | | | | Education
Design: | | Type 2 diabetes | 162 ineligible | Sex: | | Literacy Levels: | For every 1-point increase on S-TOFHLA score, 0.02-point decrease in HbA1C (P = 0.02) | | | Insurance
Cross-sectional | | Database recorded visit with primary care physician in one of the clinics in last 12 months and at least one additional visit to the same physician within the prior 6 months | | Female: 58% | | Adequate: 49% | | | | Language
| | | 261 did not make visit during enrollment period | Male 42% | 23% | Marginal: 13% | | | | Social support
Setting: | | | | | College graduate or some college: | Inadequate: 38% | | | | Depression
Family practice and general internal medicine clinic at San Francisco General Hospital, a public hospital | | | | Race/Ethnicity: | | | Literacy and percentage with HbA1C < 7.2% (tight control) (adjusted): | | | Treatment Regimen
| | | | White: 15% | | | | | | Yrs with diabetes
| | | | Black: 25% | | | | | | Diabetes education | Funding Source:
| | | | Latino: 42% | 28% | | Inadequate: 20% | | | S-TOFHLA score
| | | 36 refused | Asian: 18% | Graduate degree: | | Adequate: 33% OR = 0.57, 95% CI (0.32,1.0) (P = 0.05) | | | Accounted for clustering of patients within physicians | University of California, San Francisco
| | | 17 too ill to participate | Income: | 3% | | | | | Retinopathy and nephropathy models also controlled for hypertension and smoking, extremity amputation, cerebrovascular disease, and ischemic heart disease
| | | | < $20,000/yr: 93% | | | Literacy and percentage with HbA1C > 9.5% (poor control) (adjusted):
| | Excluded: | | | | | | | | | Pfizer Pharmaceuticals
| | End-stage renal disease | 413 completed questionnaire | Insurance Status: | | | Inadequate: 30%
Duration: | | | | Uninsured: 32% | | | Adequate: 20% OR = 2.03, 95% CI (1.11, 3.73) (P = 0.02) | | | | Agency for Healthcare Research and Quality
One interview, enrolled June to December 2000 | | Psychotic disrorder | | Medicare: 36% | | | Literacy and self-reported retinopathy (adjusted):
| | Dementia | | Medicaid: 23% | | | Inadequate: 36% | | | | National Institutes of Health
| | Blindness (corrected vision of 20/50 or worse excluded) | | Commercial: 9% | | | Adequate: 19% OR = 2.33, 95% CI (1.19, 4.57) (P = 0.01
| | | 408 had HbA1C available in database
| | | | Other Characteristics:
| | | | Language:
| | | | Spanish: 36%
| | | | English: 64%
| | | | Depression score: | | | Literacy and self-reported nephropathy (adjusted):
| | | | (possible range: 0 to 100): 38.5 (SD 22.5)
| | | | | | | OR = 1.71, 95% CI (0.75, 3.90) (P = 0.20)
| | | | Yrs with diabetes:
| | | | Mean: 9.5 (SD 8.0)
| | | | Received diabetes education: 78% | | | Literacy and self-reported lower extremity amputation (adjusted):
| | | | | | | OR = 2.48, 95% CI (0.74, 8.34) (P =0.14)
| | | | | | | Literacy and self-reported cerebrovascular disease (adjusted):
| | | | | | | OR = 2.71, 95% CI (1.06, 6.97) (P = 0.04)
| | | | | | | Literacy and self-reported ischemic heart disease (adjusted):
| | | | | | | OR = 1.73, 95% CI (0.83, 3.60) (P = 0.15)
Citation: | To determine if persons with low functional health literacy among community-dwelling Medicare enrollees in a national managed care organization had lower reported levels of preventive care utilization | Included: | 2,722 | Age: | Adequate: | Measurement Tool: | Odds of Having Received Preventive Care Services (adjusted): | | | Study location | Total: 1.92
Scott et al., 2002 | | Age: 65 to 79 | | Mean: 71 | < high school: 22% | S-TOFHLA, administered in English or Spanish | | | | Age | 1. 2; 2. NA; 3. 2; 4. 2; 5. NA; 6. 1.5; 7. 2; 8. 2
| | 3 months after enrollment in heath plan | 7,471 contacted | | High school: 39% | | Literacy: Inadequate, marginal versus adequate | | | Sex
| | | | Sex: | < high school: 39% | | | | | Race
Design: | | | | Adequate: 58% | Marginal: | | Never had influenza vaccine: | | | Education
Cross-sectional | | Language: English or Spanish | 3,247 refused | Marginal: 52% | < high school: 53% | Literacy Levels: | Inadequate: OR = 1.4, 95% CI (1.1, 1.9) | | | Income
| | | | Inadequate: 55% | High school: 28% | Adequate: 69% | Marginal: OR = 1.0, 95% CI (0.7, 1.4) | | | Any doctor visits (last 3 months)
Setting: | | | | | > high school: 20% | Marginal: 11% | Never had pneumococcal vaccine (multivariate model does not control for IADL):
Four Prudential managed care plans (Cleveland, Ohio; Houston, Texas; Tampa, Florida; Ft. Lauderdale-Miami, Florida (south Florida) | | Excluded: | 737 ineligible | Race/Ethnicity: | Inadequate: | Inadequate: 20% | | | | MMSE
| | Dementia: Missed one or more screening questions (not able to correctly identify year, month, state, year of birth, home address) | | Adequate: | < high school: 68% | | | | | Chronic condition
| | | | White: 83% | High school: 22% | | Inadequate: OR = 1.2, 95% CI (1.1, 1.7) | | | IADL limitation | Funding Source:
| | | 143 did not come to interview | Black: 7% | > high school: 10% | | Marginal: OR = 1.2, 95% CI (0.9, 1.7) | | | Literacy
| | | | Hispanic: 8% | | | No mammogram in past 2 yrs (multivariate model does not control for sex, chronic conditions, IADL): | | | | Robert Wood Johnson Foundation
| | | | Marginal: | | | Inadequate: OR = 1.5, 95% CI (1.0, 2.2)
| | | | White: 63% | | | Marginal: OR = 1.0, 95% CI (0.6, 1.5)
| | | 3,487 agreed to participate | Black: 14%
| | Those with severe cognitive impairment as measured by the MMSE | | Hispanic: 22% | | | Never had Pap smear (multivariate model does not control for sex, chronic conditions, IADL):
| | | | Inadequate: | | | Inadequate: OR = 1.7, 95% CI (1.0, 3.1)
| | | | White: 50% | | | Marginal: OR = 2.4, 95% CI (1.2, 4.7)
Data collection between fall and winter of 1996 to 1997 | | | 538 older than 80 | Black: 29%
| | | | Hispanic: 20%
| | Visual acuity: Severe impairment not correctable with eyeglasses | | | | | Differences in educational attainment not sig in any of these multivariate models
| | | 84 did not complete S-TOFHLA | Income:
| | | | < $15,000/yr:
Duration: | | | | Adequate: 32%
One interview | | | | Marginal: 50%
| | | | Inadequate: 62%
| | | | Insurance Status:
| | | | Medicare: 100%
| | | | Other Characteristics:
| | | | Doctor visit in last 3 months:
| | | | Adequate: 87%
| | | | Marginal: 82%
| | | | Inadequate: 86%
| | | | Chronic health condition:
| | | | Adequate: 64%
| | | | Marginal: 68%
| | | | Inadequate: 70%
| | | | Limitation in IADL:
| | | | Adequate: 22%
| | | | Marginal: 33%
| | | | Inadequate: 39%
Citation: | To assess patients' comprehension of their ED discharge instructions | Included: | 228 eligible | Age: | Mean highest grade: 10.4 (SD 1.9) | Measurement Tool: | Comprehension of instructions scored on a scale from 1 to 5 (from no to excellent understanding) (adjusted): | | | Education | Total: 1.75
Spandorfer et al., 1995 | | All patients discharged from the ED during 12 6-hour periods | | Mean: 36.0 (SD 16.6) | | WRAT | | | | Age | 1. 1.5; 2. NA; 3. 2; 4. 2; 5. NA; 6. 1; 7. 2; 2
| | | 5 refused | | | | | | | Sex
| | | | Sex: | | Literacy Levels: | | | | Race
Design: | | | 6 ineligible | Female: 51.6% | | Mean: 42.6 ± 14.8 (corresponds to a 6th grade reading level) | WRAT score positively related (P = 0.024) | | | Residence
Prospective observational study | | Excluded: | | | | | | | | Primary language
| | Unwilling to participate | 217 included | Race/Ethnicity: | | | Mean comprehension score: 4.2 | | | Level of physician training
| To determine if inner-city patients' literacy levels are adequate to comprehend written discharge instructions | Impaired visual acuity rendering them unable to read | | White: 6.9% | | | 23% had no understanding of at least one component of the instructions | | | Sex of physician
| | | | Black: 82% | | = 4th grade: 40% | | | | Medical versus surgical section of ED
Setting: | | | | Hispanic: 8.8% | | | Discharge instruction sheets: 11thgrade based on Flesch and Gunning-Fogg indices; information also provided verbally by physician to some (unmeasured) extent | | | Time of discharge | Funding Source:
Emergency department of hospital in a Philadelphia inner-city area with a high poverty rate | | Unable to communicate in English and no translator | | Asian: 0.5% | | | | | | Literacy | NR
| | | | Income:
| | | | NR
| | Literacy of caretaker measured for children, mentally disabled, and non-English-speaking patients
| | | | Insurance Status:
| | | | NR
Duration: | | | | Other Characteristics:
April to October 1992 | | | | English as native language: 90.8%
| | | | Patient identity:
| | | | Patient: 91.7%
| | | | Parent or guardian: 4.1%
| | | | Caretaker: 0.5%
| | | | Translator: 0.5%
Citation: | To examine the relative value of measures of family adversity, reading, and IQ as predictors of problem behavior and hence their relevance to models of problem behavior | Born at Queen Mary Maternity Hospital, Dunedin, NZ between April 1, 1972 and March 31, 1973 | Original cohort: 1,139 | Age: | NA | Measurement Tool: | Correlations between family adversity scores, IQ scores, and reading ability for boys and girls (all P< 0.01) (unadjusted): | | | Step-wise models: | Total: 1.42
Stanton et al., 1990 | | | | Data used from various ages | | Burt Word Reading Test, 1974 Revision | | | | Model 1: | 1. 1; 2. NA; 3. NA; 4. 2; 5. 1.5; 6. 1; 7. 1.5; 8. 1.5
| | | Age 3: 1,037 | | | | | | | Family adversity
Design: | | | Age 5: 991 | Sex: | | | | | | Early problem behaviour
Prospective cohort | | | Age 7: 954 | Female: 48% | | Literacy Levels: | Reading ability/family adversity:
| | More detailed description of cohort described elsewhere (Silva) | Age 9: 955 | Male: 52% | | NR | Boys: r = -0.26 | | | School-age IQ
| | | Age 11: 925 | | | Used in regression analysis | Girls: r = -0.26
Setting: | | | Age 13: 859 | Race/Ethnicity: | | | Reading ability/preschool IQ: | | | Model 2:
Followup study of children born at Queen Mary Maternity Hospital, Dunedin, New Zealand | | | Age 15: 976 | Predominantly European | | | Boys: r = 0.46 | | | Family adversity
| | Children enrolled in DMHDS | | 3% Polynesian | | | Girls: r = 0.54 | | | Early problem behavior
| | | For this study, 779 children had complete data and included in analysis | | | | Reading ability/school-age IQ: | | | | Funding Source:
| | | | Income: | | | Boys: r = 0.63 | | | School-age IQ
| | | | NR | | | Girls: r = 0.64 | | | | Medical Research Council of New Zealand
| | | | Insurance Status: | | | Change in problem behavior during primary school yrs (adjusted):
| | | | NR | | | Reading ability sig prediction in model
Duration: | | | | | | | 1 (entered as variable 4) and model
Measured at birth, ages 3, 5, 7, 11, 13, and 15 | | | | Other Characteristics: | | | 2 (entered as variable 3)
| | | | Family occupational background at child age 3:
| | | | Unskilled: 22%
| | | | Semiskilled: 55%
| | | | Skilled: 23%
Citation: | To conduct a formal methodologic comparison of the response rates, item completion rates, and reliability of self-reported health status measures by three different methods of data collection | Type 2 diabetes mellitus | 983 eligible | Age: | QLS fail: | Measurement Tool: | General health status (based on SF-36) (unadjusted): | | | No multivariate analysis concerning literacy included | Total:1.50
Sullivan et al., 1995 | | | | QLS fail: | Mean: | QLS | | | | | 1. 1.5; 2. NA; 3. 2; 4. 1.5; 5. NA; 6. 1.5; 7. 1.5; 8. 1
| | Primary care physician enrolled in PORT study | 697 to agreed to participate (70.9%) | Mean: 64.5 | 8.0 yrs | | Mean scores on the eight dimensions of SF-36 were not sig different between patients who passed and failed the QLS, with the exception of physical function
| | | | QLS pass: | QLS pass: | Literacy Levels:
Design: | | | | Mean: 58.5 | Mean: | Pass: 65%
Cross-sectional | | | | | 10.9 yrs | Fail: 35%
| | | | Sex:
Setting: | | | | QLS fail: | | | Patients who failed reported significantly poorer physical funtioning:
General medicine practice at Regenstrief Health Center, Indianapolis, Indiana | | | | Female: 70.4%
| | | | QLS pass: | | | | | | | Funding Source:
| | | | Female: 73.3% | | | Mean: 33.5 versus 39.2 (P <0.05)
| | | | Race/Ethnicity: | | | | | | | Agency for Healthcare Policy and Research
| | | | QLS fail:
| | | | AA: 64.2%
| | | | QLS pass:
Duration: | | | | AA: 57.1%
Completion of questionnaires at 6-month intervals over 3 yrs
| | | | Income
| | | | < $5,000:
| | | | QLS fail: 65.5%
| | | | QLS pass: 46.6%
| | | | Insurance Status:
| | | | NR
| | | | Other Characteristics:
| | | | Currently working:
| | | | QLS fail: 8.0%
| | | | QLS pass: 15.2%
| | | | Fair or poor self-reported vision:
| | | | QLS fail: 64.8%
| | | | QLS pass: 46.4%
Citation: | To report on the development and use of an easy-to-administer literacy screening instrument and to determine the relationship of reading levels ascertained in this way to the sociodemo-graphic and health profiles of nutrition program participants | Age: 40 to 70 | 339 | Age: | < 8 yrs: 8% | Measurement Tool: | Health outcomes (adjusted) by CARDES literacy score: | | | Age | Total: 0.67
TenHave et al., 1997 | | Washington, DC, area | | 40 to 54: 41% | 8 to 11 yrs: | CARDES (developed for this study) | | | | Sex | 1. 1; 2. NA; 3. 0; 4. 1.5; 5. NA; 6. 0.5; 7. 1; 8. 0
| | | (Response rate NR; no information provided to calculate) | 55 to 70: 59% | 20% | | Heart Healthy Knowledge: | | | Literacy
| | | | Range: 40 to 70 | 12 yrs: 32% | Score 0 to 9: < 5th grade reading level | 0 to 9: 28%
Design: | | | | | > 12 yrs: | | 10 to 16: 31%
Cross-sectional | | | | Sex: | 38% | 10 to 16: 5th to 8th grade reading level | 17 to 20: 42%
| | | | Female: 74% | | | (P = NR)
Setting: | | | | | | 17 to 20: > 8th grade reading level | Heat attack:
Cholesterol screenings in local super-markets; recruited for participation in CARDES | | | | Race/Ethnicity: | | | 0 to 9: 14%
| | | | AA: 99% | | | 0 to 9: 14%
| | | | | | Similar to REALM and TABE | 10 to 16: 4%
| | | | | | | 17 to 20: 3% | | | | Funding Source:
| | | | | | Rank order correlation with REALM: Not given; with TABE: 0.73 (Cronbach's alpha 0.87) | (P = 0.012)
| | | | Income: | | | Hospitalized for heart condition: | | | | National Heart, Lung, and Blood Institute
| | | | < $10,000: 38% | | | 0 to 9: 24%
| | | | | | 0.73 (Cronbach's alpha 0.87) | 10 to 16: 12%
| | | | Insurance Status | | | 17 to 20: 7%
| | | | NR | | | (P = 0.003)
Duration | | | | | | Literacy Levels (grade level): | Diabetes:
Repeated interviews | | | | Other Characteristics: | | | 0 to 9: 20%
| | | | Occupation: | | < 5th: 15% | 10 to 16: 20%
| | | | Administrative/ managerial: 12% | | 5th to 8th: 33% | 17 to 20: 10%
| | | | | | > 8th: 52% | (P = 0.053)
| | | | Professionals/ teachers/school personnel: 40% | | | Depression score, mean:
| | | | | | | 0 to 9: 4.58
| | | | | | | 10 to 16: 3.50
| | | | Technicians/clinicians: | | | 17 to 20: 2.56
| | | | 8% | | | (P = 0.0001)
| | | | Labor, maintenance, factory worker: 21%
| | | | | | | Information in alternate formats by CARDES literacy score (unadjusted):
| | | | Service occupations, safety, security: 19%
| | | | | | | Used nutrition guide more than audio series:
| | | | Hypertension: 50%
| | | | Cholesterol > 200 mg/day: | | | 0 to 16: 19%
| | | | 86% | | | 17 to 20: 28%
| | | | History of heart attack: 6% | | | (P = 0.02)
| | | | History of hospitalization for heart condition: 12% | | | Used nutrition guide and audio series equally:
| | | | Diabetes: 14% | | | 0 to 16: 27%
| | | | | | | 17 to 20: 28% (P = NR)
| | | | Leisure activity light/inactive: 79% | | | Used audio series more then nutrition guide:
| | | | Work activity light/inactive: | | | 0 to 16: 54%
| | | | 74% | | | 17 to 20: 28% (P = NR)
| | | | Rate Your Plate Knowledge:
| | | | 20 to 33 (least knowledgeable): 9%
| | | | 34 to 47 (somewhat knowledgeable): 55%
| | | | 48 to 60 (very knowledgeable): 36%
Citation: | To determine the literacy skills of a population of Medicaid enrollees and if there was an association between their literacy skills and their health care costs | Included: | 402 willing to participate (approximately 75% of potential subjects) | Age: | Mean: 9.7 yrs (SD 3.7) | Measurement Tool: | Medicaid charges: | | | Not listed, although stated that they conducted multivariate analyses controlling for confounders | Total: 1.50
Weiss et al., 1994 | | Age: = 18 | | Mean: 49.0 | | IDL | Entire cohort: | | | | 1. 1.5; 2. NA; 3. 1.5; 4. 2; 5. NA; 6. 2; 7. 1.5; 8. 0.5
| | English or Spanish speaking | | Range: 18 to 94 | | | Median: $1,100
| | | | Range: 0 to 13 yrs | | Literacy Levels: | Range: $0 to $95,002
Design: | | Qualified for Medicaid because of AFDC eligibility, disability, or medical need/indigence | | Sex: | | Grade equivalent: | Mean: $4,574
Retrospective cohort | | | | Female: 78.4% | | 0: 8.7% | Charges by grade level (median):
| | | | Male: 21.6% | | 1: 4.7%
| | | 1. Computer generated random selection;; 2. letter followed by phone call;; 3. if no answer to repeated calls or unwilling to participate, an alternate subject selected at random | | | 2: 5.1% | 0: $938
Setting: | | | | Race/Ethnicity: | | 3: 5.6% | 1: $1,442
Members of a large Medicaid managed care plan in Tucson, Arizona | | Enrolled in the program for at least 1 yr prior to the start of the research | | White: 42.8% | | 4: 4.2% | 2: $744
| | | | AA: 5.5% | | 5: 5.2% | 3: $392 | | | | Funding Source:
| | | | Hispanic: 45.8% | | 6: 13.7% | 4:$944
| | | | Native American: 0.5% | | 7: 14.2% | 5: $2,041 | | | | Arizona Disease Control Research Commission (Arizona Department of Health and Human Services)
| | | | Asian: 0.5% | | =8: 38.6% | 6: $1,000
| | Excluded: | | Other: 3.7% | | Mean reading levels: | 7: $1,430
Duration: | | Those with medical conditions that might preclude an accurate assessment of reading skills (e.g., dementia, mental retardation, severe visual impairment) | | | | English speaking: 6.3 | =8: $1,367
12 months | | | | Income: | | Spanish speaking: 3.1
| | | | NR | | (P = 0.018) | Medicaid charges (adjusted):
| | | | Insurance Status: | | | Relationship with literacy level:
| | | | Medicaid: 100% | | | R^2^= 0.0016 (P = 0.43)
| | | | Other Characteristics: | | | Various components of medical charges (adjusted) including inpatient care, outpatient care, emergency care, home health care, physicians' fees, ancillary services such as laboratory, x-ray, pharmacy, durable medical equipment, short-term nursing home care:
| | | | Marital status:
| | | Those with congenital or hereditary disorders, including schizophrenia, which by themselves could affect medical costs independent of any possible relationship to literacy skills | Married: 20.2%
| | | | Single: 35.8%
| | | | Divorced: 32.6%
| | | | Widowed: 11.2%
| | | | Separated: 0.2%
| | | | Employment status:
| | | | Unemployed: 84.1% | | | No sig relationship with literacy level
| | | | Working: 6.0%
| | | | Not reported: 9.9%
| | | | Self-assessment of health:
| | | Patients who had been pregnant during the year of study to avoid confounding by charges of relating to pregnancy care | Excellent: 5.5%
| | | | Good: 35.3%
| | | | Fair: 42.5%
| | | | Poor: 16.7%
| | | | Language of best skill:
| | | | English: 80.1%
| | | | Spanish: 19.9%
| | | | Medicaid enrollment category:
| | | | Disabled: 55.5%
| | | | AFDC: 26.1%
| | | | Needy/indigent: 18.4%
Citation: | To determine whether a relation exists between literacy and health status among a group of US adults with poor literacy skills | Included: | 197 met eligibility requirements | Age: | Mean: | Measurement Tool: | Score on SIP (questionnaire) measuring health status; higher SIP score indicates poorer health (adjusted): | | | Age | Total: 1.92
Weiss et al., 1992 | | Student in PACE | | Mean: 28.5 (SD 10.6) | Grade 9.9(SD 1.96) | Tests of Adult Basic Education and Mott Basic Language Skills Program | | | | Sex | 1. 2; 2. NA; 3. 2; 4. 2; 5. NA; 6. 2; 7. 1.5; 8. 2
| | Reading skills between grade level 0 and 12.9 | | | | | | | | Ethnicity
| | | | Sex: | | | | | | Marital status
Design: | | | | Female: 61% | | | Mean physical score: | | | Insurance status
Cross-sectional, participants selected randomly from within each class | | Spoke and understood English well enough to participate in study | 193 agreed to participate | | | | = 4th reading: 6.2 | | | Occupation
| | | | Race/Ethnicity: | | Literacy Levels: | > 4th reading: 2.3 | | | Income
| | | | White: 29.5% | | Mean grade: | Difference: (P =0.002) | | | Literacy
| | | | Black: 9.8% | | 7.17 (± 2.77) | Mean psychosocial score:
| | English spoken in the home when children | | Hispanic: 53.4% | | 5th to 6th: 20% | > 4th reading: 8.0 | | | | Funding Source
| | | | Native American: 6.7% | | 7th to 8th: 23%* | Difference: (P =0.02)
| | Age: = 16 | | Other: 0.6% | | = 9th: 37%* | Mean overall (total): | | | University of Arizona Foundation
Setting: | | Excluded: | | Income: | | | = 4th reading: 10.4
PACE program in Tucson, Arizona | | Mentally retarded | | Mean: $7,610/yr (SD $7,020/yr) | | | > 4th reading: 6.0
| | Known learning disability | | | | | Difference: (P = 0.02)
| | | | Insurance status
Duration: | | | | NR
One interview
| | | | Other Characteristics:
| | | | Language spoken in childhood home:
| | | | English only: 71.0%
| | | | English and Spanish: 26.9%
| | | | Country of birth:
| | | | US: 91.2%
| | | | Mexico: 6.7%
Citation: | To determine the relationship of literacy to asthma knowledge and ability to use an MDI among patients with asthma | Included: | Enrolled sequentially based in patients attending ED or AC at certain days and times | Age: | ED: | Measurement Tool: | Mean knowledge score (range 0 to 20) unadjusted: | | | Yrs of schooling | Total: 1.83
Williams, Baker, Honig, et al., 1998 | | Treatment for asthma in the ED or AC | | ED: | = 6 yrs: 3% | | | | | Self-perceived better understanding of asthma | 1. 2; 2. NA; 3. 1.5; 4. 2; 5. NA; 6. 1.5; 7. 2; 8. 2
| | | | Mean: 37.3 (SD 13.6) | 7 to 11: 29% | REALM | = 9th literacy level: 15.1
| | Age: = 18 | | AC: | 12: 40% | | = 3rd literacy level: 11.9 | | | Reported regular source of care
| | = 3-month history of asthma | | Mean: 46.7 (SD 14.9) | > 12: 28% | Literacy Levels: | r = 0.36
Design: | | | | | | | Knowledge increased at each of the four literacy levels (P < 0.01) | | | Age
Cross-sectional | | No prior diagnosis of COPD, emphysema, chronic bronchitis | | Sex: | AC: | = 3rd: 13% | | | | Duration of asthma
| | | | Female: | = 6 yrs: 5% | 4th to 6th: 27% | | | | Health status
Setting: | | | | ED: 59% | 7 to 11: 30% | 7th to 8th: 33% | Asthma knowledge score (adjusted): | | | Insurance status
Emergency department and asthma clinic at Grady Memorial Hospital, an urban public hospital in Atlanta, Georgia | | | ED: | AC: 81% | 12: 34% | = 9th: 27% | Relationship with literacy level (= 9th grade comparison group): | | | Site of study entry Literacy
| | | 398 approached, 25 excluded, 57 refused, 48 failed to complete survey | | > 12: 30% | | | | | | Funding Source:
| | Excluded: | | Race/Ethnicity: | | | Literacy | Coefficient | P value | | NR
| | Intoxication | | ED: | | | = 3rd | -2.8 | < 0.001
| | Overt psychiatric illness | | White: 5% | | | 4th to 6th | -1.5 | < 0.001
| | | | Black: 95% | | | 7th to 8th | -1.1 | < 0.001
| | Lack of cooperation | | AC: | | | Difference in knowledge score between those reading at = 9th grade and those reading at = 3rd grade (adjusted): 2.7 points, 95% CI (1.9, 3.5)
| | Native language other than English | | White: 11% | | | Metered dose inhaler skills (0 to 6 steps) (adjusted):
| | | | Black: 89% | | | Literacy | Coefficient | P value
| | Too ill to participate | AC: | | | | = 3rd | -1.3 | < 0.001
| | Vision worse than 20/100 | 255 approached, 16 excluded, 12 refused, 10 failed to complete survey | Income: | | | 4th to 6th | -0.7 | < 0.001
Duration | | | | NR | | | = 7th to 8th | -0.2 | 0.13
November 1995 to May 1996 | | Prior enrollment in the study | | | | | Difference in number of correct metered dose inhaler steps between patients reading at = 9th to those reading at = 3rd: 1.3 steps, 95% CI (0.9, 1.7)
| | | | Insurance Status:
| | | | ED:
| | | | Insured: 38%
| | | | AC:
| | | | Insured: 54%
| | | Total:
| | | 510 completed survey, 483 completed REALM, 469 completed | Other Characteristics:
| | | | Yrs of asthma:
| | | | ED:
| | | | = 1: 3%
| | | | 2 to 5: 11%
| | | | 6 to 10: 13%
| | | | 11 to 20: 21%
| | | | > 20: 52%
| | | MID assessment, 483 included in analysis | AC:
| | | | = 1:8%
| | | | 2 to 5: 23%
| | | | 6 to 10: 14%
| | | | 11 to 20: 17%
| | | | > 20: 38%
Citation: | To examine the relationship between functional health literacy level and knowledge of their chronic disease and treatment among patients with hypertension or diabetes | Included: | Harbor: | Mean Age: | HTN (n=402): | Measurement Tool: | HTN: | | | Age | Total: 1.92
Williams, Baker, Parker, et al., 1998 | | HTN or DM | 488 screened, 386 eligible, 364 completed interview | HTN (n = 402): | Adequate: | TOFHLA | Knowledge measured by 21 item test (unadjusted): | | | Yrs of school completed | 1. 2; 2. NA; 3. 2; 4. 2; 5. NA; 6. 1.5; 7. 2; 8. 2
| | At least one medication | | Adequate: 53.4 | = 6th: 2% | | | | | Duration of disease
| | | | Marginal: 57.7 | 7th to 11th: 31% | Literacy Levels: | Adequate: 16.5 ± 2.3
| | Age: = 18 | | Inadequate: 64.2 | 12th: 37% | HTN (n = 402): | Marginal: 15.2 ± 2.2
Design: | | Not previously enrolled in any literacy studies | | DM (n = 114): | Marginal: | Adequate: 39% | Inadequate: 13.2 ± 3.1
Cross-sectional | | | | Adequate: 49.8 | = 6th: 10% | Marginal: 12% | Difference: (P < 0.001)
| | | | Marginal: 53.2 | 7th to 11th: 56% | Inadequate: 49%
Setting: | | No overt psychiatric | Grady: | Inadequate: 57.5 | 12th: 26% | DM (n = 114): | Difference between inadequate and adequate literacy (adjusted):
Grady Memorial Hospital, Atlanta, Georgia, and the Harbor-UCLA Medical Center general medicine clinic in Torrance, California (both are public hospitals) | | | 284 screened, 250 eligible, 216 completed interview | | Inadequate: | Adequate: 45%
| | Not in police custody | | Sex: | = 6th: 42% | Marginal: 11% | | | | | Funding Source:
| | Not too ill to participate | | Female: | 7th to 11th: 40% | Inadequate: 44% | OR = 1.9, 95% CI (1.2, 2.6)
| | No unintelligible speech | | HTN (n = 402): | 12th: 15% | | | | | | Robert Wood Johnson Foundation
| | | | Adequate: 72% | | | DM:
| | No lack of cooperation | | Marginal: 88% | DM (n = 114): | | Knowledge measured by 10 item test (unadjusted):
| | Registered into the clinic and waiting to see a physician | | Inadequate: 69% | Adequate: | | Adequate: 8.1 ± 1.6
| | | | DM (n = 114): | = 6th: 2% | | Marginal: 7.1 ± 2.0
| | | | Adequate: 67% | 7th to 11th: 29% | | Inadequate: 5.8 ± 2.1
| | Vision equal to or better than 20/100 | | Marginal: 69% | 12th: 37% | | Difference: (P < 0.001)
| | | | Inadequate: 76% | Marginal: | | Diabetes knowledge = 5
| | | | | = 6th: 39% | | answers correct versus > 5
| | Excluded: | | Race/Ethnicity: | 7th to 11th: 39% | | answers correct (adjusted):
| | Grady only: English as second language | | HTN (n = 402): | 12th: 15% | | OR = 4.5, relationship negative and sig
Duration: | | | | Adequate: | Inadequate: | | No sig association found between literacy and blood glucose control or blood pressure
One interview | | | | White: 17% | = 6th: 78%
| | | | Black: 64% | 7th to 11th: 16%
| | | | Latino: 16% | 12th: 4%
| | | | Marginal:
| | | | White: 4%
| | | | Black: 78%
| | | | Latino: 18%
| | | | Inadequate:
| | | | White: 5%
| | | | Black: 72%
| | | | Latino: 22.5%
| | | | DM (n = 114):
| | | | Adequate:
| | | | White: 33%
| | | | Black: 37%
| | | | Latino: 29%
| | | | Marginal:
| | | | White: 0%
| | | | Black: 31%
| | | | Latino: 69%
| | | | Inadequate:
| | | | White: 2%
| | | | Black: 18%
| | | | Latino: 80%
Citation: | To examine (a) the relationship between patients' own reports of the highest grade completed in school and their actual reading level and (b) the relationship between literacy and patients' level of knowledge about self-care after receiving education involving written discharge ins tructions | Orthopedic patient | 26 | Age: | Completed | Measurement Tool: REALM | Relationship between self- reported educational level and actual reading level (unadjusted): | | | No multivariate analysis concerning literacy included | Total: 1.08
Wilson and McLemore, 1997 | | Age: = 18 | | Mean: 66 | junior high: | REALM | | | | | 1. 0.5; 2. NA; 3. 1; 4. 2; 5. NA; 6. 1; 7. 1.5; 8. 0.5
| | English-speaking | | Range: 29 to 82 | 11.5% | Literacy Levels:
| | Physically and mentally able to participate in the study | | | High school | = 3rd: 0 | r = -0.39 (P <0.05)
| | | | Sex: | graduate: | 4th to 6th: 4% | As self-reported educational level increased, patient's actual ability to read decreased
Design: | | | | Female: 65.4% | 46.2% | 7th to 8th: 19%
Cross-sectional | | | | | Some college: | = 9th: 77%
| | | | Race/Ethnicity:
Setting: | | | | White: 46%* | 19.2% | | Relationship between literacy level and patients' level of knowledge about self-care after receiving written education materials as measured by questionnaire (unadjusted):
Patients hospitalized for orthopedic surgery on knee or hip | | | | AA: 54%* | College graduate: | | | | | | Funding Source:
| | | | Income: | 23.1% | | | | | | NR
| | | | NR | (Range:
| | | | | Junior high school or greater)
| | | | Insurance Status: | | | (P = NS)
Duration: | | | | NR
One interview | | | | | | | Readability of discharge instructions (Fry readability formula):
| | | | Other Characteristics:
| | | | Hip replacement: 34.6%
| | | | Knee replacement: 65.4% | | | Total hip arthroplasty: 5th grade level
| | | | | | | Precautions for patients with arthroplasty joints: 8th grade level
| | | | | | | Total joint replacement instructions: College level
| | | | | | | Mean readability level for the three discharge instruction tools: 10th grade level
Citation: | To determine the relationship between maternal depressive symptoms and low literacy on child developmental outcomes in a welfare population | Included: | 372 families completed Wave 1 data (83% of those invited) | Age: | High school graduate, GED, or greater: 66% | Measurement Tool: | Overall, 39% of participants were depressed | | | Maternal literacy | Total: 1.86
Zaslow et al., 2001 | | Mothers and their children if: | | NR | | TALS (document literacy scale) | 25% had low literacy and depression | | | Maternal depressive symptoms | 1. 2; 2. NA; 3. 2; 4. 2; 5. 2; 6. 2.5; 7. 1.5; 8. 1.5
| | The mother would otherwise qualify for AFDC | | Sex: | | Literacy Levels: | 28% had low literacy but no depression
Design: | | | | Female: 100% | | Low literacy (Levels 1 to 2 on TALS): 53%
Cohort study | | The child was between 3 and 4 yrs of age at enrollment | | Children: NR | | | 33% did not have low literacy and no depression
Setting: | | Members of AA families | Final analysis limited to 351 | Race/Ethnicity: | | | 14% did not have low literacy but also had depression
Atlanta, Georgia (community based) | | | | AA: 100% | | | | | | | Funding Source:
Duration: | | Excluded: | | Income: | | | Child's score on depressive/withdrawn subscale of the Behavior Problems Index (adjusted): | | | | Office of the Assistant Secretary for Planning and Evaluation
5 yrs | | Mothers with a severely ill or disabled child | | Any earnings in past year: 20% | | | Sig effect of interaction of maternal literacy and maternal depression (P = 0.01) | | | | Department of Health and Human Services
| | Family member with a chronic health condition | | | | | “In the presence of lower maternal literacy, children of mothers with more depressive symptoms had more depressive/withdrawn behavior problems than children of mothers with fewer depressive symptoms”(P = 0.001)
| | | | Insurance Status: | | | “However, in the presence of higher maternal literacy, depressive/withdrawn scores did not differ according to depressive symptom level”P= NS)
| | | | Medicaid: 100%
| | | | Other Characteristics:
| | | | Mean maternal age at first birth: 21.5

Evidence Table 2: Key Question 2

Study Description | Research Objective | Eligibility Criteria | Total Sample Size | Demographic and Other Characteristics | Education | Literacy Measurement | Intervention | Main Outcomes and Results | Covariates Used in Multivariate Analysis | Quality Score
Citation: | To determine the effect of an osteoarthritis education program for low-literacy adults | NR | 100 enrolled | Age: | Mean yrs of school: 8.8 | Measurement Tool: | Specially designed osteoarthritis educational program administered by “indigenous community leaders” | Change in knowledge pre/postverbal and picture tests | No multivariate analysis concerning literacy included | Total: 0.69
Bill-Harvey et al., 1989 | | | | Mean: 73 | | | | | | 1. 1; 2. 1; 3. 0; 4. 0; 5. 0; 6. 1; 7. 1.5; 8. 1
| | | 76 completed (75%) | Range: 54 to 89 | Range: 0 to 15 | None
| | | | | =9th grade: 58% | | | Verbal knowledge change: Increase 9.5 percentage points (P < 0.001)
Design: | | | | Sex: | | Literacy Levels:
Uncontrolled trial | | | | Female: 96% | | NA
| | | | Race/Ethnicity: | | | | Picture knowledge change: Increase 0.8 percentage points (P < 0.001)
Setting: | | | | White: 34%
Senior centers and community centers within housing complexes for the elderly in Hartford, Connecticut | | | | Black: 66%
| | | | | | | | | | Funding Source:
| | | | Income: | | | | | | National Institutes of Health
| | | | NR
| | | | Insurance Status:
| | | | NR
| | | | Other Characteristics:
Duration: | | | | NR
6 weeks
Citation: | To develop and test low-literacy written materials for breast cancer prevention in AA women | Women only | Controls: 258 | Mean Age: | NR | Measurement Tool: | Control: | Women who received the materials had greater knowledge and intention to follow CBE and BSE guidelines (P < 0.001) | No multivariate analysis concerning literacy included | Total: 0.71
Coleman et al., 2003 | | | | Controls: 33.7 (14 to 69) | | | Received no intervention | | | 1. 1; 2. 2; 3. 0; 4. 0; 5. NA; 6. 1.5; 7. 0.5; 8. 0
| | | | Intervention: 41.2 (15 to 64) | | None
| | | Intervention patients: 116
Design: | | | | | | Literacy Levels: | Intervention:
Two-group non-randomized trial | | | | Sex: | | NA | Received two educational pamphlets: one with drawings, the other using photographs; written at third grade level
| | | | Female: 100%
| | | | | | | | Women who received the materials were more accurate in performing BSE on a 0 to 19 scale: Mean 10.2 versus 4.3 (P < 0.001)
Setting: | | | | Race/Ethnicity:
Women receiving care in health department clinics in Arkansas | | | | Controls:*
| | | | White: 9% | | | | | | Funding Source:
| | | | AA: 47% | | | | | | National Cancer Institute
| | | | Hispanic: 13%
| | | | Other: 1%
| | | | Intervention:* | | | | Among AA women 40 and older, women who received materials were more accurate in performing BSE (P = 0.001)
| | | | White: 45%
Duration: | | | | AA: 53%
Pre- and post test interviews | | | | Hispanic: 3%
| | | | Income:
| | | | NR
| | | | Insurance Status:
| | | | NR
| | | | Other Characteristics:
| | | | NR
Citation: | To study the effect of three approaches to increase mammography usage | Age: = 40 | 445 | Age: | 50% < high school grad | Measurement Tool: | Group 1: Personal recommendation for mammography | Mammography rate at 6 months (unadjusted): | Age | Total: 1.63
Davis, Berkel, et al., 1998 | | Ambulatory care or eye clinic patient | | Mean: 56 | | | | | Race | 1. 2; 2. 1.5; 3. 1.5; 4. 2; 5. 0.5; 6. 1.5; 7. 2; 8. 2
| | | | | | REALM | | | Literacy
| | No mammogram in the past year | | Sex: | Intervention Group 1: | | | Group 1: 21% | Mammography
Design: | | | | Female: 100% | | Literacy Levels: | Group 2: Same intervention as received by intervention group 1 and National Cancer Institute brochure on mammography designed for low-literacy women | Group 2: 18% | Knowledge at baseline
RCT | | | | | Mean grade completed: 9.8 | Mean: 4th to 6th | | Group 3: 29%
| | | | Race/Ethnicity: | | Intervention: | | Difference: (P = 0.05)
Setting: | | | | White: 30% | < 6th: 15% | Group 1:
University Hospital, Shreveport, Louisiana | | | | AA: 69% | 7th to 8th: 11% | 0 to 3rd: 25%
| | | | | 9th to 11th: 29% | 4th to 6th: 21% | | Mammography rate at 6 months (adjusted):
| | | | Income: | | 7th to 8th: 30% | | | | Funding Source:
| | | | < $20,000/yr: 97% | High school/ college: 45% | > 9th: 24% | | | | National Cancer Institute
| | | | | | Group 2: | | Sig difference between the three intervention groups (P = 0.03)
Duration: | | | | Insurance Status: | | 0 to 3rd: 29%
Intervention and 6-month record/telephone followup | | | | NR | Intervention Group 2: | 4th to 6th: 18% | Group 3: Same intervention as received by intervention group 2 and custom 12-minute interactive motivational and educational intervention for small groups, including video based on focus groups held with low-income women and led by peer educator and cancer nurse | | | The Cancer Center for Excellence in Research, Treatment and Education, Louisiana State University Medical Center, Shreveport, Louisiana
| | | | | | 7th to 8th: 30%
| | | | Other Characteristics: | Mean grade Completed: 9.5 | > 9th: 23%
| | | | NR | < 6th: 11% | Group 3: | | Mammography at 24 months (unadjusted):
| | | | | 7th to 8th: 22% | 0 to 3rd: 20%
| | | | | 9th to 11th: 28% | 4th to 6th 26% | | Group 1: 37%
| | | | | | 7th to 8th: 31% | | Group 2: 34%
| | | | | High school/ college: 37% | > 9th: 23% | | Group 3: 40%
| | | | | | | | Difference: (P = NS)
| | | | | Intervention Group 3:
| | | | | Mean grade completed: 10.0
| | | | | < 6th: 16%
| | | | | 7th to 8th: 12%
| | | | | 9th to 11th: 26%
| | | | | High school/college: 46%
Citation: | To determine whether a simple pamphlet concerning the polio vaccine prepared at a low reading level would be preferable to the available Centers for Disease Control and Prevention polio vaccine pamphlet | Parents, adults accompanying children, or adult patients seen in one of three pediatric clinics in July 1993 | 568 potential | Age: | Mean: 12.3 yrs | Measurement Tool: | Group 1: | Reading time-mean: | No multivariate analysis concerning literacy included | Total: 1.50
Davis, Bocchini, et al., 1996 | | | | Mean: 29 | Range: 2 to 20 yrs | | Centers for Disease Control and Prevention improved pamphlet (existing intervention); readability using Fog index 10th grade | Group 1: 13 min 47 sec | | 1. 1.5; 2. 2; 3. 0.5; 4. 2; 5. NA; 6. 1.5; 7. 1.5; 8. 1.5
| | | | Range: 13 to 70 | | REALM | | Group 2: 4 min 20 sec
| | | 32 refused | | Non-high school graduates: 65% | | | Difference: (P < 0.0001)
Design: | | | | Sex: | | Literacy Levels:
Nonrandomized controlled trial | | | 14 incomplete data | NR | | Mean: 54 (7th to 8th grade) | | Comprehension score-mean:
| | | | Race/Ethnicity: | | Range: 1 to 66 (= 3rd grade to = high school) | | Group 1: 56%
Setting: | | | | White: 39% | | | | Group 2: 72%
Three clinic sites in Shreveport: pediatric clinic at Louisiana State University, Caddo Parish Health Unit, and private pediatric office | | | 522 final sample | Black: 60% | | | | Difference: (P < 0.0001)
| | | | Hispanic: 1% | | > 9th grade: 53% | | | | Funding Source:
| | | | | | > 7th grade: 80% | Group 2: | Outcomes stratified by reading level: | | NR
| | | Group 1: | Income: | | | Louisiana State University pamphlet (new intervention); readability using Fog index 6th grade
| | | 233 | NR | | | | = 9th grade readers comprehension:
| | | Group 2: | Insurance Status: | | | | Group 1: 67%
| | | 289 | Privately insured: 28% | | | | Group 2: 83%
| | | | | | | | Difference: (P < 0.0001)
| | | | Other Characteristics:
Duration: | | | | Site: | | | Structured survey used to capture participant demographics, attitudes, and comprehension | =6th grade readers comprehension:
One interview | | | | Private clinic: 19% | | | | Group 1: 37%
| | | | Hospital clinic: 33% | | | | Group 2: 51%
| | | | Public health clinic: 48% | | | | Difference: (P < 0.002)
| | | | | | | | =3rd grade readers comprehension:
| | | | | | | | Group 1: 29%
| | | | | | | | Group 2: 45%
| | | | | | | | Difference: (P < 0.07)
Citation: | To compare two polio vaccine pamphlets written on a 6th grade level for reading ability, comprehension, and preference | Parents or other adults accompanying children being seen for immunization in one of the clinics | 646 potential | Mean Age: | Mean: 12.5 yrs | Measurement Tool: | Group 1: | Comprehension: | No multivariate analysis concerning literacy included | Total: 1.71
Davis, Fredrickson, et al., 1998 | | | | Group 1: 28 | = 9th: 97% | | Centers for Disease Control and Prevention improved pamphlet (existing intervention) | All reading levels: | | 1. 2; 2. 2; 3. 1; 4. 2; 5. NA; 6. 1.5; 7. 2; 8. 1.5
| | | | Group 2: 29 | = 10th: 86% | REALM | | Group 1: 60%
| | | 26 refused | | 1+ yr college: 30% | | | Group 2: 65%
| | | | Sex: | | Literacy Levels: | | Difference: (P < 0.01)
Design: | | | 10 incomplete data | Group 1: Female: 92% | | Mean: 7th to 8th grade
RCT, randomized by day of week in clinic | | | | Group 2: Female: 94% | | | | By reading levels:
| | | | | | = 9th grade: 69% | | Group 2 better than Group 1 for = 9th grade reading levels (P < .001)
| | | | Race/Ethnicity:
| | | 610 included | Group 1: | | | Group 2:
| | | | White: 50% | | | Louisiana State University pamphlet (new intervention) | | | Funding Source:
Setting: | | | | Black: 49% | | | | No sig difference between the two groups for < 9th grade levels (P < .001) | | NR
Three clinic sites in Shreveport: pediatric clinic at Louisiana State University, Caddo Parish Health Unit, and private pediatric office | | | | Group 2:
| | | | White: 52%
| | | | Black: 47%
| | | | | | | Readability using Fox index (6th grade) and Flesh Kincaid (4th grade) same for both interventions
| | | | Income: | | | | Comprehension scores of those in lowest two reading levels, 0 to 3 and 4 to 6 not sig improved with Group 2 pamphlet
| | | | NR
| | | | Insurance Status:
| | | | NR
June to July 1995 | | | | Other Characteristics:
| | | | Group 1:
| | | | Private clinic: 33%
Duration: | | | | Hospital clinic: 28%
One interview | | | | Public health clinic: 39%
| | | | Group 2:
| | | | Private clinic: 33%
| | | | Hospital clinic: 33%
| | | | Public health clinic: 34%
Citation: | To test if a simplified consent form developed at Louisiana State University Medical Center would improve the comprehension and attitude of participants compared to the standard SWOG consent form | Patients, friends, or family members at private and university oncology clinics | 183 | Age: | Mean: 11.9 yrs | Measurement Tool: | Specially developed consent form with readability of 7th grade level on Fog index versus standard form with 16th grade level on Fog index | Patient comprehension measured on a 10-item scale (percent correct): | No multivariate analysis concerning literacy included | Total: 1.43
Davis, Holcombe, et al., 1998 | | | | Mean: 48 | | | | | | 1. 1.5; 2. 2; 3. 1; 4. 2; 5. NA; 6. 1.5; 7. 1; 8. 1
| | | | Range: 19 to 85 | | REALM
| | | | Sex: | | Literacy Levels:
Design: | | Residents of low-income housing project | | Female: 76% | | REALM mean: 52 (average 7th to 8th grade level) | | Intervention form: 58%, 95% CI (48.6, 67.0); correct SWOG form: 56%, 95% CI (43.8, 66.8) (P = NS)
Nonrandomized trial
| | | | Race/Ethnicity:
| | | | White: 44% | | < 45 on REALM (6th grade level or lower): 25%
Setting: | | | | AA: 56%
Private and university oncology clinics and a low-income housing complex | | | | | | | | Comprehension of both forms sig declined with lower reading level | | Funding Source:
| | | | Income: | | | | | | NR
| | | | NR
| | | | Insurance Status: | | | | Intervention form preferred by those reading at below a 9th grade level
| | | | NR
Duration: | | | | Other Characteristics:
One interview | | | | Cancer: 29%
Citation: | To determine whether alteration of the readability level of patients concerning information on the drug warfarin would influence comprehension of the material | Able to read English | 108 patients | Age: | NR | Measurement Tool: | Group 1: | Knowledge about warfarin according to literacy level and readability: | No multivariate analysis concerning literacy included | Total: 1.50
Eaton and Holloway, 1980 | | Able to see normal size type | | Mean: 48 | | | Warfarin materials at grade 5 readability | | | 1. 1; 2. 1.5; 3. 1; 4. 2; 5. 1.5; 6. 2; 7. 2; 8. 1
| | | | | | ABLE
| | Not taking warfarin | | Sex:
Design: | | Outpatients at Minneapolis VA Medical Center | | NR | | Literacy Levels: | | Literacy level explained 24% of variance (P < 0.001)
RCT | | | | | | Not stated, just used in analysis
| | | | Race/Ethnicity: | | | Group 2:
Setting: | | | | NR | | | Warfarin materials at grade 10 readability | Readability explained 8% of variance (P < 0.001)
Outpatient clinics at Minneapolis VA Medical Center, Minnesota | | | | Income:
| | | | NR | | | | | | Funding Source:
| | | | | | | | Perception of clarity of materials: | | Partially supported by the VA
| | | | Insurance Status: | | | Readability computed with Raygon Readability Estimate
| To study the effect of alteration on attitudes of the study population toward drug information materials | | | NR | | | | Depended on reading ability for Group 2 materials at 10th grade readability, not so for Group 1 with 5th grade materials
Duration:
One interview | | | | Other Characteristics:
| | | | NR
| | | | | | | Comprehension evaluated with 23-item true/false test written at 5th grade level
| | | | | | | Attitudes evaluated through multiple-choice test
Citation: | To compare the efficacy of a 12-week, family-based culture-specific dietary intervention with a no-treatment control to reduce cancer risk among low-literacy, low-income Hispanics | Included: | 38 mothers | Age: | Mothers: | Measurement Tool: | Controls: | No sig differences in any measures between treatment and control groups, before and after interventions | Not listed, but multivariate analysis is mentioned | Total: 1.38
Fitzgibbon et al., 1996 | | At least one child aged 7 to 12 | | Mothers: | Mean: 9.1 yrs (SD 4.0) | | Standard pamphlets on health behaviors and nutrition, with no accompanying classes | | | 1. 1; 2. 2; 3. 2; 4. 0; 5. 2; 6. 1.5; 7. 1; 8. 1.5
| | | 17 sons | Mean: 35 (SD 6.6) | | None
| | Mother and children willing to attend 12 weekly 1-hour classes and complete an assessment | | Children:
Design: | | | 31 daughters | Mean: 9 (SD 2.0) | | Literacy Levels:
RCT, randomized at the level of the family | | | | | | NR
| | | | Sex: | | | | Mothers' measures include:
| | | | Female: 100%
| | | | | | | | Fat intake
| | Ability to read English or Spanish not required for participation | | Race/Ethnicity: | | | Intervention: 12-week, culture-specific, cancer prevention curriculum that encouraged adoption of a low-fat, high-fiber diet; activity-based curriculum; accommodated both English and Spanish speakers; instruction took place at the literacy training site (familiar to all participants); incorporated ethnic foods; made foods appealing to children; lots of discussion in classes | Saturated fat intake
Setting: | | | | Hispanic: 100% | | | | Fiber intake | | Funding Source:
Literacy training program in a largely Hispanic community of Chicago, Illinois | | | | Puerto Rican: 55% | | | | Exercise | | American Cancer Society
| | | | Mexican American: 29% | | | | Nutrition knowledge
| | | | | | | | Children's measures include:
| | Excluded: | | Income:
| | Self-admitted alcoholics or consumed more than two alcoholic drinks per day | | < $5,000: 52.6% | | | | Dietary intake
| | | | $5,000 to $11,999: 28.9% | | | | Nutrition knowledge
Duration: | | | | $12,000 to $15,999: 2.6%
12 weeks | | | | $16,000 to $24,999: 15.8%
| | | | Insurance Status:
| | | | NR
| | | | Other Characteristics:
| | | | Mothers:
| | | | BMI:
| | | | Mean: 28.7 (SD 5.4)
| | | | SES:
| | | | Mean: 16.3 (SD 7.5)
| | | | Preferred language:
| | | | English: 58%
Citation: | To test the effect of a specially designed hypertension education and behavior change program for low-literacy city employees of Birmingham, Alabama | City employees who were found to have elevated blood pressure (SBP > 140 or DBP > 90) on screening exams | 600 employees offered participation | Age: | Grade school: | Measurement Tool: | Specially designed educational program for workers in unskilled labor departments using color graphics, models, and games with culturally appropriate examples; weight and blood pressure assessed each visit; goal-setting; food examples; monetary incentives | Change in SBP: | No multivariate analysis concerning literacy included | Total: 1.13
Fouad et al., 1997 | | | | < 45: 63% | Intervention: 15% | | | Intervention: -4.5 mm Hg (P = 0.03) | | 1. 1; 2. 2; 3. 1.5; 4. 0; 5. 1; 6. 1.5; 7. 1; 8. 1
| | | | | | None
| | | | Sex: | Control: 17% | | | Control: -2.4 (P = 0.19)
Design: | | | | Female: 14% | High school: | Literacy Levels:
Quasi-experimental; “cases” who completed program matched with nonparticipating controls | | | | | Intervention: | NR | | Difference: (P = 0.42)
| | | 130 enrolled | Race/Ethnicity: | 47%
| | | | White: 36% | Control: 45% | | | Change in DBP:
| | | 81 completed program, data available for 77 | Black: 63% | Trade school: | | | Intervention: -2.7 mm Hg (0.06)
| | | | | Intervention: | | | Control: -1.0 mm Hg (0.40) | | Funding Source:
| | | | Income: | 23% | | | | | National Heart, Lung, and Blood Institute
| | | | NR | Control: 24%
| | | | | College: | | | Difference: (P = 0.34)
| | | | Insurance Status: | Intervention:
Setting: | | | | NR | 10%
Birmingham, Alabama | | | 81 controls drawn from nonparticipants | | Control: 13%
| | | | Other Characteristics:
| | | | NR
Duration:
1 yr per participant
| | | 162 total
| | | | | | | Intervention and control received newsletters, tip sheets, and posters
Citation: | To test an intervention consisting of an audio CD and picture book designed to improve dietary patterns | NR | 7,744 | Age: | NR | Measurement Tool: | Audio CD and picture book, extensively tested in focus groups and through pilot tests | Dietary behavior as measured by the Food Habits Summary score: | No multivariate analysis concerning literacy included | Total: 0.8
Gans et al., 1998 | | | | NR | | | | | | 1. 0; 2. 2; 3. NA; 4. NA; 5. NA; 6. 1; 7. 1; 8. 0
| | | | | | None
| | | | Sex:
Design: | | | | NR | | Literacy Levels: | | Mean change -0.17, at 3-month followup (P < 0.001)
Uncontrolled trial | | | | | | NA
| | | | Race/Ethnicity:
| | | | Hispanic: 20%
Setting: | | | | | | | CD had 21 “tracks” (each 2.5 to 3.5 minutes) that the user could listen to
NR | | | | Income:
| | | | NR | | | | | | Funding Source:
Duration: | | | | | | | | | | National Heart, Lung, and Blood Institute
3 months | | | | Insurance Status:
| | | | NR
| | | | Other Characteristics:
| | | | NR
Citation: | To determine the impact of an educational program on health attitudes, low-fat eating behaviors, dietary fat consumption, and total blood cholesterol levels in patients with low literacy skills | EFNEP participant | 64% of those who provided baseline information completed the study | Age: | Intervention: | Measurement Tool: | Intervention: | Attitude scale (adjusted), uses Model 1 covariates: | Model 1: | Total: 1.19
Hartman et al., 1997 | | English speaking | | Intervention: | < high school degree: | | “Help Yourself to Health,” a low-fat nutrition education curriculum; provides simple, practical, and relevant nutrition information in a fun and entertaining format | | Children | 1. 1.5; 2. 1; 3. 1; 4. 2; 5. 0.5; 6. 1; 7. 1; 8. 1.5
| | | | Mean: 31.1 (SD 0.9) | | ABLE, Level II | | | Marital status
| | | | Control: | 54% | | | Intervention: 0.21 | Physical activity
Design: | | | | Mean: 27.3 (SD 0.9) | High school diploma: | Literacy Levels: | | Control: 0.22 | Sex
RCT, randomized at level of educator, not at level of participant | | | | | | Intervention: | | Difference: -0.01, 95% CI (-0.01, 0.00) | Initial scale value
| | | | | 39% | =grade 8: 67% | | | Volunteer status
| | | | Sex: | GED: 7% | Grades 9 to 12: 24% | | | BMI
| | | Subjects completed: | Intervention: | | | | Eating Pattern Scale (adjusted), uses Model 2 covariates: | Age
| | | | Female: 90% | | > grade 12: 9% | | | Ethnicity
| | | 130 intervention, 70 control | Control: | Control: | Control: | | | Income | Funding Source:
| | | | Female: 97% | < high school diploma: | =grade 8: 73% | | Intervention: 0.54 | Reading ability | National Institutes of Health
Setting: | | | | | 50% | Grades 9 to 12: 11% | | Control: 0.57
EFNEP program in the Twin Cities Metropolitan area, Minnesota | | | | Race/Ethnicity: | High school diploma: | | | Difference: -0.03, 95% CI (-0.01, -0.005) | Model 2:
| | | | Intervention: | | > grade 12: 16% | Control: | | Age
| | | | White: 64% | 44% | | “Eating Right is Basic 2” (usual EFNEP materials); focuses generally on food budgeting, food safety, and healthy eating | | BMI
| | | | AA: 22% | GED: 6% | | | Dietary variables all use Model 3 covariates: Energy intake (adjusted): | Children
| | | | Other: 12% | | | | | Ethnicity
| | | | Control: | | | | | Income
Duration: | | | | White: 36% | | | | | Marital status
8-week mean time from pretest to posttest | | | | AA: 51% | | | | | Reading ability
| | | | Other: 11% | | | | Intervention: 1,857 kcal | Sex
| | | | | | | | Control: 1,683 kcal | Initial scale value
| | | | Income: | | | | Difference: 174, 95% CI (-107, 455) | Volunteer status
| | | | Intervention: | | | | | Model 3:
| | | | < $5,000: 23% | | | | Total fat intake (adjusted): | Age
| | | | $5,000 to $9,999: 37% | | | | | BMI
| | | | $10,000 to $20,000: 9% | | | | Intervention: 33.1 kcal | Children
| | | | $20,000+: 31% | | | | Control: 34.2 kcal | Ethnicity
| | | | Control: | | | | Difference: -1.1, 95% CI (-4.3, 2.1) | Marital status
| | | | < $5,000: 24% | | | | | Reading ability
| | | | $5,000 to $9,999: 27% | | | | | Sex
| | | | $10,000 to $20,000: 13% | | | | Saturated fat intake (% energy) (adjusted): | Initial value
| | | | $20,000+: 36% | | | | | Time
| | | | | | | | Intervention: 11.7% | Volunteer status
| | | | Insurance Status: | | | | Control: 12.6%
| | | | NR | | | | Difference: -0.9, 95% CI (-2.5, 0.8)
| | | | Other Characteristics:
| | | | Maritial status: | | | | Cholesterol intake (mg/1,000 kcal) (adjusted):
| | | | Intervention:
| | | | Single: 55%
| | | | Married: 24% | | | | Intervention: 127.3
| | | | Previously married: 21% | | | | Control: 146.6
| | | | Control: | | | | Difference: -19.3, 95% CI (-50.7, 12.1)
| | | | Single: 58%
| | | | Married: 16%
| | | | Previously married: 26% | | | | Blood cholesterol level (mg/dl) (adjusted):
| | | | | | | | Intervention: 182.6
| | | | | | | | Control: 179.1
| | | | | | | | Difference: 3.5, 95% CI (-7.1, 14.2)
Citation: | To compare the level of medication knowledge of elderly ED patients receiving instruction by one of two teaching methods: | Age: = 60 | 63 entered study | Age: | Mean: 11.25 yrs | Measurement Tool: | Control: | KMS (lower scores better) (unadjusted): | Medication complexity | Total: 1.63
Hayes, 1998 | | Able to speak and read English | | Mean: 75.6 | Range: 4 to 18 yrs | | Preprinted instructions (usual) | | Literacy | 1. 2; 2. 2; 3. 1; 4. 2; 5. 2; 6. 1.5; 7. 1; 8. 1.5
| | | | Range: 60 to 98 | | REALM | | Control: 52 | Living arrangement
Design: | | Urgent or deferrable category at triage and deemed stable by the nurse | 3 excluded because could not be contacted for followup | | < 9th grade: 23% | | | Intervention: 47.6 | Education
RCT, posttest only | | | | Sex: | Some college: 28% | Literacy Levels: | | Difference: 4.5, 95% CI (0.39, 8.51) (P = 0.016) | Age
| | | | Female: 63% | | Mean: 59.15 | Intervention: | | Sex
| | | | | | Range: 15 to 66 | Geragogy-based instructions (instruction designed for elderly adult learners)
Setting: | | Able to understand and sign consent form | | Race/Ethnicity: | | =6th grade level: 23%
Emergency departments in rural midwestern areas | | | | White: 100% | | | | KMS mean difference (adjusted):
| | | 60 used in analyses | | | 7th to 8th: 65%
| | Discharged home from ED on at least one prescribed medication | | Income: | | = 9th: 12% | | 4.30, 95% CI (0.51, 8.09) | | Funding Source:
| | | | NR | | | | | | Emergency Nurse's Foundation/ Sigma Theta Tau software contributed by Logicare Corporation
| (1) Control: the usual preprinted discharge instructions | | | | | | | Only medication complexity and experimental group membership covariates were sig, literacy was not
Duration: | | | | Insurance Status: | | | Telephone interview 48 to 72 hours after discharge
Interview 48 to 72 hours after discharge | | Able to use telephone | | NR
| | Cognitively intact per the SPMSQ (less than two errors on adjusted scale)
| | | | Other Characteristics:
| | | | Mean SPMSQ: 9.84 out of 10
| (2) Intervention: geragogy schemaband instruction using individualized computer-generated discharge instructions
Citation: | To test the effect of a dietary intervention for low-literacy, low-income adults | Adults in vocational or basic education classes | 351 partici-pants from 24 classes randomized, 79% completed baseline and first followup measure | Mean Age: | =8th grade: | Measurement Tool: | Six special nutrition education classes, each 90 minutes | Nutrition knowledge: | No multivariate analysis concerning literacy included | Total: 1.69
Howard-Pitney et al., 1997 | | | | Intervention: 31 | Intervention: 6% | Tool: | | Net change in % correct SNAP versus general nutrition classes: +7.7% (P = 0.01) | | 1. 1.5; 2. 2; 3. 1.5; 4. 2; 5. 1.5; 6. 2; 7. 1.5; 8. 1.5
| | | | Control: 31 | Control: 4% | WRAT
| | | | | 9th to 11th grade: Intervention: 38% Control: 36% | Literacy Levels:
Design: | | | | Sex: | Intervention: 38% | Low literacy: 8th grade level or below: 66%
Randomized trial | | | | Female: | Control: 36% | | Intervention:
| | | | Intervention: 86% | 12th grade: | | Curriculum that focused primarily on lowering dietary fat intake (SNAP) | Nutrition attitudes:
| | | | Control: 82% | Intervention: 34% | Average grade level reading ability: 7.4 | | Net change mean SNAP versus general nutrition classes: +0.2 (P = 0.02)
Setting: | | | | | Control: 36%
Vocational and general education classes in San Jose, California | | | | Race/Ethnicity: | = 12th grade: | | | | | Funding Source:
| | | 183 in SNAP classes | Intervention: | Intervention: 21% | 8th grade level or below: 66% | | | | National Heart, Lung, and Blood Institute
| | | | Asian: 10% | Control: 24%
| | | | Hispanic: 58% | | | Control:
| | | 168 in general nutrition classes | White: 20% | | | Existing general nutrition curriculum | Nutrition self-efficacy:
| | | | Other: 12%
Duration: | | | | Control: | | | | Net change mean SNAP versus general nutrition classes: +0.2 (P = 0.04)
Approximately 5 months | | | | Asian: 13%
| | | | Hispanic: 59%
| | | | White: 15%
| | | | Other: 12%
| | | | Income:
| | | | < $10,000/yr:
| | | | Intervention: 63%
| | | | Control: 66%
| | | | Insurance Status:
| | | | NR
| | | | Other Characteristics:
| | | | NR
Citation: | To determine the ability of illiterate female patients to interpret instructional illustrations on breast-feeding | Illiterate (not having passed standard 3 and not being able to read and to write simple sentences) | 60 participated in first attendance | Age: | NR | Measurement Tool: | Three different graphic illustrations concerning breast- relative to bottle-feeding presented to each patient: | Ability to identify the graphic (% of patients correctly identifying content): | No multivariate analysis concerning literacy included | Total: 0.13
Hugo and Skibbe, 1991 | | | | Range: 18 to 40 | | Tool: | | | | 1. 0; 2. 1; 3. 0; 4. 0; 5. 0; 6. 0; 7. 0; 8. 0
| | | | Sex: | | Illiteracy: not having passed standard 3 and not being able to read and to write simple sentences | | Simplified black and white: 9% (same 9% as in detailed)
Design: | | | | Female: 100%
Experimental, before-and-after study | | Participant in prenatal clinic | 47 completed the questionnaire at second visit
| | | | Race/Ethnicity: | | | | Detailed black and white: 9% (same 9% as in simplified)
| | Age: 18 to 40 Primagravida “Coloured” ethnic population group that attended antenatal clinics at Tygerberg Hospital | | “Coloured”: 100% | | | 1. simplified black and white diagram,; 2. detailed black-and-white illustration,; 3. color illustration
| | | | | | Literacy Levels:
Setting: | | | | Income: | | Ranged from total illiteracy to very limited reading ability | | | | Funding Source:
Prenatal clinic in Tygerberg Hospital, South Africa | | | | NR | | | | | | NR
| | | | Insurance Status
| | | | NR
Two successive occasions in 1989 | | | | Other Characteristics:
occasions in 1989 | | | | NR
Duration:
Two interviews
Citation: | To evaluate the effectiveness of verbal teaching and of a color-coded chart that had been designed to tailor a medication regimen to the elderly person's daily schedule | Age: = 65 | 80 participated, convenience sample | Age: | Mean: 8 yrs | Measurement Tool: | Group 1: Verbal teaching about medications | Knowledge gain (unadjusted): Group 1 and Group 2: | No multivariate analysis concerning literacy included | Total: 1.44
Hussey, 1994 | | At least one chronic health problem | | Mean:75(SD 5.4) | | | | | | 1. 1.5; 2. 2; 3. 0.5; 4. 2; 5. 2; 6. 1.5; 7. 1; 8. 1
| | | | | | Comprehension Subtest of the Gates-MacGinitie Reading Test
Design: | | Low SES or indigent Not blind or colorblind | | Sex: | | | Group 2:Group 1 intervention + color-coded medication schedule | Sig increase in knowledge among total population (P < 0.001)
Controlled trial, alternate assignment to groups, not randomized | | | | Female: 70%
| | | | Race/Ethnicity: | | Literacy Levels: | | No sig difference between Group 1 and Group 2
| | | | Caucasian: 33% | | Average estimated at 3rd to 4th grade reading level
| | | | AA: 62%
| | | | Hispanic: 5% | | | | | | Funding Source:
Setting: | | | | | | | | Compliance
Geriatric outpatient clinic in a large county hospital in the southwestern United States | | | | Income | | | | Group 1 and Group 2:
| | | | < $10,552/yr: 100% of patients | | | | Sig increase in compliance after verbal teaching (P = 0.007)
| To measure the effects on both knowledge and compliance
| | | | Insurance Status:
| | | | NR
| | | | | | | | Comparing Group 1 to Group 2:
Duration: | | | | Other Characteristics:
2 to 3 weeks | | | | Lived alone: 42.5% | | | | Among patients with low compliance scores at baseline, Group 2 had more improvement than Group 1
| | | | Lived with spouse: 33.8%
| | | | Average number of diagnoses: 1.9
| | | | | | | | No difference between the two groups with high compliance scores (data not provided)
| | | | Average number of doses/day: 7.4
Citation: | To determine whether the use of a simple, low-literacy educational tool enhances patient-physician dialogue about pneumococcal vaccination and increases rates of immunization | Primary care visit | 922 eligible | Age: | = 8th grade: 37.0% | Measurement Tool: | Group 1 (control): Low-literacy nutrition brochure | Clinician discuss vaccine with patient (unadjusted): | Race | Total: 1.63
Jacobson et al., 1999 | | Not yet immunized | | Mean: 63 (SD 12.7) | | | | | Sex | 1. 1.5; 2. 2; 3. 2; 4. 0; 5. 2; 6. 2; 7. 2; 8. 1.5
| | One of four indications: (1) age = 65, (2) diabetes, (3) heart failure, (4) other chronic medical problems | 487 had previous vaccination, 2 skipped triage area | | 9th to 11th grade: 27.7% | None | | | Age
| | | | Sex: | | | | Group 1: 9.9% | Education
Design: | | | | Female:69.3% | | Literacy Levels: | | Group 2: 39.4% | Health status
RCT | | | | | = high school: 35.3% | Previously measured in this population with TOFHLA | Group 2 (intervention): Low-literacy pneumococcal vaccine brochure written at below 5th grade level as assessed by Flesh-Kincaid | RR = 3.97, 95% CI (2.71, 5.83)(P < 0.001) | Insurance status
| | | Race/Ethnicity: | | | | | | Level of clinician training
Setting: | | | | White: 6.5% | | | | | Vaccine indication
Ambulatory care clinic at Grady Memorial Hospital, Atlanta, Georgia | | Not blind | 433 enrolled | AA: 92.6%
| | No dementia | | Other: 0.9% | | | | Patient received vaccine (unadjusted):
| | English speaking | Intention to treat analysis used | | | Marginal or inadequate literacy > 80% in elderly population at this clinic | | | | Funding Source:
| | Not previously vaccinated | | Income: | | | | Group 1: 3.8% | | National Vaccine Program, Centers for Disease Control and Prevention
| | | | NR | | | | Group 2: 19.9%
| | | | | | | | RR = 5.28, 95% CI (2.80, 9.93) (P < 0.001)
Duration | | | | Insurance Status | | | Outcomes assessed through brief questionnaire | | | Georgia Emerging Infections Program
One interview | | | | Uninsured: 24.9% | | | | Patient read brochure (unadjusted):
| | | | Government/private: 75.1% | | | | | | Indigent Care Trust Funds from State of Georgia
| | | | | | | | No sig difference between Groups 1 and 2
| | | | Other Characteristics: | | | | | | Office of Health Promotion and Disease Prevention at Grady Health Systems
| | | | NR | | | | Patient showed brochure to physician (unadjusted):
| | | | | | | | Group 1: 17.4%
| | | | | | | | Group 2: 37.1%
| | | | | | | | RR = 2.13, 95% CI (1.54, 2.94) (P < 0.001)
| | | | | | | | Clinician recommended vaccine (unadjusted):
| | | | | | | | Group 1: 6.1%
| | | | | | | | Group 2: 27.1%
| | | | | | | | RR = 4.43, 95% CI (2.67, 7.30) (P < 0.001)
| | | | | | | | Group 2 sig more likely than Group 1 to receive vaccine or discuss it with their clinician (adjusted):
| | | | | | | | (P < 0.001)
Citation: | To evaluate the knowledge, level of satisfaction, and treatment preferences of men newly diagnosed with prostate cancer after participation in a CD-ROM shared decision-making program and the relationship between prostate cancer knowledge and health literacy | New diagnosis of prostate cancer | 31 recruited | Age: | Less than high school: 23.3% | Measurement Tool: | Intervention: CD-ROM about prostate cancer; includes textual descriptions of stages of cancer and associated treatment options, illustrated by anatomical drawings | Knowledge measured by PCKQ and educational attainment (unadjusted): | No multivariate analysis concerning literacy included | Total: 1.19
Kim et al., 2001 | | | | Age at time of diagnosis: 67 ± 9.5 yrs | | | | | | 1. 1.5; 2. 2; 3. 0.5; 4. 2; 5. 1; 6. 1; 7. 1.5; 8. 0
| | | 30 completed | | | REALM
Design:
One-group uncontrolled trial | | | | Sex: | High school graduate: 43.4% | Literacy Levels:
| | | (Response rate cannot be calculated) | Male : 100% | | Mean score (7th to 8th grade) 57.1 (SD ± 10.9) | | Less than high school: PCKQ: 62.1%
Setting: | | | | Race/Ethnicity: | Advanced education: 33.3% | | | High school graduate: PCKQ: 74.1%
Urology clinics in two VA hospitals in Chicago, Illinois | | | | White: 50% | | 4th to 6th grade: 10%
| | | | AA: 43% | | | | Advanced education: PCKQ: 82.2%
| | | | Asian American: 7% | | 7th to 8th grade: 26.7% | | | | Funding Source:
| | | | | | | | Difference: (P = NS) | | Schering Plough Inc.
| | | | | | = 9th grade: 63.3%
| | | | Income: | | | Includes presentations by physicians, video clips showing patients receiving treatment, and video testimonials by prostate cancer patients and their families | Correlation between PCKQ and REALM score (unadjusted):
Duration: | | | | NR | | | | | | VA
NR | | | | | | | | r = 0.65
| | | | Insurance Status: | | | | Difference: (P = 0.0001)
| | | | NR
| | | | Other Characteristics: | | | | Satisfaction with information presented and likelihood of following treatment preferences not sig different by literacy or educational attainment (data not provided)
| | | | Married: 63.3%
| | | | Clinical stage cancer:
| | | | A: 16.7%
| | | | B: 70%
| | | | C: 3.3%
| | | | D: 10%
Citation: | To evaluate the effect of a special cardiovascular nutrition education package designed for AAs based on CARDES | Included: | 435 persons screened at CARDES clinic | Age: | Less than 12th grade: 24% | Measurement Tool: | Group 1 (control): Received periodic brief counseling by nutritionist, food cards, and nutrition guide | Change in total cholesterol and systolic blood pressure at 12 months | No multivariate analysis concerning literacy included | Total: 1.63
Kumanyika et al., 1999 | | | | | | | | | | 1. 1.5; 2. 2; 3. 2; 4. 0.5; 5. 1.5; 6. 2; 7. 2; 8. 1.5
| | Persons 40 to 70 yrs with a history of hypertension or an abnormal total cholesterol (= 5.2 mmol/l) | | 40 to 54: 41% | | Specially designed scale
| | | | 55 to 70: 59%
| | | | | | Literacy Levels:
Design: | | | | Sex: | | = 8th grade; | | Total cholesterol (women):
RCT | | | 388 eligible | Female: 74% | | Group 1: 47%
| | | | | | Group 2: 49% | | Group 1: -0.43 mmol/l
Setting: | | | 330 enrolled | Race/Ethnicity: | | | | Group 2: -0.41 mmol/l
Community-based trial; participants recruited from supermarket screenings held in primarily AA neighbor-hoods in Washington, DC | | Excluded: | | AA: 100% | | | Group 2 (intervention): Received same as Group 1 and also received CARDES materials including audio program and a series of four monthly nutrition classes | Difference: (P = 0.8)
| | Possible renal disease, alcoholism, depression, or other psychiatric illness | | | | | | | | Funding Source:
| | | | Income: | | | | Total cholesterol (men): | | National Institutes of Health
| | | | < $15,000/yr: 52% | | | | Group 1: -0.36 mmol/l
| | | | | | | | Group 2: -0.50 mmol/l
| | | | Insurance Status: | | | | Difference: (P = 0.4)
| | | | NR
| | | | | | | | Systolic blood pressure (women):
| | | | Other Characteristics:
| | | | History of heart disease: | | | | Group 1: -10.6 mm Hg
| | | | Group 1: 15% | | | | Group 2: -7.4 mm Hg
Duration: | | | | Group 2: 7% | | | | Difference: (P = 0.2)
1 yr | | | | History of diabetes:
| | | | Group 1: 14% | | | | Systolic blood pressure (men):
| | | | Group 2: 15%
| | | | | | | | Group 1: -0.8 mm Hg
| | | | | | | | Group 2: +0.9 mm Hg
| | | | | | | | Difference: (P = 0.5)
Citation: | To develop and test culturally appropriate low-literacy smoking cessation intervention materials designed to increase quit rates and prevent relapse postpartum for low-income AA and Hispanic women | Included: | 768 | Age: | NR | Measurement Tool: | Intervention: 15-minute one-on-one sessions including (1) counseling providing information on risk of smoking or reinforcement to continue abstinence; | Baseline smokers: | No multivariate analysis concerning literacy included | Total: 1.00
| | | | | | | | Odds of quitting reported at 9 months gestation: | | 1. 1.5; 2. 1.5; 3. 1; 4. 0; 5. 1; 6. 1; 7. 1; 8. 1
Lillington et al., 1995 | | WIC participant | | Mean: 26.8 | | NR
| | Age: > 18 | 1,102 smokers and ex-smokers eligible | Range: 18 to 43
| | Pregnant, any stage of gestation | | | | Literacy Levels: | | OR = 1.75, 95% CI (1.19, 2.55)
Design: | | | | Sex: | | Not measured and no report of previous measure
RCT with clinic randomization | | Current smoker or exsmoker who quit in the past 12 months | | Femal : 100%
| | | | | | | | Odds of quitting reported at 6 weeks postpartum:
| | | | Race/Ethnicity:
Setting: | | | 18% (198) refused | AA: 53%
Four WIC sites in south and central Los Angeles | | Excluded: | | Hispanic: 42.6% | | | | OR = 2.17, 95% CI (1.21, 3.91) | | Funding Source:
| | Early delivery | | White: 3.6% | | | (2) self-help guide of behavior change strategies: Time for Change (3 step approach to quitting with 12 behavior change activities to be completed; | | | State of California Tobacco Control Program
| | | 12% (132) ineligible | Other: 0.7%
| | | | | | | | Ex-smokers:
| | | | Income: | | | | Odds of quitting reported at 9 months gestation:
October 1990 to December 1992 | | | (Response rate: 79%) | NR | | | | | | National Cancer Institute
| | | | Insurance Status: | | | | OR = 1.06, 95% CI (0.99, 1.13)
Duration: | | | 555 at followup | NR
1.5 to 10.5 months
| | | | Other Characteristics: | | | | Odds of quitting reported at 6 weeks postpartum:
| | | | Gestation: | | | (3) reinforcement booster cards 1 month after study entry;
| | | | 0 to 3 months: 13.9%
| | | | 4 to 6 months: 50.1% | | | | OR = 1.28, 95% CI (1.10, 1.49)
| | | | 7 to 9 months: 36%
| | | | | | | (4) incentive contest: weekly drawing for baby items for all people who turned in behavior sheets
| | | | Gravida:
| | | | Multiparous: 86.5% | | | | Subgroup Analysis:
| | | | Primiparous: 13.5% | | | | Baseline AA smokers:
| | | | Smoking status:
| | | | Current: 40.5% | | | | Odds of quitting reported at 9 months gestation:
| | | | Ex: 59.5%
| | | | | | | | OR = 1.93, 95% CI (1.23, 3.03)
| | | | | | | Control: Usual care, including printed information about the risks of smoking during pregnancy and a group quit smoking message at their initial visit
| | | | | | | | Odds of quitting reported at 6 weeks postpartum:
| | | | | | | | OR = 3.13, 95% CI (1.48, 6.60)
| | | | | | | | Baseline Hispanic smokers:
| | | | | | | | Odds of quitting reported at 9 months gestation:
| | | | | | | Third grade reading level in English and Spanish, but tool to assess not reported
| | | | | | | | OR = 1.33, 95% CI (0.58, 3.05)
| | | | | | | | Odds of quitting reported at 6 weeks postpartum:
| | | | | | | | OR = 1.20, 95% CI (0.33, 4.36)
Citation: | To determine whether printed or videotaped information is more effective in enhancing colon cancer knowledge | Age: = 50 | 1,100 | Age: | Median: 11 yrs | Measurement Tool: | Group 1 (control): No intervention | Knowledge improvement on a 24-question posttest, based on pretest scores: | No multivariate analysis concerning literacy included | Total: 1.75
| | | | | | | | | | 1. 1.5; 2. 2; 3. 2; 4. 2; 5. 1; 6. 1; 7. 2; 8. 1.5
Meade et al., 1994 | | Able to speak and read English | | Mean: 60.6 | | WRAT dichotomized:
| | Absence of visual and hearing impairments | | Sex: | | = 7th grade | Group 2: Booklet written at 5th to 6th grade reading level
Design: | | | | Female: 72% | | < 7th grade | | Group 1: 3%
RCT, randomized by permuted block method into one of three groups | | Able to give free consent | | | | | | Group 2: 23%
| | | | Race/Ethnicity: | | Literacy Levels: | | Group 3: 26%
| | Eligibility for at least one colon cancer screening measure | | White: 44% | | Median: 7th grade | | Groups 2 and 3 sig better than Group 1 (P < 0.05)
| | | | Black: 54%
| | | | | | | Group 3: Videotape content similar to booklet | | | Funding Source:
| | | | Income: | | | | No sig difference between Groups 2 and 3 | | Wisconsin Department of Health and Social Services
Setting: | | | | NR
Primary care clinic at Milwaukee County Medical Complex, Wisconsin
| | | | Insurance status: | | | | Subgroup analysis by dichotomized literacy level (< 7th, = 7th) in Groups 2 and 3; no sig differences in score improvement according to literacy level
| | | | NR | | | Pretest/posttest design
| | | | Other Characteristics:
| | | | NR | | | 24 questions at 5th to 6th grade reading level
Duration:
Pretest, 7.5-minute intervention, and posttest
Citation: | To test the effect of two cervical cancer and condyloma information brochures on comprehension of information, one with illustrations and one without | Included: | 254 recruited | Age: | NR | Measurement Tool: | Two different versions of a cervical cancer screening informational brochure | Comprehension scores: | No multivariate analysis concerning literacy included | Total: 1.50
| | | | | | | | | | 1. 0.5; 2. 2; 3. 2; 4. 1.5; 5. NA; 6. 1.5; 7. 1.5; 8. 1.5
Michielutte et al., 1992 | | Women = 18 | | NR | | WRAT-R (adapted for this study) | | Total sample:
| | | | | | | | Version 1: 65.2%
| | Excluded: | 217 final sample | Sex: | | | | Version 2: 53.3%
Design: | | Women who reported no ability to read or who reported “serious illnesses” | | NR | | Literacy Levels: | | Difference: (P = 0.076)
RCT | | | | | | Range: 19 to 88
| | | 112 received illustrated brochure | Race/Ethnicity: | | | Version 1: Illustrated, narrative text (SMOG 8.4) | Low WRAT-R:
Setting: | | | | NR | | Results dichotomized into high and low literacy at the median score: 46 | | Version 1: 61%
One private family practice and three public health clinics: obstetrics/gynecology, family planning, and STDs | | | | | | | | Version 2: 35%
| | | | Income: | | | | Difference: (P = 0.007) | | Funding Source:
| | | | NR | | | | | | NR
| | | 105 received nonillustrated version | | | | Version 2: Simple bulleted text only (SMOG 7.7) | High WRAT-R:
| | | | Insurance Status: | | | | Version 1: 70%
| | | | NR | | | | Version 2: 72%
| | | | | | | | Difference: (P = 0.814)
| | | | Other Characteristics:
| | | | NR
Duration:
One session
Citation: | To determine if an educational program (monthly sessions with or without video tapes) designed specifically for patients with diabetes and low literacy could improve glucose and weight control outcomes | Included: | Initial screening done by computer record | Age: | Mean yrs: | Measurement Tool: | Group 1: | Change in HbA_1_ from baseline to month 7 (unadjusted): | Age | Total: 1.25
Mulrow et al., 1987 | | Patients with diabetes who were overweight (> 130% ideal body weight) and not taking insulin | | Mean: 53 | Group 1: 9.0 | | Monthly videotape lessons with printed handouts, viewed during 30-minute session, conducted in groups of 3 to 5; materials written at the 4th to 6th grade level, met monthly for 6 months | | Sex | 1. 1; 2. 2; 3. 1.5; 4. 0; 5. 1; 6. 2; 7. 1.5; 8. 1
| | | | | Group 2: 9.0 | None | | | Race
| | | | Sex: | Group 3: 9.7 | | | Group 1: Median increase of 0.2% | Education
Design: | | | | Female: 55% | | Literacy Levels: | | | Duration of diabetes
RCT | | | | | | NR | | Group 2: Median decrease of 0.3% | Compliance beliefs
| | | 290 patients invited | Race/Ethnicity:
Setting: | | Excluded: | | West Indian: 49% | | | | Group 3: Median decrease of 0.3%
Diabetes clinic in Central | | Diabetes onset before age 29
| | | 150 responded | Income:
| | History of diabetic ketoacidosis | | NR | | | | No statistical differences within or between groups | | Funding Source:
Duration: | | Age: > 70 | 120 enrolled | Insurance Status: | | | | | | Pfizer
11 months | | | | NA | | | | | | Pharmaceuticals
| | | 68 % completed | | | | | Findings at 11 months similar
| | | | Other Characteristics: | | | Group 2: Same as Group 1 but without videotapes, and first session was 1 hour in length | Change in weight at 7 months (unadjusted):
| | | | Mean HbA: 10.2% | | | | Group 1: 1.0 kg weight loss
| | | | | | | | Group 2: 0.1 kg weight loss
| | | | | | | | Group 3: No change
| | | | | | | Group 3: Same initial first session as Group 2, but no future intervention | Difference: (P < 0.05
| | | | | | | | No sig difference at 11 months
| | | | | | | | Knowledge score was not sig affected by the interventions
| | | | | | | All given test to assess knowledge outcomes in month 7, repeated at month 11
| | | | | | | | Weight or HbA_1_% change (adjusted):
| | | | | | | | No sig difference found
Citation: | To design a nutrition curriculum that could be used in adult educational sites and to measure its efficacy toward increasing nutrition knowledge and changing dietary practices | Participant in the adult reading class | 28 | Age | Mean: 10.4 yrs | Measurement Tool: | Intervention: | Change in score on pre/posttests: | No multivariate analysis concerning literacy included | Total: 1.56
Murphy et al., 1996 | | | | Mean: 26 | | | 8-hour, 8-day curriculum including lessons on the food groups, vitamins, portion sizes, reading or labels, meal pnalling, low-fat snack choices, and identification of the nutritive value of foods; included written materials, visual aids, and participatory exercies | | | 1. 2; 2. 2; 3. 1.5; 4. 2; 5. 2; 6. 1; 7. 1.5; 8. 0.5
| | Reading at or below 6th grade reading level | | | | REALM
| | | | Sex: | | | | Measuring portion size (unadjustd):
Design: | | | | Female: 86% | | Literacy Levels:
Randomized trial, randomized by classroom | | | | | | Mean: 25.3 | | Intervention group improved 0.4 points
| | | | Race/Ethnicity: | | Range: 1 to 61
| | | | Black: 100% | | | | (P < 0.05
Setting: | | | | Income: | | Intervention Group: | | Controls improved 0.3
Adult basic education reading classes at a welfare-to-work site in Shreveport, Louisiana | | | | Welfare population | | Mean: 7.3 | | points (P = NS)
| | | | Insurance Status: | | Range: 1 to 20 | | | | Funding Source:
| | | | NR | | Control Group: | | Reading labels (unadjusted): | | NR
| | | | Other Characteristics: | | Mean: 43.3
| | | | NR | | Range: 8 to 51 | | Intervention improved
Duration: | | | | | | (Control group had a sig higher mean reading level) | | 1.6 points (P < 0.01
2 months | | | | | | | | Controls declined 0.3
| | | | | | | | points (P = NS)
| | | | | | | | Consumption behaviors (self-report) (unadjusted):
| | | | | | | Controls:
| | | | | | | No intervention
| | | | | | | | (P = NS)
Citation: | To determine if an instructional videotape was more effective for increasing short-term knowledge about sleep apnea than a simplified brochure designed at the same literacy level | Included: | 195 eligible | Age: | Mean yrs of schooling: 12 | Measurement Tool: | Intervention: 13-minute video presenting definition of sleep apnea, associated health problems, types of apnea, symptoms, testing, treatment, benefits of treatment; substantial instructional graphics, demonstrations, conversation | Knowledge of an 11-item questionnaire: | Race | Total: 1.00
Murphy et al., 2000 | | Age: = 18 | | Mean: 45 | | REALM | | | Sex | 1. 1; 2. 1.5; 3. 0.5; 4. 2; 5. 0.5; 6. 1; 7. 1; 8. 0.5
| | Primary caregiver answered if patient younger than age 18 | 192 particiated | Range: 18 to 72 | | | | Those with = 9th grade reading level answered 10/11 questions more accurately than those with reading level < 9th grade after reading the brochure (unadjusted) | Clinic site
| | | | | Range: 3rd grade to post-graduate | Literacy Levels:
Design: | | | | Sex: | | Mean: 53.2 (grade 7 to 8)
Nonrandomized controlled trial (patients assigned on alternating basis to read or watch video) | | | Of these, 20 were caregivers | Female: 46%
| | | | Race/Ethnicity: | | Median: 63 (grade = 9)
| | | | Black: 41%
| | | | White: 58% | | Score < grade 9: 40%
| | | | Other: 1% | | Brochure (Control): | | | | Funding Source:
| | | | Income: | | Grade 0 to 3: 9% | | Those with reading ability < 9th grade performed significantly better on 2 questions when viewing video versus broucher (unadjusted): | | Partially supported by Louisiana University Health Sciences Center, Shreveport, Louisiana
Setting: | | | | NR | | Grade 4 to 6: 11%
Sleep clinic at Louisiana State University, Health Sciences Center | | | | | | Grade 7 to 8: 24%
| | | | Insurance Status: | | Grade = 9: 56%
| | | | NR | | Video (Intervention):
| | | | Other Characteristics: | | Grade 0 to 3: 13%
| | | | Medical diagnosis: | | Grade 4 to 6: 6%
Duration: | | | | Sleep apenea: 82% | | Grade 7 to 8: 18% | Control:
Immediate postvideo measurement | | | | Narcolepsy: 8% | | Grade = 9: 64% | Brochure mimicking content of video | (1) type of sleep apnea that is caused when air passages blocked: 66% versus 43% (P < 0.05); (2) identify what CPAP does: 94% versus 78% (P < 0.05); no sig difference for other questions
| | | | Other: 10% | | | Both written at 12th grade reading level according to Fog index
| | | | | | | | Outcomes concerning (1) type of sleep apnea that is caused when air passages blocked and (2) identification of CPAP; low-literacy group that viewed video more likely to obtain knowledge than low-literacy group that read brochure (adjusted)
| | | | | | | | Those with reading ability = 9th grade performed better on 1 question when saw video rather than read brochure (unadjusted): (1) type of sleep apnea that is caused when air passages blocked: 100% versus 92% (P < 0.05)
Citation: | To examine the effect of a videotaped cholesterol education program designed for low-income, ethnically diverse, innercity-dwelling older adults with a wide range of reading abilities | Low-income, ethnically diverse city dwellers | From a potential pool of 200, clients were called by phone and invited to participate | Age: | Mean: 11.4 yrs | Measurement Tool: | Cholesterol information videotape delivered at 2-week followup visit | Change in mean cholesterol knowledge score from baseline to T2 (2 weeks) and to T3 (6 weeks): | No multivariate analysis concerning literacy included | Total: 1.31
Pepe and Chodozko-Zajko, 1997 | | | | Mean: 69 | | | | | | 1. 1.5; 2. 2; 3. 0.5; 4. 2; 5. 1; 6. 2; 7. 1.5; 8. 0
| | Age: 60 to 80 | | Range: 61 to 78 | | REALM
| | Used to helth department
| | | | Sex: | | Literacy Levels:
Design: | | | | Female: 45%* | | Mean: 63 | | Baseline: 62%
Before-and-after study | | | | | | Range: 55 to 66 | | Two-week followup: 77%
| | | | Race/Ethnicity: | | | Pretest/posttest design with posttest given 1 month following intervention | Six-week followup: 72%
| | | | White: 50%* | | < 9th grade: 45% | | Difference over time: (P < 0.05
Setting: | | | First 20 clients to accept were enrolled | AA: 30%* | | = 9th grade: 55% | | | | Funding Source:
Clients of an urban health department in the Midwest | | | | Other: 20%* | | | | Pretest knowledge: | | NR
| | | | Income: | | | | = 9th grade reading level: 70%
| | | | NR | | | | < 9th grade reading level: 57%
Duration: | | | | Insurance Status: | | | | Two-week test:
6 weeks | | | | NR | | | | = 9th grade reading level: 79%
| | | | Other Characteristics: | | | | < 9th grade reading level: 63%
| | | | None | | | | Two-week test:
| | | | | | | | = 9th grade reading level: 79%
| | | | | | | | < 9th grade reading level: 63%
| | | | | | | | Six-week followup:
| | | | | | | | = 9th grade reading level: 755
| | | | | | | | < 9th grade reading level: 54%
| | | | | | | | Correlation between reading ability and cholesterol knowledge:
| | | | | | | | Baseline: r = 0.43 (P <0.05
| | | | | | | | Two-week: r = 0.48 (P <0.05)
| | | | | | | | Six-week: r = 0.66 (P <0.05)
| | | | | | | | Change over time in cholesterol knowledge not different between reading groups, implying that different literacy level groups did not learn at a different rate due to the intervention
Citation: | To evaluate the effects associated with the implementation of the FSC project for parents of children in Head Start | Parent/caretaker of a child in Head Start | Baseline: | Age: | Group 1 (baseline): | Measurement Tool: | Group 1 (control): | Change in depression scores (Center for Epidemiological Studies-Depression scale): | No multivariate analysis concerning literacy included | Total: 1.25
Poresky and Daniels, 2001 | | | 80 families | NR | | | | | | 1. 1; 2. 1.5; 3. 1; 4. 2; 5. 1; 6. 1.5; 7. 1; 8. 1
| | Group: 1 Regular Head Start program | | | High school diploma: | Comprehensive | Regular Head
| | | Year 1 followup: | Sex: | | Adult Student | Start program; details not given
Design: | | Group 2: FSC enhanced Head Start program | 71 families | Female: 94% | 48% | Assessment Scale
RCT | | | | | GED: 30%
| | | | Race/Ethnicity: | Associate's degree: 3% | A score above 225 is considered to be high school proficiency | Group 2 (intervention): | Change over time in percent depressed (unadjusted):
Setting: | | | Year 2 followup: | Euro-Americana: 66%*
Head Start programs in rural northeastern Kansas | | | | AA: 20%* | Bachelor's degree: 3% | | FSC enhanced Head Start program; FSC case managers developed and implemented formalized case plans for parents; worked with parents to develop a goal plan; met weekly with parents to assist them and assess progress; helped link parents with relevant community resources; goals to become employed, reach literacy goals, and reduce substance abuse
| | | 60 families | Hispanic American: 5% | | | | Group 1:
| | | | Native American: 4%* | | | | Baseline: 35% | | Funding Source:
| Goals related to literacy, employability, and substance abuse | | | Asian American: 3%* | Group 2 (baseline): | Literacy Levels: | | Time 1: 23% | | NR
| | | | Other: 3%* | High school diploma: | Group 1 (n = 23): | | Time 2: 33%
Duration: | | | | Income: | | Mean 250.52 | | (P = NS)
2 yrs | | | | = $15,000/yr baseline: | 53% | | | Group 2:
| | | | Group 1: 8% | GED: 18% | Group 2 (baseline) | | Baseline: 48%
| | | | Group 2: 10% | Associate's degree: 3% | (n = 29): | | Time 1: 39%
| | | | > $15,000 Year 2: | | Mean 259.52 | | Time 2: 23%
| | | | Group 1: 10% | Bachelor's degree: 9% | | | (P = NS)
| | | | Group 2: 40% | | | | Change in reading ability (Comprehensive Adult Student Assessment scale):
| | | | Insurance Stauts: | | | | Group 1:
| | | | NR | | | | Baseline: 250.52
| | | | Other Characteristics: | | | | Time 1: 251.13
| | | | NR | | | | Time 2: 250.83
| | | | | | | | (P = NS)
| | | | | | | | Group 2:
| | | | | | | | Baseline: 259.52
| | | | | | | | Time 1: 283.34
| | | | | | | | Time 2: 301.34
| | | | | | | | (P < 0.05)
Citation: | To compare a PAG sheet requiring limited reading skills to a TIPP sheet for providing injury prevention to low-income urban families | Parents of children = 6 yrs who receive their primary medical care in the continuity clinic | 115 enrolled | Age: | NR | Measurement Tool: | Intervention: | Difference in recall of injury prevention information: | No multivariate analysis concerning literacy included | Total: 1.13
Powell et al., 2000 | | | | PAG: | | | Verbal information and PAG sheet (four to six pictures of black or Hispanic child in injury situation); 7th grade reading level text | | | 1. 1; 2. 1.5; 3. 1; 4. 0; 5. 0.5; 6. 2; 7. 2; 8. 1
| | | | Child: Mean age 38 months | | NR
Design: | | | | Parent: 27 yrs | | | | Items recalled:
Nonrandomized controlled trial | | Telephone in the home | (Response rate NR; calculation cannot be done) | TIPP: | | Literacy Levels: | | PAG: 2.1 ± 1.5
| | Language: English | | Child: 19 months | | Not measured and no report of previous measure | | TIPP: 1.6 ± 1.1
Intervention: | | | | Parent: 28 yrs | | | | No sig differences recalled in items overall or in relation to fire/burns, falls, guns, or drowning
Morning clinic parents
| To evaluate caretaker recall of injury prevention information | | | Sex:
| | | | NR | | | | | | Funding Source:
Control: | | | | | | | Control: | | | NR
Afternoon clinic parents | | | | Race/Ethnicity: | | | Verbal information and TIPP sheet; 9th grade reading level text
| | | | Minority: | | | Scale for assessment of readability not given
| | | | PAG: 83% | | | Telephone recall survey 14 to 28 days following clinic visit; caller blinded to study group
Setting: | | | | TIPP: 90%
Pediatric clinic at Northwestern University Medical Center in Chicago, Illinois
| | | | Income:
| | | | Public aid:
| | | | PAG: 80%
| | | | TIPP: 85%
| | | | Insurance Status:
Duration: | | | | NR
14 to 28 days
| | | | Other Characteristics:
| | | | NR
Citation: | To evaluate comprehension of a prototype over-the-counter package label for an emergency contraceptive pill product | Female | 663 interviewed | Age: | = 8th grade: | Measurement Tool: | Prototype product label and insert for emergency contraceptive pill | Understanding of communication objectives: | No multivariate analysis concerning literacy included | Total: 1.13
Raymond et al., 2002 | | Age: 12 to 50 | | Median: 21 | 4.6% | | | | | 1. 1.5; 2. 2; 3. 1; 4. 2; 5. 0; 6. 1.5; 7. 0.5; 8. 0.5
| | Able to read English well enough to read an over-the-counter product label | 7 did not meet inclusion criteria | Range: 12 to 50 | 9th to 11th grade: 22.6% | REALM
Design: | | | | Sex: | High school or GED: 30.4% | | | 121 comparisons within subgroups were performed, but data not shown
Before-and-after study | | Without a health care or marketing background | | Female: 100% | Vocational/technical school: 2.8% | Literacy Levels:
| | | | Race/Ethnicity | | Among subgroups of subjects age 18 or older who had not completed college (n = 395)
Setting: | | | 656 included in analysis | Race: | | | Contents of the intervention are displayed in the paper
Malls and family planning clinics in or near eight large US cities (Denver, Los Angeles, Chicago, San Antonio, Philadelphia, Miami, Phoenix, Washington, DC) | | Without a history of participating in the study | | White: 51.4% | Some college: | | | “ The only apparent pattern was that women of lower literacy were significantly less likely to understand almost all objectives than more literate women. However, 8 of the 11 objectives were each understood by more than 80% of women with low literacy.”
| | | | Black: 24.6% | 17.9%
| | | | Other: 24.0% | College or higher: | | | | | Funding Source:
| | | | Ethnicity: | 21.7% | = 6th grade: 4.6% | Patients given actual package and asked several questions about use of the product | | | Merck Fund, Women's Capital Corps
| | | | Hispanic: 23.5% | | 7th to 8th grade: 30.8%
| | | | Income: | | = 9th grade: 64.6%
| | | | $0 to $15,000: 11.6%
| | | | $15.001 to $25,000: 12.8%
| | | | $25,001 to $35,000: 20.6%
| | | | $35,0001 to $45,000: 22.6%
| | | | > $45,000: 32.4%
Duration:
June to July 2001 | | | | Insurance Status:
| | | | NR
| | | | Other Characteristics:
| | | | NR
Citation: | To determine the effect of an interactive videodisc program designed to improve self-care with respect to fatigue symptoms for patients with cancer | Included: | 174 | Age: | NR | Measurement Tool: | Pre- and posttest measure of selfcare ability, measured by multiple-choice test developed by the researchers | Change in self-care ability (measured on study-specific scale): | Age | Total: 1.31
Wydra, 2001 | | Age: = 18 | | Intervention: 57.2 | | | | | Literacy level | 1. 1; 2. 2; 3. 0.5; 4. 1.5; 5. 0; 6. 1.5; 7. 2; 8. 2
| | Receiving outpatient cancer treatment | 86 intervention patients | Control: 54.2 | | WRAT3 | | | Computer experience
Design: | | | | | | | | Intervention patients reported greater self-care ability after the intervention (P < 0.0001) | Learning style
RCT | | Provide written consent | | Sex: | | Literacy Levels: | | | Race
| | | | Female: | | Intervention: | | | Institution
Setting: | | | 88 control patients | Intervention: 45% | | = average: 66% | | | Education
Four comprehensive cancer centers (Lebanon, New Hampshire; Philadelphia, Pennsylvania; San Antonio, Texas; and Los Angeles, California) | | Excluded: | | Control: 53% | | > average: 34% | | | Sex
| | Less than 5th grade reading level | 159 observations used in analysis | Race/Ethnicity: | | Control: | | Change in self-care ability not sig related to literacy level (P = 0.31) but sig related to education (P = 0.01)
| | Brain or visual dysfunction | | Intervention: | | = average: 60% | Intervention:
| | | | White: 81% | | > average: 40% | Interactive videodisc module | | | Funding Source:
| | | | AA: 10% | | Note: Low literacy defined as deficient to average score (= 109) | | | | National Center for Nursing Research
| | | | Latino: 8% | | | Control: | | | National Cancer Institute
| | | | Control: | | | Conventional instruction (whatever was normally provided by the treatment facility)
| | | | White: 81%
| | | | AA: 9%
| | | | Latino: 8%
| | | | Missing: 2%
Duration:
One session and one mail questionnaire | | | | Income:
| | | | NR
| | | | Insurance Status:
| | | | NR
| | | | Other Characteristics:
| | | | Computer experience:
| | | | Intervention:
| | | | None: 10%
| | | | Little: 36%
| | | | Much: 53%
| | | | Control:
| | | | None: 11%
| | | | Little: 35%
| | | | Much: 51%
| | | | Missing: 2%

## Appendix C References

Andrasik F, Kabela E, Quinn S, et al. Psychological functioning of children who have recurrent migraine. Pain. 1988;34(1):43-52. [pmid: 3405619].
Arnold C L, Davis T C, Berkel H J, et al. Smoking status, reading level, and knowledge of tobacco effects among low-income pregnant women. Prevent Med. 2001;32(4):313-20.
Baker D W, Gazmararian J A, Williams M V, et al. Functional health literacy and the risk of hospital admission among Medicare managed care enrollees. Am J Pub Health. 2002;92(8):1278-83. [pmid: 12144984]. [pmcid: 1447230].
Baker D W, Parker R M, Williams M V, et al. Health literacy and the risk of hospital admission. J Gen Int Med. 1998;13(12):791-8.
Baker D W, Parker R M, Williams M V, et al. The relationship of patient reading ability to self-reported health and use of health services. Am J Pub Health. 1997;87(6):1027-30. [pmid: 9224190]. [pmcid: 1380944].
Battersby C, Hartley K, Fletcher A E, et al. Cognitive function in hypertension: a community based study. J Hum Hyperten. 1993;7(2):117-23.
Bennett C L, Ferreira M R, Davis T C, et al. Relation between literacy, race, and stage of presentation among low-income patients with prostate cancer. J Clin Oncol. 1998;16(9):3101-4. [pmid: 9738581].
Bill-Harvey D, Rippey R, Abeles M, et al. Outcome of an osteoarthritis education program for low-literacy patients taught by indigenous instructors. Patient Educat Counsel. 1989;13(2):133-42.
Coleman E A, Coon S, Mohrmann C, et al. Developing and testing lay literature about breast cancer screening for African American women. Clin J Oncol Nurs. 2003;7(1):66-71. [pmid: 12629937].
Conlin K K, Schumann L. Research. Literacy in the health care system: a study on open heart surgery patients. J Am Acad Nurse Pract. 2002;14(1):38-42. [pmid: 11845640].
Davis T C, Arnold C, Berkel H J, et al. Knowledge and attitude on screening mammography among low-literate, low-income women. Cancer. 1996;78(9):1912-20. [pmid: 8909311].
Davis T C, Berkel H J, Arnold C L, et al. Intervention to increase mammography utilization in a public hospital. J Gen Intern Med. 1998;13(4):230-3. [pmid: 9565385]. [pmcid: 1496943].
Davis T C, Bocchini J A J, Fredrickson D, et al. Parent comprehension of polio vaccine information pamphlets. Pediatrics. 1996;97(6 Pt 1):804-10. [pmid: 8657518].
Davis T C, Byrd R S, Arnold C L, et al. Low literacy and violence among adolescents in a summer sports program. J Adolesc Health. 1999;24(6):403-11. [pmid: 10401968].
Davis T C, Fredrickson D D, Arnold C, et al. A polio immunization pamphlet with increased appeal and simplified language does not improve comprehension to an acceptable level. Patient Educat Counsel. 1998;33(1):25-37.
Davis T C, Holcombe R F, Berkel H J, et al. Informed consent for clinical trials: a comparative study of standard versus simplified forms. J Nat Cancer Inst. 1998;90(9):668-74. [pmid: 9586663].
Eaton M L, Holloway R L. Patient comprehension of written drug information. Am J Hosp Pharm. 1980;37(2):240-3. [pmid: 7361799].
Fisch M, Unverzagt F, Hanna M, et al. Information preferences, reading ability, and emotional changes in outpatients during the process of obtaining informed consent for autologous bone-marrow transplantation. J Cancer Educat. 1998;13(2):71-5.
Fitzgibbon M L, Stolley M R, Avellone M E, et al. Involving parents in cancer risk reduction: a program for Hispanic American families. Health Psychol. 1996;15(6):413-22. [pmid: 8973920].
Fortenberry J D, McFarlane M M, Hennessy M, et al. Relation of health literacy to gonorrhoea related care. Sex Trans Infect. 2001;77(3):206-11.
Fouad M N, Kiefe C I, Bartolucci A A, et al. A hypertension control program tailored to unskilled and minority workers. Ethnicit Dis. 1997;7(3):191-9.
Frack S A, Woodruff S I, Candelaria J, et al. Correlates of compliance with measurement protocols in a Latino nutrition-intervention study. Am J Prevent Med. 1997;13(2):131-6.
Fredrickson D D, Washington R L, Pham N, et al. Reading grade levels and health behaviors of parents at child clinics. Kansas Med. 1995;96(3):127-9.
Gans K M, Lovell H J, Fortunet R, et al. Gem no. 289. Low-literacy audio intervention for lowering fat intake. J Nutr Educat. 1998;30(6):410B.
Gazmararian J, Baker D, Parker R, et al. A multivariate analysis of factors associated with depression: evaluating the role of health literacy as a potential contributor. Arch Int Med. 2000;160(21):3307-14. [pmid: 11088094].
Gazmararian J A, Baker D W, Williams M V, et al. Health literacy among Medicare enrollees in a managed care organization. J Am Med Assn. 1999;281(6):545-51.
Gazmararian J A, Parker R M, Baker D W. Reading skills and family planning knowledge and practices in a low-income managed-care population. Obstet Gynecol. 1999;93(2):239-44. [pmid: 9932563].
Golin C E, Liu H, Hays R D, et al. A prospective study of predictors of adherence to combination antiretroviral medication. J Gen Intern Med. 2002;17(10):756-65. [pmid: 12390551]. [pmcid: 1495120].
Gordon M M, Hampson R, Capell H A, et al. Illiteracy in rheumatoid arthritis patients as determined by the Rapid Estimate of Adult Literacy in Medicine (REALM) score. Rheumatol. 2002;41(7):750-4.
Hartman T J, McCarthy P R, Park R J, et al. Results of a community-based low-literacy nutrition education program. J Comm Health. 1997;22(5):325-41.
Hawthorne G. Preteenage drug use in Australia: the key predictors and school-based drug education. J Adolesc Health. 1996;20(5):384-95. [pmid: 9168386].
Hayes K S. Randomized trial of geragogy-based medication instruction in the emergency department. Nurs Res. 1998;47(4):211-8. [pmid: 9683116].
Howard-Pitney B, Winkleby M A, Albright C L, et al. The Stanford Nutrition Action Program: a dietary fat intervention for low-literacy adults. Am J Pub Health. 1997;87(12):1971-6. [pmid: 9431286]. [pmcid: 1381239].
Hugo J, Skibbe A. Facing visual illiteracy in South African health education: a pilot study. J Audiovisual Media Med. 1991;14(2):47-50.
Hussey L C. Minimizing effects of low literacy on medication knowledge and compliance among the elderly. Clin Nurs Res. 1994;3(2):132-45. [pmid: 7513587].
Jacobson T A, Thomas D M, Morton F J, et al. Use of a low-literacy patient education tool to enhance pneumococcal vaccination rates. A randomized controlled trial. J Am Med Assoc. 1999;282(7):646-50.
Kalichman S C, Benotsch E, Suarez T, et al. Health literacy and health-related knowledge among persons living with HIV/AIDS. Am J Prev Med. 2000;18(4):325-31. [pmid: 10788736].
Kalichman S C, Ramachandran B, Catz S. Adherence to combination antiretroviral therapies in HIV patients of low health literacy. J Gen Int Med. 1999;14(5):267-73.
Kalichman S C, Rompa D. Emotional reactions to health status changes and emotional well-being among HIV-positive persons with limited reading literacy. J Clin Psychol Med Set. 2000a;7(4):203-11.
Kalichman S C, Rompa D. Functional health literacy is associated with health status and health-related knowledge in people living with HIV-AIDS. J Acq Immune Def Synd Hum Retrovirol. 2000b;25(4):337-44.
Kalichman S C, Rompa D, Cage M. Reliability and validity of self-reported CD4 lymphocyte count and viral load test results in people living with HIV/AIDS. Int J STD & AIDS. 2000;11(9):579-85. [pmid: 11138915].
Kaufman H, Skipper B, Small L, et al. Effect of literacy on breast-feeding outcomes. South Med J. 2001;94(3):293-6. [pmid: 11284516].
Kim S P, Knight S J, Tomori C, et al. Health literacy and shared decision making for prostate cancer patients with low socioeconomic status. Cancer Investigat. 2001;19(7):684-91.
Kumanyika S K, Adams-Campbell L, Van Horn B, et al. Outcomes of a cardiovascular nutrition counseling program in African-Americans with elevated blood pressure or cholesterol level. J Am Diet Assoc. 1999;99(11):1380-91. [pmid: 10570675].
Li B D, Brown W A, Ampil F L, et al. Patient compliance is critical for equivalent clinical outcomes for breast cancer treated by breast-conservation therapy. Ann Surg. 2000;231(6):883-9. [pmid: 10816632]. [pmcid: 1421078].
Lillington L, Royce J, Novak D, et al. Evaluation of a smoking cessation program for pregnant minority women. Cancer Pract. 1995;3(3):157-63. [pmid: 7599672].
Lindau S T, Tomori C, Lyons T, et al. The association of health literacy with cervical cancer prevention knowledge and health behaviors in a multiethnic cohort of women. Am J Obstet Gynecol. 2002;186(5):938-43. [pmid: 12015518].
Meade C D, McKinney W P, Barnas G P. Educating patients with limited literacy skills: the effectiveness of printed and videotaped materials about colon cancer. Am J Pub Health. 1994;84(1):119-21. [pmid: 8279598]. [pmcid: 1614927].
Michielutte R, Bahnson J, Dignan M B, et al. The use of illustrations and narrative text style to improve readability of a health education brochure. J Cancer Educat. 1992;7(3):251-60.
Miller C K, O'Donnell D C, Searight H R, et al. The Deaconess Informed Consent Comprehension Test: an assessment tool for clinical research subjects. Pharmacotherapy. 1996;16(5):872-8. [pmid: 8888082].
Miller L G, Liu H, Hays R D, et al. Knowledge of antiretroviral regimen dosing and adherence: a longitudinal study. Clin Infect Dis. 2003;36(4):514-8. [pmid: 12567311].
Moon R Y, Cheng T L, Patel K M, et al. Parental literacy level and understanding of medical information. Pediatrics. 1998;102(2):e25. [pmid: 9685471].
Mulrow C, Bailey S, Sonksen P H, et al. Evaluation of an Audiovisual Diabetes Education Program: negative results of a randomized trial of patients with non-insulin-dependent diabetes mellitus. J Gen Intern Med. 1987;2(4):215-9. [pmid: 2441013].
Murphy P W, Chesson A L, Walker L, et al. Comparing the effectiveness of video and written material for improving knowledge among sleep disorders clinic patients with limited literacy skills. Southern Med J. 2000;93(3):297-304. [pmid: 10728518].
Murphy P W, Davis T C, Mayeaux E J, et al. Teaching nutrition education in adult learning centers: linking literacy, health care, and the community. J Comm Health Nurs. 1996;13(3):149-58.
Pepe M V, Chodzko-Zajko W J. Impact of older adults' reading ability on the comprehension and recall of cholesterol information. J Health Educat. 1997;28(1):21-7.
Poresky R H, Daniels A M. Two-year comparison of income, education, and depression among parents participating in regular Head Start or supplementary Family Service Center Services. Psychol Reports. 2001;88(3 Pt 1):787-96.
Powell E C, Tanz R R, Uyeda A, et al. Injury prevention education using pictorial information. Pediatrics. 2000;105(1):e16. [pmid: 10617753].
Raymond E G, Dalebout S M, Camp S I. Comprehension of a prototype over-the-counter label for an emergency contraceptive pill product. Obstet Gynecol. 2002;100(2):342-9. [pmid: 12151161].
Ross L A, Frier B M, Kelnar C J, et al. Child and parental mental ability and glycaemic control in children with Type 1 diabetes. Diabetic Med. 2001;18(5):364-9. [pmid: 11472446].
Schillinger D, Grumbach K, Piette J, et al. Association of health literacy with diabetes outcomes. J Am Med Assoc. 2002;288(4):475-82.
Scott T L, Gazmararian J A, Williams M V, et al. Health literacy and preventive health care use among Medicare enrollees in a managed care organization. Med Care. 2002;40(5):395-404. [pmid: 11961474].
Spandorfer J M, Karras D J, Hughes L A, et al. Comprehension of discharge instructions by patients in an urban emergency department. Ann Emerg Med. 1995;25(1):71-4. [pmid: 7802373].
Stanton W R, Feehan M, McGee R, et al. The relative value of reading ability and IQ as predictors of teacher-reported behavior problems. J Learn Disabil. 1990;23(8):514-7. [pmid: 2246604].
Sullivan L M, Dukes K A, Harris L, et al. A comparison of various methods of collecting self-reported health outcomes data among low-income and minority patients. Med Care 1995. 33(4 Suppl):AS183-94.
TenHave T R, Van Horn B, Kumanyika S, et al. Literacy assessment in a cardiovascular nutrition education setting. Patient Educat Counsel. 1997;31(2):139-50.
Weiss B D, Blanchard J S, McGee D L, et al. Illiteracy among Medicaid recipients and its relationship to health care costs. J Health Care Poor Underserved. 1994;5(2):99-111. [pmid: 8043732].
Weiss B D, Hart G, McGee D L, et al. Health status of illiterate adults: relation between literacy and health status among persons with low literacy skills. J Am Board Fam Pract. 1992;5(3):257-64. [pmid: 1580173].
Williams M V, Baker D W, Honig E G, et al. Inadequate literacy is a barrier to asthma knowledge and self-care. Chest. 1998;114(4):1008-15. [pmid: 9792569].
Williams M V, Baker D W, Parker R M, et al. Relationship of functional health literacy to patients' knowledge of their chronic disease. A study of patients with hypertension and diabetes. Arch Int Med. 1998;158(2):166-72. [pmid: 9448555].
Wilson F L, McLemore R. Patient literacy levels: a consideration when designing patient education programs. Rehab Nursing. 1997;22(6):311-7.
Wydra E W. The effectiveness of a self-care management interactive multimedia module. Oncol Nursing Forum. 2001;28(9):1399-407.
Zaslow M J, Hair E C, Dion M R, et al. Maternal depressive symptoms and low literacy as potential barriers to employment in a sample of families receiving welfare: are there two-generational implications?. Women Health. 2001;32(3):211-51. [pmid: 11480894].