# Appendix A. Exact Search Strings

Database: MEDLINE <1966 to October Week 1 2002>

Search Strategy:

1. literacy.mp. (1258)
2. limit 1 to human (1143)

Database: MEDLINE <1966 to October Week 1 2002>

Search Strategy:

1. literacy.mp. (1258)
2. limit 1 to human (1143)
3. 1 not 2 (115)

Ovid Technologies, Inc. Email Service

Search for: (1 or 2 or 3 or 4 or 5 or 6 or 7 or 8) not literacy.mp.

Citations: 1–200

Database: MEDLINE <1966 to October Week 3 2002>

Search Strategy:

1. WRAT.mp. (101)
2. wide range achievement.mp. (152)
3. Rapid estimate of adult.mp. (26)
4. tofhla.mp. (10)
5. test of functional health.mp. (18)
6. reading ability.mp. (458)
7. reading skill.mp. (86)
8. numeracy.mp. (41)
9. (1 or 2 or 3 or 4 or 5 or 6 or 7 or 8) not literacy.mp. (701)
10. from 9 keep 1–701 (701)

Database: CINAHL <1982 to October Week 4 2002>

Search Strategy:

1. literacy.mp. (918)
2. numeracy.mp. (17)
3. 1 or 2 (932)
4. from 3 keep 1–932 (932)

PSYCINFO

Search History

#2 “health literacy”(45 records)

#1 “health literacy”(45 records)

The search: “health literacy” in the database(s) PsycINFO Weekly 2002/10 Week 5, PsycINFO Weekly 2002/10 Week 4, PsycINFO Weekly 2002/10 Week 3, PsycINFO Weekly 2002/10 Week 2, PsycINFO Weekly 2002/10 Week 1, PsycINFO 2002/08-2002/09, PsycINFO 2002/01-2002/07, PsycINFO 2001 Part B, PsycINFO 2001 Part A, PsycINFO 2000, PsycINFO 1999, PsycINFO 1998, PsycINFO 1996-1997, PsycINFO 1993-1995, PsycINFO 1990-1992, PsycINFO 1988-1989, PsycINFO 1985-1987, PsycINFO 1978-1984, PsycINFO 1967-1977, PsycINFO 1872-1966 returned 45 records

ERIC

Search History

#2 “health literacy”(25 records)

#1 “health literacy”(25 records)

The search: “health literacy” in the database(s) ERIC returned 25 records

AARP's AGELINE yielded 13 “health literacy” citations.

Search term: LITERACY [No restrictions]

The Cochrane Database of Systematic Reviews

Complete reviews (8 records selected)

PAIS

Search History

#2 health and literacy(49 records)

#1 health literacy(4 records)

The search: health and literacy in the database(s) PAIS International 1972

-2002/12 returned 49 records