# List of Acronyms/Abbreviations

ACL | Anterior Cruciate Ligament
AHEAD | Association of Higher Education and Disability
AHRQ | Agency For Healthcare Research And Quality
ASA | American Society of Anesthesiologists
BMI | Body Mass Index
cf | Compared to
CI | Confidence Interval
DVT | Deep Vein Thrombosis
E/G | Excellent/Good
EMR | Electronic Medical Records
EPC | Evidence-based Practice Centers
GKS | Global Knee Score
HIPAA | Health Insurance Portability And Accountability Act
HSS | Hospital for Special Surgery
IRS | Internal Revenue Service
JA | Joint Arthroplasty
kg | Kilogram
KRH | Kinematic Rotating Hinged Knee Prosthesis
KS | Knee Society
LOS | Length of Stay
MeSH | Medical Subject Headings
NIAMD | National Institute of Arthritis and Metabolic Diseases
NIH | National Institutes of Health
OA | Osteoarthritis
OLS | Ordinary Least Square Regression
OMAR | NIH Office of Medical Applications Research
OR | Odds Ratio
p | Probability
PCL | Posterior Cruciate Ligament
POD | Post Operative Day
PVD | Peripheral Vascular Disease
r | Regression Coefficient
RA | Rheumatoid Arthritis
RCTs | Randomized Controlled Trials
ROM | Range of Motion
RR | Relative Risk
S/P | Satisfactory/Poor
S-ROM | Implant made by Depuy
THA | Total Hip Arthroplasty
THR | Total Hip Replacement
TKA | Total Knee Arthroplasty
TKAR | Total Knee Arthroplasty Revision
UKA | Unicompartmental Knee Arthroplasty
UKR | Unicondylar Knee Replacements
WOMAC | Western Ontario and Macmaster University Osteoarthritis Index