# References and Included Studies

(appearing in text and Evidence Tables)

1 Acheson R M, Collart A B. New Haven survey of joint diseases. XVII. Relationship between some systemic characteristics and osteoarthrosis in a general population. Ann Rheum Dis. 1975;34(5):379-87. [pmid: 1221922]. [pmcid: 1006437].
2 Peyron J G. Osteoarthritis. The epidemiologic viewpoint. Clin Orthop. 1986;213:13-9. [pmid: 3536247].
3 CDC. Public health and aging: Projected prevalence of self-reported arthritis or chronic joint symptoms among persons aged 65 years--United States, 2005-2030. Morbidity and Mortality Weekly Report 2003;52(21, May 30, 2003):489.
4 Elders M J. The increasing impact of arthritis on public health. J Rheumatol Suppl. 2000;60:6-8. [pmid: 11032095].
5 Callahan C M, Drake B G, Heck D A, et al. Patient outcomes following tricompartmental total knee replacement. A meta-analysis postoperative alignment of total knee replacement. Its effect on survival. JAMA. 1994;271(17):1349-57. [pmid: 8158821].
6 Alicea J. Scoring systems and their validation for the arthritic knee. In: Insall JN, Churchill SN, eds. Surgery of the Knee. 3rd ed. New York: Livingston; 2001:1507–15.
7 Insall J N, Dorr L D, Scott R D, et al. Rationale of the Knee Society clinical rating system. Orthopaedics & Related Research. 1989;248:13-4.
8 Bellamy N, Buchanan W W, Goldsmith C H, et al. Validation study of WOMAC: A health status instrument for measuring clinically important patient relevant outcomes to antirheumatic drug therapy in patients with osteoarthritis of the hip or knee. The Journal of Rheumatology. 1988;15(12):1833-40. [pmid: 3068365].
9 Orthopedic Network News. 2002 hip and knee implant review. CMS MedPar (www.OrthopedicNetworkNews.com). Accessed 9/8/03.
10 National Center for Health Statistics. American Academy and American Association of Orthopaedic Surgeons Bulletin. 1999;47(3):14.
11 Tierney W M, Fitzgerald J F, Heck D, et al. Tricompartmental knee replacement: A comparison of orthopaedic surgeons' self reported performance rates with surgical indications, intraindications, and expected outcomes. Clinical Orthopaedics. 1994;305:209-17. [pmid: 8050231].
12 Wright J G, Coyte P, Hawker G, et al. Variation in orthopedic surgeons' perceptions for and outcomes of knee replacement. Can Med Assoc J. 1995;152:687-97. [pmid: 7882231]. [pmcid: 1337616].
13 Mancuso C A, Ranawat C S, Esdaile J M, et al. Indications for total hip and total knee arthroplasties. Results of orthopaedic surveys. J Arthroplasty. Jan. 1996;11(1):34-46. [pmid: 8676117].
14 Coyte P C, Hawker G, Croxford R, et al. Variation in rheumatologists' and family physicians' perceptions of the indications for and outcomes of knee replacement surgery. J Rheumatol. Apr. 1996;23(4):730-8. [pmid: 8730135].
15 Wright J G, Hawker G A, Bombardier C, et al. Physician enthusiasm as an explanation for area variation in the utilization of knee replacement surgery. Med Care. Sep. 1999;37(9):946-56. [pmid: 10493472].
16 Malmlin L A, Melfi C A, Parchman M L, et al. Management of osteoarthritis of the knee by primary care physicians. Arch Fam Med. 1998;7:563-7. [pmid: 9821832].
17 Naylor C D, Williams J I. Primary hip and knee replacement surgery: Ontario criteria for case selection and surgical priority. Qual Health Care. 1996;5:20-30. [pmid: 10157268].
18 Dieppe P, Basler H D, Chard J, et al. Knee replacement surgery for osteoarthritis: Effectiveness, practice variations, indications and possible determinants of utilization. Rheumatology (Oxford). 1999;38(1):73-83. [pmcid: 128936]. [pmid: 15340661].
19 Hadorn D C, Holmes A C. The New Zealand priority criteria project. Part 1: Overview. BMJ. 1997a;314(7074):131-4. [pmid: 9006477]. [pmcid: 2125609].
20 Hadorn D C, Holmes A C. The New Zealand priority criteria project. Part 2: Coronary artery bypass graft surgery. BMJ. 1997b;314(7074):135-8. [pmid: 9006478]. [pmcid: 2125624].
21 Saleh K J, Dykes D C, Tweedie R L, et al. Functional outcome after total knee arthroplasty revision: a meta-analysis. J Arthroplasty. Dec. 2002;17(8):967-77. [pmid: 12478505].
22 Kane RL, ed. Understanding Health Care Outcomes Research. Gaithersburg, MD: Aspen Publishers, Inc; 1997.
23 Borenstein M, Rothstein H. Comprehensive Meta Analysis: A computer program for research synthesis. Englewood, NJ: Biostat, Inc.; 1999.
24 Leclerc J R, Gent M, Hirsh J, et al. The incidence of symptomatic venous thromboembolism during and after prophylaxis with enoxaparin: a multi-institutional cohort study of patients who underwent hip or knee arthroplasty. Canadian Collaborative Group. Arch Intern Med. 1998;158(8):873-8. [pmid: 9570173].
25 Mauerhan D R, Nelson C L, Smith D L, et al. Prophylaxis against infection in total joint arthroplasty. One day of cefuroxime compared with three days of cefazolin. J Bone Joint Surg Am. Jan. 1994;76(1):39-45. [pmid: 8288664].
26 Jones R E, Skedros J G, Chan A J, et al. Total knee arthroplasty using the S-ROM mobile-bearing hinge prosthesis. J Arthroplasty. Apr. 2001;16(3):279-87. [pmid: 11307123].
27 Deshmukh R, Hayes J, Pinder I. Does body weight influence outcome after total knee arthroplasty? A 1-year analysis. J Arthroplasty. Apr. 2002;17(3):315-9. [pmid: 11938508].
28 Fortin P, Clarke A, Joseph L, et al. Outcomes of total hip and knee replacement: preoperative functional status predicts outcomes at six months after surgery. Arthritis Rheum. Aug. 1999;42(8):1722-8. [pmid: 10446873].
29 Hawker G, Wright J, Coyte P, et al. Health-related quality of life after knee replacement. J Bone Joint Surg Am. Feb. 1998;80(2):163-73. [pmid: 9486722].
30 Konig A, Kirschner S, Walther M, et al. Hybrid total knee arthroplasty. Arch Orthop Trauma Surg. 1998;118(12):66-9. [pmid: 9833109].
31 Hawker G A, Wright J G, Coyte P C, et al. Differences between men and women in the rate of use of hip and knee arthroplasty.[comment]. New England Journal of Medicine. Apr 6. 2000;342(14):1016-22. [pmid: 10749964].
32 Dunlop D D, Song J, Manheim L M, et al. Racial disparities in joint replacement use among older adults. Med Care. Feb. 2003;41(2):288-98. [pmid: 12555056].
33 Wilson MG, May DS, Kelly JJ. Racial differences in the use of total knee arthroplasty for osteoarthritis among older Americans. Ethn Dis 1994 Winter;4(1):57–67.
34 Insall J N, Dethmers D A. Revision of total knee arthroplasty. Clinical Orthopaedics & Related Research. 1982;170:123-30. [pmid: 7127937].
35 Mendenhall S. Get the lowdown on orthopaedic implants. Mater Manag Health Care. 1996;5(4):30-2. [pmid: 10157554].
36 Haas S B, Insall J N, Montgomery W III, et al. Revision total knee arthroplasty with use of modular components with stems inserted without cement. Journal of Bone & Joint Surgery—American Volume. 1995;77(11):1700-7.
37 Whiteside L A, Bicalho P S. Radiologic and hisologic analysis of morselized allegraft in revision total knee replacement. Clinical Orthopaedics & Related Research. 1998;357:149-56. [pmid: 9917712].
38 Callahan C M, Drake B G, Heck D A, et al. Patient outcomes following unicompartmental or bicompartmental arthroplasty. A meta-analysis. J Arthroplasty. 1995;10(2):141-50. [pmid: 7798094].
39 Brooks DH, Fehring TK, Griffin WL, et al. Polyethylene exchange only for prosthetic knee instability. Clin Orthop 2002 Dec;(405):182–8.
40 Babis G C, Trousdale R T, Morrey B F. The effectiveness of isolated tibial insert exchange in revision total knee arthroplasty. J Bone Joint Surg Am. Jan. 2002;84-A(1):64-8. [pmid: 11792781].
41 Miller M, Benjamin JB, Marson B, et al. The effect of implant constraint on results of conversion of unicompartmental knee arthroplasty to total knee arthroplasty. Orthopedics 2002 Dec;25(12):1353–7; discussion 7.
42 Christensen C P, Crawford J J, Olin M D, et al. Revision of the stiff total knee arthroplasty. J Arthroplasty. Jun. 2002;17(4):409-15. [pmid: 12066268].
43 Gofton WT, Tsigaras H, Butler RA, et al. Revision total knee arthroplasty: fixation with modular stems. Clin Orthop 2002 Nov;(404):158–68.
44 Nazarian DG, Mehta S, Booth Jr RE. A comparison of stemmed and unstemmed components in revision knee arthroplasty. Clin Orthop 2002 Nov;(404):256–62.
45 Lonner JH, Lotke PA, Kim J, et al. Impaction grafting and wire mesh for uncontained defects in revision knee arthroplasty. Clin Orthop 2002 Nov;(404):145–51.
46 Benjamin J, Engh G, Parsley B, et al. Morselized bone grafting of defects in revision total knee arthroplasty. Clin Orthop 2001 Nov;(392):62–7.
47 Hanssen A D. Bone-grafting for severe patellar bone loss during revision knee arthroplasty. J Bone Joint Surg Am. Feb. 2001;83-A(2):171-6. [pmid: 11216677].
48 Leopold S S, Silverton C D, Barden R M, et al. Isolated revision of the patellar component in total knee arthroplasty. J Bone Joint Surg Am. Jan. 2003;85-A(1):41-7. [pmid: 12533570].
49 Parvizi J, Seel MJ, Hanssen AD, et al. Patellar component resection arthroplasty for the severely compromised patella. Clin Orthop 2002 Apr;(397):356–61.
50 Werle J R, Goodman S B, Imrie S N. Revision total knee arthroplasty using large distal femoral augments for severe metaphyseal bone deficiency: a preliminary study. Orthopedics. Mar. 2002;25(3):325-7. [pmid: 11918039].
51 Springer BD, Hanssen AD, Sim FH, et al. The kinematic rotating hinge prosthesis for complex knee arthroplasty. Clin Orthop 2001 Nov;(392):283–91.
52 Ververeli P, Sutton D, Hearn S, et al. Continuous passive motion after total knee arthroplasty. Analysis of cost and benefits. Clin Orthop 1995 Dec;(321):208–15.
53 Worland R, Arredondo J, Angles F, et al. Home continuous passive motion machine versus professional physical therapy following total knee replacement. J Arthroplasty. Oct. 1998;13(7):784-7. [pmid: 9802665].
54 Hasegawa M, Ohashi T, Uchida A. Heterotopic ossification around distal femur after total knee arthroplasty. Arch Orthop Trauma Surg. 2002;122(5):274-8. [pmid: 12070646].
55 Hsu R, Tsai Y, Huang T, et al. Hybrid total knee arthroplasty: a 3- to 6-year outcome analysis. J Formos Med Assoc. Jun. 1998;97(6):410-5. [pmid: 9650470].
56 Larson C, McDowell C, Lachiewicz P. One-peg versus three-peg patella component fixation in total knee arthroplasty. Clin Orthop 2001 Nov;(392):94–100.
57 Liu T, Chen S. Simultaneous bilateral total knee arthroplasty in a single procedure. Int Orthop. 1998;22(6):390-3. [pmid: 10093808].
58 Moskal J Diduch D Postoperative radiographs after total knee arthroplasty: a cost-containment strategy Am J Knee Surg 1998Spring11 2 89 93 9586737
59 Pereira D, Jaffe F, Ortiguera C. Posterior cruciate ligament-sparing versus posterior cruciate ligament-sacrificing arthroplasty. Functional results using the same prosthesis. J Arthroplasty. Feb. 1998;13(2):138-44. [pmid: 9526206].
60 Rand J, Gustilo R. Comparison of inset and resurfacing patellar prostheses in total knee arthroplasty. J Orthop Surg. 1996;4(1):13-22.
61 Diduch D, Insall J, Scott W, et al. Total knee replacement in young, active patients. Long-term follow-up and functional outcome. J Bone Joint Surg Am. Apr. 1997;79(4):575-82. [pmid: 9111404].
62 Evanich C, Tkach T, von Glinski S, et al. 6- to 10-year experience using countersunk metal-backed patellas. J Arthroplasty. Feb. 1997;12(2):149-54. [pmid: 9139096].
63 Healy W, Iorio R, Ko J, et al. Impact of cost reduction programs on short-term patient outcome and hospital cost of total knee arthroplasty. J Bone Joint Surg Am. Mar. 2002;84-A(3):348-53. [pmid: 11886902].
64 Ikejiani C, Leighton R, Petrie D. Comparison of patellar resurfacing versus nonresurfacing in total knee arthroplasty. Can J Surg. Feb. 2000;43(1):35-8. [pmid: 10714255].
65 Malkani A, Rand J, Bryan R, et al. Total knee arthroplasty with the kinematic condylar prosthesis. A ten-year follow-up study. J Bone Jt Surg Am. Mar. 1995;77(3):423-31.
66 O'Rourke M, Callaghan J, Goetz D, et al. Osteolysis associated with a cemented modular posterior-cruciate-substituting total knee design: five to eight-year follow-up. J Bone Jt Surg Am. Aug. 2002;84-A(8):1362-71.
67 Regner L, Carlsson L, Karrholm J, et al. Clinical and radiologic survivorship of cementless tibial components fixed with finned polyethylene pegs. J Arthroplasty. Oct. 1997;12(7):751-8. [pmid: 9411025].
68 Schroder H, Berthelsen A, Hassani G, et al. Cementless porous-coated total knee arthroplasty: 10-year results in a consecutive series. J Arthroplasty. Aug. 2001;16(5):559-67. [pmid: 11503114].
69 Bert J, Gross M, Kline C. Patient demand matching in total knee arthroplasty: is it necessary? Am J Knee Surg 2001 Winter;14(1):39–42.
70 Bourne R, Rorabeck C, Vaz M, et al. Resurfacing versus not resurfacing the patella during total knee replacement. Clin Orthop 1995 Dec;(321):156–61.
71 Cohen R, Forrest C, Benjamin J. Safety and efficacy of bilateral total knee arthroplasty. J Arthroplasty. Aug. 1997;12(5):497-502. [pmid: 9268788].
72 Heck D, Robinson R, Partridge C, et al. Patient outcomes after knee replacement. Clin Orthop 1998 Nov;(356):93–110.
73 Lin Y, Su J, Lin G, et al. Impact of a clinical pathway for total knee arthroplasty. Kaohsiung J Med Sci. Mar. 2002;18(3):134-40. [pmid: 12149828].
74 Matsueda M, Gustilo R. Subvastus and medial parapatellar approaches in total knee arthroplasty. Clin Orthop 2000 Feb;(371):161–8.
75 Bullens P, van Loon C, de Waal Malefijt M, et al. Patient satisfaction after total knee arthroplasty: a comparison between subjective and objective outcome assessments. J Arthroplasty. Sep. 2001;16(6):740-7. [pmid: 11547372].
76 Elke R, Meier G, Warnke K, et al. Outcome analysis of total knee-replacements in patients with rheumatoid arthritis versus osteoarthritis. Arch Orthop Trauma Surg. 1995;114(6):330-4. [pmid: 8588964].
77 Jenny J, Jenny G. Preservation of anterior cruciate ligament in total knee arthroplasty. Arch Orthop Trauma Surg. 1998;118(3):145-8. [pmid: 9932189].
78 Meding J, Ritter M, Faris P, et al. Does the preoperative radiographic degree of osteoarthritis correlate to results in primary total knee arthroplasty?. J Arthroplasty. Jan. 2001;16(1):13-6. [pmid: 11172264].
79 Ranawat C, Luessenhop C, Rodriguez J. The press-fit condylar modular total knee system. Four-to-six-year results with a posterior-cruciate-substituting design. J Bone Jt Surg Am. Mar. 1997;79(3):342-8.
80 Rodriguez J, Saddler S, Edelman S, et al. Long-term results of total knee arthroplasty in class 3 and 4 rheumatoid arthritis. J Arthroplasty. Feb. 1996;11(2):141-5. [pmid: 8648306].
81 Yang K, Yeo S, Lee B, et al. Total knee arthroplasty in diabetic patients: a study of 109 consecutive cases. J Arthroplasty. Jan. 2001;16(1):102-6. [pmid: 11172278].
82 Brown T Diduch D Moskal J Component size asymmetry in bilateral total knee arthroplasty Am J Knee Surg 2001Spring14 2 81 4 11401174
83 Cloutier J, Sabouret P, Deghrar A. Total knee arthroplasty with retention of both cruciate ligaments. A 9 to 11 year follow-up study. Eur J Orthop Surg Traumatol. 2001;11(1):41-6.
84 Duffy G, Berry D, Rand J. Cement versus cementless fixation in total knee arthroplasty. Clin Orthop 1998 Nov;(356):66–72.
85 Ewald F, Wright R, Poss R, et al. Kinematic total knee arthroplasty: a 10- to 14-year prospective follow-up review. J Arthroplasty. Jun. 1999;14(4):473-80. [pmid: 10428229].
86 Gill G, Joshi A. Long-term results of cemented, posterior cruciate ligament-retaining total knee arthroplasty in osteoarthritis. Am J Knee Surg 2001 Fall;14(4):209–14.
87 Indelli P, Aglietti P, Buzzi R, et al. The Insall-Burstein II prosthesis: A 5- to 9-year follow-up study in osteoarthritic knees. J Arthroplasty. 2002;17(5):544-9. [pmid: 12168167].
88 Martin S, McManus J, Scott R, et al. Press-fit condylar total knee arthroplasty. 5- to 9-year follow-up evaluation. J Arthroplasty. Sep. 1997;12(6):603-14. [pmid: 9306210].
89 Miyasaka K, Ranawat C, Mullaji A. 10- to 20-year followup of total knee arthroplasty for valgus deformities. Clin Orthop 1997 Dec;(345):29–37.
90 Mokris J, Smith S, Anderson S. Primary total knee arthroplasty using the Genesis Total Knee Arthroplasty System: 3- to 6-year follow-up study of 105 knees. J Arthroplasty. Jan. 1997;12(1):91-8. [pmid: 9021508].
91 Mont M, Yoon T, Krackow K, et al. Eliminating patellofemoral complications in total knee arthroplasty: clinical and radiographic results of 121 consecutive cases using the Duracon system. J Arthroplasty. Jun. 1999;14(4):446-55. [pmid: 10428225].
92 Rinta-Kiikka I, Savilahti S, Pajamaki J, et al. A five to seven years follow-up of 102 cementless Synatomic knee arthroplasties. Ann Chir Gynaecol. 1996;85(1):77-85. [pmid: 8739939].
93 Sextro G, Berry D, Rand J. Total knee arthroplasty using cruciate-retaining kinematic condylar prosthesis. Clin Orthop. Jul. 2001;388:33-40. [pmid: 11451130].
94 Bachmeier C, March L, Cross M, et al. A comparison of outcomes in osteoarthritis patients undergoing total hip and knee replacement surgery. Osteoarthritis Cartilage. Feb. 2001;9(2):137-46. [pmid: 11330253].
95 Beaupre L, Davies D, Jones C, et al. Exercise combined with continuous passive motion or slider board therapy compared with exercise only: a randomized controlled trial of patients following total knee arthroplasty. Phys Ther. Apr. 2001;81(4):1029-37. [pmid: 11296803].
96 Jones C A, Voaklander D C, Johnston D W, et al. The effect of age on pain, function, and quality of life after total hip and knee arthroplasty. Arch Intern Med. Feb. 2001;161(3):454-60. [pmid: 11176772].
97 Stickles B, Phillips L, Brox W, et al. Defining the relationship between obesity and total joint arthroplasty. Obes Res. Mar. 2001;9(3):219-23. [pmid: 11323448].
98 Clark C, Rorabeck C, MacDonald S, et al. Posterior-stabilized and cruciate-retaining total knee replacement: a randomized study. Clin Orthop 2001 Nov;(392):208–12.
99 Bert J, Gross M, Kline C. Outcome results after total knee arthroplasty: does the patient's physical and mental health improve? Am J Knee Surg 2000 Fall;13(4):223–7.
100 Kiebzak G, Campbell M, Mauerhan D. The SF-36 general health status survey documents the burden of osteoarthritis and the benefits of total joint arthroplasty: But why should we use it?. Am J Managed Care. 2002;8(5):463-74.
101 Baldwin J, Rubinstein RJ. The effect of bone quality on the outcome of ingrowth total knee arthroplasty. Am J Knee Surg 1996 Spring;9(2):45–9; discussion 9–50.
102 Harwin S. Patellofemoral complications in symmetrical total knee arthroplasty. J Arthroplasty. Oct. 1998;13(7):753-62. [pmid: 9802660].
103 Gioe T, Bowman K. A randomized comparison of all-polyethylene and metal-backed tibial components. Clin Orthop 2000 Nov;(380):108–15.
104 Hube R, Sotereanos N, Reichel H. The midvastus approach for total knee arthroplasty. Orthop Traumatol. 2002;10(3):235-44.
105 Jordan L, Olivo J, Voorhorst P. Survivorship analysis of cementless meniscal bearing total knee arthroplasty. Clin Orthop 1997 May;(338):119–23.
106 Konig A, Scheidler M, Rader C, et al. The need for a dual rating system in total knee arthroplasty. Clin Orthop 1997 Dec;(345):161–7.
107 Title C, Rodriguez J, Ranawat C. Posterior cruciate-sacrificing versus posterior cruciate-substituting total knee arthroplasty: a study of clinical and functional outcomes in matched patients. J Arthroplasty. Jun. 2001;16(4):409-14. [pmid: 11402401].
108 Gill G, Joshi A, Mills D. Total condylar knee arthroplasty. 16- to 21-year results. Clin Orthop 1999 Oct;(367):210–5.
109 Ritter M, Worland R, Saliski J, et al. Flat-on-flat, nonconstrained, compression molded polyethylene total knee replacement. Clin Orthop 1995 Dec;(321):79–85.
110 Griffin F, Scuderi G, Insall J, et al. Total knee arthroplasty in patients who were obese with 10 years followup. Clin Orthop 1998 Nov;(356):28–33.
111 Konig A, Walther M, Kirschner S, et al. Balance sheets of knee and functional scores 5 years after total knee arthroplasty for osteoarthritis: a source for patient information. J Arthroplasty. Apr. 2000;15(3):289-94. [pmid: 10794223].
112 Lombardi Jr A, Mallory T, Fada R, et al. An algorithm for the posterior cruciate ligament in total knee arthroplasty. Clin Orthop 2001 Nov;(392):75–87.
113 Blanchard J, Meuwly J Y, Leyvraz P F, et al. Prevention of deep-vein thrombosis after total knee replacement. Randomised comparison between a low-molecular-weight heparin (nadroparin) and mechanical prophylaxis with a foot-pump system. J Bone Joint Surg Br. 1999;81(4):654-9. [pmid: 10463739].
114 Colwell CW Jr, Spiro TE, Trowbridge AA, et al. Efficacy and safety of enoxaparin versus unfractionated heparin for prevention of deep venous thrombosis after elective knee arthroplasty. Enoxaparin Clinical Trial Group. Clin Orthop 1995; (321):19–27.
115 Francis C W, Pellegrini V D Jr, Leibert K M, et al. Comparison of two warfarin regimens in the prevention of venous thrombosis following total knee replacement. Thromb Haemost. 1996;75(5):706-11. [pmid: 8725709].
116 Heit J A, Elliott C G, Trowbridge A A, et al. Ardeparin sodium for extended out-of-hospital prophylaxis against venous thromboembolism after total hip or knee replacement. A randomized, double-blind, placebo-controlled trial. Ann Intern Med. 2000;132(11):853-61. [pmid: 10836911].
117 Leclerc J R, Geerts W H, Desjardins L, et al. Prevention of venous thromboembolism after knee arthroplasty. A randomized, double-blind trial comparing enoxaparin with warfarin. Ann Intern Med. 1996;124(7):619-26. [pmid: 8607589].
118 Perhoniemi V, Vuorinen J, Myllynen P, et al. The effect of enoxaparin in prevention of deep venous thrombosis in hip and knee surgery--a comparison with the dihydroergotamine-heparin combination. Ann Chir Gynaecol. 1996;85(4):359-63. [pmid: 9014067].
119 Robinson K S, Anderson D R, Gross M, et al. Ultrasonographic screening before hospital discharge for deep venous thrombosis after arthroplasty: the post-arthroplasty screening study. A randomized, controlled trial. Ann Intern Med. 1997;127(6):439-45. [pmid: 9313000].
120 Westrich G H, Sculco T P. Prophylaxis against deep venous thrombosis after total knee arthroplasty: Pneumatic plantar compression and aspirin compared with aspirin alone. J Bone Jt Surg Am. 1996;78(6):826-34.
121 Chiu F Y, Chen C M, Lin C F, et al. Cefuroxime-impregnated cement in primary total knee arthroplasty: a prospective, randomized study of three hundred and forty knees. J Bone Joint Surg Am. 2002;84-A(5):759-62. [pmid: 12004017].
122 Periti P, Stringa G, Mini E. Comparative multicenter trial of teicoplanin versus cefazolin for antimicrobial prophylaxis in prosthetic joint implant surgery. Italian Study Group for Antimicrobial Prophylaxis in Orthopedic Surgery. Eur J Clin Microbiol Infect Dis. 1999;18(2):113-9. [pmid: 10219575].
123 Abdel-Salam A, Eyres K S. Effects of tourniquet during total knee arthroplasty. A prospective randomised study. J Bone Joint Surg Br. 1995;77(2):250-3. [pmid: 7706340].
124 Wakankar H M, Nicholl J E, Koka R, et al. The tourniquet in total knee arthroplasty. A prospective, randomised study. J Bone Jt Surg Br. 1999;81(1):30-3.
125 Katz B, Freund D, Heck D, et al. Demographic variation in the rate of knee replacement: a multi-year analysis. Health Serv Res. Jun. 1996;31(2):125-40. [pmid: 8675435]. [pmcid: 1070109].
126 McBean AM, Gornick M. Differences by race in the rates of procedures performed in hospitals for Medicare beneficiaries. Health Care Financ Rev 1994 Summer;15(4):77–90.
127 Escarce J J, Epstein K R, Colby D C, et al. Racial differences in the elderly's use of medical procedures and diagnostic tests. Am J Public Health. Jul. 1993;83(7):948-54. [pmid: 8328615]. [pmcid: 1694780].
128 Norton E, Garfinkel S, McQuay L, et al. The effect of hospital volume on the in-hospital complication rate in knee replacement patients. Health Serv Res 1998 Dec 1998;33(5 Pt 1):1191–210. Comment in: Health Serv Res 1998 Dec;33(5 Pt 1):85–90. PMID: 9865216.
129 Brighton B, Tornetta P. Part I. Methodological issues in the design of orthopaedic studies: Hierarchy of evidence. From case reports to randomized controlled trials. Clinical Orthopaedics & Related Research. 2003;413:19-24. [pmid: 12897592].
130 Moseley J B, O'Malley K, Petersen N J, et al. A controlled trial of arthroscopic surgery for osteoarthritis of the knee. New Engl J Med. 2002;347:81-8. [pmid: 12110735].
131 Cho M K, Bero L A. Instruments for assessing the quality of drug studies published in the medical literature. JAMA. 1994;272(2):101-4. [pmid: 8015115].
132 Harbour R, Miller J. A new system for grading recommendations in evidence based guidelines. BMJ. 2001;323(7308):334-6. [pmid: 11498496].
133 Reisch J S, Tyson J E, Mize S G. Aid to the evaluation of therapeutic studies. Pediatrics. 1989;84(5):815-27. [pmid: 2797977].
134 Gross M. A critique of the methodologies used in clinical studies of hip-joint arthroplasty published in the English-language orthopaedic literature. Journal of Bone & Joint Surgery—American Volume. 1988;70(9):1364-71.
135 Gartland J J. Orthopaedic clinical research. Deficiencies in experimental design and determinations of outcomes. Journal of Bone & Joint Surgery—American Volume. 1988;70(9):1357-64.
136 Smith J S, Watts H G. Methods for locating missing patients for the purpose of long-term clinical studies. Journal of Bone & Joint Surgery—American Volume. 1998;80(3):431-8.
137 Saleh K J, Radosevich D M, Kassim R A, et al. Comparison of commonly used orthopaedic outcome measures using palm-top computers and paper surveys. J Orthop Res. 2002;20(6):1146-51. [pmid: 12472221].
138 Larson C, Lachiewicz P. Patellofemoral complications with the Insall-Burstein II posterior-stabilized total knee arthroplasty. J Arthroplasty. Apr. 1999;14(3):288-92. [pmid: 10220181].
139 Ritter M, Berend M, Meding J, et al. Long-term followup of anatomic graduated components posterior cruciate-retaining total knee replacement. Clin Orthop. Jul. 2001;388:51-7. [pmid: 11451132].
140 Baldwin J, El-Saied M, Rubinstein R J. Uncemented total knee arthroplasty: report of 109 titanium knees with cancellous-structured porous coating. Orthopedics. Feb. 1996;19(2):123-30. [pmid: 8834287].